# Results

## Results of Literature Searches

The search and selection of articles are summarized in the literature flow diagram (Figure 2). Database searches resulted in 4,071 potentially relevant articles. After dual review of abstracts and titles, 729 articles were selected for full-text dual review and 201 studies (in 235 publications) were determined to meet inclusion criteria and were included in this review. Data extraction and risk of bias assessment tables for all included studies are available in Appendixes E and F.

Figure 2 Literature flow diagram

KQ = Key Question

^a^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^b^ Other sources include prior reports, reference lists of relevant articles, systematic reviews, etc.

^c^ Some studies have multiple publications and some are included for more than one Key Question.

Figure 2 is a literature flow diagram depicting the search and selection of articles for the present review. The diagram shows that 4,071 abstracts of potentially relevant articles were identified by a research librarian experienced in conducting literature searches for CERs. The librarian searched in Ovid MEDLINE (January 1990 –October2014), Cochrane Central Register of Controlled Trials (through September 2014), Cochrane Database of Systematic Reviews (through September 2014), Health Technology Assessment (through 3rd Quarter, 2014), National Health Sciences Economic Evaluation Database (through 3rd Quarter, 2014), and Database of Abstracts of Reviews of Effects (through 3rd Quarter, 2014) to capture both published and grey literature, as well as other sources, while 729 articles were reviewed at the full-text level after excluding 3,342 non-relevant abstracts and background articles. From the 729 articles reviewed for inclusion, 43 were excluded due to wrong population, 128 due to wrong intervention, 11 due to wrong outcomes, 30 due to wrong comparator, 127 due to wrong study design for key question, 35 due to wrong publication type, 75 due to non-English language but possibly relevant, 1 had an inadequate duration, 32 due to being a systematic review or meta-analysis used only as a source document, 3 due to no original data or duplicate data, 8 were case-control design for biomarkers, and 1 had an inadequate reference standard. After excluding these studies, 235 publications were included that provide evidence for any of the eight Key Questions. The following numbers of studies were included: 57 studies in 60 publications for Key Question 1, 42 studies for Key Question 1a, 37 studies in 46 publications for Key Question 3, 54 studies in 66 publications for Key Question 3a, 29 studies for Key Question 3b, 2 studies for Key Question 3c, 53 studies in 57 publications for Key Question 3d, 2 studies for Key Question 4, 14 studies in 19 publications for Key Question 6, 7 studies for Key Question 7, and 22 studies for Key Queston 8. No studies were included for Key Questions 2, 5, 5a-d or 8a.

## Key Question 1 What is the diagnostic accuracy of various urinary biomarkers compared with other urinary biomarkers or standard diagnostic methods (cystoscopy, cytology, and imaging) in (1) people with signs or symptoms warranting evaluation for possible bladder cancer or (2) people undergoing surveillance for previously treated bladder cancer?

### Key Points

- Quantitative NMP22: Sensitivity was 0.69 (95% CI 0.62 to 0.75) and specificity 0.77 (95% CI 0.70 to 0.83), based on 19 studies, for a positive likelihood ratio of 3.05 (95% CI 2.28 to 4.10) and negative likelihood ratio of 0.40 (95% CI 0.32 to 0.50) (SOE: moderate)
  ○ For evaluation of symptoms: Sensitivity was 0.67 (95% CI 0.55 to 0.77; 9 studies) and specificity 0.84 (95% CI 0.75 to 0.90; 7 studies).
  ○ For surveillance: Sensitivity was 0.61 (95% CI 0.49 to 0.71; 10 studies) and specificity 0.71 (95% CI 0.60 to 0.81; 8 studies).
- Qualitative NMP22: Sensitivity of qualitative NMP22 was 0.58 (95% CI 0.39 to 0.75) and specificity 0.88 (95% CI 0.78 to 0.94), based on four studies, for a positive likelihood ratio of 4.89 (95% CI 3.23 to 7.40) and negative likelihood ratio of 0.48 (95% CI 0.33 to 0.71) (SOE: low).
  ○ For evaluation of symptoms: Sensitivity was 0.47 (95% CI 0.33 to 0.61) and specificity 0.93 (95% CI 0.81 to 0.97), based on two studies.
  ○ For surveillance: Sensitivity was 0.70 (95% CI 0.40 to 0.89) and specificity 0.83 (95% 0.75 to 0.89), based on two studies.
- Qualitative BTA: Sensitivity was 0.64 (95% CI 0.58 to 0.69, 22 studies) and specificity 0.77 (95% CI 0.73 to 0.81, 21 studies), for a positive likelihood ratio of 2.80 (95% CI 2.31 to 3.39) and negative likelihood ratio of 0.47 (95% CI 0.30 to 0.55 (SOE: moderate).
  ○ For evaluation of symptoms: Sensitivity was 0.76 (95% CI 0.67 to 0.83; 8 studies), and specificity 0.78 (95% CI 0.66 to 0.87; 6 studies).
  ○ For surveillance: Sensitivity was 0.60 (95% CI 0.55 to 0.65; 11 studies) and specificity 0.76 (95% CI 0.69 to 0.83; 8 studies).
- Quantitative BTA: Sensitivity was 0.65 (95% CI 0.54 to 0.75) and specificity 0.74 (95% CI 0.64 to 0.82), based on four studies, for a positive likelihood ratio of 2.52 (95% CI 1.86 to 3.41) and negative likelihood ratio of 0.47 (95% CI 0.37 to 0.61) (SOE: low).
  ○ For evaluation of symptoms: Sensitivity was 0.76 (95% CI 0.61 to 0.87) and specificity 0.53 (95% CI 0.38 to 0.68), based on one study.
  ○ For surveillance: Sensitivity was 0.58 (95% CI 0.46 to 0.69) and specificity 0.79 (95% CI 0.72 to 0.85), based on two studies.
- FISH: Sensitivity was 0.63 (95% CI 0.50 to 0.75) and specificity 0.87 (95% CI 0.79 to 0.93), based on 11 studies, for a positive likelihood ratio of 5.02 (95% CI 2.93 to 8.60) and negative likelihood ratio of 0.42 (95% CI 0.30 to 0.59) (SOE: moderate).
  ○ For evaluation of symptoms: Sensitivity was 0.73 (95% CI 0.50 to 0.88) and specificity was 0.95 (0.87 to 0.98), based on two studies, for a positive likelihood ratio of 14.2 (95% CI 5.2 to 39) and negative likelihood ratio of 0.29 (95% CI 0.14 to 0.60).
  ○ For surveillance: Sensitivity was 0.55 (95% CI 0.36 to 0.72; 7 studies) and specificity was 0.80 (95% CI 0.66 to 0.89; 6 studies).
- ImmunoCyt: Sensitivity was 0.78 (95% CI 0.68 to 0.85) and specificity 0.78 (95% CI 0.72 to 0.82), based on 14 studies, for a positive likelihood ratio of 3.49 (95% 2.82 to 4.32) and negative likelihood ratio of 0.29 (95% CI 0.20 to 0.41) (SOE: moderate).
  ○ For evaluation of symptoms: Sensitivity was 0.85 (95% CI 0.78 to 0.90; 6 studies) and specificity was 0.83 (95% CI 0.77 to 0.87; 7 studies).
  ○ For surveillance: Sensitivity was 0.75 (95% CI 0.64 to 0.83; 7 studies) and specificity was 0.76 (95% CI 0.70 to 0.81; 8 studies).
- CxBladder: Sensitivity was 0.82 (95% CI 0.70 to 0.90) and specificity of 0.85 (95% CI 0.81 to 0.88) for evaluation of symptoms, based on one study, for a positive likelihood ratio of 5.53 (95% CI 4.28 to 7.15) and negative likelihood ratio of 0.21 (95% CI 0.13 to 0.36) (SOE: low).
- Direct (within-study) comparisons
  ○ There was no difference between quantitative NMP22 (cutoff >10 U/mL)versus qualitative BTA in sensitivity (0.69, 95% CI 0.62 to 0.76 vs. 0.66, 95% CIO 0.59 to 0.73, for a difference of 0.03, 95% CI -0.04 to 0.10) or specificity (0.73, 95% CI 0.62 to 0.82 vs. 0.76, 95% CI 0.66 to 0.84, for a difference of 0.03, 95% CI -0.08 to 0.01), based on seven studies (SOE: moderate).
  ○ ImmunoCyt was associated with higher sensitivity than FISH (0.71, 95% CI 0.54 to 0.84 vs. 0.61, 95% CI 0.43 to 0.76, for a difference of 0.11, 95% CI 0.001 to 0.21) but lower specificity (0.71, 95% CI 0.62 to 0.79 vs. 0.79, 95% CI 0.71 to 0.85, for a difference of -0.08, 95% CI -0.15 to -0.001), based on three studies (SOE: low).
  ○ Evidence for other head-to-head comparisons of urinary biomarkers was based on small numbers of studies with imprecise estimates and methodological shortcomings, precluding reliable conclusions regarding comparative test performance (SOE: insufficient).
  ○ Sixteen studies found sensitivity of various urinary biomarkers plus cytology associated with higher sensitivity than the urinary biomarker alone (0.81, 95% CI 0.75 to 0.86 vs. 0.69, 95% CI 0.61 to 0.76, for a difference of 0.13, 95% CI 0.08 to 0.17), with no difference in specificity (SOE: moderate).

### Detailed Synthesis

Fifty-seven studies in 60 publications evaluated the diagnostic accuracy of urinary biomarkers for diagnosis of bladder cancer (Table 2, Appendix E1, F1).30-89 Quantitative NMP22 was evaluated in 19 studies,30,32,33,39,52,53,57,60,61,63,65-67,72,73,75,83,87,89 4 studies in 5 publications evaluated qualitative NMP 22,^35,36,38,47,52^ 23 studies in 24 publications evaluated qualitative BTA,32,33,39-42,44,45,49,51,56,58-60,62,64,67-70,77,80,83,87,89 4 studies evaluated quantitative BTA,34,42,69,83 10 studies evaluated FISH,37,43,55,62,71,75,76,84,85,87 13 studies in 14 publications evaluated ImmunoCyt,31,46,48,50,54,74,78,79,81,82,85-88 and 1 study evaluated CxBladder.52 Sample sizes ranged from 26 to 3,916 and the proportion of patients with bladder cancer ranged from 3 to 81 percent. The focus of 8 studies in 9 publications was diagnostic testing for patients with signs or symptoms suggestive of bladder cancer for initial diagnosis, 16 studies focused on diagnostic testing for surveillance in patients previously treated for non–muscle-invasive bladder cancer (NMIBC), and 19 studies evaluated mixed populations. Forty-three studies in 44 publications were conducted in the United States or Europe30-37,39-51,53-55,57,59-68,70-73,75,83,87,89 and 26 studies in 27 publications used a prospective design.30,35-38,41,42,44-47,50,52,54,56-62,64,66,68,69,71,89 Two studies were rated low risk of bias,35,36 52 studies medium risk of bias,30-34,37-39,41-46,48-76,78-82,84-89 and three studies high risk of bias40,77,83 (See Appendix F). Eleven studies reported blinded interpretation of the reference standard,30,35,36,38,44,45,54,57,62,71,73 12 studies reported enrollment of a random or consecutive sample of patients,30,31,35,36,38,43,46,50,52,54,55,59 and 38 studies reported predefined criteria for a positive test.30-42,44-51,53-73,75,83,87,89

Table 2 Biomarker study characteristics

Author, Year Country | Biomarker | Method of Data Collection | Reason for Testing: Evaluation of Symptoms, Surveillance, or Mixed | Subject Characteristics | Proportion with Bladder Cancer, Bladder Cancer Stage and Grade
Cha, 2012^74^ Germany | ImmunoCyt | Prospective | Evaluation of symptoms | Median age: 65 years Male: 78% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: 68% microscopic hematuria and 32% macroscopic hematuria Prior bladder cancer stage/grade: None with prior bladder cancer | 202/1182 (21%) Tumor stage: 160 Ta, 44 T1, 26 T2-T4 Tumor grade: 138 low grade, 97 high grade
Chahal, 2001^30^ United Kingdom | NMP22 (quantitative) | Prospective | Mixed | Age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 16/96 (17%) Primary tumor stage: 7 Ta, 5 T1, 3 T2, 1 T1 Tumor grade: 6 G1, 3 G2, 7 G3 17/115 Recurrent tumor stage: 15 Ta, 2 T1 Tumor grade: 13 G1, 3 G2, 1 G3
Feil, 2003^31^ Germany | ImmunoCyt | Unclear | Mixed | Mean age: 62 years Male: 82% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 26/113 (23%) Tumor stage: 11 Ta, 8 T1, 7 T2 Tumor grade: 7 G1, 19 G2/G3
Friedrich, 2002^32^ Germany | BTA stat NMP22 (quantitative) | Unclear | Mixed | Age: Not reported Sex: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: 30 Ta, 15 T1 | 54/115 (47%) Tumor stage 25 Ta, 20 T1, 8 ≥T2, 1 CIS Tumor grade: 7 G1, 31 G2, 16 G3
Giannopoulos, 2001^33^ Greece | NMP22 (quantitative, Bladderchek) BTA stat | Unclear | Mixed | Mean age: 66 years Male: 85% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 118/234 (50%) Tumor stage: 57 Ta, 32 T1, 20 T2-4, 6 CIS, 3 Tx Tumor grade: 30 G1, 45 G2, 43 G3
Gibanel, 2002^34^ Spain | BTA TRAK | Unclear | Mixed | Age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Previous bladder cancer stage/grade: Not reported | 21/65 (32%) Tumor stage: 2 Tis, 12 Ta, 2 T1, 5 T2-4 Tumor grade: 9 G1, 4 G2, 6 G3
Grossman, 2005^35^ United States (also Lotan 2009^47^) | NMP22 (qualitative, BladderChek) | Prospective | Evaluation of symptoms | Mean age: 59 years Male: 57%Race/ethnicity: 82% White, non-Hispanic; 9% Smoker: Not reported Signs or symptoms: Not reported | 79/1331 (5.9%) Tumor stage: 30 Ta, 27 T1, 6 T2 or T2a, 4 T3a or T3b, 7 Tx, 5 CIS Tumor grade: 27 well differentiated, 18 moderately differentiated, 25 poorly differentiated, 9 grade unknown
Grossman, 2006^36^ United States | NMP22 (qualitative, BladderChek) | Prospective | Surveillance | Mean age: 71 years Male: 75% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 103/668 (15%) Tumor stage: 50 Ta, 17 T1, 8 T2, 1 T3, 2 T4, 8 CIS, 17 Tx Tumor grade: 38 well differentiated, 16 moderately differentiated, 32 poorly differentiated
Gudjonsson, 2008^37^ Sweden | FISH (UroVysion) | Prospective | Surveillance | Mean age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: All Ta, T1, or CIS; otherwise not reported | 27/152 (18%) Tumor stage/grade: 1 low malignant potential, 16 TaG1-G2, 1 TaG1 + CIS, 5 Tis, 4 T1G2-G3
Gupta, 2009^38^ India | NMP22 (qualitative, BladderChek) | Prospective | Surveillance | Mean age: 57 years Male: 87% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: 91 Ta, 45 T1, 9 CIS; 18 low malignant potential, 83 low grade, 44 high grade | 56/145 (39%) Tumor stage: 31 Ta, 13 T1, 3 CIS Tumor grade: 6 low malignant potential, 27 low grade, 14 high grade
Gutierrez Banos, 2001^39^ Spain | NMP22 (quantitative) BTA stat | Unclear | Mixed | Mean age: 68 years Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms (n=64): 88% macroscopic hematuria, 6.2% irritative symptoms, 6.2% other Prior bladder cancer stage/grade: Not reported | 76/150 (51%) Tumor stage: 16 Ta, 46 T1, 14 T2-T4 Tumor grade: 16 G1, 29 G2, 31 G3
Halling, 2002^40^ United States | BTA statFISH (UroVysion) | Unclear | Mixed | Mean age: 70 yearsMale: 75%Race/ethnicity: Not reportedSmoker: Not reportedSigns and symptoms: Not reportedPrior bladder cancer stage/grade: Not reported | 75/265 (28%)Tumor stage: 38 Ta, 19 T1-T4, 17 CISTumor grade: 12 G1, 25 G2, 37 G3
Horstmann, 2009^75^ Germany | NMP22 (quantitative) ImmunoCyt FISH (UroVysion) | Unclear | Surveillance | Mean age: 77 years Male: 82% Race/ethnicity: Not reported Smoker: Not reported Signs and symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 113/221 (51%) Tumor stage: 69 Ta, 15 T1, 11 T2-T4, 18 CIS Tumor grade: 32 G1, 53 G2, 28 G3
Ianari, 1997^41^ Italy | BTA stat | Prospective | Surveillance | Median age: 66 years Male: 83% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 13/75 (17%) Tumor stage: 18 Ta, 4 T1 and CIS, 13 T2, 4 T3, 1 T4, 3 CIS Tumor grade: 1 G1, 2 G2, 3 G3, 7 Gx
Irani, 1999^42^ France | BTA stat BTA TRAK | Prospective | Evaluation of symptoms | Mean age: Not reported Male: 83% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 49/81 (60%) Tumor stage: 28 Ta, 11 T1, 10 ≥T2 Tumor grade: 19 G1, 18 G2, 12 G3
Junker, 2006^76^ Germany | FISH (UroVysion) | Unclear | Mixed | Mean age: Not reported Male: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 112/141 (79%) Tumor stage: 76 Ta, 24 T1, 11 T2-T3, 1 CIS Tumor grade: Not reported
Karnwal, 2010^43^ United States | FISH (UroVysion) | Retrospective | Surveillance | Mean age: 56 years Male: 68% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: 33 Ta, 22 T1, 2 T1 and CIS; 23 G1, 20 G2, 16 G3 | 48/59 (81%) Tumor grade: 23 G1 or G2, 25 G3
Leyh, 1997a44 Germany, UK, and France | BTA stat | Prospective | Mixed | Mean age: 60 yearsMale: 64%Race/ethnicity: Not reportedSmoker: Not reportedSigns or symptoms (n=413): 122 macroscopic hematuria, 323 microscopic hematuria, 75 dysuria, 148 bladder irritability, 77 urinary urgency, 39 flank pain, 44 suspicious cystoscopy, 21 abnormal intravenous urographyPrior bladder cancer stage/grade: Not reported | 71/414 (17%)Tumor stage: 28 Ta, 23 T1, 18 ≥T2, 4 CISTumor grade: 6 G1, 36 G2, 25 G3
Leyh, 1997b45 Germany and France | BTA stat | Prospective | Surveillance | Mean age: 67 years Male: 77% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 39/164 (24%) Tumor stage: 15 Ta, 10 T1, 10 ≥T2 Tumor grade: 10 G1, 16 G2, 12 G3
Leyh, 1999^77^ Austria, France, Germany, and Italy | BTA stat | Prospective | Evaluation of symptoms | Mean age: 64 years Male: 72% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 107/231 (46%) Tumor stage: 58 Ta, 27 T1, 17 T2-T4, 5 CIS Tumor grade: 26 G1, 45 G2, 36 G3
Lodde, 2003^46^ Italy | uCyt+ (ImmunoCyt) | Prospective | Mixed | Mean age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 51/91 (56%) primary Tumor stage: 29 Ta, 13 T1, 6 ≥T2, 3 CIS Tumor grade: 20 G1, 18 G2, 13 G3 51/134 (38%) recurrent Tumor stage: 33 Ta, 3 t1, 5 ≥T2, 10 CIS Tumor grade: 23 G1, 10 G2, 18 G3
Messing, 2005^48^ United States | ImmunoCyt | Unclear | Surveillance | Age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: All T1 or less; no other data provided | 61/327 (19%) Tumor stage: 35 Ta, 8 T1, 2 T2, 5 CIS, 9 Tx Tumor grade: 28 G1, 10 G2, 6 G3
Mian, 1999^50^ Italy | ImmunoCyt | Prospective | Mixed | Mean age: 66 yearsMale: 77%Race/ethnicity: Not reportedSmoker: Not reportedSigns or symptoms: Not reportedPrior bladder cancer stage/grade: Not reported | 56/142 (39%) primary, 23/107 (21%) recurrentTumor stage: 43 Ta, 20 T1, 12 ≥T2, 4 CISTumor grade: 25 G1, 25 G2, 29 G3
Mian, 2000^49^ Italy and Austria | BTA stat | Retrospective | Mixed | Mean age: 66 years Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 53/180 (29%) Tumor stage: 28 Ta, 13 T1, 7 ≥T2, 1 CIS Tumor grade: 18 G1, 19 G2, 16 G3
Nasuti, 1999^51^ United States | BTA stat | Unclear | Evaluation of symptoms | Age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported | 3/100 (3%) Tumor stage: 2 noninvasive, 1 invasive Tumor grade: 2 G2, 1 G3
Olsson, 2001^78^ Sweden | ImmunoCyt | Unclear | Mixed | Mean age: 68 years Male: 79% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: 50% with hematuria Prior bladder cancer stage/grade: Not reported | 31/114 (27%) Tumor stage: 18 Ta, 7 T1, 4 T2, 2 CIS Tumor grade: 8 G1, 14 G2, 8 G3
O'Sullivan, 2012^52^ New Zealand | CxBladder NMP22 (qualitative, Bladderchek) NMP22 (quantitative) | Prospective | Evaluation of symptoms | Median age: 69 years Male: 80% Race/ethnicity: 87% European, 6.8% Maori Smoker: 16% current, 44% ex-smoker, 40% never smoker Signs or symptoms: 100% macroscopic hematuria | 66/485 (14%) Tumor stage: 38 Ta, 16 T1, 9 T2, 2 ≥T3, 2 CIS Tumor grade: 3 G1, 38 G2, 24, G3 (WHO 1973); 32 low, 4 mixed, 29 high (WHO ISUP 1998)
Paoluzzi, 1999^53^ Italy | NMP22 (quantitative) | Unclear | Evaluation of symptoms | Age: Not reported Male: 85% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: 100% macroscopic or microscopic hematuria | 32/90 (36%) Tumor stage: Not reported Tumor grade: Not reported
Piaton, 2003^79^ Pfister, 2003^54^ France | ImmunoCyt | Prospective | Mixed | Mean age: 66 years Male: 79% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 57/236 (24%) primary; 85/458 (19%) recurrent Tumor stage: 75 Ta, 28 T1, 28 T2 or greater, 8 CIS Tumor grade: 31 G1, 40 G2, 68 G3
Placer, 2002^55^ Spain | FISH (UroVysion) | Unclear | Mixed | Mean age: 70 years Male: 88% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 47/86 (55%)Tumor stage: 26 Ta, 12 T1, 9 T2-T4Tumor grade: 16 G1, 12 G2, 19 G3
Pode, 1999^56^ Israel | BTA stat | Prospective | Mixed | Mean age: Not reported Male: 83% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms of bladder cancer: 88 with hematuria or irritative voiding symptoms, otherwise not reported Prior bladder cancer stage/grade: Not reported | 71/88 (81%) primary; 57/162 (35%) recurrent Tumor stage: 72 Ta, 29 T1, 13 T2 or T3a, 14 T3b or higher Tumor grade: 25 G1, 58 G2, 45 G3
Ponsky, 2001^57^ United States | NMP22 (quantitative) | Prospective | Mixed | Mean age: 70 years in patients with cancer 61 years in patients without cancer 72% male Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: 143 macroscopic hematuria, 226 microscopic hematuria, 239 urinary frequency or dysuria Prior bladder cancer stage: Not reported | 52/608 (8.6%) Tumor stage and grade: 30 Ta and grade 1 to 2, 12 T1 and grade 2 to 3, 7 T2 and grade 3 or greater, 3 Tis
Quek, 2002^58^ Singapore | BTA stat | Prospective | Mixed | Mean age: 54 years 68% male Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: 60 macroscopic hematuria, 29 microhematuria, 13 vesical irritability Prior bladder cancer stage: Not reported | 15% (16/106) primary; 31% (4/13) recurrent Tumor stage: 4 Ta, 10 T1, 6 T2-T4 Tumor grade: 7 G1, 6 G2, 7 G3
Raitanen, 2001a59 and 2001b80 Finland | BTA stat | Prospective | Surveillance | Mean age: 69 years79% male Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: 242 Ta, 187 T1, 20 CIS, 52 Tx; 220 G1, 215 G2, 52 G3, 14 Gx | 131/501 (26%)Tumor stage: 56 Ta, 23 T1, 3 T2-3, 12 CIS, 37 TxTumor grade: 52 G1, 37 G2, 8 G3, 34 Gx
Saad, 2002^60^ UK | NMP22 (quantitative) BTA stat | Prospective | Evaluation of symptoms | Mean age: 70 years Male: 83% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported | 52/73 (71%) with bladder cancer Tumor stage: 23 Ta, 20 T1, 8 T2, 6 CIS Tumor grade: 13 G1, 22 G2, 17 G3
Sanchez-Carbayo, 2001^61^ Spain | NMP22 (quantitative) | Prospective | Evaluation of symptoms | Mean age: 66 years 65% male Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: All had microscopic hematuria | 43/112 (38%) Tumor stage: 5 Ta, 28 T1, 7 T2, 2 T3, 1 CIS Tumor grade: 11 G1, 15 G2, 17 G3
Sarosdy, 2002^62^ United States | FISH (UroVysion) BTA stat | Prospective | Surveillance | Mean age: 71 years 75% male Nonwhite race/ethnicity: 13% Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: 118 Ta, 20 T1, 4 T2, 29 CIS, 5 Tx; 70 G1, 56 G2, 46 G3, 4 Gx | 62/176 (35%) Tumor stage: 32 Ta, 6 T1, 3 T2, 7 CIS, 11 Tx Tumor grade: 22 G1, 9 G2, 18 G3
Sawczuk, 2000^63^ United States | NMP22 (quantitative) | Unclear | Surveillance | Mean age: 69 years Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: 35 Ta, 14 T1, 2 T2, 5 T3-4; 31 G1 or G2, 25 G3 or G4 (7 with associated CIS) | 34/56 (61%) Tumor stage: 27 Ta, 4 T1, 3 T3b or 4 Tumor grade: 22 G1-2, 12 G3-4
Schamhart, 1998^64^ the Netherlands | BTA stat | Prospective | Mixed | Mean age: 66 years Sex: 81% male Nonwhite race/ethnicity: 0% Smoker: Not reported Signs and symptoms: 10% macroscopic hematuria, 4.7% microscopic hematuria, 0.5% flank pain, 2.6% dysuria, 4.7% dysuria, 2.6% urgency, 5.2% other symptoms Prior bladder cancer stage/grade: Not reported | 62/149 (42%)Tumor stage: 42 Ta, 6 T1, 5 ≥T2, 3 CISTumor grade: 5 G1, 32 G2, 17 G3, 20 G3 + CIS
Schmitz-Drager, 2007a82 Germany | ImmunoCyt | Unclear | Evaluation of symptoms | Mean age: 57 years Male: 77% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: All had painless microscopic hematuria Prior bladder cancer stage/grade: No prior bladder cancer | 8/189 (4.2%) Tumor stage: 5 Ta, 1 T1, 2 T2-T3 Tumor grade: 5 low malignant potential, 3 high grade
Schmitz-Drager, 2007b81 Germany | ImmunoCyt | Unclear | Evaluation of symptoms | Mean age: 58 years Male: 89% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: All had painless macroscopic hematuria Prior bladder cancer stage/grade: No prior bladder cancer | 15/59 (25%) Tumor stage: 5 Ta, 3 T1, 6 T2-T4 Tumor grade: 5 low-grade, 9 high-grade
Serretta, 1998^65^ Italy | NMP22 (quantitative) | Unclear | Surveillance | Mean age: 65 years Male: 89% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage and grade: 7 Tis, 49 Ta, 71 T1, 10 T2-3; 12 G1, 74 G2, 51 G3 | 42/137 (31%) Tumor stage: Not reported Tumor grade: Not reported
Serretta, 2000^83^ Italy | NMP22 (quantitative) BTA Stat BTA TRAK | Unclear | Surveillance | Mean age: 65 years Male: 84% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage and grade: 53 Ta, 107 T1, 12 T2-3, 7 CIS, 16 G1, 93 G2, 70 G3 | 55/179 (31%) Tumor stage: 13 Ta, 27 T1, 12 T2-3, 3 CIS, 7 G1, 19 G2, 29 G3 Tumor grade: 7 G1, 19 G2, 29 G3
Shariat, 2006^66^ United States, Europe, Japan, Canada | NMP22 (quantitative) | Prospective | Surveillance | Median age: 68 years Male: 76% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 1045/2871 (36%) Tumor stage: 448 Ta, 276 T1, 220 ≥T2 Tumor grade: 233 G1, 420 G2, 329 G3
Sharma, 1999^67^ United States | NMP22 (quantitative) BTA stat | Unclear | Mixed | Mean age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: 40% microscopic hematuria, 28% macroscopic hematuria, 32% chronic irritative voiding symptoms Prior bladder cancer stage/grade: Not reported | 34/278 (12%) with bladder cancer; 6/199 (3.0%) in people without prior bladder cancer; 28/79 (35%) in people with prior cancer Tumor stage: Not reported Tumor grade: Not reported
Song, 2010^84^ South Korea | FISH (UroVysion) | Prospective | Evaluation of symptoms | Mean age: 62 years Male: 82% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Hematuria Prior bladder cancer stage/grade: Not reported | 95/602 (16%) Tumor stage: 38 Ta, 29 T1, 24 T2-T3, 4 CIS Tumor grade: 20 G1, 35 G2, 16 G3
Sullivan, 2009^85^ USA | FISH (UroVysion) ImmunoCyt | Unclear | Surveillance | Mean age: Not reported Male: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: All undergoing surveillance Prior bladder cancer stage/grade: Not reported | 25/100 (12%) Tumor stage: 19 Ta, 4 T1, 2 T2 Tumor grade: 13 low grade, 11 high grade
Tetu, 2005^86^ Canada | ImmunoCyt | Retrospective | Mixed | Mean age: Not reported Male: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 136/870 (16%) Tumor stage: 65 Ta, 6 T1, 19 T2-T4, 14 CIS Tumor grade: 31 low malignant potential, 33 low-grade papillary carcinoma, 40 high grade papillary carcinoma
Thomas, 1999^69^ Europe | BTA TRAK | Prospective | Mixed | Mean age: 64 yearsMale: 70%Caucasian: 98%Smoker: Not reportedSigns or symptoms: Not reportedPrior bladder cancer stage/grade: Not reported | 100/220 (45%) overall; 49/96 (51%) primary; 51/124 (41%) recurrent Tumor stage: 55 Ta, 24 T1, 16 T2-T4, 5 CISTumor grade: 25 G1, 41 G2, 34 G3
Toma, 2004^87^ Germany | NMP22 (quantitative) ImmunoCyt BTA stat FISH (UroVysion) | Unclear | Mixed | Age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 42/126 (33%) Tumor stage: 21 Ta, 15 T1, 6 T2-T4, 2 CIS Tumor grade: 7 G1, 23 G2, 12 G3
United Kingdom and Eire Bladder Tumour Antigen Study Group, 1997^68^ UK | BTA stat | Prospective | Surveillance | Age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 102/272 (38%) Tumor stage: Not reported Tumor grade: Not reported
van Der Poel, 1998^70^ the Netherlands | BTA stat | Unclear | Surveillance | Age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 58/103 (56%) Tumor stage: 40 Ta, 7 T1, 4 T2, 3 T3, 3 CIS Tumor grade: 7 G1, 27 G2, 20 G3
Varella-Garcia, 2004^71^ United States | FISH (UroVysion) | Prospective | Surveillance | Mean age: 69 years Male: 84% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 7/19 (37%) with bladder cancer Tumor stage: 3 Ta, 2 T1, 2 T2 Tumor grade: 2 G1, 3 G2, 2 G3
Vriesema, 2001^88^ the Netherlands | ImmunoCyt | Prospective | Surveillance | Mean age: 68 years Male: 83% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: Not reported | 22/86 (26%) with bladder cancer Tumor stage: 17 Ta, 3 T1, 1 T2-T4, 1 CIS Tumor grade: Not reported
Wiener, 1998^89^ Austria | NMP22 (quantitative) BTA stat | Prospective | Mixed | Mean age: 65 years Male: 68% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: 65% Prior bladder cancer stage/grade: Not reported | 91/291 (31%) with bladder cancer Tumor stage: 47 Ta, 25 T1, 19 T2-T4 Tumor grade: 23 G1, 38 G2, 30 G3
Witjes, 1998^72^ the Netherlands | NMP22 (quantitative) | Unclear | Surveillance | Age: Not reported Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported Prior bladder cancer stage/grade: NMIBC, otherwise not reported | 12/50 (24%) with bladder cancer Tumor stage: 2 Ta, 1 T1, 3 T2, 1 Tis, 5 not available Tumor grade: 1 G1, 3 G2, 2 G3, 5 not available
Zippe, 1999^73^ United States | NMP22 (quantitative) | Unclear | Primary | Mean age: 64 years Male: 77% Race/ethnicity: Not reported Smoker: Not reported Signs or symptoms: Not reported | 8/146 (5.5%) with bladder cancer Tumor stage: 3 Ta, 1 Ta/T1, 1 T1, 2 T2, 1 Tis Tumor grade: 2 G1, 1 G1/2, 2 G2, 1 G2/G3, 2 G3

BTA stat = bladder tumor antigen Polymedco rapid test; BTA TRAK = bladder tumor antigen quantitative immunoassay; FISH = fluorescence in situ hybridization; NMP22 = nuclear matrix protein-22; uCyt+ = ImmunoCyt assay.

#### Quantitative NMP22

Sensitivity of quantitative NMP22 was 0.69 (95% CI 0.62 to 0.75) and specificity was 0.77 (95% CI 0.70 to 0.83), based on 19 studies, for a positive likelihood ratio of 3.05 (95% CI 2.28 to 4.10) and negative likelihood ratio of 0.40 (95% CI 0.32 to 0.50) (Table 3; Figure 3).30,32,33,39,52,53,57,60,61,63,65-67,72,73,75,83,87,89 All studies except for two33,52 used a cutoff of >10 for a positive test. Excluding these two studies resulted in similar sensitivity (0.70, 95% CI 0.63 to 0.77) and specificity (0.77, 95% CI 0.69 to 0.83). Diagnostic accuracy was similar for evaluation of symptoms (sensitivity 0.67 [95% CI 0.55 to 0.77]; 9 studies and specificity 0.84 [95% CI 0.75 to 0.90]; 7 studies)30,33,52,53,60,61,67,73,89 and for surveillance (sensitivity 0.61 [95% CI 0.49 to 0.71]; 10 studies and specificity 0.71 [95% CI 0.60 to 0.81]; 8 studies).30,33,63,65-67,72,75,83,89 Excluding one study rated high risk of bias83 and restricting the analysis to studies that used a prospective design, were conducted in the United States or Europe, or used a prespecified threshold to define a positive test, had little effect on pooled estimates and did not reduce statistical heterogeneity. Restricting the analysis to studies t hat reported blinded interpretation of the reference standard resulted in higher specificity, but the pooled estimate was only based on three studies (0.89, 95% CI 0.78 to 0.95).30,57,73

Table 3 Test performance of urinary biomarkers for diagnosis of bladder cancer

Biomarker | | Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Specificity (95% CI); τ^2^ (p value) | Number of Studies | LR+ | LR-
NMP22 quantitative | Overall | 0.69 (0.62 to 0.75); 0.33 (p=0.0005) | 19 | 0.77 (0.70 to 0.83); 0.62 (p<0.0001) | 19 | 3.05 (2.28 to 4.10) | 0.40 (0.32 to 0.50)
NMP22 quantitative | Excluding studies that didn't use cutoff of >10 | 0.70 (0.63 to 0.77); 0.35 (p=0.001) | 17 | 0.77 (0.69 to 0.83); 0.66 (p=0.0001) | 17 | 3.04 (2.19 to 4.20) | 0.39 (0.30 to 0.50)
NMP22 quantitative | Excluding high risk of bias studies | 0.68 (0.61 to 0.75); 0.32 (p=0.001) | 18 | 0.79 (0.72 to 0.84); 0.55 (p<0.0001) | 18 | 3.18 (2.37 to 4.27) | 0.40 (0.32 to 0.50)
NMP22 quantitative | Prospective design | -0.63 (0.53 to 0.73); 0.29 (p=0.001) | 8 | 0.85 (0.78 to 0.90); 0.41 (p<0.0001) | 8 | 4.21 (2.70 to 6.55) | 0.43 (0.32 to 0.57)
NMP22 quantitative | United States or Europe | 0.70 (0.63 to 0.76); 0.29 (p=0.001) | 18 | 0.77 (0.69 to 0.83); 0.58 (p<0.0001) | 18 | 2.99 (2.22 to 4.02) | 0.77 (0.69 to 0.83)
NMP22 quantitative | Prespecified threshold for positive test | 0.72 (0.66 to 0.78); 0.23 (p=0.001) | 16 | 0.75 (0.67 to 0.82); 0.53 (p<0.0001) | 16 | 2.90 (2.14 to 3.94) | 0.37 (0.29 to 0.47)
NMP22 quantitative | Blinded interpretation of reference standard | 0.73 (0.53 to 0.87); 0.34 (p=0.0005) | 3 | 0.89 (0.78 to 0.95); 0.46 (p<0.0001) | 3 | 6.73 (3.26 to 13.9) | 0.30 (0.16 to 0.57)
NMP22 quantitative | Evaluation of symptoms | 0.67 (0.55 to 0.77); 0.34 (p=0.04) | 9 | 0.84 (0.75 to 0.90); 0.45 (p=0.02) | 7 | 4.20 (2.65 to 6.67) | 0.40 (0.29 to 0.55)
NMP22 quantitative | Surveillance | 0.61 (0.49 to 0.71); 0.45 (p=0.04) | 10 | 0.71 (0.60 to 0.81); 0.54 (p=0.01) | 8 | 2.10 (1.58 to 2.80) | 0.55 (0.44 to 0.69)
NMP22 qualitative | Overall | 0.58 (0.39 to 0.75); 0.57 (p=0.14) | 4 | 0.88 (0.78 to 0.94); 0.50 (p=0.13) | 4 | 4.89 (3.23 to 7.40) | 0.48 (0.33 to 0.71)
NMP22 qualitative | Low risk of bias studies | 0.53 (0.29 to 0.75); 0.46 (p=0.11) | 2 | 0.87 (0.74 to 0.94); 0.35 (p=0.10) | 2 | 3.91 (2.70 to 5.66) | 0.55 (0.36 to 0.84)
NMP22 qualitative | United States or Europe | 0.53 (0.29 to 0.75); 0.46 (p=0.11) | 2 | 0.87 (0.74 to 0.94); 0.35 (p=0.10) | 2 | 3.91 (2.70 to 5.66) | 0.55 (0.36 to 0.84)
NMP22 qualitative | Blinded interpretation of reference standard | 0.65 (0.45 to 0.81); 0.47 (p=0.26) | 3 | 0.84 (0.80 to 0.88); 0.05 (p=0.36) | 3 | 4.19 (3.40 to 5.16) | 0.41 (0.25 to 0.69)
NMP22 qualitative | Evaluation of symptoms | 0.47 (0.33 to 0.61); 0.12 (p=0.38) | 2 | 0.93 (0.81 to 0.97); 0.52 (p=0.31) | 2 | 6.27 (2.98 to 13.2) | 0.58 (0.46 to 0.72)
NMP22 qualitative | Surveillance | 0.70 (0.40 to 0.89); 0.74 (p=0.36) | 2 | 0.83 (0.75 to 0.89); 0.74 (p=0.31) | 2 | 4.20 (3.22 to 5.47) | 0.36 (0.16 to 0.81)
Qualitative BTA | Overall | 0.64 (0.58 to 0.69); 0.26 (p<0.0001) | 22 | 0.77 (0.73 to 0.81); 0.27 (p<0.0001) | 21 | 2.80 (2.31 to 3.39) | 0.47 (0.30 to 0.55)
Qualitative BTA | Excluding high risk of bias studies | 0.63 (0.57 to 0.69); 0.26 (p<0.0001) | 19 | 0.79 (0.74 to 0.83); 0.22 (p<0.0001) | 18 | 2.95 (2.42 to 3.61) | 0.47 (0.40 to 0.56)
Qualitative BTA | Prospective design | 0.62 (0.55 to 0.69); 0.25 (p<0.0001) | 14 | 0.78 (0.72 to 0.83); 0.26 (p<0.0001) | 13 | 2.84 (2.23 to 3.61) | 0.48 (0.40 to 0.58)
Qualitative BTA | United States or Europe | 0.63 (0.57 to 0.69); 0.26 (p<0.0001) | 20 | 0.78 (0.74 to 0.82); 0.24 (p<0.0001) | 19 | 2.91 (2.39 to 3.54) | 0.47 (0.40 to 0.55)
Qualitative BTA | Blinded interpretation of reference standard | 0.64 (0.48 to 0.77); 0.26 (p<0.0001) | 3 | 0.85 (0.75 to 0.91); 0.23 (p<0.0001) | 3 | 4.1 (2.49 to 6.85) | 0.43 (0.29 to 0.64)
Qualitative BTA | Evaluation of symptoms | 0.76 (0.67 to 0.83); 0.21 (p=0.05) | 8 | 0.78 (0.66 to 0.87); 0.50 (p=0.02) | 6 | 3.42 (2.04 to 5.74) | 0.31 (0.21 to 0.46)
Qualitative BTA | Surveillance | 0.60 (0.55 to 0.65); 0.02 (p=0.27) | 11 | 0.76 (0.69 to 0.83); 0.26 (p=0.02) | 8 | 2.53 (1.92 to 3.34) | 0.52 (0.47 to 0.59)
Quantitative BTA | Overall | 0.65 (0.54 to 0.75); 0.10 (p=0.32) | 4 | 0.74 (0.64 to 0.82); 0.14 (p=0.27) | 4 | 2.52 (1.86 to 3.41) | 0.47 (0.37 to 0.61)
Quantitative BTA | Excluding high risk of bias studies | 0.66 (0.53 to 0.77); 0.13 (p=0.42) | 3 | 0.72 (0.59 to 0.83); 0.17 (p=0.41) | 3 | 2.38 (1.69 to 3.35) | 0.47 (0.36 to 0.62)
Quantitative BTA | Used threshold of >14 for positive test | 0.69 (0.60 to 0.76); 0.02 (p=0.77) | 3 | 0.71 (0.63 to 0.77); 0.02 (p=0.76) | 3 | 2.35 (1.82 to 3.04) | 0.44 (0.34 to 0.58)
Quantitative BTA | Evaluation of symptoms | 0.76 (0.61 to 0.87) | 1 | 0.53 (0.38 to 0.68) | 1 | 1.61 (1.14 to 2.28) | 0.46 (0.26 to 0.81)
Quantitative BTA | Surveillance | 0.58 (0.46 to 0.69); <0.0001 (p=1.0) | 2 | 0.79 (0.72 to 0.85); <0.0001 (p=1.0) | 2 | 2.77 (1.66 to 4.61) | 0.54 (0.39 to 0.76)
FISH | Overall | 0.63 (0.50 to 0.75); 0.74 (p=0.01) | 11 | 0.87 (0.79 to 0.93); 0.90 (p=0.003) | 11 | 5.02 (2.93 to 8.60) | 0.42 (0.30 to 0.59)
FISH | Prospective design | 0.60 (0.37 to 0.79); 0.72 (p=0.01) | 4 | 0.91 (0.79 to 0.97); 0.83 (p=0.004) | 4 | 7.00 (2.72 to 18.0) | 0.44 (0.25 to 0.76)
FISH | Excluding high risk of bias studies | 0.61 (0.48 to 0.72); 0.57 (p=0.01) | 10 | 0.86 (0.77 to 0.92); 0.74 (p=0.003) | 10 | 4.24 (2.69 to 6.67) | 0.46 (0.35 to 0.61)
FISH | Blinded interpretation of reference standard | 0.76 (0.43 to 0.93); 0.70 (p=0.01) | 2 | 0.83 (0.50 to 0.96); 0.85 (p=0.005) | 2 | 4.43 (1.20 to 16.4) | 0.29 (0.10 to 0.86)
FISH | Evaluation of symptoms | 0.73 (0.50 to 0.88); 0.36 (p=0.40) | 2 | 0.95 (0.87 to 0.98); <0.0001 (p=1.0) | 1 | 14.2 (5.2 to 39) | 0.29 (0.14 to 0.60)
FISH | Surveillance | 0.55 (0.36 to 0.72); 0.85 (p=0.03) | 7 | 0.80 (0.66 to 0.89); 0.80 (p=0.03) | 6 | 2.75 (1.95 to 3.89) | 0.56 (0.42 to 0.76)
ImmunoCyt | Overall | 0.78 (0.68 to 0.85); 0.71 (p=0.003) | 14 | 0.78 (0.72 to 0.82); 0.25 (p=0.001) | 14 | 3.49 (2.82 to 4.32) | 0.29 (0.20 to 0.41)
ImmunoCyt | Excluding studies rated high risk of bias | 0.78 (0.68 to 0.86); 0.70 (p=0.003) | 13 | 0.79 (0.74 to 0.83); 0.18 (p=0.002) | 13 | 3.73 (3.09 to 4.51) | 0.28 (0.19 to 0.40)
ImmunoCyt | Prospective design | 0.74 (0.54 TO 0.87); 0.70 (p=0.003) | 4 | 0.80 (0.70 to 0.87); 0.24 (p=0.001) | 4 | 3.68 (2.44 to 5.55) | 0.32 (0.17 to 0.61)
ImmunoCyt | Evaluation of symptoms | 0.85 (0.78 to 0.90); 0.10 (p=0.30) | 6 | 0.83 (0.77 to 0.87); 0.11 (p=0.07) | 7 | 4.89 (3.79 to 6.30) | 0.18 (0.12 to 0.26)
ImmunoCyt | Surveillance | 0.75 (0.64 to 0.83); 0.34 (p=0.05) | 7 | 0.76 (0.70 to 0.81); 0.14 (p=0.04) | 8 | 3.09 (2.56 to 3.72) | 0.33 (0.24 to 0.46)
CxBladder | Evaluation of symptoms^a^ | 0.82 (0.70 to 0.90) | 1 | 0.85 (0.81 to 0.88) | 1 | 5.53 (4.28 to 7.15) | 0.21 (0.13 to 0.36)

BTA = bladder tumor antigen; CI = confidence interval; FISH = fluorescence in situ hybridization; LR+ = positive likelihood ratio; LR- = negative likelihood ratio; NMP22 = nuclear matrix protein-22

a Based on threshold selected for specificity of 0.85.

Figure 3 Sensitivity and specificity of quantitative NMP22

CI = confidence interval; NMP22 = nuclear matrix protein-22

Figure 3 is a set of 2 forest plots titled sensitivity and specificity of quantitative NMP22. The plots depict meta-analyses of the sensitivity of quantitative NMP22 on the left and specificity of quantitative NMP22 on the right. The sensitivity and specificity values are represented by squares in each graph. Sensitivity and specificity were reported or calculated for 19 studies, with a pooled sensitivity of 0.69 (95% confidence interval 0.62 to 0.75), and the overall I-squared value of 0.33 (p=0.0005) and a pooled specificity of 0.77 (95% confidence interval 0.70 to 0.83) and the overall I-squared value of 0.62 (p<0.0001).

#### Qualitative NMP22

Sensitivity of qualitative NMP22 was 0.58 (95% CI 0.39 to 0.75) and specificity was 0.88 (95% CI 0.78 to 0.94), based on four studies, for a positive likelihood ratio of 4.89 (95% CI 3.23 to 7.40) and negative likelihood ratio of 0.48 (95% CI 0.33 to 0.71) (Table 3; Figure 4).35,36,38,52 Restricting the analysis to two studies that were rated low risk of bias resulted in similar estimates (sensitivity 0.53 [95% CI 0.29 to 0.75] and specificity 0.87 [95% CI 0.74 to 0.94]).35,36 Two studies each reported diagnostic accuracy for evaluation of symptoms (sensitivity 0.47 [95% CI 0.33 to 0.61] and specificity 0.93 [95% CI 0.81 to 0.97])35,52 and for surveillance (sensitivity 0.70 [95% CI 0.40 to 0.89] and specificity 0.83 [95% 0.75 to 0.89]),36,38 resulting in imprecise estimates. Other subgroup and sensitivity analysis were also limited by the small numbers of studies.

Figure 4 Sensitivity and specificity of qualitative NMP22

CI = confidence interval; NMP22 = nuclear matrix protein-22

Figure 4 is a set of 2 forest plots titled sensitivity and specificity of qualitative NMP22. The plots depict meta-analyses of the sensitivity of qualitative NMP22 on the left and specificity of qualitative NMP22 on the right. The sensitivity and specificity values are represented by squares in each graph. Sensitivity and specificity were reported or calculated for 4 studies, with a pooled sensitivity of 0.58 (95% confidence interval 0.39 to 0.75), and the overall I-squared value of 0.56 (p=0.14) and a pooled specificity of 0.90 (95% confidence interval 0.79 to 0.95) and the overall I-squared value of 0.60 (p=0.13).

#### Qualitative BTA

Sensitivity of qualitative BTA was 0.64 (95% CI 0.58 to 0.69, 22 studies)32,33,39-42,44,45,49,51,56,58,60,64,67,68,70,77,80,83,87,89 and specificity was 0.77 (95% CI 0.73 to 0.81, 21 studies),32,33,39,40,42,44,45,49,51,56,58,60,64,67,68,70,77,80,83,87,89 for a positive likelihood ratio of 2.80 (95% CI 2.31 to 3.39) and negative likelihood ratio of 0.47 (95% CI 0.30 to 0.55) (Table 3; Figure 5). Excluding three studies rated high risk of bias40,77,83 resulted in similar pooled estimates and did not reduce statistical heterogeneity. Sensitivity was higher for evaluation of symptoms (0.76, 95% CI 0.67 to 0.83; 8 studies)33,45,51,56,60,67,77,89 than for surveillance (0.60, 95% CI 0.55 to 0.65; 11 studies),33,41,44,45,56,59,67,68,77,80,83,89 but specificity was similar (0.78 [95% CI 0.66 to 0.87]; 6 studies and 0.76 [95% CI 0.69 to 0.83]; 8 studies, respectively. Restricting analyses to studies that used a prospective design, were conducted in the United States or Europe, or reported interpretation of the reference standard blinded to BTA test results, had little effect on pooled estimates and did not reduce statistical heterogeneity.

Figure 5 Sensitivity and specificity of qualitative BTA

BTA = bladder tumor antigen; CI = confidence interval

Figure 5 is a set of 2 forest plots titled sensitivity and specificity of qualitative BTA. The plots depict meta-analyses of the sensitivity of qualitative BTA on the left and specificity of qualitative BTA on the right. The sensitivity and specificity values are represented by squares in each graph. Sensitivity and specificity were reported or calculated for 22 studies, with a pooled sensitivity of 0.64 (95% confidence interval 0.58 to 0.69), and the overall I-squared value of 0.26 (p<0.0001) and a pooled specificity of 0.77 (95% confidence interval 0.73 to 0.81) and the overall I-squared value of 0.27 (p<0.0001).

#### Quantitative BTA

Sensitivity of quantitative BTA was 0.65 (95% CI 0.54 to 0.75) and specificity was 0.74 (95% CI 0.64 to 0.82), based on four studies, for a positive likelihood ratio of 2.52 (95% CI 1.86 to 3.41) and negative likelihood ratio of 0.47 (95% CI 0.37 to 0.61) (Table 3; Figure 6).34,42,69,83 Estimates were similar in three studies that used a threshold of >14 to define a positive test42,69,83 and when one high risk of bias study83 was excluded from the analysis. Only one study69 reported diagnostic accuracy for evaluation of symptoms (sensitivity 0.76 [95% CI 0.61 to 0.87]; specificity 0.53 [95% CI 0.38 to 0.68]) and two studies69,83 for surveillance (sensitivity 0.58 [95% CI 0.46 to 0.69]; specificity 0.79 [95% CI 0.72 to 0.85]).

Figure 6 Sensitivity and specificity of quantitative BTA

BTA = bladder tumor antigen; CI = confidence interval

Figure 6 is a set of 2 forest plots titled sensitivity and specificity of quantitative BTA. The plots depict meta-analyses of the sensitivity of qualitative BTA on the left and specificity of qualitative BTA on the right. The sensitivity and specificity values are represented by squares in each graph. Sensitivity and specificity were reported or calculated for 4 studies, with a pooled sensitivity of 0.65 (95% confidence interval 0.54 to 0.75), and the overall I-squared value of 0.10 (p=0.3215) and a pooled specificity of 0.74 (95% confidence interval 0.64 to 0.82) and the overall I-squared value of 0.14 (p=0.2726).

#### FISH

Sensitivity of FISH was 0.63 (95% CI 0.50 to 0.75) and specificity was 0.87 (95% CI 0.79 to 0.93), based on 11 studies, for a positive likelihood ratio of 5.02 (95% CI 2.93 to 8.60) and negative likelihood ratio of 0.42 (95% CI 0.30 to 0.59) (Table 3; Figure 7).37,40,43,55,62,71,75,76,84,85,87 Estimates were similar when one high risk of bias study40 was excluded, prostatitis or when the analysis was restricted to studies that used a prospective design or reported interpretation of the reference standard blinded to FISH results. For surveillance, sensitivity was 0.55 (95% CI 0.36 to 0.72; 7 studies) and specificity was 0.80- (95% CI 0.66 to 0.89; 6 studies).37,43,55,62,71,75,85 For evaluation of symptoms, sensitivity of FISH was 0.73 (95% CI 0.50 to 0.88), based on two studies.55,84 Only one study reported specificity of FISH for evaluation of symptoms (0.95, 95% CI 0.87 to 0.98)).84

Figure 7 Sensitivity and specificity of FISH

CI = confidence interval; FISH = fluorescence in situ hybridization

Figure 7 is a set of 2 forest plots titled sensitivity and specificity of FISH. The plots depict meta-analyses of the sensitivity of FISH on the left and specificity of FISH on the right. The sensitivity and specificity values are represented by squares in each graph. Sensitivity and specificity were reported or calculated for 11 studies, with a pooled sensitivity of 0.63 (95% confidence interval 0.50 to 0.75), and the overall I-squared value of 0.74 (p=0.0060) and a pooled specificity of 0.87 (95% confidence interval 0.79 to 0.93) and the overall I-squared value of 0.90 (p=0.0034).

#### ImmunoCyt

Sensitivity of ImmunoCyt was 0.78 (95% CI 0.68 to 0.85) and specificity was 0.78 (95% CI 0.72 to 0.82), based on 14 studies, for a positive likelihood ratio of 3.49 (95% CI 2.82 to 4.32) and negative likelihood ratio of 0.29 (95% CI 0.20 to 0.41) (Table 3; Figure 8).31,46,48,50,74,75,78,79,81,82,85-88 Excluding one high risk of bias study86 or restricting the analysis to studies that used a prospective design had little effect on estimates. For evaluation of symptoms, sensitivity was 0.85 (95% CI 0.78 to 0.90; 6 studies) and specificity was 0.83 (95% CI 0.77 to 0.87; 7 studies), 46,50,74,78,79,81,82 and for surveillance, sensitivity was 0.75 (95% CI 0.64 to 0.83; 7 studies) and specificity was 0.76 (95% CI 0.70 to 0.81; 8 studies).46,48,50,75,78,79,85,88

Figure 8 Sensitivity and specificity of ImmunoCyt

CI = confidence interval

Figure 8 is a set of 2 forest plots titled sensitivity and specificity of Immunocyt. The plots depict meta-analyses of the sensitivity of Immunocyt on the left and specificity of Immunocyt on the right. The sensitivity and specificity values are represented by squares in each graph. Sensitivity and specificity were reported or calculated for 14 studies, with a pooled sensitivity of 0.78 (95% confidence interval 0.68 to 0.85), and the overall I-squared value of 0.71 (p=0.0030) and a pooled specificity of 0.78 (95% confidence interval 0.72 to 0.82) and the overall I-squared value of 0.25 (p=0.0008).

#### CxBladder

One study (rated medium risk of bias) of CxBladder reported a sensitivity of 0.82 (95% CI 0.70 to 0.90) and specificity of 0.85 (95% CI 0.81 to 0.88) for evaluation of symptoms, for a positive likelihood ratio of 5.53 (95% CI 4.28 to 7.15) and negative likelihood ratio of 0.21 (95% CI 0.13 to 0.36) (Table 3).52

#### Head-to-Head Comparisons

Relatively few studies directly compared the diagnostic accuracy of different urinary biomarkers in the same population against cystoscopy and biopsy (Table 4). In seven studies, there were no differences between quantitative NMP22 (based on a cutoff of >10 U/mL) versus qualitative BTA in sensitivity (0.69, 95% CI 0.62 to 0.76 vs. 0.66, 95% CI 0.59 to 0.73, for a difference of 0.03, 95% CI -0.04 to 0.10) or specificity (0.73, 95% CI 0.62 to 0.82 vs. 0.76, 95% CI 0.66 to 0.84, for a difference of 0.03, 95% CI -0.08 to 0.01).32,39,60,67,83,87,89 Findings were similar when one high risk of bias study was excluded,83 when the analysis was restricted to studies that used a prospective design,60,67,89 or when analyses were stratified according to different tumor stages or grades.

Table 4 Direct (within-study) comparisons of diagnostic accuracy of urinary biomarkers for diagnosis of bladder cancer

Biomarkers | | Sensitivity A (95% CI) | Sensitivity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies | Specificity A (95% CI) | Specificity B (95% CI) | Difference (95% CI); τ^2^ (p value) | Number of Studies
Quantitative NMP22 (A) vs. qualitative BTA (B) | Restricted to NMP22 studies using a cutoff of >10 U/mL | 0.69 (0.62 to 0.76) | 0.66 (0.59 to 0.73) | 0.03 (-0.04 to 0.10); 0.09 (p=0.04) | 7 | 0.73 (0.62 to 0.82) | 0.76 (0.66 to 0.84) | -0.03 (-0.08 to 0.01); 0.42 (p=0.02) | 7
Quantitative NMP22 (A) vs. qualitative BTA (B) | Tumor stage Ta | 0.54 (0.45 to 0.62) | 0.53 (0.45 to 0.61) | 0.01 (-0.11 to 0.13); <0.0001 (p=1.0) | 5 | No data | No data | -- | --
Quantitative NMP22 (A) vs. qualitative BTA (B) | T1 | 0.81 (0.67 to 0.90) | 0.77 (0.63 to 0.88) | 0.03 (-0.07 to 0.13); 0.41 (p=0.08) | 5 | No data | No data | -- | --
Quantitative NMP22 (A) vs. qualitative BTA (B) | Tumor grade G1 | 0.52 (0.40 to 0.63) | 0.44 (0.33 to 0.56) | 0.08 (-0.09 to 0.25); <0.0001 (p=1.0) | 5 | No data | No data | -- | --
Quantitative NMP22 (A) vs. qualitative BTA (B) | G2 | 0.67 (0.57 to 0.76) | 0.65 (0.55 to 0.74) | 0.01 (-0.10 to 0.12); 0.08 (p=0.17) | 5 | No data | No data | -- | --
Quantitative NMP22 (A) vs. qualitative BTA (B) | Evaluation of symptoms | 0.66 (0.55 to 0.76) | 0.64 (0.53 to 0.74) | 0.02 (-0.09 to 0.14); 0.05 (p=0.44) | 3 | 0.77 (0.61 to o.88) | 0.75 (0.57 to 0.86) | 0.03 (-0.06 to 0.11); 0.25 (p=0.33) | 3
Quantitative NMP22 (A) vs. qualitative BTA (B) | Surveillance | 0.60 (0.30 to 0.85) | 0.51 (0.22 to 0.79) | 0.10 (-0.10 to 0.29); 1.0 (p=0.28) | 3 | 0.65 (0.54 to 0.75) | 0.69 (0.58 to 0.78) | -0.04 (-0.15 to 0.08); 0.04 (p=0.47) | 2
BTA qualitative (A) vs. FISH (B) | Overall | 0.73 (0.62 to 0.82) | 0.76 (0.65 to 0.84) | -0.03 (-0.14 to 0.09); 0.04 (p=0.52) | 2 | 0.76 (0.69 to 0.82) | 0.92 (0.87 to 0.96) | -0.16 (-0.24 to -0.08); 0.002 (p=0.83) | 2
BTA qualitative (A) vs. FISH (B) | Tumor stage Ta | 0.57 (0.47 to 0.67) | 0.64 (0.54 to 0.74) | -0.07 (-0.21 to 0.07); <0.0001 (p=1.0) | 3 | No data | No data | -- | --
BTA qualitative (A) vs. FISH (B) | T1 | 0.81 (0.59 to 0.93) | 0.71 (0.49 to 0.87) | 0.10 (-0.16 to 0.35); <0.0001 (p=1.0) | 2 | No data | No data | -- | --
BTA qualitative (A) vs. FISH (B) | Tumor grade G1 | 0.37 (0.23 to 0.52) | 0.50 (0.35 to 0.65) | -0.13 (-0.35 to 0.08); <0.0001 (p=1.0) | 3 | No data | No data | -- | --
BTA qualitative (A) vs. FISH (B) | G2 | 0.72 (0.59 to 0.82) | 0.70 (0.57 to 0.81) | 0.02 (-0.15 to 0.18); <0.0001 (p=1.0) | 3 | No data | No data | -- | --
BTA qualitative (A) vs. ImmunoCyt (B) | Overall | 0.67 (0.52 to 0.81) | 0.79 (0.66 to 0.91) | -0.12 (-0.31 to 0.07); (p=0.22)^a^ | 1 | 0.78 (0.69 to 0.87) | 0.74 (0.65 to 0.84) | 0.04 (-0.09 to 0.17); (p=0.57)^a^ | 1
BTA qualitative (A) vs. BTA quantitative (B) | Overall | 0.64 (0.52 to 0.74) | 0.74 (0.62 to 0.83) | -0.10 (-0.25 to 0.05); <0.0001 (p=1.0) | 2 | 0.67 (0.57 to 0.77) | 0.73 (0.63 to 0.81) | -0.06 (-0.19 to 0.08); <0.0001 (p=1.0) | 2
CxBladder (A) vs. NMP22 quantitative (B) | Evaluation of symptoms | 0.82 (0.70 to 0.90) | 0.50 (0.37 to 0.63) | 0.32 (0.17 to 0.47); (p=0.0001)^a^ | 1 | 0.85 (0.81 to 0.88) | 0.88 (0.85 to 0.91) | -0.03 (-0.07 to 0.02) (p=0.22)^a^
CxBladder (A) vs. NMP22 qualitative (B) | Evaluation of symptoms | 0.82 (0.70 to 0.90) | 0.38 (0.26 to 0.51) | 0.44 (0.29 to 0.59); (p<0.0001)^a^ | 1 | 0.85 (0.81 to 0.88) | 0.96 (0.94 to 0.98) | -0.11 (-0.15 to -0.07); (p<0.0001)^a^ | 1
NMP22 quantitative (A) vs. NMP22 qualitative (B) | Evaluation of symptoms | 0.50 (0.37 to 0.63) | 0.38 (0.26 to 0.51) | 0.12 (-0.05 to 0.29); (p=0.16)^a^ | 1 | 0.88 (0.85 to 0.91) | 0.96 (0.94 to 0.98) | -0.08 (-0.12 to -0.05); (p<0.0001)^a^ | 1
NMP22 quantitative (A) vs. NMP22 qualitative (B) | Evaluation of symptoms | 0.70 (0.50 to 0.90) | 0.62 (0.39 to 0.86) | 0.08 (-0.24 to 0.39); (p=0.64)^a^ | 1 | 0.56 (0.42 to 0.69) | 0.79 (0.69 to 0.90) | -0.24 (-0.41 to -0.07); (p=0.01)^a^ | 1
NMP22 quantitative (A) vs. ImmunoCyt (B) | Evaluation of symptoms | 0.69 (0.61 to 0.76) | 0.75 (0.67 to 0.81) | -0.06 (-0.17 to 0.04); 0.001 (p=0.87) | 2 | 0.56 (0.47 to 0.65) | 0.72 (0.64 to 0.80) | -0.16 (-0.28 to -0.04); 0.02 (p=0.55) | 2
NMP22 quantitative (A) vs. ImmunoCyt (B) | Tumor grade G1 | 0.59 (0.43 to 0.73) | 0.67 (0.51 to 0.80) | -0.08 (-0.29 to 0.14); <0.0001 (p=1.0) | 2 | No data | No data | -- | --
NMP22 quantitative (A) vs. ImmunoCyt (B) | G2 | 0.66 (0.54 to 0.76) | 0.79 (0.68 to 0.87) | -0.13 (-0.27 to 0.01) | 2 | No data | No data | -- | --
NMP22 quantitative (A) vs. FISH (B) | Evaluation of symptoms | 0.68 (0.60 to 0.75) | 0.74 (0.66 to 0.80) | -0.06 (-0.16 to 0.04); 0.001 (p=0.85) | 2 | 0.58 (0.40 to 0.74) | 0.76 (0.60 to 0.87) | -0.18 (-0.28 to -0.08); 0.22 (p=0.33) | 2
NMP22 quantitative (A) vs. FISH (B) | Tumor grade G1 | 0.59 (0.43 to 0.73) | 0.54 (0.38 to 0.69) | 0.05 (-0.17 to 0.27); <0.0001 (p=1.0) | 2 | No data | No data | -- | --
NMP22 quantitative (A) vs. FISH (B) | G2 | 0.66 (0.54 to 0.76) | 0.76 (0.66 to 0.85) | -0.11 (-0.25 to 0.04); <0.0001 (p=1.0) | 2 | No data | No data | -- | --
ImmunoCyt (A) vs. FISH (B) | Evaluation of symptoms | 0.71 (0.54 to 0.84) | 0.61 (0.43 to 0.76) | 0.11 (0.001 to 0.21); 0.31 (p=0.30) | 3 | 0.71 (0.62 to 0.79) | 0.79 (0.71 to 0.85) | -0.08 (-0.15 to -0.001); 0.07 (p=0.34) | 3
ImmunoCyt (A) vs. FISH (B) | Tumor stage Ta | 0.71 (0.46 to 0.87) | 0.36 (0.17 to 0.61) | 0.35 (0.13 to 0.56); 0.29 (p=0.40) | 2 | No data | No data | -- | --
ImmunoCyt (A) vs. FISH (B) | T1 | 0.89 (0.66 to 0.97) | 0.58 (0.36 to 0.77) | 0.32 (0.05 to 0.58); <0.0001 (p=1.0) | 2 | No data | No data | -- | --
ImmunoCyt (A) vs. FISH (B) | Low grade (G1 or low grade) | 0.65 (0.47 to 0.80) | 0.42 (0.25 to 0.60) | 0.24 (0.05 to 0.24); 0.17 (p=0.40) | 3 | No data | No data | -- | --
Biomarker + cytology (A) versus biomarker alone (B) | Overall | 0.81 (0.75 to 0.86) | 0.69 (0.61 to 0.76) | 0.13 (0.08 to 0.17); 0.42 (p=0.0003) | 16 | 0.74 (0.70 to 0.78) | 0.75 (0.71 to 0.79) | -0.01 (-0.04 to 0.02); 0.12 (p=0.001) | 13
Biomarker + cytology (A) versus biomarker alone (B) | Tumor stage Ta | 0.82 (0.75 to 0.87) | 0.79 (0.72 to 0.85) | 0.03 (-0.05 to 0.11); 0.01 (p=0.73) | 5 | No data | No data | -- | --
Biomarker + cytology (A) versus biomarker alone (B) | T1 | 0.87 (0.75 to 0.94) | 0.85 (0.73 to 0.92) | 0.02 (-0.11 to 0.15); <0.0001 (p=1.0) | 5 | No data | No data | -- | --
Biomarker + cytology (A) versus biomarker alone (B) | Low grade (G1, low grade, or low malignant potential) | 0.74 (0.63 to 0.82) | 0.73 (0.63 to 0.82) | -0.01 (-0.10 to 0.09) | 6 | No data | No data | -- | --
ImmunoCyt + cytology (A) versus ImmunoCyt alone (B) | | 0.79 (0.68 to 0.87) | 0.69 (0.56 to 0.80) | 0.09 (0.03 to 0.16); 0.55 (p=0.01) | 8 | 0.74 (0.68 to 0.79) | 0.75 (0.70 to 0.80) | -0.02 (-0.05 to 0.01); 0.13 (p=0.01) | 7

BTA = bladder tumor antigen; CI = confidence interval; CIS = carcinoma in situ; FISH = fluorescence in situ hybridization; NMP22 = nuclear matrix protein-22; U/mL = units per milliliter

a Based on Fisher's exact test

Three studies found ImmunoCyt associated with higher sensitivity than FISH (0.71 [95% CI 0.54 to 0.84] vs. 0.61 [95% CI 0.43 to 0.76], for a difference of 0.11 [95% CI 0.001 to 0.21]) but lower specificity (0.71 [95% CI 0.62 to 0.79] vs. 0.79 [95% CI 0.71 to 0.85], for a difference of -0.08 [95% CI -0.15 to -0.001]).75,85,87 ImmunoCyt was also associated with higher sensitivity than FISH for Ta, T1, and low grade numbers (differences in sensitivity ranged from 0.24 to 0.35).

Two studies found qualitative BTA associated with lower specificity than FISH (difference -0.16, 95% CI -0.24 to -0.08),40,87 two studies found quantitative NMP22 associated with lower specificity than ImmunoCyt (difference -0.16, 95% CI -0.28 to -0.04),75,87 and two studies found quantitative NMP22 associated with lower specificity than FISH (difference -0.18, 95% CI -0.28 to -0.08),75,87 with no clear differences in sensitivity. Evidence for other head-to-head comparisons of urinary biomarkers was based on one or two studies with imprecise estimates and methodological shortcomings, precluding reliable conclusions regarding comparative test performance (Table 4).

Sixteen studies found sensitivity of various urinary biomarkers plus cytology associated with higher sensitivity than the urinary biomarker alone (0.81, 95% CI 0.75 to 0.86 vs. 0.69, 95% CI 0.61 to 0.76, for a difference of 0.13, 95% CI 0.08 to 0.17), with no difference in specificity (Table 4);31,34,36,38,45,48,50,53,55,69,77,79,85-88 results were similar in a subgroup of eight studies of ImmunoCyt plus Cytology versus ImmunoCyt alone.31,48,50,79,85-88 In studies that stratified analyses according to tumor stage and grade, there were no clear differences in sensitivity for Ta, T1, or low grade (G1, low grade, or low malignant potential).31,48,50,79,85-88

## Key Question 1a Does the diagnostic accuracy differ according to patient characteristics (e.g., age, sex, race/ethnicity) or according to the nature of the presenting signs or symptoms?

### Key Points

- Effects of tumor stage: Across urinary biomarkers, sensitivity increased with higher tumor stage. Evidence was most robust for quantitative NMP22 (11 studies), qualitative BTA (18 studies), and FISH (8 studies); the association between higher tumor stage and increased sensitivity was least pronounced for ImmunoCyt (10 studies). Sensitivity for CIS tumors was generally similar to or slight lower than for T1 tumors (SOE: high).
- Effects of tumor grade: Across urinary biomarkers, sensitivity increased with higher tumor grade. Evidence was most robust for quantitative NMP22 (12 studies), ImmunoCyt (10 studies), qualitative BTA (18 studies), and FISH (9 studies) (SOE: high).
- Effects of tumor size: Two studies found sensitivity was higher for larger (>1 cm or >2 cm) smaller tumors (SOE: low).
- Evidence on the effects of patient characteristics such as age, sex, smoking status, and presence of other clinical conditions on diagnostic accuracy of urinary biomarkers was limited, but did not clearly or consistently indicate effects on sensitivity or specificity (SOE: low).

### Detailed Synthesis

Across urinary biomarkers, sensitivity increased with higher tumor stage (Table 5). For quantitative NMP 22, sensitivity for Ta tumors was 0.48 (95% CI 0.36 to 0.60; 10 studies), for T1 tumors was 0.72 (95% CI 0.60 to 0.81; 11 studies), and for ≥T2 tumors was 0.82 (95% CI 0.70 to 0.89; 11 studies; p=0.002 for overall difference between categories).30,32,33,39,52,60,61,83,87,89 The difference in sensitivity between T1 and Ta tumors was 0.23 (95% CI 0.14 to 0.32) and between ≥T2 and T1 tumors was 0.10 (95% CI 0.01 to 0.20). For qualitative BTA, sensitivity for Ta tumors was 0.49 (95% CI 0.41 to 0.56; 18 studies), for T1 tumors was 0.74 (95% CI 0.66 to 0.80; 17 studies), and for ≥T2 tumors was 0.89 (95% CI 0.83 to 0.93; 17 studies; p<0.0001 for overall difference between categories).32,33,39,40,42,44,45,49,56,58,60,62,64,70,77,83,87,89 The difference in sensitivity between T1 and Ta tumors was 0.25 (95% CI 0.18 to 0.32) and between ≥T2 and T1 tumors was 0.15 (95% CI 0.08 to 0.22). A similar pattern was observed for FISH, based on eight studies (Table 4).40,55,62,71,76,84,85,87 For quantitative NMP22, FISH, and qualitative BTA, sensitivity for CIS tumors was similar or slightly lower than for T1 tumors. For ImmunoCyt, the association between higher tumor stage and increased sensitivity was less clear. Sensitivity for Ta tumors was 0.74 (0.63 to 0.83) and for T1 and ≥T2 tumors was 0.81, based on 10 studies.31,46,48,50,81,82,85-87

Table 5 Sensitivity of urinary biomarkers for bladder cancer according to tumor stage and grade

Biomarker | | Sensitivity (95% CI); τ^2^ (p value) | Number of Studies | Comparison | Difference in Sensitivity | Overall Difference Across Categories: p value for chi-square
NMP22 (quantitative) | Tumor stage Ta | 0.48 (0.36 to 0.60); 0.46 (p=0.01) | 10 | T1 vs. Ta | 0.23 (0.14 to 0.32) | p=0.002
NMP22 (quantitative) | T1 | 0.72 (0.60 to 0.81) | 11 | ≥T2 vs. T1 | 0.10 (0.01 to 0.20) | --
NMP22 (quantitative) | ≥T2 | 0.82 (0.70 to 0.89) | 11 | Ta vs. CIS | -0.18 (-0.43 to 0.07) | --
NMP22 (quantitative) | CIS | 0.66 (0.38 to 0.86) | 6 | -- | -- | --
NMP22 (quantitative) | Tumor grade G1 | 0.44 (0.32 to 0.57); 0.44 (p=0.004) | 12 | G2 vs. G1 | 0.14 (0.05 to 0.24) | p<0.0001
NMP22 (quantitative) | G2 | 0.58 (0.47 to 0.69) | 12 | G3 vs. G2 | 0.16 (0.09 to 0.24) | --
NMP22 (quantitative) | G3 | 0.75 (0.65 to 0.83) | 12 | -- | -- | --
NMP22 (qualitative) | Tumor stage Ta | 0.39 (0.30 to 0.49); 0.02 (p=0.57) | 3 | T1 vs. Ta | 0.14 (-0.02 to 0.29) | p=0.37
NMP22 (qualitative) | T1 | 0.53 (0.40 to 0.66) | 3 | ≥T2 vs. T1 | 0.58 (-0.05 to 0.36) | --
NMP22 (qualitative) | ≥T2 | 0.69 (0.51 to 0.83) | 3 | Ta vs. CIS | -0.18 (-0.56 to 0.21) | --
NMP22 (qualitative) | CIS | 0.57 (0.22 to 0.86) | 2 | -- | -- | --
NMP22 (qualitative) | Tumor grade G1 | 0.36 (0.23 to 0.51); 0.07 (p=0.36) | 3 | G2 vs. G1 | 0.06 (-0.12 to 0.25) | p=0.03
NMP22 (qualitative) | G2 | 0.42 (0.29 to 0.56) | 3 | G3 vs. G2 | 0.30 (0.13 to 0.46) | --
NMP22 (qualitative) | G3 | 0.65 (0.52 to 0.77) | 3 | -- | -- | --
FISH | Tumor stage Ta | 0.49 (0.31 to 0.66); 0.89 (p=0.02) | 8 | T1 vs. Ta | 0.30 (0.18 to 0.42) | p=0.002
FISH | T1 | 0.79 (0.61 to 0.90) | 7 | ≥T2 vs. T1 | 0.11 (-0.01 to 0.23) | --
FISH | ≥T2 | 0.89 (0.75 to 0.96) | 7 | Ta vs. CIS | -0.42 (-0.60 to -0.24) | --
FISH | CIS | 0.91 (0.66 to 0.98) | 4 | -- | -- | --
FISH | Tumor grade G1 | 0.46 (0.34 to 0.59); 0.17 (p=0.07) | 7 | G2 vs. G1 | 0.28 (0.15 to 0.40) | p<0.0001
FISH | G2 | 0.74 (0.63 to 0.82) | 7 | G3 vs. G2 | 0.21 (0.11 to 0.30)
FISH | G3 | 0.94 (0.88 to 0.98) | 7 | -- | -- | --
Quantitative BTA | Tumor stage Ta | 0.53 (0.39 to 0.66); 0.04 (p=0.71) | 4 | T1 vs. Ta | 0.29 (0.13 to 0.46) | p=0.11
Quantitative BTA | T1 | 0.82 (0.67 to 0.91) | 4 | ≥T2 vs. T1 | 0.06 (-0.09 to 0.22) | --
Quantitative BTA | ≥T2 | 0.88 (0.72 to 0.96) | 4 | Ta vs. CIS | -0.05 (-0.44 to 0.34) | --
Quantitative BTA | CIS | 0.58 (0.23 to 0.86) | 2 | -- | -- | --
Quantitative BTA | Tumor grade G1 | 0.51 (0.36 to 0.67); 0.08 (p=0.42) | 4 | G2 vs. G1 | 0.12 (-0.06 to 0.29) | p=0.03
Quantitative BTA | G2 | 0.63 (0.47 to 0.76) | 4 | G3 vs. G2 | 0.23 (0.07 to 0.38) | --
Quantitative BTA | G3 | 0.86 (0.73 to 0.93) | 4 | -- | -- | --
Qualitative BTA | Tumor stage Ta | 0.49 (0.41 to 0.56); 0.28 (p=0.0003) | 18 | T1 vs. Ta | 0.25 (0.18 to 0.32) | p<0.0001
Qualitative BTA | T1 | 0.74 (0.66 to 0.80) | 17 | ≥T2 vs. T1 | 0.15 (0.08 to 0.22) | --
Qualitative BTA | ≥T2 | 0.89 (0.83 to 0.93) | 17 | Ta vs. CIS | -0.20 (-0.34 to -0.06) | --
Qualitative BTA | CIS | 0.68 (0.52 to 0.81) | 10 | -- | -- | --
Qualitative BTA | Tumor grade G1 | 0.39 (0.30 to 0.48); 0.40 (p=0.0001) | 19 | G2 vs. G1 | 0.24 (0.17 to 0.32) | p<0.0001
Qualitative BTA | G2 | 0.63 (0.54 to 0.71) | 19 | G3 vs. G2 | 0.18 (0.12 to 0.25) | --
Qualitative BTA | G3 | 0.81 (0.75 to 0.87) | 19 | -- | -- | --
ImmunoCyt | Tumor stage Ta | 0.74 (0.63 to 0.83); 0.42 (p=0.01) | 9 | T1 vs. Ta | 0.06 (-0.05 to 0.17) | p=0.60
ImmunoCyt | T1 | 0.81 (0.67 to 0.90) | 9 | ≥T2 vs. T1 | 0.002 (-0.13 to 0.13) | --
ImmunoCyt | ≥T2 | 0.81 (0.68 to 0.89) | 10 | Ta vs. CIS | -0.16 (-0.27 to -0.05) | --
ImmunoCyt | CIS | 0.90 (0.76 to 0.96) | 9 | -- | -- | --
ImmunoCyt | Tumor grade G1 | 0.73 (0.63 to 0.81) | 6 | G2 vs. G1 | 0.10 (0.01 to 0.19) | p=0.20
ImmunoCyt | G2 | 0.83 (0.75 to 0.89) | 6 | G3 vs. G2 | 0.003 (-0.07 to 0.08) | --
ImmunoCyt | G3 | 0.83 (0.75 to 0.89) | 6 | -- | -- | --
ImmunoCyt | Low grade^a^ | 0.74 (0.66 to 0.80); 0.09 (p=0.05) | 10 | High vs. low grade | 0.10 (0.03 to 0.17) | --
ImmunoCyt | High grade^a^ | 0.83 (0.78 to 0.88) | 10 | -- | -- | --

BTA = bladder tumor antigen; CI = confidence interval; CIS = carcinoma in situ; FISH = fluorescence in situ hybridization; NMP22 = nuclear matrix protein-22

a Low grade=G1, low grade, or low malignant potential, high grade=G2, G3, or high grade.

Sensitivity also increased across urinary biomarkers with higher tumor grade (Table 5). For quantitative NMP22, sensitivity for G1 tumors was 0.44 (95% CI 0.32 to 0.57), for G2 tumors was 0.58 (95% CI 0.47 to 0.69), and for G3 tumors was 0.75 (95% CI 0.65 to 0.83), based on 12 studies (p<0.0001 for difference between categories).30,32,33,39,52,60,61,63,75,83,87,89 The difference in sensitivity between G2 and G1 tumors was 0.14 (95% CI 0.05 to 0.24) and between G3 and G2 tumors was 0.16 (95% CI 0.09 to 0.24). For qualitative BTA, sensitivity for G1 tumors was 0.39 (95% CI 0.30 to 0.48), for G2 tumors was 0.63 (95% CI 0.54 to 0.71), and for G3 tumors was 0.81 (95% CI 0.75 to 0.87), based on 19 studies (p<0.0001 for difference between categories).32,33,39-42,44,45,49,56,58,60,62,64,70,77,83,87,89 The difference in sensitivity between G2 and G1 tumors was 0.24 (95% CI 0.17 to 0.32) and between G3 and G2 tumors was 0.18 (95% CI 0.12 to 0.25). A similar pattern was observed for FISH, based on seven studies (Table 5).40,55,62,71,75,84,87 For ImmunoCyt, sensitivity for low-grade (G1, low grade, or low malignant potential) tumors was 0.74 (95% CI 0.66 to 0.80) and for high-grade tumors (G2, G3, or high grade) was 0.83 (95% CI 0.78 to 0.88), for a difference of 0.10 (95% CI 0.03 to 0.17), based on 10 studies.46,48,50,75,79,81,82,85-87

Similar patterns for effects of tumor stage and grade were observed for other urinary biomarkers (Table 5). However, estimates were based on smaller numbers of studies and were less precise, and differences were not always statistically significant.

One study found higher sensitivity of qualitative BTA for tumors 2 to 5 cm (0.96) and >5 cm (1.0) than for tumors <2 cm (0.60, Fisher's exact p<0.0005)56 and one study found higher sensitivity of FISH for tumors 1-3 cm (0.93) or >3 cm (0.94) than for tumors <1 cm (0.46, Fisher's exact p=0.001).55

Few studies evaluated effects of patient characteristics on diagnostic accuracy of urinary biomarkers. One study found quantitative and qualitative NMP22 and CxBladder each associated with higher sensitivity for multifocal versus unifocal tumors, though differences were not statistically significant.52 There were no clear differences in diagnostic accuracy according to sex, age, or smoking status.35,52,58 Three studies74,81,82 of ImmunoCyt that specifically enrolled patients with microscopic or macroscopic hematuria reported sensitivity and specificity that was similar to the overall estimates from studies of patients with signs or symptoms of bladder cancer. One study of quantitative NMP22 did not find a difference in sensitivity between patients who had received prior intravesical therapy and those who had not.65

Eight studies of various urinary biomarkers did not find consistent differences in specificity according to factors such as presence of other urological cancers, renal calculi, prostatitis, benign prostatic hypertrophy, urinary tract infection, or hematuria, though specificity was higher when other urological conditions were not present in some studies.50,52,67,69,77,81,82,89

## Key Question 2 For patients with non–muscle-invasive bladder cancer, does the use of a formal risk-adapted assessment approach to treatment decisions (e.g., based on Guidelines of the European Association of Urology or on urinary biomarker tests) decrease mortality or improve other outcomes (e.g., recurrence, progression, need for cystectomy, quality of life) compared with treatment not guided by a formal assessed risk-adapted approach?

### Key Points

- No study compared clinical outcomes associated with use of a formal risk-adapted approach to guide treatment of NMIBC versus treatment not guided by a risk-adapted approach (SOE: insufficient).

### Detailed Synthesis

Though scoring systems to predict the risk of bladder cancer recurrence and disease progression are available and have undergone some validation,90-94 no study compared clinical outcomes associated with use of a formal risk-adapted approach to guide treatment of NMIBC versus treatment not guided by a risk-adapted approach.

## Key Question 3 For patients with non–muscle-invasive bladder cancer treated with transurethral resection of bladder tumor, what is the effectiveness of various intravesical chemotherapeutic or immunotherapeutic agents for decreasing mortality or improving other outcomes (e.g., recurrence, progression, need for cystectomy, quality of life) compared with TURBT alone?

### Key Points

#### BCG

- BCG was associated with decreased risk of bladder cancer recurrence (3 trials, RR 0.56, 95% CI 0.43 to 0.71, I^2^=0%) and progression (4 trials, RR 0.39, 95% CI 0.24 to 0.64, I^2^=40%) versus no intravesical therapy. No trial evaluated effects of BCG versus no intravesical therapy on risk of all cause mortality. One trial found BCG associated with decreased risk of bladder cancer mortality, but the difference was not statistically significant (RR 0.62, 95% CI 0.32 to 1.19). (SOE: insufficient for all-cause and bladder cancer mortality; SOE: low for recurrence and progression).

#### MMC

- Mitomycin C (MMC) was associated with decreased risk of bladder cancer recurrence versus no intravesical therapy (8 trials, RR 0.71, 95% CI 0.57 to 0.89, I^2^=72%), but there was no difference in risk of all cause-mortality (1 trial, HR 1.17, 95% CI 0.89 to 1.53) and effects on bladder cancer-specific mortality (1 trial, HR 0.71, 95% CI 0.34 to 1.46) and bladder cancer progression (5 trials, RR 0.68, 95% CI 0.39 to 1.20, I^2^=0%) were not statistically significant (SOE: moderate for recurrence, low for progression, all-cause mortality, and bladder cancer-specific mortality).

#### Doxorubicin

- Doxorubicin was associated with decreased risk of bladder cancer recurrence versus no intravesical therapy (10 trials, RR 0.80, 95% CI 0.72 to 0.88, I^2^=46%), no difference in risk of bladder cancer progression (5 trials, RR 1.03, 95% CI 0.72 to 1.46, I^2^=0%), and no clear effects on all-cause mortality (2 trials) or bladder cancer specific mortality (1 trial) (SOE: moderate for recurrence, low for progression, all-cause mortality, and bladder-cancer specific mortality).

#### Epirubicin

- Epirubicin was associated with decreased risk of bladder cancer recurrence (9 trials, RR 0.63, 95% CI 0.53 to 0.75, I^2^=64%) (SOE: moderate) but the effect on bladder cancer progression was not statistically significant (8 trials, RR 0.79, 95% CI 0.84 to 1.30, I^2^=27%) (SOE: low).

#### Gemcitabine

- One trial found no difference between single instillation gemcitabine versus no intravesical therapy in risk of bladder cancer recurrence (RR 0.98, 95% CI 0.70 to 1.36); estimates for progression (RR 3.00, 95% CI 0.32 to 28.4), all-cause mortality (RR 0.50, 95% CI 0.13 to 2.00), and bladder cancer-specific mortality were very imprecise (RR 1.00, 95% CI 0.06 to 15.81) (SOE: low for bladder cancer recurrence; SOE: insufficient for all-cause and bladder cancer mortality and progression).

#### Interferon Alpha

- Interferon alpha was associated with decreased risk of bladder cancer recurrence versus no intravesical therapy that was not statistically significant (3 trials, RR 0.75, 95% CI 0.53 to 1.06, I^2^=50%), decreased risk of bladder cancer progression (2 trials, RR 0.33, 95% CI 0.14 to 0.76, I^2^=0%), and no difference in risk of bladder cancer specific mortality (1 trial, RR 1.00, 95% CI 0.15 to 6.75) (SOE: low).

#### Interferon Gamma

- Interferon-gamma was associated with decreased risk of bladder cancer recurrence versus no intravesical therapy (1 trial, RR 0.72, 95% CI 0.51 to 1.01), with no difference in risk of bladder cancer progression (1 trial, RR 1.08, 95% CI 0.07 to 16.4) (SOE: low).

#### Thiotepa

- Thiotepa was associated with decreased risk of bladder cancer recurrence versus no intravesical therapy that was not statistically significant (5 trials, RR 0.78, 95% CI 0.58 to 1.06, I^2^=69%), with insufficient evidence to determine effects on progression or mortality (SOE: low for recurrence, insufficient for all-cause and bladder cancer mortality and progression).

### Detailed Synthesis

Thirty-seven trials (reported in 46 publications) evaluated intravesical therapy plus TURBT versus TURBT without intravesical therapy (Tables 6, 7, 8, 9, 10, 11, 12; Appendixes E2, F2).95-140 Five trials evaluated BCG,102-111 seven trials MMC,111-118 nine trials doxorubicin,112,113,115,116,119-125 10 trials epirubicin,103,119,126-134 3 trials interferon alpha,132,133,137,141 one trial interferon-gamma,138 two trials thiotepa,139,140 and one trial gemcitabine.135 Samples sizes ranged from 24 to 553 and duration of followup from a median of 9 months to 10.7 years. Mean age ranged from 52.1 to 71 years and the proportion of patients who were male ranged from 62.9 to 98 percent. Eight trials excluded patients with G3 tumors and 15 trials excluded patients with CIS lesions. In the other trials, the proportion with G3 tumors ranged from 0 to 43 percent and the proportion with CIS lesions ranged from 0 to 88 percent. Seven trials focused on patients with primary tumors and 11 trials focused on patients with recurrent tumors. One trial was rated high risk of bias,105,110 and 35 trials medium risk of bias (Appendix F2)102-104,106-109,111-140 Two trials reported blinding of outcomes assessors;127,132,133 no trial blinded care provider or patients. Other methodological limitations included inadequate description of randomization and allocation concealment, and high attrition or failure to report attrition. Results are summarized in Table 15.

Table 6 Summary of bacillus Calmette-Guérin study characteristics and results

Comparison | Author, Year | Population | Intervention | Results/Followup
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | DeBruyne, 1992^160^ Debruyne, 1988^150^ Witjes, 1998^159^ | Primary or recurrent superficial bladder cancer, including CIS, Ta, T1 | A. BCG-RIVM (5 × 10^8 CFU) in 50 mL saline weekly for 6 weeks B. MMC 30 mg in 50 mL saline weekly for 4 weeks then monthly for 6 months | Recurrence: 42% vs. 36% 7 year followup: Recurrence 48% vs. 43% Progression 12% vs. 7% Mortality: 46 vs. 51 Malignant disease: 15 vs. 18 Median followup: 21 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Di Stassi, 2003^155^ | Histologically proven multifocal carcinoma in situ of the bladder and most had concurrent pT1 papillary transitional cell carcinoma | A. BCG 81 mg, 6 weekly instillations then monthly instillations for 10 months B. MMC 40 mg, 6 weekly instillations then monthly instillations for 10 months C. MMC 40 mg (electromotive), 6 weekly instillations then monthly instillations for 10 months | Overall mortality: 11/36 vs. 12/36 vs. 9/36 Recurrence: 19/36 vs. 27/36 vs. 19/36 Progression: 6/36 vs. 8/36 vs. 6/36 Granulomatous cystitis: 24/36 vs. 9/36 vs. 13/36 Fever: 7/36 vs. 0/36 vs. 0/36 Hematuria: 26/36 vs. 6/36 vs. 8/36 Median followup: 43 vs. 42 vs. 45 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Friedrich, 2007^154^ | Patients with primary transitional cell carcinoma of the bladder or tumor recurrence after TURBT without prior adjuvant therapy were eligible if pTaG1 tumor (size>3cm, recurrent or multifocal tumor) or pTaG2 up to pT1 tumor (G1-3). Patients with apT1G3 tumor were eligible in case of a unifocal small tumor (≤2.5 cm). | A. BCG RVIM, 6 weekly instillations B. MMC 20 mg, 6 weekly instillations C. MMC 20 mg, 6 weekly instillations followed by monthly instillations for 3 years | Recurrence: 41/163 vs. 46/179 vs. 16/153 Dysuria: 28/163 vs. 21/179 vs. 31/153 Hematuria: 19/163 vs. 1/179 vs. 14/153 Fever: 15/163 vs. 4/179 vs. 4/153 Median followup: 2.9 years
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Gardmark, 2007^157^ Lundholm, 1996^152^ Malmstrom, 1999^158^ | Stage Ta, grades 1 to 3 or stage T1, grades 1 and 2 tumors were included provided there had been at least 3 tumor events during the prior 18 months. Patients with stage T1 grade 3 and those with primary or concomitant dysplasia or carcinoma in situ were included without having had prior tumor events | A. BCG 120 mg, 6 weekly instillations followed by monthly instillations for 1 year then quarterly for 1 year B. MMC 40 mg, 6 weekly instillations followed by monthly instillations for 1 year then quarterly for 1 year | Overall mortality: 68/125 vs. 72/125 Bladder cancer mortality: 19/125 vs. 26/125 Progression: 24/125 vs. 34/125 Fever: 29/125 vs. 7/125 DC instillations: 16/125 vs. 10/125 Dysuria: 100/125 vs. 87/125 Hematuria: 112/125 vs. 78/125 Median followup: 39 months; Also 10 year followup
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Gulpinar, 2012^162^ | Patients with intermediate or high risk for recurrence and progression according to the EAU guidelines were included. Patients with stage pTaG1or pTaG2 tumors were included if tumor size>3cm or recurrent or multifocal tumors. Patients with CIS, pTaG3 tumors and all pT1 tumors were included | A. BCG 5×10^8^ CFU, 6 weekly instillations beginning at least 15 days from TURBT B. MMC 40, single dose at surgery followed by 6 weekly BCG instillations beginning at least 15 days from TURBT | Recurrence: 5/26 vs. 9/25 Progression: 1/26 vs. 1/25 Cystectomy: 1/26 vs. 1/25 Median followup: 41months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Jarvinen, 2009^161^ Rintala, 1991^149^ | Frequently recurrent TaT1 tumors and/or CISTa-T1 cancers with a minimum of two episodes of recurrence during the preceding 1.5 years | A. BCG 75 mg, 5 weekly instillations beginning 2 weeks after TURBT then monthly instillations for 2 years B. MMC 30-40 mg, 5 weekly instillations beginning 2 weeks after TURBT then monthly instillations for 2 years | Overall mortality: 36/44 vs. 36/45 Bladder cancer mortality: 4/44 vs. 9/45 Recurrence: 26/44 vs. 36/45 Progression: 4/44 vs. 10/45 DC instillations: 10/44 vs. 5/45 Mean followup: 28 months; Also median followup 8.5 years
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Jarvinen, 2012^167^ Rintala, 1995^169^ (Jarvinen, 2012^167^, Rintala, 1995^169^ and Rintala, 1996^168^ are part of same trial but results reported by subgroup) | Primary, secondary, or concomitant CIS | A. BCG 75 mg + MMC varied dose, 4 weekly instillations of MMC then MMC alternating with BCG monthly for 2 years B. MMC varied dose, 4 weekly doses followed by monthly doses for two years | Overall mortality: 20/28 vs. 30/40 Bladder cancer mortality: 8/28 vs. 12/40 Recurrence: 19/28 vs. 35/40 Progression: 8/28 vs. 14/40 Cystectomy: 1/28 vs. 7/40 Mean followup: 33 months; Also median followup 7.2 years
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Kaasinen, 2003^163^ | High-grade primary, secondary, or concomitant (with pTa or pT1 tumor) carcinoma in situ of the urinary bladder | A. BCG 120 mg, 6 weekly instillations followed by monthly instillations up to one year B. MMC 40 mg, 6 weekly instillations followed monthly alternating instillations with BCG for up to 1 year | Bladder cancer mortality: 10/145 vs. 13/159 Recurrence: 53/145 vs. 71/159 Progression: 20/145 vs. 34/159 Cystectomy: 4/145 vs. 4/159 DC instillations: 37/145 vs. 10/159 Median followup: 56 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Krege, 1996^111^ | Histological evidence of superficial bladder cancer (stage pTa/1 grades 1 to 3) | A. BCG 120 mg, 6 weekly instillation then monthly for 4 months B. MMC 20 mg, instillations every 2 weeks for 1 year then monthly for 1 year | Recurrence: 26/102 vs. 30/112 Cystitis: 35/102 vs. 18/112 Cystectomy: 1/102 vs. 0/112 Fever: 18/102 vs. 0/112 Hematuria: 6/102 vs. 3/112 Mean followup: 20 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Lamm, 1995^147^ | Histologically proven, completely resected Ta (noninvasive) or T1 (lamina propria invasive) transitional cell carcinoma and at increased risk for tumor recurrence (2 occurrences of tumor within 56 weeks, stage T1 within 16 weeks of registration, or 3 or more tumors presenting simultaneously within 16 weeks) | A. BCG 50 mg, 6 weekly instillations then at 8 and 12 weeks, then monthly up to 1 year B. MMC 20 mg, 6 weekly instillations then at 8 and 12 weeks, then monthly up to 1 year | Overall mortality: 25/191 vs. 28/186 Bladder cancer mortality: 8/191 vs. 12/186 Recurrence: 77/191 vs. 101/186 Progression: 15/191 vs. 24/191 Fever: 38/222 vs. 8/220 Dysuria: 115/222 vs. 80/222 Hematuria: 85/222 vs. 57/220 Median followup: 913 days
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Mangiarotti, 2008^153^ | Nonmuscle invasive bladder cancer not previously treated with any chemotherapeutic or immunotherapeutic agent | A. BCG 50 mg, 6 weekly instillations then monthly for up to 1 year B. MMC 40 mg, 8 weekly instillations then monthly for up to 1 year | Overall mortality: 1/46 vs. 0/46 Recurrence: 23/46 vs. 23/46 Granulomatous cystitis: 16/46 vs. 10/46 Fever: 2/46 vs. 2/46 DC instillations: 2/46 vs. 11/46 Hematuria: 0/46 vs. 2/46 Mean followup: 66 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Mohsen, 2010^165^ | At least 2 histologically verified recurrent stage Ta or T1 during the preceding 1.5 years | A. BCG 5×10^8^ CFU, 6 weekly instillations 1 month after TURBT, then monthly for months 3-12 B. MMC 40 mg perioperatively, then 4 weekly instillations, then BCG monthly for months 2-13 | Recurrence: 16/27 vs. 9/29 Cystectomy: 2/27 vs. 1/29 Mean followup: 24 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Ojea, 2007^151^ | Intermediate risk with stages TaG2 and T1G1-2 superficial bladder tumors without carcinoma in situ | A. BCG 27 mg, 6 weekly instillations then 6 biweekly instillations B. BCG 13.5 mg, 6 weekly instillations then 6 biweekly instillations C. MMC 30 mg, 6 weekly instillations then 6 biweekly instillations | A vs. B vs. C Overall mortality: 13/142 vs. 17/139 vs. 27/149 Bladder cancer mortality: 3/142 vs. 5/139 vs. 7/149 Recurrence: 38/142 vs. 50/139 vs. 58/149 Progression: 14/142 vs. 18/139 vs. 14/149 Local side effects: 93/142 vs. 9/139 vs. 45/149 Systemic side effects: 16/142 vs. 15/139 vs. 7/149 Median followup: 57 vs. 61 vs. 53 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Oosterlinck, 2011^164^ | Primary, concurrent, or recurrent biopsy-proven CIS | A. BCG 5×10^8^ CFU, 6 weekly instillations, then 3 weeks rest, then 3 weekly instillations, then 3 weekly instillations every 6 months up to 3 years B. MMC 40 mg, 6 weekly instillations then 6 weekly instillations of BCG then 3 weekly instillations (one MMC then 2 BCG) every 6 months up to 3 years | Overall mortality: 11/48 vs. 7/48 Bladder cancer mortality: 6/48 vs. 3/48 Recurrence: 26/48 vs. 23/48 Progression: 5/48 vs. 2/48 Cystectomy: 5/48 vs. 8/48 Median followup: 4.7 years
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Rintala, 1996^168^ (Jarvinen, 2012^167^, Rintala, 1995^169^ and Rintala, 1996^168^ are part of same trial but results reported by subgroup | recurrent stage Ta or T1 papillary transitional cell carcinoma; no CIS | 4 weekly instillation of MMC then: A. BCG 5×10^8^ CFU + MMC 40 mg (alternating monthly) for two years B. MMC 40 monthly for two years | Recurrence: 57/92 vs. 58/90 DC instillations: 18/92 vs. 19/90 Mean followup: 34 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Sekine, 2001^145^ | Tis with or without T1 bladder cancer | A: BCG, type of BCG, dose, and number and timing of instillations not reported B: MMC, 20 mg and doxorubicin, 30 mg sequential therapy, number and timing of instillations not reported | Compete response to initial therapy (no residual CIS and negative urine cytology for at least 4 weeks): 86% (18/21) vs. 81% (17/21), RR 1.06 (95% CI 0.81 to 1.39) within 2 months of completion of therapy Complete response, including crossover therapy: 90% (19/21) vs. 100% (21/21), RR 0.90 (95% CI 0.79 to 1.04) Recurrence after complete response: 11% (2/21) vs. 52% (11/21), RR 0.18 (95% CI 0.05 to 0.72) Progression: 14% (3/21) vs. 10% (2/21), RR 1.50 (95% CI 0.28 to 8.08) Bladder cancer mortality: 10% (2/19) vs. 4.8% (1/21), RR 2.21 (95% CI 0.22 to 22.5) Duration of followup: 47 months (range 3 to 143 months) Method of followup: cystoscopy and urine cytology every 3 months and urography every 12 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Witjes, 1996^156^ Witjes, 1993^148^ Vegt, 1995^211^ | Histologically proven papillary pTa-pT1 transitional cell transitional cell carcinoma of the bladder with or without CIS | A. BCG TICE 5×10^8^ CFU, 6 weekly instillations with a B. BCG RIVM 5×10^8^, 6 weekly instillations C. MMC 30 mg, 4 weekly instillations then monthly for 5 months If recurrence then additional instillations in all groups | A vs. B vs. C Recurrence: 75/117 vs. 62/134 vs. 58/136 Progression: 7/117 vs. 8/134 vs. 8/136 Granulomatous cystitis: 38/140 vs. 34/149 vs. 27/148 Local side effects: 23/140 vs. 22/149 vs. 7/148 Systemic side effects: 38/140 vs. 27/149 vs. 6/148 Median followup: 32 months
BCG vs. MMC; BCG vs. MMC+BCG; BCG+MMC vs. MMC | Witjes, 1998b166 | Histologically proved primary multiple (more than 2 tumors) or recurrent multiple (2 or more tumors) stage pTa or pT1 transitional cell carcinoma, solitary or multiple grade III tumors and primary or concomitant CIS | A. BCG 5×10^8^ CFU + MMC 40 mg, 4 weekly instillations of MMC then 6 weekly instillations of BCG B. MMC 40, 10 weekly instillations | Overall mortality: 21/90 vs. 14/92 Bladder cancer mortality: 5/90 vs. 8/92 Recurrence: 35/90 vs. 42/92 Progression: 5/90 vs. 4/92 Local side effects: 12/90 vs. 9/92 Granulomatous cystitis: 37/90 vs. 29/92 Systemic side effects: 21/90 vs. 20/92 Fever: 11/90 vs. 3/92 Median followup: 32 months
BCG vs. Epirubicin; BCG vs. Epirubicin + BCG | Ali-El-Dein, 1999^180^ | Grade 2 or 3, stage pT1 disease, rapid disease recurrence within 6 months of initial resection, multicentricity, aneuploid DNA pattern, tumor size equal to or not more than 3 cm, assoc carcinoma in situ or other dysplastic mucosal changes and/or positive postoperative urinary cytology | A. BCG 5×10^8^-5×10^9^ CFU, 6 weekly then 10 monthly instillations B. Epirubicin 50 mg + BCG 5×10^8^-5×10^9^ CFU, 6 weekly then 10 monthly instillations alternating BCG and epirubicin | Recurrence: 12/58 vs. 7/66 Progression: 5/58 vs. 3/66 Granulomatous cystitis: 36/58 vs. 18/66 Hematuria: 4/58 vs. 0/66 Fever: 3/58 vs. 0/66 DC instillations: 12/58 vs. 3/66 Systemic side effects: 21/58 vs. 4/66 Mean followup: 30 months
BCG vs. Epirubicin; BCG vs. Epirubicin + BCG | Bilen, 2000^181^ | Superficial transitional-cell carcinoma of the bladder; patients with pT1 who had an additional one of four prognostic factors (grade 3 tumors, multiple tumors, tumors greater than 40 mm, recurrent tumors) were included | A. BCG 81 mg, 6 weekly instillations B. Epirubicin 50 mg + BCG 81 mg, epirubicin given weeks 1-4 and week 12 and BCG given weeks 5-7, and 9-11 | Recurrence: 4/21 vs. 3/20 Progression: 2/21 vs. 1/20 Hematuria: 8/21 vs. 4/20 Fever: 3/21 vs. 2/20 Dysuria: 9/21 vs. 7/20 Median followup: 18 months
BCG vs. Epirubicin; BCG vs. Epirubicin + BCG | Cai, 2008^179^ | High risk NMIBC patients with recurrent urothelial cancer and with tumor recurrence at same stage and grade of the initial tumor at diagnosis | A. BCG 5×10^8^ CFU, 6 weekly instillations with boosters at 3, 6, 12, 18, 24, 30, and 36 months B. Epirubicin 80 mg + BCG 5×10^8^ CFU, epirubicin given perioperatively then 6 weekly instillations of BCG with BCG boosters 3, 6, 12, 18, 24, 30, and 36 months | Recurrence: 40/81 vs. 34/80 Progression: 4/81 vs. 2/80 Median followup: 15 months
BCG vs. Epirubicin; BCG vs. Epirubicin + BCG | Cheng, 2005^174^ | Superficial bladder cancer (Ta or T1) with one or more of the following: stage>a, grade>1size>1cm or multiple or recurrent tumors | A. BCG 81 mg, 6 weekly instillations then 10 monthly instillations B. Epirubicin 50 mg, 4 weekly instillations then 5 monthly instillation then quarterly for 6 months | Overall mortality: 41/102 vs. 41/107 Bladder cancer mortality: 13/102 vs. 7/107 Recurrence: 30/102 vs. 59/107 Progression: 16/102 vs. 16/107 Median followup: 23 months for recurrence, 47 months for progression, 61 months for survival
BCG vs. Epirubicin; BCG vs. Epirubicin + BCG | De Reijke, 2005^177^ | Patients with biopsy proven primary, secondary or concurrent CIS of the bladder with or without primary urinary cytology. | A. BCG 81 mg, 6 weekly instillations then at months 3, 6, 12, 18, 24, 30, 36 B. Epirubicin 50 mg, 8 weekly instillations then at months 3, 6, 12, 18, 24, 30, 36 | Overall mortality: 26/84 vs. 34/84 Bladder cancer mortality: 9/84 vs. 13/84 Granulomatous cystitis: 21/80 vs. 7/82 Hematuria: 33/80 vs. 23/82 Fever: 6/80 vs. 0/82 DC instillations: 26/81 vs. 8/82 Local side effects: 16/80 vs. 5/82 Dysuria: 19/80 vs. 8/82 Median followup: 67 months
BCG vs. Epirubicin; BCG vs. Epirubicin + BCG | Melekos, 1993^103^ | Histologically proven superficial transitional cell carcinoma of the bladder; primary or recurrent neoplasms | A. BCG 150 mg, 6 weekly instillations then quarterly for 2 years then semi-annually B. Epirubicin 50 mg, 6 weekly instillations then quarterly for 2 years then semi-annually | Recurrence: 20/62 vs. 27/67 Progression: 4/62 vs. 6/67 Granulomatous cystitis: 49/62 vs. 23/67 Hematuria: 14/62 vs. 10/67 Fever: 17/62 vs. 2/67 Total months of followup: 1784 vs. 1745 months
BCG vs. Epirubicin; BCG vs. Epirubicin + BCG | Melekos, 1996^175^ | Completely resectable recurrent (at least 2 recurrences in the most recent 12 months) or multiple (more than 2) papillary superficial bladder tumors Ta and T1 of any grade | A. BCG 5×10^8^ CFU, 6 weekly instillations then quarterly for 2 years then semiannually (if T1 or TaG2/G3 then 3 weekly doses at 6 months) B. Epirubicin 50 mg, 4 weekly instillations then quarterly for 2 years then semiannually (if T1 or TaG2/G3 then 3 weekly doses at 3 and 6 months) | Recurrence: 26/58 vs. 34/61 Progression: 7/58 vs. 10/61 Granulomatous cystitis: 39/58 vs. 23/61 Hematuria: 14/58 vs. 10/61 Median followup: 43 months
BCG vs. Epirubicin; BCG vs. Epirubicin + BCG | Hinotsu, 2011^176^ | Recurrent or multiple tumors with confirmed Ta or T1 transitional cell carcinoma; must have 1 of the following: (a) at least 3 tumors (b) recurrence is at least the third such event or (c) recurrence diagnosed within 12 months from previous TURBT for NMIBC | A. BCG 81 mg, 6 weekly instillations then 3 weekly instillations at months 3, 6, 12 and 18 B. BCG 81 mg, 6 weekly instillations B. Epirubicin 40 mg, 2 weekly instillations then biweekly times 7 | A vs. B vs. C* Recurrence: 5/41 vs. 14/42 vs. 22/32 Progression: 0/41 vs. 3/42 vs. 7/32 *groups A and B combined in analysis Median followup: 2 years
BCG vs. Epirubicin; BCG vs. Epirubicin + BCG | Sylvester, 2010^173^ Van Der Meijden, 2001^178^ | Intermediate or high risk superficial bladder tumors; single or multiple, primary or recurrent, completely resectable stages Ta-T1, G1 to G3, biopsy proven TCC | A. BCG 5×10^8^ CFU, 6 weekly instillations then 3 weekly instillations at months 3, 6, 12, 18, 24, 30 and 36 B. Epirubicin 50 mg, 6 weekly instillations then 3 weekly instillations at months 3, 6, 12, 18, 24, 30 and 36 | Overall mortality: 84/281 vs. 106/173 Bladder cancer mortality: 41/102 vs. 41/107 Recurrence: 103/281 vs. 147/173 Progression: 19/281 vs. 24/173 Granulomatous cystitis: 111/263 vs. 82/265 Hematuria: 93/263 vs. 45/264 DC instillations: 190/265 vs. 201/265 Median followup: 4 years; Also median followup 9 years
BCG vs. Gemcitabine; BCG vs. BCG + Gemcitabine | Cho, 2009^187^ | Patients with intermediate-risk (i.e., Ta, T1, G1-G2 multifocal, recurrent lesions>3 cm, or high-risk (T1, G3 lesions or CIS) were included | A. BCG 12.5 mg, 6 weekly instillations B. Gemcitabine 1000 mg first dose then 2000 mg at week 1, then BCG weekly for 6 weeks | Recurrence: 17/51 vs. 14/36 Progression: 5/51 vs. 3/36 Dysuria: 17/51 vs. 13/36 Hematuria: 3/51 vs. 7/36 Mean followup: 32 and 34 months
BCG vs. Gemcitabine; BCG vs. BCG + Gemcitabine | Di Lorenzo, 2010^184^ | Patients with high risk NMIBC based on the European Organization for Research and Treatment of Cancer Scoring System failing BCG therapy for whom radical cystectomy was indicated but not conducted because of refusal or ineligibility because of age or comorbidities and high anesthesiological risk | A. BCG 81 mg, 6 weekly instillations then 3 weekly instillations at 3, 6 and 12 months B. Gemcitabine 2000 mg twice weekly for 6 weeks then 3 weekly instillations at 3, 6 and 12 months | Overall mortality: 1/35 vs. 0/21 Recurrence: 35/40 vs. 21/40 Progression: 13/35 vs. 7/21 Dysuria: 8/40 vs. 6/40 Hematuria: 5/40 vs. 2/40 Fever: 3/40 vs. 1/40 Median followup: 15 months
BCG vs. Gemcitabine; BCG vs. BCG + Gemcitabine | Gontero, 2013^186^ | Intermediate risk NMIBC (namely Ta-1, G1-2, multifocal or unique and recurrent, more than 3 cm in diameter) were eligible | A. BCG 27 mg, 6 weekly instillations then 3 weekly instillations at 3, 6 and 12 months B. Gemcitabine 2000 mg , 6 weekly instillations then monthly instillations up to 1 year | Recurrence: 14/47 vs. 16/41 Progression: 3/47 vs. 5/41 Dysuria: 21/57 vs. 13/56 Hematuria: 9/57 vs. 0/56 Fever: 10/57 vs. 0/56 Followup 1 year
BCG vs. Gemcitabine; BCG vs. BCG + Gemcitabine | Porena, 2010^185^ | Superficial TCC; high risk superficial bladder cancer according to EAU guidelines | A. BCG 5×10^8^ CFU, 6 weekly instillations then instillations at 3, 6, 12, 18, 24, 30 and 36 months B. Gemcitabine 2000 mg, 6 weekly instillations then instillations at 3, 6, 12, 18, 24, 30 and 36 months | Recurrence: 9/32 vs. 17/32 Local toxicity: 4/32 vs. 3/32 Systemic toxicity: 2/32 vs. 4/32 Mean followup: 44 months
BCG vs. Interferon alpha-2a; BCG vs. Interferon alpha-2b + BCG | Jimenez-Cruz, 1997^188^ | Recurrent histologically proved superficial transitional cell carcinoma of the bladder (Stage T1, grade 1 to 3) | A. BCG 150 mg, 4 weekly instillations then biweekly for 2 months then monthly for 9 months B. Interferon alpha-2a 54 MU, 4 weekly instillations then biweekly for 2 months then monthly for 9 months | Recurrence: 24/61 vs. 34/49 Progression: 6/61 vs. 7/49 Dysuria: 52/61 vs. 0/49 Fever: 3/61 vs. 0/49 Cystectomy: 3/61 vs. 0/49 Mean followup: 21 vs. 18 months
BCG vs. Interferon alpha-2a; BCG vs. Interferon alpha-2b + BCG | Kaasinen, 2000^189^ | At least 2 histologically verified recurrent stage Ta or T1 grade 1 to 2 tumors without concomitant CIS, Grade 3 tumors also included | All patients received 5 instillations of MMC 40 mg prior to randomization A. BCG 5×10^8^ CFU, 12 monthly instillations B. Interferon alpha-2b 50 MU + BCG 5×10^8^ CFU, 12 monthly instillations (alternating drugs) | Recurrence: 29/102 vs. 70/103 Progression: 3/102 vs. 4/103 Median followup: 56 months
BCG vs. Interferon alpha-2a; BCG vs. Interferon alpha-2b + BCG | Nepple, 2010^190^ | Histologically confirmed CIS, Ta, T1 urothelial cancer diagnosed within 8 weeks | A. BCG 50 mg then BCG 16.6 mg, 6 weekly instillations then 3 weekly instillations of BCG 16.6 mg at 4, 7, 13, 19, 25 and 37 months B. Interferon alpha-2b 50 MU + BCG 16.6 mg, 6 weekly instillations then 3 weekly instillations of BCG 16.6 mg at 4, 7, 13, 19, 25 and 37 months (Patients were also randomized to regular or mega-dose vitamins.) | Recurrence: 104/324 vs. 127/346 Constitutional symptoms: 58/324 vs. 38/346 Fever: 36/324 vs. 17/346 Followup 24 months
BCG vs. Doxorubicin | Hinotsu, 2006^170^ | Histopathologically proven transitional cell carcinoma (Stage pTa or pT1 and grade 1 to 2) | A. BCG 80 mg, 6 weekly instillations B. Doxorubicin 20 mg, 2 weekly instillations then 7 biweekly followed by 8 monthly instillations | DC instillations: 1/41 vs. 2/42 Hematuria: 20/41 vs. 34/42 Fever: 28/41 vs. 35/42 Dysuria: 13/41 vs. 27/42 Median followup: 667 days
BCG vs. Doxorubicin | Lamm, 1991^171^ | Transitional-cell carcinoma with tumors at stage Ta or T1 of any grade with two or more recurrences in the most recent 12 months, CIS, or both | A. BCG 120 mg, 6 weekly instillations then single instillations at 3, 6, 12, 16 and 24 months B. Doxorubicin 50 mg, 4 weekly instillations then 11 monthly instillations | Overall mortality: 45/127 vs. 48/135 Recurrence: 78/127 vs. 110/135 Hematuria: 46/127 vs. 36/135 Fever: 52/127 vs. 11/135 Dysuria: 76/127 vs. 65/135
BCG vs. Doxorubicin | Martinez-Pineiro, 1990^172^ | Histologically proved superficial transitional cell carcinoma; Initially Ta or T1 tumors admitted, later only T1 cancer patients admitted | A. BCG 150 mg, 4 weekly instillations then 11 monthly instillations B. Doxorubicin 50 mg, 4 weekly instillations then 11 monthly instillations | Overall mortality: 0/67 vs. 1/53 Bladder cancer mortality: 0/67 vs. 1/53 Recurrence: 9/67 vs. 23/53 Progression: 1/67 vs. 4/53 Dysuria: 28/67 vs. 7/53 Cystectomy: 1/67 vs. 3/53 Cystitis: 11/67 vs. 0/53 Median followup: 3 years
BCG vs. Thiotepa | Brosman, 1982^142^ | NMIBC patients with at least one tumor recurrence within the preceding four months | A: BCG: 6 × 10^9 TICE BCG in 60mL saline B: Thiotepa: 60mg in 60mL saline Both treatment groups were treated with weekly × 6 instillations, every 2 weeks for 3 months, then monthly until a total treatment period of 24 months. | Recurrence: 0/39 (includes 12 nonrandomized patients) vs. 9/19 (47%) Minimum followup: 24 months
BCG vs. Thiotepa | Martinez-Pineiro, 1990^172^ | Histologically proved superficial transitional cell carcinoma; Initially Ta or T1 tumors admitted, later only T1 cancer patients admitted | A. BCG 150 mg, 4 weekly instillations then 11 monthly instillations B. Doxorubicin 50 mg, 4 weekly instillations then 11 monthly instillations | Overall mortality: 0/67 vs. 1/56 Bladder cancer mortality: 0/67 vs. 0/56 Recurrence: 9/67 vs. 20/56 Progression: 1/67 vs. 2/56 Dysuria: 28/67 vs. 8/56 Cystectomy: 1/67 vs. 0/56 Cystitis: 11/67 vs. 0/56 Median followup: 3 years
BCG vs. Epirubicin + Interferon alpha-2b | Duchek, 2010^182^ Hemdan, 2014^183^ | Patients with newly detected T1 G2-G3 urinary bladder cancer | A. BCG 2 mL OncoTice, 6 weekly instillations then 3 weekly instillations at 3, 6, 12, 18 and 24 months B. Epirubicin 50 mg + Interferon alpha-2b 10 MU, 6 weekly instillations then monthly at months 3-12 then at months 15, 18, 21 and 24 | Disease-free survival favors BCG at 6 and 24 months (p=0.065; p=0.012, respectively) Bladder cancer mortality: 8/126 vs. 10/124 5-year Recurrence: 50/126 vs. 75/124 No difference in progression-free survival (p=not reported) Cystectomy: 9/126 vs. 13/124 DC instillations: 11/126 vs. 2/124 No difference in urinary symptoms (p=not reported) Followup 24 months; Also median followup 6.9 years
BCG vs. No intravesical therapy | Herr, 1995^102^ Herr, 1988^106^ Herr, 1997^107^ Cookson, 1997^108^ Pinsky, 1985^109^ | Recurrent, superficial transitional-cell carcinoma of the bladder (Ta, T1, Tis) | A. BCG 120 mg, 6 weekly instillations B. Control | Bladder cancer mortality: 10/43 vs. 17/45 Progression: 23/43 vs. 41/43 Cystectomy: 11/43 vs. 18/43 Median followup: 72 months; Also median followup: 108 vs. 140 months
BCG vs. No intravesical therapy | Melekos, 1990^104^ | Superficial bladder carcinoma (Ta and T1) | A. BCG 150 mg, 8 weekly instillations then every 3 months for 24 months B. Control | Recurrence: 22/67 vs. 19/33 Progression: 7/67 vs. 13/33 Mean followup: 29 vs. 30 months
BCG vs. No intravesical therapy | Melekos, 1993^103^ | Histologically proven superficial transitional cell carcinoma of the bladder; primary or recurrent neoplasms | A. BCG 150 mg, 6 weekly instillations then quarterly for 2 years then semi-annually B. Control | Recurrence: 20/62 vs. 19/32 Progression: 4/62 vs. 7/32 Total months of followup: 1784 vs. 603
BCG vs. No intravesical therapy | Pagano, 1991^105^ Pagano, 1990^110^ | Patients followed for one year after the study or until recurrence or progression were included in the report. Multiple (>3 tumors at entry), superficial papillary and nonpapillary tumors | A. BCG 75 mg, 6 weekly instillations then monthly for 1 year then quarterly for 1 year B. Control | Progression: 3/70 vs. 11/63 Mean followup: 21 months

BCG = bacillus Calmette-Guérin; BCG (RIVM) = RIVM strain of bacillus Calmette-Guérin; CFU = colony forming unit; CIS = carcinoma in situ; DC = dendritic cells; EAU = European Association of Urology ; FISH = fluorescence in situ hybridization; FU = followup; G1 = Grade 1; G2 = Grade 2; G3 = Grade 3; MMC = Mitomycin C; MU = million units; NMIBC = non–muscle-invasive bladder cancer; NMP22 = nuclear matrix protein-22; pT1 = Tumor stage 1 determined by pathology; pTa = Tumor stage a determined by pathology; T1 = Tumor stage 1; Ta = Tumor stage a; TCC = transitional cell carcinoma; Tis = carcinoma in situ; TURBT = transurethral resection of bladder tumor

Table 7 Summary of MMC study characteristics

Author, Year | Setting and Study Years | Interventions (number analyzed for recurrence) | Duration of Followup and Method | Population Characteristics by Treatment Group (age, race/ethnicity, sex, stage of disease, functional status)
Addeo, 2010^194^ | Italy Multicenter 2003 – 2005 | A: MMC, 40 mg (in 50 mL normal saline). Total 5 instillations: First within 2 days after TURBT, then 4 weekly treatments. (n=55) B: Gemcitabine, 2,000 mg (in 50 mL normal saline). “6-week induction course of infusion”, dosing not otherwise specified. (n=54) A and B: Maintenance therapy of 10 monthly treatments for initial responders who remained free of recurrence. | Duration: 36 months (median) for each group Method: Not reported | Age (mean), years: 67.9 vs. 64.9 Age (median), years: 70 vs. 66.5 Male: 85.5% vs. 85.2% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: 100% vs.100% (recurrent only) Stage: Ta: 63.6% vs.68.5%; T1: 36.4% vs. 31.5% Grade: G1: 25.5% vs. 20.4%; G2: 49.1% vs. 51.9%; G3: 25.5% vs. 27.8% Functional Status: Not reported
Akaza, 1987^112^ Study One (followup of Niijima, 1983^116^) | Japan Multicenter 1980 – 1985 | A: Doxorubicin, 30 mg (in 30 mL saline). Total 8 instillations. (n=149) B: Doxorubicin, 20 mg (in 40 mL saline). Total 8 instillations. (n=148) C: MMC: 20 mg (in 40 mL saline). Total 8 instillations. (n=139) D: No adjuvant treatment. TURBT alone. (n=139) For A, B, and C: First instillation within 1 week of TURBT. Twice weekly × 4 weeks | Duration: 5 years (maximum), overall. Method: cystoscopy and urinary cytology. | Age (average), years: 62.3 vs. 62.9 vs. 62.9 vs. 62.9 Male: 82.6% vs. 75.7% vs. 74.8% vs. 74.1% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: 29.5% vs. 31.1% vs. 33.8% vs. 35.3% Stage: Not reported Grade: Not reported Functional Status: Not reported Size: <1 cm: 40.3% vs. 37.2% vs. 43.9% vs. 46.0%; 1-3 cm: 43.0% vs. 52.7% vs. 38.8% vs. 48.2%; 3-5 cm: 14.8% vs. 74.3% vs. 12.2% vs. 5.0% Number of tumors: 1: 64.4% vs. 63.5% vs. 48.2% vs. 60.4%; 2-4: 26.2% vs. 25.7% vs. 39.6% vs. 30.2%; 5+: 80.5% vs. 10.8% vs. 11.5% vs. 9.4%
Akaza, 1987^112^ Study Two | Japan Multicenter 1982 - 1985 | A: Doxorubicin, 30 mg (in 30 mL saline). Total 21 instillations over 2 years. (n=151) B: Doxorubicin, 20 mg (in 40 mL saline). Total 21 instillations over 2 years. (n=158) C: MMC: 20 mg (in 40 mL saline). Total 21 instillations over 2 years. (n=150) D: No adjuvant treatment. TURBT alone. (n=148) For A, B, and C: First instillation within 1 week of TURBT. Once weekly × 2 weeks, then once every 2 weeks × 14 weeks, then once monthly × 8 months, then once every 3 month × 1 year | Duration: 3.5 years (maximum), overall. Method: cystoscopy and urinary cytology. | Age (average), years: 63.1 vs. 62.1 vs. 62.3 vs. 62.0 Male): 80.1% vs. 82.3% vs. 82.0% vs. 81.1% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: None (primary only) Stage: Not reported Grade: Not reported Functional Status: Not reported Size: <1 cm: 31.8% vs. 30.4% vs. 36.0% vs. 38.5%; 1-3 cm: 51.0% vs. 53.2% vs. 44.0% vs. 49.3%; 3-5 cm: 14.6% vs. 11.4% vs. 11.3% vs. 6.8% Number of tumors: 1: 64.2% vs. 55.7% vs. 55.3% vs. 66.9%; 2-4: 29.8% vs. 30.4% vs. 33.3% vs. 23.6%; 5+: 6.0% vs. 12.7% vs. 10.7% vs. 8.1%
Akaza, 1992^113^ Study Two (followup of sub-group of Akaza, 1987^112^) | Japan Multicenter 1982 - 1990 | A: Doxorubicin, 30 mg (in 30 mL saline). Total 21 instillations over 2 years. (n=44) B: Doxorubicin, 20 mg (in 40 mL saline). Total 21 instillations over 2 years. (n=42) C: MMC: 20 mg (in 40 mL saline). Total 21 instillations over 2 years. (n=41) D: No adjuvant treatment. TURBT alone. (n=31) For A, B, and C: First instillation within 1 week of TURBT. Once weekly × 2 weeks, then once every 2 weeks × 14 weeks, then once monthly × 8 months, then once every 3 month × 1 year | Duration: 6.6 years (median), overall. Method: with cystoscopy and urinary cytology. | Only reported overall; Not reported by treatment group Age ≤50 years: 13.3% Age ≤60 years: 17.7% Age <70 years: 35.4% Age ≥70 years: 33.5% Sex (male): 84.8% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: None (primary only) Stage: Tis: 1.3%; Ta: 44.3%; T1: 40.5%; Ta or T1: 13.9% Grade: G1: 48.7% G2: 45.6%; G1 or G2: 5.7% Functional Status: Not reported
Boccardo, 1994^193^ | Italy Multicenter 1987 - 1989 | A: MMC, 40 mg (in 50 mL saline). Total 8 instillations: weekly dose × 8 weeks. (n=141) B: Interferon alfa-2b, 50 million units (in 50 mL normal saline). Total 8 instillations: weekly dose × 8 weeks. (n=146) | Duration: 42 months (maximum). Method: cystoscopy and urine cytology. | Age (median), years: 64 vs. 63 Male: 87.9% vs. 84.9% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: None (primary only) Stage/Grade: pTa/G2: 55.3% vs. 53.4%; pT1/G1-G2: 45.7% vs. 45.6% Functional Status: Not reported Size: <3 cm: 75.2% vs. 78.1%; ≥3 cm: 24.1% vs. 21.9% Number of tumors: 1: 63.2% vs. 61.7%; 2: 14.9% vs. 17.1%; 3+: 20.5% vs. 21.2%
De Nunzio, 2011^114^ | Italy Single center 2000 - 2009 | A: MMC, 40 mg (in 50 mL saline). Single instillation within 24 hours of TURBT. (n=97) B: TURBT only. No adjuvant therapy. (n=105) | Duration: 90 months vs. 85 months (median). Method: cystoscopy and urine cytology. | Age (median), years: 60.8 vs. 61.5 Male: 62.9% vs. 68.6% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: None (primary only) Stage: Ta: 100% vs. 100% Grade: G1: 70.1% vs. 77.1%; G2: 29.9% vs. 22.9% Functional Status: Not reported
Flanigan, 1986^143^ | USA Single center 1981-1984 | A: MMC 40 mg in 40 cc sterile water, 8 weekly instillations, then monthly for 2 years (n=25) B: Thiotepa 60 mg in 60 cc sterile water, 8 weekly instillations, then monthly for 2 years (n=22, includes 7 cross-overs due to MMC toxicity) | Duration (mean): MMC: 13.5 months Thiotepa: not reported Method: Cystoscopy and cytology every 3 months for the first 2 years and every 6 months thereafter. | Age: Not reported Male: Not reported Race/ethnicity: Not reported Stage/grade: Ta, G1 or G2: 2 vs. 1 T1, G1: 6 vs. 8 T1, G2: 13 vs. 11 T1, G3: 3 vs. 2 Focal Tis: 1 vs. 0 Functional status: Not reported
Giannopoulos, 2003^141^ | Greece Multicenter 1997 - 2001 | A: Interferon-gamma 1b, 15 million units (in 50 mL normal saline). Total 20 instillations: First instillation 2 weeks after TURBT; then once a week × 7, then once biweekly × 4, then once monthly × 8. (n=60) B: MMC, 40 mg (in 50 mL normal saline). Total 20 instillations: First instillation 2 weeks after TURBT; then once a week × 7, then once biweekly × 4, then once monthly × 8. (n=63) | Duration: 26.5 months vs. 24 months (median). Method: Cystoscopy and urine cytology. Random cold cup biopsies at 6 months and 12 months. | Age (median), years: 68 vs. 60 Male: 80.0% vs. 88.9% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: None (primary only) Stage: Ta: 66.7% vs. 60.3%; T1: 33.3% vs. 39.7% Grade: G2: 100% vs. 100% Functional Status: Not reported
Gustafson, 1991^115^ | Sweden Single center Study years not reported | A: MMC. Dosages “varied according to individual patient's bladder capacity”. Range: “5 mg in 20 mL” to “40 mg in 250 mL”. Total 15 instillations: First instillation approximately 2 weeks after TURBT; instillations weekly × 4 weeks, then monthly × 11 months. (n=19) B: Doxorubicin. Dosages “varied according to individual patient's bladder capacity”. Range: “10 mg in 20 mL” to “80 mg in 250 mL”. Total 15 instillations: Same protocol as A. (n=20)C: TURBT only. No adjuvant therapy. (n=21) | Duration: 47 months vs. 45 months vs. 35 months (mean). Method: Cystoscopy | Age (mean), years: 67 (overall) Male: “Four to one”, male/female (overall) Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: Not reported Stage: Ta: 89.5% vs. 90.0% vs. 95.2%; T1: 10.5% vs. 10.0% vs. 4.8% Grade: G1: 36.8% vs. 35% vs. 33.3%; G2: 63.2% vs. 65% vs. 61.9%; G3: 0.0% vs. 0.0% vs. 4.8% Functional Status: Not reported
Huland, 1990^191^ | Germany Multicenter 1983 - 1985 | A: MMC (20 mg/20 mL). Total 42 instillations: Every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. (n=209) B: MMC (20 mg/20 mL). Total 42 instillations: Every week × 8 weeks, then every 4 weeks for rest of 1st year and 2 additional years. (n=96) C: MMC (20 mg/20 mL). Total 20 instillations: Every week × 20 weeks. (n=75) D: Doxorubicin (50 mg/50 mL). Total 42 instillations: Every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. (n=39) For all groups: Instillations started 4 to 6 weeks after discharge from hospital. | Duration: 26.7 months vs. 27.4 months vs. 26.7 months vs. 30.2 months (mean). Method: Cystoscopy | Age (mean), men/women, years: 61.1/67.5 vs. 66.3/68.1 vs. 65.1/64.6 vs. .68.0/58.3 Male: 82.3% vs. 77.1% vs. 77.3% vs. 74.4% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: 32.1% vs. 25.0% vs. 25.3% vs. 43.6% Stage: Ta: 73.7% vs. 78.1% vs. 76.0% vs. 59.0%; T1: 23.0% vs. 19.8% vs. 21.3% vs. 33.3%; Tis: 3.3% vs. 2.1% vs. 29.3% vs. 7.7% Grade: G1: 47.4% vs. 58.3% vs. 52.0% vs. 43.6%; G2: 47.7% vs. 35.4% vs. 37.3% vs. 38.5%; G3: 1.9% vs. 4.2% vs. 8.0% vs. 10.3%; CIS: 3.3% vs. 2.1% vs. 2.7% vs. 7.7% Functional Status: Not reported
Jauhiainen, 1987^144^ | Finland Single center Study years not reported | A: MMC, range 20 mg to 40 mg. Dosages varied according to patient's bladder capacity. (n=26) B: Doxorubicin, range: 50 mg to 100 mg. Dosages varied according to patient's bladder capacity. (n=15) First instillation not less than 14 days after TURBT; 5 times weekly, then monthly. | Duration: Mean: 23.6 months vs. 23.3 months. Method: Followup with cystoscopy and biopsy cytology. | Age (mean): 68.1 vs. 65.2 Male: 84% (42/50) of a larger series, of which only 41 were randomized. Race/ethnicity: not reported Recurrent bladder cancer: 100% vs. 100% Stage: All Ta or T1, Functional Status: Not reported
Kim, 1989^97^ | Korea Single center 1983-1986 | A: MMC, 40 mg (in 50 mL saline). Weekly for 8 weeks. (n=21) B: TURBT alone.(n=22) | Duration, mean: 32 months vs. 31 months. Method: Cystoscopy and cytology every 3 to 4 months. | Age, mean: 51.6 vs. 57.0 Male: 90.5% vs. 86.4% Race/ethnicity: not reported Recurrent bladder cancer: 71.4% vs. 55.5% Stage: Ta: 23.8% vs. 27.3%; T1: 76.2% vs. 72.7% Functional Status: not reported
Krege, 1996^111^ | Germany, Multicenter, number not reported 1985-1992 | A. MMC 20 mg (in 50 mL saline). Total 38 instillations: First approximately 7 days after TURBT, then every 2 weeks during year 1 and monthly during year 2 (n=113) B. TURBT only. No adjuvant therapy. (n=122) | Duration: 20 months, overall (mean) Method not reported | Age (mean), years: 65 (not specified by group) Male: 84% vs. 75% Race/ethnicity: Not reported Smoking: Not reported Stage: Ta: 74% vs. 78%; T1: 26% vs. 22% Grade: G1: 39% vs. 39%; G2: 51% vs. 57%; G3: 11% vs. 5% Functional Status: Not reported
Liu, 2006^192^ | China Multicenter 1997 - 1998 | A: Epirubicin, 80 mg (in 40 mL normal saline). Single instillation within 6 hours of TURBT. (n=14) B: Epirubicin, 40 mg. Total 16 - 18 instillations: Every week for 6 ∼ 8 weeks, then every month for 10 months. (n=15) C: MMC, 40 mg. Total 16 - 18 instillations: Every week for 6 ∼ 8 weeks, then every month for 10 months. (n=15) | Duration: 5 years (all patients). Method: Cystoscopy and urine cytology. | Age (mean), years: 62.2 (overall) Male: Not reported Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: 23.4% (overall) Stage and Grade: TaG1: 6.3% vs. 0.0% vs. 0.0%; TaG2: 6.3% vs. 6.6% vs. 6.3%; T1G1: 12.5% vs. 26.7% vs. 12.5%; T1G2: 75.0% vs. 66.7% vs. 81.3% Functional Status: Not reported
Niijima, 1983^116^ (see Akaza, 1987^112^) | Japan Multicenter 1980 - 1985 | A: Doxorubicin, 30 mg (in 30 mL saline). Total 8 instillations. (n=149) B: Doxorubicin, 20 mg (in 40 mL saline). Total 8 instillations. (n=148) C: MMC: 20 mg (in 40 mL saline). Total 8 instillations. (n=139) D: No adjuvant treatment. TURBT alone. (n=139) For A, B, and C: First instillation within 1 week of TURBT. Twice weekly × 4 weeks | Duration: 5 years (maximum), overall. Method: Cystoscopy and urinary cytology. | Age (average), years: 62.3 vs. 62.9 vs. 62.9 vs. 62.9 Male: 82.6% vs. 75.7% vs. 74.8% vs. 74.1% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: 29.5% vs. 31.1% vs. 33.8% vs. 35.3% Stage: Not reported Grade: Not reported Functional Status: Not reported Size: <1 cm: 40.3% vs. 37.2% vs. 43.9% vs. 46.0%; 1-3 cm: 43.0% vs. 52.7% vs. 38.8% vs. 48.2%; 3-5 cm: 14.8% vs. 74.3% vs. 12.2% vs. 5.0% Number of tumors: 1: 64.4% vs. 63.5% vs. 48.2% vs. 60.4%; 2-4: 26.2% vs. 25.7% vs. 39.6% vs. 30.2%; 5+: 80.5% vs. 10.8% vs. 11.5% vs. 9.4%
Solsona, 1999^117^ | Spain Single center 1988 - 1992 | A: MMC, 30 mg (in 50 mL saline). Single intravesical dose, usually within 6 hours of TURBT. (n=57) B: TURBT only. No adjuvant therapy. (n=64) | Duration: 94 months vs. 93 months (median). Method: Cystoscopy and urine cytology. | Age (mean), years: 62.2 vs. 59.9 Male: 91.2% vs. 92.2% Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: 10.5% vs. 12.5% Stage Ta: 49.1% vs. 48.4% Stage T1: 50.9% vs. 51.6% Grade G1: 52.6% vs. 51.6% Grade G2: 47.4% vs. 48.4% Functional Status: All patients with WHO performance status ≤2.
Tolley, 1996^118^ (followup Tolley, 1988^261^) | United Kingdom Multicenter 1984 - 1986 | A: MMC, 40 mg (in 40 mL water). Single instillation within 24 hours of TURBT. (n=149) B: MMC, 40 mg (in 40 mL water). Total 5 instillations: First within 24 hours of TURBT, then every 3 months × 1 year. (n=146) C: TURBT only. No adjuvant therapy. (n=157) | Duration: 7 years (median) for groups A and B; not reported for group C. Method: Cystoscopy | Age 24-50: 13% vs. 9% vs. 9% Age 51-60: 24% vs. 23% vs. 29% Age 61-70: 36% vs. 37% vs. 34% Age 71-80: 23% vs. 30% vs. 25% Age 81-100: 4% vs. 1% vs. 3% Male: Not reported Race/ethnicity: Not reported Smoking status: Not reported Recurrent bladder cancer: None (primary only) Stage Ta: 50% vs. 52% vs. 56% Stage T1: 48% vs. 50% vs. 43% Grade 1: 37% vs. 34% vs. 45% Grade 2: 52% vs. 55% vs. 46% Grade 3: 10% vs. 10% vs. 8% Functional Status: Not reported
Tsushima, 1987^101^ | Japan Number of sites unclear 1981-unclear end date | A: Doxorubicin, 50 mg in 100 mL saline. B: MMC, 30 mg in 100 mL. C: TURBT or transurethral coagulation alone. For A and B: Six times in first 2 weeks after TURBT, then on 2 consecutive days every 4 weeks × 2 years. If recurrence, repeat TURBT or TUC and resume 2 consecutive days every 4 weeks until 2 years after initial treatment. For C: If recurrence, repeat TURBT or TUC × 2 recurrences, then removed from protocol. | Duration, median: 15 months vs. 21 months vs. 13 months. Method: Cystoscopy every 3 months. | Age (average), years: 66.1 Male: 84.8% vs. 81.1% vs. 81.8% Race/ethnicity: not reported Recurrent bladder cancer: 39.4% vs. 16.2% vs. 33.3% Stage: All Ta or T1 Functional Status: not reported
Zincke, 1985^146^ | USA Single center Study years not reported | A. MMC 40 mg in 40 mL distilled water B. Thiotepa 60 mg in 60 mL distilled water Biweekly treatment for 5 treatments. If no tumor was present at the 3-month assessment the treatment interval was lengthened to every 4 weeks for 6 months. If there still was no recurrence, there was no further treatment. If tumor recurred during the primary treatment, patients were given the opposite drug. | Duration, mean: 16.1 months Method: Cystoscopy and cytology every 3 months for 1 year, then every 6 months for 1 year, and yearly thereafter | Age (mean): 64 Male: 71/83 Race/ethnicity: not reported Tumor grade: G1: 16/29 vs. 13/29 G2: 23/47 vs. 24/47 G3, G4: 3/7 vs. 4/7

CIS = carcinoma in situ; G1 = Grade 1; G2 = Grade 2; G3 = Grade 3; MMC = Mitomycin C; pT1 = Tumor stage 1 determined by pathology; pTa = Tumor stage a determined by pathology; T1 = Tumor stage 1; Ta = Tumor stage a; Tis = carcinoma in situ; TURBT = transurethral resection of bladder tumor; WHO = World Health Organization

Table 8 Summary of MMC study results

Author, Year | Interventions (number analyzed for recurrence) | Recurrence | Progression | Mortality
Addeo, 2010^194^ | A: MMC, 40 mg (in 50 mL normal saline). Total 5 instillations: First within 2 days after TURBT, then 4 weekly treatments. (n=55) B: Gemcitabine, 2,000 mg (in 50 mL normal saline). “6-week induction course of infusion”, dosing not otherwise specified. (n=54) A and B: Maintenance therapy of 10 monthly treatments for initial responders who remained free of recurrence. | Recurrence rate/100 patient-months: 1.72 vs.1.26; p=0.31 Median time to recurrence: 15.0 months vs. “not reached” Relative risk of recurrence: 0.94 vs. 0.72; p=0.291 Disease-free survival: B>A; log-rank test, p=0.0021 | Patients with tumor progression by stage: 18.2% (10/55) vs. 11.1% (6/54); p=0.14
Akaza, 1987^112^ Study One (followup of Niijima, 1983^116^) | A: Doxorubicin, 30 mg (in 30 mL saline). Total 8 instillations. B: Doxorubicin, 20 mg (in 40 mL saline). Total 8 instillations. C: MMC: 20 mg (in 40 mL saline). Total 8 instillations. D: No adjuvant treatment. TURBT alone. For A, B, and C: First instillation within 1 week of TURBT. Twice weekly × 4 weeks | Recurrence-free survival at 1800 days, generalized Wilcoxon test: B>D, p<0.05 C>D, p<0.05
Akaza, 1987^112^ Study Two | A: Doxorubicin, 30 mg (in 30 mL saline). Total 21 instillations over 2 years. B: Doxorubicin, 20 mg (in 40 mL saline). Total 21 instillations over 2 years. C: MMC: 20 mg (in 40 mL saline). Total 21 instillations over 2 years. D: No adjuvant treatment. TURBT alone. For A, B, and C: First instillation within 1 week of TURBT. Once weekly × 2 weeks, then once every 2 weeks × 14 weeks, then once monthly × 8 months, then once every 3 month × 1 year | Recurrence-free survival rate at 1 year: 74.8% vs. 75.0 vs. 76.3% vs. 66.7%. Recurrence-free survival rate at 2 years: 62.3% vs. 59.1 vs. 62.3% vs. 51.8%. Recurrence-free survival at 1260 days, generalized Wilcoxon test: A>D, p<0.05 B>D, p<0.05 C>D, p<0.05
Akaza, 1992^113^ Study Two (followup of sub-group of Akaza, 1987^112^) | A: Doxorubicin, 30 mg (in 30 mL saline). Total 21 instillations over 2 years. B: Doxorubicin, 20 mg (in 40 mL saline). Total 21 instillations over 2 years. C: MMC: 20 mg (in 40 mL saline). Total 21 instillations over 2 years. D: No adjuvant treatment. TURBT alone. For A, B, and C: First instillation within 1 week of TURBT. Once weekly × 2 weeks, then once every 2 weeks × 14 weeks, then once monthly × 8 months, then once every 3 month × 1 year | Recurrence/year (number of recurrences/total observation period): 0.473 vs. 0.512 vs. 0.472 vs. 0.510 | Progression (in stage, grade, or both): 43.2% (19/44) vs. 31.0% (13/42) vs. 26.8% (11/41) vs. 38.7% (12/31) “Statistics: no difference”
Boccardo, 1994^193^ | A: MMC, 40 mg (in 50 mL saline). Total 8 instillations: weekly dose × 8 weeks. (n=141) B: Interferon alfa-2b, 50 million units (in 50 mL normal saline). Total 8 instillations: weekly dose × 8 weeks. (n=146) | Recurrence: 36.9% (52/141) vs. 47.9% (70/146) Relative recurrence rate: 0.82 vs. 1.2; p=0.04 Median time to recurrence, months: 36.0 vs. 21.0; p=0.048 Recurrence rate/100 patient/month: 2.4 vs. 3.4; p=0.04 | Patients developing muscle-invasive cancer or second tumor: 5.7% (8/141) vs. 4.1% (6/146)
De Nunzio, 2011^114^ | A: MMC, 40 mg (in 50 mL saline). Single instillation within 24 hours of TURBT. (n=97) B: TURBT only. No adjuvant therapy. (n=105) | Recurrence: 10.3% (10/97) vs. 43.8% (46/105), p=0.001; HR (95% CI): 0.20 (0.10-0.395) Early recurrence (≤1 year): 40.0% (4/10) vs. 34.8% (16/46), p=0.008 Early recurrence tumor size, median: 0.8 cm vs. 0.8, p=0.34 Early recurrence grade: G1: 75% (3/4) vs. 87.5% (14/16), p=0.53; G2: 25% (1/4) vs. 12.5% (2/16), p=0.53; G3: 0.0% vs. 0.0%, p=0.53 Late recurrence (>1 year): 60.0% (6/10) vs. 60.9% (28/46), p=0.0001 Late recurrence tumor size, median: 1.2 cm vs. 1.5, p=0.001 Late recurrence grade: G1: 66.7% (4/6) vs. 71.4% (20/28), p=0.60; G2: 33.3% (2/6) vs. 21.4% (6/28), p=0.60; G3: 0.0% (0/6) vs. 7.1% (2/28), p=0.60 All recurrences in treatment arm were Ta; 30.4% (14/46) of recurrences in control arm were T1 Absolute risk reduction (A vs. B): Overall=31%, Early recurrence=11%, Late recurrence=20% NNT to prevent one recurrence: Overall=3.26, Early=8.99; Late=5.12 | Progression (≥T2): 0.0% (0/97) vs. 0.95% (1/105), p=0.33
Flanigan, 1986^143^ | A: MMC 40 mg in 40 cc sterile water, 8 weekly instillations, then monthly for 2 years (n=25) B: Thiotepa 60 mg in 60 cc sterile water, 8 weekly instillations, then monthly for 2 years (n=22, includes 7 cross-overs due to MMC toxicity) | Recurrence: 16% vs. 9.1%, RR 1.76 (95% CI 0.36 to 8.70) Recurrence, by tumor stage: Ta, G1 or G2: 0 vs. 0 T1, G1: 0 vs. 0 T1, G2: 3/13 vs. 1/11 T1, G3: 1/3 vs. 1/2 | Progression: 12% vs. 4.5%, RR 2.64 (95% CI 0.30 to 23.6)
Giannopoulos, 2003^141^ | A: Interferon-gamma 1b, 15 million units (in 50 mL normal saline). Total 20 instillations: First instillation 2 weeks after TURBT; then once a week × 7, then once biweekly × 4, then once monthly × 8. (n=60) B: MMC, 40 mg (in 50 mL normal saline). Total 20 instillations: First instillation 2 weeks after TURBT; then once a week × 7, then once biweekly × 4, then once monthly × 8. (n=63) | Recurrence-free at 1 year: 90.0% (54/60) vs. 76.2% (48/63) Recurrence-free survival at 1 year, log-rank test, p=0.04 Recurrence-free for total study period: 73.3% (44/60) vs. 57.1% (36/63) Recurrence-free survival for total study period, log-rank test, p=0.051
Gustafson, 1991^115^ | A: MMC. Dosages “varied according to individual patient's bladder capacity”. Range: “5 mg in 20 mL” to “40 mg in 250 mL”. Total 15 instillations: First instillation approximately 2 weeks after TURBT; instillations weekly × 4 weeks, then monthly × 11 months. (n=19) B: Doxorubicin. Dosages “varied according to individual patient's bladder capacity”. Range: “10 mg in 20 mL” to “80 mg in 250 mL”. Total 15 instillations: Same protocol as A. (n=20) C: TURBT only. No adjuvant therapy. (n=21) | Recurrence-free survival during treatment year: 52.6% (10/19) vs. 15.0% (3/20) vs. 14.3% (3/21) Recurrence-free survival for duration of followup: 26.3% (5/19) vs. 10.0% (2/20) vs. 4.8% (1/21) Recurrence rate/100 patient-months: 7.7 vs. 18.3 vs. 18.6, p=0.02 Mean disease-free interval, months (A vs. B): 14 vs. 6, p=0.02 | Progression: Increased stage only: 0.0% (0/19) vs. 5.0% (1/20) vs. 4.8% (1/21) Increased grade only: 0.0% (0/19) vs. 15.0% (3/20) vs. 9.5% (2/21) Increased stage and grade: 10.5% (2/19) vs. 10.0% (2/20) vs. 0.0% (0/21)
Huland, 1990^191^ | A: MMC (20 mg/20 mL). Total 42 instillations: Every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. (n=209) B: MMC (20 mg/20 mL). Total 42 instillations: Every week × 8 weeks, then every 4 weeks for rest of 1st year and 2 additional years. (n=96) C: MMC (20 mg/20 mL). Total 20 instillations: Every week × 20 weeks. (n=75) D: Doxorubicin (50 mg/50 mL). Total 42 instillations: Every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. (n=39) For all groups: Instillations started 4 to 6 weeks after discharge from hospital. | Recurrence: 15.3% (32/209) vs. 9.4% (9/96) vs. 17.3% (13/75) vs. 23.1% (9/39); differences reported as not statistically significant, p-values not reported. Recurrence per 100 patient-months: 0.68 vs. 0.49 vs. 0.65 vs. 0.76 | Progression of stage: 2.9% (6/209) vs. 1.0% (1/96) vs. 5.3% (4/75) vs. 7.7% (3/39) Progression of grade: 1.9% (4/209) vs. 1.0% (1/96) vs. 4.0% (3/75) vs. 10.3% (4/39)
Jauhiainen, 1987^144^ | A: MMC, range 20 mg to 40 mg. Dosages varied according to patient's bladder capacity. (n=26) B: Doxorubicin, range: 50 mg to 100 mg. Dosages varied according to patient's bladder capacity. (n=15) For A and B: First instillation not less than 14 days after TURBT; then 5 times weekly, then monthly. | Recurrence: 11.5% (3/26) vs. 40.0% (6/15) Disease-free interval: A>B, Mantel-Cox statistic p=0.0079. | Progression of stage, multifocality, or grade: 7.7% (2/26) vs. 0.0% (0/15)
Kim, 1989^97^ | A: MMC, 40 mg (in 50 mL saline). Weekly for 8 weeks. (n=21) B: TURBT alone. (n=22) | Recurrence rate: 42.9% vs. 40.9% (3 months); 81.0% vs. 77.3% (24 months); 81.0% vs. 81.0% (3 years; log-rank test p>0.05). Mean tumor free interval: 7.24 months vs. 7.24 months. Recurrence per 100 patient-months: 8.7 vs. 8.9 | Progression to muscle invasive or metastases: 9.5% (2/21) vs. 18.2% (4/22). Stage: T1: 100% (2/2) vs. 100% (4/4) Grade: G2: 50% (1/2) vs. 50% (2/4); G3: 50% (1/2) vs. 50% (2/4) Recurrent: 50% (1/2) vs. 75% (3/4) Size: <3 cm: 50% (1/2) vs. 25% (1/4); ≥3 cm: 50% (1/2) vs. 75% (3/4) Number of tumors: <3: 0.0% (0/2) vs. 25% (1/4); >3: 100% (2/2) vs. 75% (3/4)
Krege, 1996^111^ | A. MMC 20 mg (in 50 mL saline). Total 38 instillations: First approximately 7 days after TURBT, then every 2 weeks during year 1 and monthly during year 2 (n=113) B. TURBT only. No adjuvant therapy. (n=122) | Recurrence: 27% (30/113) vs. 46% (56/122)
Liu, 2006^192^ | A: Epirubicin, 80 mg (in 40 mL normal saline). Single instillation within 6 hours of TURBT. (n=14) B: Epirubicin, 40 mg. Total 16 - 18 instillations: Every week for 6 ∼ 8 weeks, then every month for 10 months. (n=15) C: MMC, 40 mg. Total 16 - 18 instillations: Every week for 6 ∼ 8 weeks, then every month for 10 months. (n=15) | Recurrence: 35.7% (5/14) vs. 33.3% (5/15) vs. 40% (6/15), p>0.05 Recurrence-free at 1 year: 100% (14/14) vs. 86.7% (13/15) vs.93.3% (14/15) Recurrence-free at 2 years: 85.7% (12/14) vs. 80.0% (12/15) vs.66.7% (13/15) Recurrence-free at 3 years: 71.4% (10/14) vs. 73.3% (11/15) vs. 80.0% (12/15) Recurrence-free at 5 years: 64.3% (9/14) vs. 66.7% (10/15) vs.60.0% (9/15) Mean interval to recurrence, months: 8 vs. 4 vs. 5
Niijima, 1983^116^ | A: Doxorubicin, 30 mg (in 30 mL saline). Total 8 instillations. B: Doxorubicin, 20 mg (in 40 mL saline). Total 8 instillations. C: MMC: 20 mg (in 40 mL saline). Total 8 instillations. D: No adjuvant treatment. TURBT alone. For A, B, and C: First instillation within 1 week of TURBT. Twice weekly × 4 weeks | Recurrence-free survival rate at 540 days: 56.6% vs. 52.0% vs. 42.4% vs. 38.5%, generalized Wilcoxon test: A vs. D, p<0.05 B vs. D, p<0.05 C vs. D, p<0.10
Solsona, 1999^117^ | A: MMC, 30 mg (in 50 mL saline). Single intravesical dose, usually within 6 hours of TURBT. (n=57) B: TURBT only. No adjuvant therapy. (n=64) | Recurrence: 40.4% (23/57) vs. 54.7% (35/64), p=0.115 Early recurrence (≤2 years): 15.8% (9/57) vs. 34.4% (22/64), p=0.019 Late recurrence (>2 years): 22.8% (13/57) vs. 21.9% (14/64), p=0.575 Early + Late: 10.5% (6/57) vs. 12.5% (8/64), p=0.734 Recurrence free at 24 months: 84.2% vs. 65.6%; log-rank test, p=0.013 Recurrence free at 108 months: 57.0% vs. 42.2%; log-rank test, p=0.057 | Progression: 1.8% (1/57) vs. 1.6% (1/64)
Tolley, 1996^118^ (followup Tolley, 1988^261^) | A: MMC, 40 mg (in 40 mL water). Single instillation within 24 hours of TURBT. (n=149) B: MMC, 40 mg (in 40 mL water). Total 5 instillations: First within 24 hours of TURBT, then every 3 months × 1 year. (n=146) C: TURBT only. No adjuvant therapy. (n=157) | Recurrence at 24 months: 42% vs. 31% vs. 82%; A vs. C, p=0.001; B vs. C, p<0.001; A vs. B, p=0.14 Recurrence, relative risk, HR (95% CI): A vs. C (ref): 0.66 (0.48 to 0.91), log-rank test, p=0.01; B vs. C (ref): 0.50 (0.36 to 0.70), log-rank test, p=0.0001; A vs. B (ref): 0.74 (0.51 to 1.06), log-rank test, p=0.10 | Progression, relative risk, HR (95% CI): A vs. C: 0.84 (0.42 to 1.52), log-rank test, p=0.64; B vs. C: 0.82 (0.40 to 1.68), log-rank test, p=0.59; A vs. B: 0.97 (0.46 to 2.06), log-rank test, p=0.94 | All-cause mortality: 33.6% (50/149) vs. 42.5% (62/146) vs. 32.5% (51/157); A+B vs. C (ref): HR 1.1 (95% CI 0.80 to 1.53) Bladder cancer mortality: 5.4% (8/149) vs. 5.5% (8/146) vs. 7.6% (12/157)
Zincke, 1985^146^ | A. MMC 40 mg in 40 mL distilled water (n=42) B. Thiotepa 60 mg in 60 mL distilled water (n=41) Biweekly treatment for 5 treatments. If no tumor was present at the 3-month assessment the treatment interval was lengthened to every 4 weeks for 6 months. If there still was no recurrence, there was no further treatment. If tumor recurred during the primary treatment, patients were given the opposite drug. | Recurrence: 14/42 (33%) vs. 12/41 (29%), RR 1.14 (95% CI 0.60 to 2.16) Percent free of recurrence at 1 year: 67% vs. 78% Recurrence, months from diagnosis to treatment: <1 month: 3/18 vs. 1/20, p=0.3 ≥1 month: 11/24 vs. 11/21, p=0.8 Recurrence, age: <65 years: 7/20 vs. 2/21, p=0.04 ≥65 years: 7/22 vs. 10/20, 0.2

CI = confidence interval; G1 = Grade 1; G2 = Grade 2; G3 = Grade 3; HR = hazard ratio; MMC = Mitomycin C; NNT = number needed to treat; T1 = Tumor stage 1; T2 = tumor stage 2; Ta = Tumor stage a; TURBT = transurethral resection of bladder tumor

Table 9 Summary of doxorubicin study characteristics

Author, Year | Setting and Study Years | Interventions (number analyzed for recurrence) | Duration of Followup and Method | Population Characteristics by Treatment Group (age, race/ethnicity, sex, stage of disease, functional status)
Abrams, 1981^95^ | United Kingdom Single center Study years not reported | A: Doxorubicin, 50 mg (in 50 mL saline). Single instillation, within 24 hours of TURBT. B: No adjuvant treatment. TURBT alone. | Duration: 6 months for all patients. Method: Cystoscopy | All characteristics reported for 60 randomized patients (30 per group), not the groups analyzed: Age (mean), years: 72 vs. 68 Male: 70% vs. 79% Race/ethnicity: Not reported Recurrent bladder cancer: 100% vs. 100% Stage: Ta: 73.3% vs. 76.7%; T1: 26.7% vs. 23.3%; Functional Status: Not reported
Akaza, 1987^112^ [Study One] (followup of Niijima, 1983^116^) | Japan Multicenter 1980 - 1985 | A: Doxorubicin, 30 mg (in 30 mL saline). Total 8 instillations: First within 1 week of TURBT, twice weekly × 4 weeks. (n=149) B: Doxorubicin, 20 mg (in 40 mL saline). Total 8 instillations: First within 1 week of TURBT, twice weekly × 4 weeks. (n=148) C: MMC: 20 mg (in 40 mL saline). Total 8 instillations: First within 1 week of TURBT, twice weekly × 4 weeks. (n=139) D: No adjuvant treatment. TURBT alone. (n=139) | Duration: 5 years, maximum; Not reported as median/mean, nor for each group. Method: Cystoscopy and urinary cytology. | Age (average), years: 62.3 vs. 62.9 vs. 62.9 vs. 62.9 Male: 82.6% vs. 75.7% vs. 74.8% vs. 74.1% Race/ethnicity: Not reported Recurrent bladder cancer: 29.5% vs. 31.1% vs. 33.8% vs. 35.3% Stage: Not reported (“no differences”) Functional Status: Not reported Number of tumors: 1: 64.4% vs. 63.5% vs. 48.2% vs. 60.4%; 2-4: 26.2% vs. 25.7% vs. 39.6% vs. 30.2%; 5+: 80.5% vs. 10.8% vs. 11.5% vs. 9.4%
Akaza, 1987^112^ [Study Two] | Japan Multicenter 1982 - 1985 | A: Doxorubicin, 30 mg (in 30 mL saline). Total 21 instillations. (n=151) B: Doxorubicin, 20 mg (in 40 mL saline). Total 21 instillations. (n=158) C: MMC: 20 mg (in 40 mL saline). Total 21 instillations. (n=150) D: No adjuvant treatment. TURBT alone. (n=148) For A, B, and C: First instillation within 1 week of TURBT; once weekly × 2 weeks, then once every 2 weeks × 14 weeks, then once monthly × 8 months, then once every 3 month × 1 year. | Duration: 3.5 years, maximum; Not reported as median/mean, nor for each group. Method: Cystoscopy and urinary cytology | Age (average), years: 63.1 vs. 62.1 vs. 62.3 vs. 62.0 Male: 80.1% vs. 82.3% vs. 82.0% vs. 81.1% Race/ethnicity: Not reported Recurrent bladder cancer: None (primary only) Stage: Not reported (“no differences”) Functional Status: Not reported
Akaza, 1992^113^ [Study Two] (followup of Akaza, 1987^112^) | Japan Multicenter 1982 - 1990 | A: Doxorubicin, 30 mg (in 30 mL saline). Total 21 instillations. (n=44) B: Doxorubicin, 20 mg (in 40 mL saline). Total 21 instillations. (n=42) C: MMC: 20 mg (in 40 mL saline). Total 21 instillations. (n=41) D: No adjuvant treatment. TURBT alone. (n=31) For A, B, and C: First instillation within 1 week of TURBT; once weekly × 2 weeks, then once every 2 weeks × 14 weeks, then once monthly × 8 months, then once every 3 month × 1 year. | Duration: median 2,366 days (6.5 years); range: 480-2,817 days. Method: Cystoscopy and urinary cytology. | Not reported by treatment group Age: ≤50 years: 13.3%; ≤60 years: 17.7%; <70 years: 35.4%; ≥70 years: 33.5% Male: 84.8% Race/ethnicity: Not reported Recurrent bladder cancer: None (primary only) Stage: Tis: 1.3%; Ta: 44.3%; T1: 40.5%; Ta or T1: 13.9% Functional Status: Not reported
Ali-El-Dein, 1997^119^ (Journal of Urology) | Egypt Single center 1991 - 1995 | A: Epirubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=64) B: Epirubicin, 80 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=68) C: Doxorubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=60) D: TURBT only. No adjuvant therapy. (n=61) | Duration: 30.1 months (mean) for all groups. Method: Cysto-urethroscopy, urine cytology, and flow cytometry | Age: Not reported Male: 81.4%,overall; not reported by group Race/ethnicity: Not reported Recurrent bladder cancer: 37.5% vs. 41.2% vs. 43.3% vs.45.9% Stage: pTa: 10.9% vs. 17.6% vs. 6.7% vs.9.8%; pT1: 89.1% vs. 82.4% vs. 93.3% vs.90.2%; Tis associated: 6.3% vs. 11.8% vs. 0.0% vs.0.0% Functional Status: Not reported
Cheng, 2005^120^ | Hong Kong Single center 1986 - 1991 | A: Doxorubicin, 50 mg (in 50 mL saline). Total 12 instillations: First at 2 weeks after TURBT, then weekly × 4 weeks, then monthly × 5 months, then every 3 months × 6 months. (n=46) B: TURBT only. No adjuvant therapy. (n=36) | Duration, median: Recurrence: 45 months Progression: 128 months Mortality: 131.5 months Method: Cystoscopy and urine cytology. | Age (mean), years: 65.5 vs. 62.1 Male: 71.7% vs. 86.1% Race/ethnicity: Not reported Recurrent bladder cancer: Not reported Stage: Ta: 67.4% vs. 63.9%; T1: 21.7% vs. 13.9%; Not reported: 10.9% vs. 22.2% Functional Status: Not reported
Eto, 1994^195^ | Japan Multicenter 1990 - 1992 | A: Epirubicin, 30 mg (in 30 mL physiological saline). Total 19 instillations: 2 times/week for 4 weeks, then 1 time/month for 11 months. (n=60) B: Doxorubicin, 30 mg (in 30 mL physiological saline). Total 19 instillations: 2 times/week for 4 weeks, then 1 time/month for 11 months. (n=54) | Duration: 674 days vs. 606 days (mean). Method: Cystoscopy and urine cytology. | Age (median), years: 65 vs. 67 Male: 85.0% vs. 87.0% Race/ethnicity: Not reported Recurrent bladder cancer: 14.8% vs. 16.3%; Unknown: 10% vs. 9.3% Stage: Ta: 35.0% vs. 31.5%; T1: 48.3% vs. 57.4%; Unknown: 16.7% vs. 11.1% Functional Status: Not reported
Gustafson, 1991^115^ | Sweden Number centers not reported Study years not reported | A: MMC. Dosages “varied according to individual patient's bladder capacity”. Range: “5 mg in 20 mL” to “40 mg in 250 mL”. Total 15 instillations: First instillation approximately 2 weeks after TURBT; instillations weekly × 4 weeks, then monthly × 11 months. (n=19) B: Doxorubicin. Dosages “varied according to individual patient's bladder capacity”. Range: “10 mg in 20 mL” to “80 mg in 250 mL”. Total 15 instillations: Same protocol as A. (n=20) C: TURBT only. No adjuvant therapy. (n=21) | Duration: 47 months vs. 45 months vs. 35 months (mean). Method: Followup with cystoscopy. | Age (mean), years: 67 (overall) Male: “Four to one”, male/female (overall) Race/ethnicity: Not reported Recurrent bladder cancer: Not reported Stage: Ta: 89.5% vs. 90.0% vs. 95.2%; T1: 10.5% vs. 10.0% vs. 4.8% Functional Status: Not reported
Huland, 1990^191^ | Germany Multicenter 1983 - 1985 | A: MMC (20 mg/20 mL). Total 42 instillations: First at 4-6 weeks after hospital discharge, then every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. (n=209)B: MMC (20 mg/20 mL). Total 42 instillations: First at 4-6 weeks after hospital discharge, then every week × 8 weeks, then every 4 weeks for rest of 1st year and 2 additional years. (n=96)C: MMC (20 mg/20 mL). Total 20 instillations: First at 4-6 weeks after hospital discharge, then every week × 20 weeks. (n=75)D: Doxorubicin (50 mg/50 mL). Total 42 instillations: First at 4-6 weeks after hospital discharge, then every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. (n=39) | Duration: 26.7 months vs. 27.4 months vs. 26.7 months vs. 30.2 months (mean). Method: Cystoscopy | Age (mean), men/women, years: 61.1/67.5 vs. 66.3/68.1 vs. 65.1/64.6 vs. .68.0/58.3 Male: 82.3% vs. 77.1% vs. 77.3% vs. 74.4% Race/ethnicity: Not reported Recurrent bladder cancer: 32.1% vs. 25.0% vs. 25.3% vs. 43.6% Stage: Ta: 73.7% vs. 78.1% vs. 76.0% vs. 59.0%; T1: 23.0% vs. 19.8% vs. 21.3% vs. 33.3%; Tis: 3.3% vs. 2.1% vs. 2.7% vs. 7.7% Functional Status: Not reported
Kurth, 1997^121^ | Europe Multicenter 1979 - 1983 | A: Doxorubicin, 50 mg (in 50 mL normal saline). Total 15 instillations: First at 3 to 14 days after TURBT, then weekly for 1 month, then monthly for 11 months. Nitrofurantoin, 100 mg, was given after each instillation 3 times/day × 3 days. (n=166) B: TURBT only. No adjuvant therapy. (n=70) | Duration: Median followup: Recurrence: 3.4 years Progression: 5 years Mortality from malignancy: 7.2 years Mortality overall: 10.7 years. Method: Cystoscopy. | Age: <50 years: 8% vs. 7%; 50-59 years: 21% vs. 28%; 60-69 years: 28% vs. 35%; 70-79 years: 39% vs. 24%; ≥80 years: 4% vs. 7%; Unknown: 1% vs. 0% Male: 80% vs. 90% Race/ethnicity: Not reported Recurrent bladder cancer: 30.2% vs. 34.7% Stage: T0: 0% vs. 0%; Ta: 50% vs. 58%; T1: 45% vs. 40%; Tis: 4% vs. 1%; Unknown: 1% vs. 0% Functional Status: Not reported
Martinez-Pineiro, 1990^172^ | Spain Single center 1980-1988 | A. Thiotepa 50 mg (in 50 mL saline). (n=56) B. Doxorubicin 50 mg (in 50 mL saline). Total 16 instillations. (n=53) A and B: First treatment within 14 days of TURBT, then weekly × 4 weeks, then monthly × 11 months. | Duration: 34 months vs. 40 months Range (months): (6-78) vs. (5-97) Method: Cystoscopy and urinary cytology. | Age (Median), years: 64 vs. 62 Male: 84% vs. 89% Race/ethnicity: Not reported Stage: Ta: 41% vs. 40%; T1: 59% vs. 60% Associated Tis: 9% vs. 11%
Matsumura, 1992^123^ | Japan Multicenter 1987 - 1989 | A: Doxorubicin, 20 mg (in 40 mL physiological saline). Total 21 instillations over 2 years after TURBT: Timing of first dose not specified; instillations once a week × 2, then every 2 weeks × 7, then once a month × 8, then once every 3 months × 4. (n=126) B: Doxorubicin, 20 mg (in 40 mL physiological saline). Total 6 instillations over 2 weeks before TURBT: specific schedule not reported. (n=75) C: No adjuvant treatment. TURBT alone. (n=83) | Duration: 240 days, (n=284) 720 days (maximum), (n=156) Method: not reported. | Age: ≤49 years: 7.1% vs. 4.0% vs.12.1%; 50-59 years: 15.1% vs. 20.0% vs. 13.3%; 60-69 years: 34.1% vs. 32.0% vs. 31.3%; ≥70 years: 42.9% vs. 44.0% vs. 42.2% Male: 81.7% vs. 78.7% vs. 84.3% Race/ethnicity: Not reported Recurrent bladder cancer: 59.5% vs. 61.3% vs. 50.6% Stage: Ta: 32.5% vs. 20.6% vs. 32.5%; T1: 42.9% vs. 20.6% vs. 36.1%; Tis: 0.8% vs. 2.7% vs. 3.6%; Unknown: 23.8% vs. 28.0% vs. 26.5% Functional Status: Not reported
Niijima, 1983^116^ (see Akaza, 1987^112^) | Japan Multicenter 1980 - 1985 | A: Doxorubicin, 30 mg (in 30 mL saline). Total 8 instillations. (n=149) B: Doxorubicin, 20 mg (in 40 mL saline). Total 8 instillations. (n=148) C: MMC: 20 mg (in 40 mL saline). Total 8 instillations. (n=139) D: No adjuvant treatment. TURBT alone. (n=139) For A, B, and C: First instillation within 1 week of TURBT. Twice weekly × 4 weeks | Duration: 5 years (maximum) Method: Cystoscopy and urinary cytology. | Age (average), years: 62.3 vs. 62.9 vs. 62.9 vs. 62.9 Male: 82.6% vs. 75.7% vs. 74.8% vs. 74.1% Race/ethnicity: Not reported Recurrent bladder cancer: 29.5% vs. 31.1% vs. 33.8% vs. 35.3% Stage: Not reported Grade: Not reported Functional Status: Not reported
Obata, 1994^124^ | Japan Multicenter 1985 - 1987 | A: Doxorubicin, 20 mg (in 40 mL physiological saline). Total 19 instillations over 1 year, after TURBT: Timing of first dose not specified; instillations twice a week × 4 weeks, then once a month × 11 months. (n=90) B: No adjuvant treatment. TURBT alone. (n=76) | Duration: Until January, 1991. Not reported as mean/median nor by group. Method: not reported. | Age: ≤49 years: 11.1% vs. 8.0%; 50-59 years: 15.6% vs. 25.0%; 60-69 years: 40.0% vs. 32.9%; ≥70 years: 33.3% vs. 34.2% Male: 77.8% vs. 81.6% Race/ethnicity: Not reported Recurrent bladder cancer: 54.4% vs. 48.7% Stage: Ta: 33.3% vs. 43.4%; T1: 52.2% vs. 42.1%; Tx: 12.2% vs. 11.8% Functional Status: Not reported
Okamura, 2002^125^ | Japan Multicenter 1994 - 1998 | A: Doxorubicin, 30 mg (in 30 mL normal saline). Single intravesical instillation within 6 hours of TURBT. (n=81) B: TURBT only. No adjuvant therapy. (n=79) | Duration: 40.8 months (median) all patients. Method: Cystoscopy and urine cytology. | Age (mean), years: 59.7 vs. 61.9 Male: Not reported Race/ethnicity: Not reported Recurrent bladder cancer: 7.4% vs. 2.5% Stage: pTa: 95.1% vs. 93.7%; pT1: 4.9% vs. 6.3% Functional Status: All patients had Eastern Cooperative Oncology Group performance status ≤2
Shuin, 1994^196^ | Japan Multicenter 1990 - 1993 | A: Epirubicin, 30 mg (in 40 mL saline). Total 17 instillations: Timing of first not specified; every 2 weeks × 3 months, then every 4 weeks for remainder of 1 year. B: Doxorubicin, 30 mg (in 40 mL saline). Total 17 instillations: Timing of first not specified; every 2 weeks × 3 months, then every 4 weeks for remainder of 1 year. | Duration: Overall 43 months. Mean/median followup duration not reported. Method: not described. | Age: <40 years: 6% vs. 3%; 40-49 years: 3% vs. 9% 50-59 years: 9% vs. 24% 60-69 years: 25% vs. 21% ≥70: 56% vs. 42% Male: 81% vs. 82% Race/ethnicity: Not reported Recurrent bladder cancer: All (recurrent only) Stage Ta: 69% vs. 64% Stage T1: 25% vs. 27% Stage unknown: 6% vs. 9% Functional status: Not reported

G0 = lowest grade bladder cancer; G1 = Grade 1 ; G2 = Grade 2; G3 = Grade 3; Gx = Grade unknown; MMC = Mytomycin C; pTa = Tumor stage a determined by pathology; pT1 = Tumor stage 1 determined by pathology; T0 = no evidence of a primary tumor in the bladder; T1 = Tumor stage 1; Ta = Tumor stage a; Tis = Carcinoma in situ; TURBT = transurethral resection of bladder tumor; Tx = tumor stage unknown

Table 10 Summary of doxorubicin study results

Author, Year | Interventions (number analyzed for recurrence) | Recurrence | Progression | Mortality
Abrams, 1981^95^ | A: Doxorubicin, 50 mg (in 50 mL saline). Single instillation, within 24 hours of TURBT. B: No adjuvant treatment. TURBT alone. | Recurrence at 6 months: 79.3% (23/29) vs. 89.3% (25/28)
Akaza, 1987^112^ [Study One] (followup of Niijima, 1983^116^) | A: Doxorubicin, 30 mg (in 30 mL saline). Total 8 instillations: First within 1 week of TURBT, twice weekly × 4 weeks. (n=149) B: Doxorubicin, 20 mg (in 40 mL saline). Total 8 instillations: First within 1 week of TURBT, twice weekly × 4 weeks. (n=148) C: MMC: 20 mg (in 40 mL saline). Total 8 instillations: First within 1 week of TURBT, twice weekly × 4 weeks. (n=139) D: No adjuvant treatment. TURBT alone. (n=139) | Recurrence-free survival rate at 540 days*: 56.6% vs. 52.0% vs. 42.4% vs. 38.5%, generalized Wilcoxon test: A vs. D, p<0.05 B vs. D, p<0.05 C vs. D, p<0.10 Recurrence-free survival at 1800 days, generalized Wilcoxon test: B>D, p<0.05 C>D, p<0.05 * from Niijima, 1983
Akaza, 1987^112^ [Study Two] | A: Doxorubicin, 30 mg (in 30 mL saline). Total 21 instillations. (n=151) B: Doxorubicin, 20 mg (in 40 mL saline). Total 21 instillations. (n=158) C: MMC: 20 mg (in 40 mL saline). Total 21 instillations. (n=150) D: No adjuvant treatment. TURBT alone. (n=148) For A, B, and C: First instillation within 1 week of TURBT; once weekly × 2 weeks, then once every 2 weeks × 14 weeks, then once monthly × 8 months, then once every 3 month × 1 year. | Recurrence-free survival rate at 1 year: 74.8% vs. 75.0% vs. 76.3% vs. 66.7% Recurrence-free survival rate at 2 years: 62.3% vs. 59.1% vs. 62.3% vs. 51.8% Recurrence-free survival at 1260 days, generalized Wilcoxon test: A>D, p<0.05 B>D, p<0.05 C>D, p<0.05
Akaza, 1992^113^ [Study Two] (followup of Akaza, 1987^112^) | A: Doxorubicin, 30 mg (in 30 mL saline). Total 21 instillations. (n=44) B: Doxorubicin, 20 mg (in 40 mL saline). Total 21 instillations. (n=42) C: MMC: 20 mg (in 40 mL saline). Total 21 instillations. (n=41) D: No adjuvant treatment. TURBT alone. (n=31) For A, B, and C: First instillation within 1 week of TURBT; once weekly × 2 weeks, then once every 2 weeks × 14 weeks, then once monthly × 8 months, then once every 3 month × 1 year. | Recurrence: Recurrence/year (number of recurrences/total observation period: 0.473 vs. 0.512 vs. 0.472 vs. 0.510 | Progression (in stage, grade, or both): 43.2% (19/44) vs. 31.0% (13/42) vs. 26.8% (11/41) vs. 38.7% (12/31), “Statistics: no difference”
Ali-El-Dein, 1997^119^ (Journal of Urology) | A: Epirubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=64) B: Epirubicin, 80 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=68) C: Doxorubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=60) D: TURBT only. No adjuvant therapy. (n=61) | Recurrence: 25.0% (16/64) vs. 17.6% (12/68) vs. 36.7% (22/60) vs.65.6% (40/61); A, B, and C vs. D, p=0.0002; A and B vs. C, p=0.02; A vs. B, p>0.05. Mean time to first recurrence, months (95% CI): 16 (12.2-19.8) vs. 15.4 (11.4-19.4) vs. 18.9 (14.4-23.4) vs. 6.3 (5.2-7.4), A, B, and C vs. D, p<0.001; A and B vs. C, p=0.05; A vs. B, p=0.05 (all log-rank test) Recurrence rate/100 patient/months: 0.83 vs. 0.60 vs. 1.18 vs. 2.73, A, B, and C vs. D, p<0.001; A and B vs. C, p<0.05; A vs. B, p<0.05. | Progression: 10.9% (7/64) vs. 4.4% (3/68) vs. 10.0% (6/60) vs.8.2% (5/61). Mean interval to progression, months (95% CI): 31 (22-40) vs. 31 (18-44) vs. 33 (26-40) vs. 37 (30-44), log-rank test, p=0.6 (all log-rank test).
Cheng, 2005^120^ | A: Doxorubicin, 50 mg (in 50 mL saline). Total 12 instillations: First at 2 weeks after TURBT, then weekly × 4 weeks, then monthly × 5 months, then every 3 months × 6 months. (n=46) B: TURBT only. No adjuvant therapy. (n=36) | Recurrence: 37.0% (17/46) vs. 52.8% (19/36) Recurrence-free survival (median), months: 190 vs. 89 Recurrence-free survival at 10 years (Kaplan-Meier estimate): 67% vs. 50% Recurrence-free survival, log rank test, p=0.12 Time to recurrence (median), months: 13 vs. 8 | Progression: 13.0% (6/46) vs. 5.6% (2/36) Progression-free survival at 10 years (Kaplan-Meier estimate): 84% vs. 89% Progression-free survival, log rank test, p=0.44 Time to progression (median), months: 34 vs. 61 | Mortality (disease-specific): 6.5% vs. 2.8% Disease-specific survival at 10 years (Kaplan-Meier estimate): 95% vs. 97% Median time to death (disease-specific), months: 73 vs. 55 Mortality (other causes): 30.4% vs. 16.7% Overall survival at 10 years (Kaplan-Meier estimate): 68% vs. 83%
Eto, 1994^195^ | A: Epirubicin, 30 mg (in 30 mL physiological saline). Total 19 instillations: 2 times/week for 4 weeks, then 1 time/month for 11 months. (n=60) B: Doxorubicin, 30 mg (in 30 mL physiological saline). Total 19 instillations: 2 times/week for 4 weeks, then 1 time/month for 11 months. (n=54) | Recurrence free at 1 year: 92.8% vs. 86.4%, generalized Wilcoxon test, p=nonsignificant. Recurrence free at 2 years: 88.6% vs. 81.8%, generalized Wilcoxon test, p=nonsignificant.
Gustafson, 1991^115^ | A: MMC. Dosages “varied according to individual patient's bladder capacity”. Range: “5 mg in 20 mL” to “40 mg in 250 mL”. Total 15 instillations: First instillation approximately 2 weeks after TURBT; instillations weekly × 4 weeks, then monthly × 11 months. (n=19) B: Doxorubicin. Dosages “varied according to individual patient's bladder capacity”. Range: “10 mg in 20 mL” to “80 mg in 250 mL”. Total 15 instillations: Same protocol as A. (n=20) C: TURBT only. No adjuvant therapy. (n=21) | Recurrence-free survival during treatment year: 52.6% (10/19) vs. 15.0% (3/20) vs. 14.3% (3/21) Recurrence-free survival for duration of followup: 26.3% (5/19) vs. 10.0% (2/20) vs. 4.8% (1/21) Recurrence rate/100 patient-months: 7.7 vs. 18.3 vs. 18.6, p=0.02 Mean disease-free interval, months (A vs. B): 14 vs. 6, p=0.02 | Progression: Increased stage only: 0.0% (0/19) vs. 5.0% (1/20) vs. 4.8% (1/21) Increased grade only: 0.0% (0/19) vs. 15.0% (3/20) vs. 9.5% (2/21) Increased stage and grade: 10.5% (2/19) vs. 10.0% (2/20) vs. 0.0% (0/21)
Huland, 1990^191^ | A: MMC (20 mg/20 mL). Total 42 instillations: First at 4-6 weeks after hospital discharge, then every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. (n=209) B: MMC (20 mg/20 mL). Total 42 instillations: First at 4-6 weeks after hospital discharge, then every week × 8 weeks, then every 4 weeks for rest of 1st year and 2 additional years. (n=96) C: MMC (20 mg/20 mL). Total 20 instillations: First at 4-6 weeks after hospital discharge, then every week × 20 weeks. (n=75) D: Doxorubicin (50 mg/50 mL). Total 42 instillations: First at 4-6 weeks after hospital discharge, then every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. (n=39) | Recurrence: 15.3% (32/209) vs. 9.4% (9/96) vs. 17.3% (13/75) vs. 23.1% (9/39); differences reported as not statistically significant, p-values not reported. Recurrence per 100 patient-months: 0.68 vs. 0.49 vs. 0.65 vs. 0.76 | Progression of stage: 2.9% (6/209) vs. 1.0% (1/96) vs. 5.3% (4/75) vs. 7.7% (3/39) Progression of grade: 1.9% (4/209) vs. 1.0% (1/96) vs. 4.0% (3/75) vs. 10.3% (4/39)
Kurth, 1997^121^ | A: Doxorubicin, 50 mg (in 50 mL normal saline). Total 15 instillations: First at 3 to 14 days after TURBT, then weekly for 1 month, then monthly for 11 months. Nitrofurantoin, 100 mg, was given after each instillation 3 times/day × 3 days. (n=166) B: TURBT only. No adjuvant therapy. (n=70) | Recurrence: 50% (83/166) vs. 67% (47/70) Recurrence-free at 3 years: 48% (95% CI 40-56) vs. 29% (95% CI 17-41) Recurrence rate per year: 0.30 vs. 0.68; p-value significant. Time to first recurrence: A>B, log-rank test, p<0.001. | Progression: 13.8% (25/181) vs. 18.1% (13/72) Progression-free at 5 years: 86% (95% CI 80-92) vs. 87% (95% CI 77-96) Free of distant metastases at 5 years: 97% (95% CI 94-100) vs. 98% (95% CI 95-100) | Survival (death from malignancy) at 5 years: 92% (95% CI 88-96) vs. 97% (95% CI 92-100) Survival (death from malignancy) at 10 years: 82% (95% CI 75-89) vs. 82% (95% CI 70-95) Survival (all cause) at 5 years: 74% (95% CI 67-81) vs. 73% (95% CI 61-84) Survival (all cause) at 10 years: 46% (95% CI 37-54) vs. 42% (95% CI 29-56)
Martinez-Pineiro, 1990^172^ | A. Doxorubicin 50 mg (in 50 mL saline). Total 16 instillations. (n=53) B. Thiotepa 50 mg (in 50 mL saline). (n=56) A and B: First treatment within 14 days of TURBT, then weekly × 4 weeks, then monthly × 11 months. | Recurrence: 43% (23/53) vs. 36% (20/56), p>0.05; Mantel-Haenszel test, p=NS Months to recurrence (mean): 31 vs. 29 | Progression: 8% (4/53) vs. 4% (2/56) | Death due to metastatic disease: 1 vs. 0 Noncancer death: 0 vs. 1
Matsumura, 1992^123^ | A: Doxorubicin, 20 mg (in 40 mL physiological saline). Total 21 instillations over 2 years after TURBT: Timing of first dose not specified; instillations once a week × 2, then every 2 weeks × 7, then once a month × 8, then once every 3 months × 4. (n=126) B: Doxorubicin, 20 mg (in 40 mL physiological saline). Total 6 instillations over 2 weeks before TURBT: specific schedule not reported. (n=75) C: No adjuvant treatment. TURBT alone. (n=83) | Recurrence-free survival rate at 240 days: 73.8% vs. 57.8% vs. 61.2%; A vs. B, p<0.05; other comparisons, p=NS Recurrence-free survival rate at 480 days: 52.0% vs. 37.0% vs. 32.0%; A vs. C, p<0.01; other comparisons, p=NS Recurrence-free survival rate at 720 days: 38.2% vs. 18.8% vs. 17.8%; A vs. B, p<0.05; A vs. C, p<0.01; other comparisons, p=NS
Niijima, 1983^116^ | A: Doxorubicin, 30 mg (in 30 mL saline). Total 8 instillations. B: Doxorubicin, 20 mg (in 40 mL saline). Total 8 instillations. C: MMC: 20 mg (in 40 mL saline). Total 8 instillations. D: No adjuvant treatment. TURBT alone. For A, B, and C: First instillation within 1 week of TURBT. Twice weekly × 4 weeks | Recurrence-free survival rate at 540 days: 56.6% vs. 52.0% vs. 42.4% vs. 38.5%, generalized Wilcoxon test: A vs. D, p<0.05 B vs. D, p<0.05 C vs. D, p<0.10
Obata, 1994^124^ | A: Doxorubicin, 20 mg (in 40 mL physiological saline). Total 19 instillations over 1 year, after TURBT: Timing of first dose not specified; instillations twice a week × 4 weeks, then once a month × 11 months. (n=90) B: No adjuvant treatment. TURBT alone. (n=76) | Recurrence-free survival rate at 3 years: 44% vs. 30% (p-value not reported).
Okamura, 2002^125^ | A: Doxorubicin, 30 mg (in 30 mL normal saline). Single intravesical instillation within 6 hours of TURBT. (n=81) B: TURBT only. No adjuvant therapy. (n=79) | Recurrence-free survival: A>B, log-rank test, p=0.0026. Time to initial recurrence (mean), months: 41.9 vs. 18.0 Recurrence rate per year: 0.11 ± 0.22 vs. 0.24 ± 0.36, p=0.007 Adjusted HR for recurrence (B as reference): 0.31 (95% CI 0.17-0.56, p=0.0001); adjusted covariates not specified.
Shuin, 1994^196^ | A: Epirubicin, 30 mg (in 40 mL saline). Total 17 instillations: Timing of first not specified; every 2 weeks × 3 months, then every 4 weeks for remainder of 1 year. B: Doxorubicin, 30 mg (in 40 mL saline). Total 17 instillations: Timing of first not specified; every 2 weeks × 3 months, then every 4 weeks for remainder of 1 year. | Recurrence: 25% (8/32) vs. 27% (9/33), chi-square test, p=NS. Recurrence-free period, mean (range): 9.7 months (4 to 17) vs. 8.5 months (3 to 16), “no significant difference” (type of statistical testing and p-value not specified). | Progression: “There has been no case of grade G3 or invasive cancer in either group.”

CI = confidence interval; G3 = Grade 3; HR = hazard ratio; MMC = Mytomycin C; NS = not significant; TURBT = transurethral resection of bladder tumor

Table 11 Summary of epirubicin study characteristics

Author, Year | Setting and Study Years | Interventions (number analyzed for recurrence) | Duration of Followup and Method | Population Characteristics by Treatment Group (age, race/ethnicity, sex, stage of disease, functional status)
Ali-El-Dein, 1997^119^ (Journal of Urology) | Egypt Single center 1991 - 1995 | A: Epirubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=64) B: Epirubicin, 80 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=68) C: Doxorubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=60) D: TURBT only. No adjuvant therapy. (n=61) | Duration, mean: 30.1 months for all groups. Method: Cysto-urethroscopy, urine cytology, and flow cytometry. | Age: Not reported Male: 81.4%,overall; not reported by group Race/ethnicity: Not reported Recurrent bladder cancer: 37.5% vs. 41.2% vs. 43.3% vs.45.9% Stage: pTa: 10.9% vs. 17.6% vs. 6.7% vs.9.8%; pT1: 89.1% vs. 82.4% vs. 93.3% vs.90.2%; Tis associated: 6.3% vs. 11.8% vs. 0.0% vs.0.0% Functional Status: Not reported
Ali-El-Dein, 1997^126^ (British Journal of Urology) | Egypt Single center 1992 - 1996 | A: Epirubicin, 50 mg (in 50 mL normal saline). Single instillation immediately after TURBT. (n=55) B: Epirubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=59) C: TURBT only. No adjuvant therapy. (n=54) | Duration, mean: 32.2 months Method: Cystourethroscopy, urine cytology, and flow cytometry. | Age (mean), years: 52.1 vs. 55 vs. 53.4 Male: 67.3% vs. 74.6% vs. 70.4% Race/ethnicity: Not reported Recurrent bladder cancer: 47.2% vs. 52.5% vs. 44.4% Stage: pTa: 16.3% vs. 25.4% vs. 18.5%; pT1: 83.7% vs. 74.6% vs. 81.5% Functional Status: Not reported
Berrum-Svennung, 2008^127^ | Sweden Multicenter 1998 - 2004 | A: Epirubicin, 50 mg (in 50 mL saline). Single instillation within 6 hours after TURBT. (n=155) B: Placebo. Saline, 50 mL. Single instillation within 6 hours after TURBT. ( n=152) | Duration: 2 years, not reported as median/mean, nor for each group. Method: Cystoscopy. | Age (median), years: 74 vs. 71 Age (mean), years: 71 vs. 69 Male: 69.7% vs. 77.6% Race/ethnicity: Not reported Recurrent bladder cancer: 49.7% vs. 50.7% Stage/Grade: Ta/G1-G2: 85.2% vs. 82.2%; T1/G1-G2: 5.7% vs. 8.0%; Unknown: 9.7% vs. 9.9% Functional Status: Not reported
Eto, 1994^195^ | Japan Multicenter 1990 - 1992 | A: Epirubicin, 30 mg (in 30 mL physiological saline). Total 19 instillations: 2 times/week for 4 weeks, then 1 time/month for 11 months. (n=60) B: Doxorubicin, 30 mg (in 30 mL physiological saline). Total 19 instillations: 2 times/week for 4 weeks, then 1 time/month for 11 months. (n=54) | Duration, mean: 674 days vs. 606 days Method: Cystoscopy and urine cytology. | Age (median), years: 65 vs. 67 Male: 85.0% vs. 87.0% Race/ethnicity: Not reported Recurrent bladder cancer: 14.8% vs. 16.3%; Unknown: 10% vs. 9.3% Stage: Ta: 35.0% vs. 31.5%; T1: 48.3% vs. 57.4%; Gx: 16.7% vs. 11.1% Functional Status: Not reported
Gudjónsson, 2009^128^ | Sweden Multicenter 1997 - 2004 | A: Epirubicin, 80 mg (in 30 mL saline). Single instillation within 24 hours of TURBT. (n=102) B: TURBT only. No adjuvant therapy. (n=117) | Duration, median: 3.9 years, for all patients. 3.6 years for patients without recurrence. Method: Cystoscopy and urine cytology. | Age (mean), years: 70 vs. 70 Male: 72.5% vs. 69.3% Race/ethnicity: Not reported Recurrent bladder cancer: 46.1% vs. 48.7% Stage: Ta: 81.4% vs. 86.3%; T1: 9.8% vs. 6.8%; Unknown: 7.8% vs. 6.0%; “Low malignant potential”: 1.0% vs. 0.9% Functional Status: Not reported
Igawa, 1996^129^ | JapanNumber centers not reported.Study years not reported. | A: Epirubicin, 20 mg (in 40 mL saline). Total 24 instillations: First instillation within 2 weeks of TURBT, once a month × 24 months. (n=43)B: TURBT only. No adjuvant therapy. (n=32) | Duration, median: 20 months, all patients Method: Cystoscopy. | Population characteristics not reported according to treatment status.
Liu, 2006^192^ | China Number centers not reported 1997 - 1998 | A: Epirubicin, 80 mg (in 40 mL normal saline). Single instillation within 6 hours of TURBT. (n=14) B: Epirubicin, 40 mg. Total 16 - 18 instillations: Every week for 6 ∼ 8 weeks, then every month for 10 months. (n=15) C: MMC, 40 mg. Total 16 - 18 instillations: Every week for 6 ∼ 8 weeks, then every month for 10 months. (n=15) | Duration: 5 years (all patients). Method: Cystoscopy and urine cytology. | Age (mean), years: 62.2 Male: Not reported Race/ethnicity: Not reported Recurrent bladder cancer: 23.4% (overall) Stage and Grade: TaG1: 6.3% vs. 0.0% vs. 0.0%; TaG2: 6.3% vs. 6.6% vs. 6.3%; T1G1: 12.5% vs. 26.7% vs. 12.5%; T1G2: 75.0% vs. 66.7% vs. 81.3% Functional Status: Not reported
Melekos, 1992^130^ | Greece Number centers not reported. Study years not reported. | A: Epirubicin, 50 mg (in 5 mL sterile saline). Total minimum 6 instillations for all patients: First instillation within 2 weeks after TURBT, one dose weekly × 6 weeks. Then, single dose given at each followup exam for patients who were recurrence-free during following 2 years. (n=43) B: TURBT only. No adjuvant therapy. (n=22) | Duration: not reported. Method: Cystoscopy and urine cytology. | Age (mean), years: 66.2 vs. 67.4 Male: 83.7% vs. 86.4% Race/ethnicity: Not reported Recurrent bladder cancer: 32.6% vs. 31.8% Stage: Ta: 60.5% vs. 59.1%; T1: 39.5% vs. 40.1%; Associated Tis: 4.7% vs. 4.5% Functional Status: Not reported
Melekos, 1993^103^ | Greece Number of centers not reported. Study years not reported. | A. Epirubicin, 50 mg (in 50 mL saline). Total instillations variable: All patients received initial 6-week course, then maintenance therapy every 3 months for first 2 years then every 6 months if at high risk for recurrence and initially responsive to treatment then received a separate 4-week course at month 6 of followup. (n=67) B. TURBT only. No adjuvant therapy. (n=32) | Duration: 50 months, overall. Method: Cystoscopy and urine cytology. | Age (mean), years: 66 vs. 68 Male: 84% vs. 84% Race/ethnicity: Not reported Stage: Ta: 63% vs. 66%; T1: 37% vs. 34% Tis: 4% vs. 6% Functional Status: Not reported
Oosterlinck, 1993^131^ | Europe Multicenter 1986 - 1989 | A: Epirubicin, 80 mg (in 50 mL physiological solution). Single instillation minimum for each patient, within 6 hours after TURBT. For recurrence, repeat TURBT and repeat instillation for each recurrence until maximum of 3 additional instillations. (n=194) B: Placebo. Sterile water, 50 mL. Single instillation minimum for each patient, within 6 hours after TURBT. For recurrence, repeat TURBT and repeat instillation for each recurrence until maximum of 3 additional instillations. (n=205) | Duration, average: 2 years, 4.5 years maximum Method: Cystoscopy and urine cytology. | Reported for randomized groups (205 vs. 215) Age: Not reported % Male: Not reported Race/ethnicity: Not reported Recurrent bladder cancer: 21.0% vs. 23.0% Stage: pTa: 70.7% vs. 76.7%; pT1: 29.3% vs. 23.0%; Unknown: 0.0% vs. 0.5% Functional Status: Not reported
Rajala, 1999^133^ | Finland Multicenter 1991 - 1994 | A: Interferon-α-2b, 50 million units (in 100 mL physiological saline). Single intravesical instillation immediately after TURBT. (n=66) B: Epirubicin, 100 mg (in 100 mL physiological saline). Single intravesical instillation immediately after TURBT. (n=68)C: TURBT only. No adjuvant therapy. (n=66) | Duration: 2 years Method: Cystoscopy and urine cytology. | Age: Not reported Male: 81.8% vs. 70.6% vs. 65.2 Race/ethnicity: Not reported Recurrent bladder cancer: None (primary only) Stage: pTa: 80.3% vs. 79.4% vs. 83.3%; pT1: 19.7% vs. 20.6% vs. 16.7% Functional Status: Not reported
Rajala, 2002^132^ | Finland Multicenter 1991 - 1994 | A: Interferon-α-2b, 50 million units (in 100 mL physiological saline). Single intravesical instillation immediately after TURBT. (n=66) B: Epirubicin, 100 mg (in 100 mL physiological saline). Single intravesical instillation immediately after TURBT. (n=68) C: TURBT only. No adjuvant therapy. (n=66) | Duration, median: 72 months Method: Cystoscopy and urine cytology. | Age (mean), years: 66.3 vs. 65.1 vs. 64.6 Male: 81.8% vs. 70.6% vs. 65.2 Race/ethnicity: Not reported Recurrent bladder cancer: None (primary only) Stage: pTa: 80.3% vs. 79.4% vs. 83.3%; pT1: 19.7% vs. 20.6% vs. 16.7% Functional Status: Not reported
Saika, 2010^134^ | Japan Multicenter 1995 - 2001 | A. Epirubicin, 20 mg (in 40 mL physiological saline). Total 2 instillations: First immediately after (<1 hour) TURBT, second in the early morning of the following day. (n=79) B. Epirubicin, 50 mg (in 100 mL physiological saline). Total 2 instillations: First immediately after (<1 hour) TURBT, second in the early morning of the following day. (n=84) C. TURBT only. No adjuvant therapy. (n=77) | Duration, median: 44 months vs. 46 months vs. 42 months Method: Cystoscopy. | Based on eligible patents (n=257): Age (median), years: 69 vs. 69 vs. 71 Male: 81% vs. 89% vs. 88% Race/ethnicity: Not reported Recurrent bladder cancer: 40% vs. 43% vs. 40% Stage Ta: 54% vs. 60% vs. 64% Stage T1: 46% vs. 40% vs. 36% Functional status: Not reported
Shuin, 1994^196^ | Japan Multicenter 1990 - 1993 | A: Epirubicin, 30 mg (in 40 mL saline). Total 17 instillations: Timing of first not specified; every 2 weeks × 3 months, then every 4 weeks for remainder of 1 year. B: Doxorubicin, 30 mg (in 40 mL saline). Total 17 instillations: Timing of first not specified; every 2 weeks × 3 months, then every 4 weeks for remainder of 1 year. | Duration: not reported Method: not described | Age: <40 years: 6% vs. 3% 40-49 years: 3% vs. 9% 50-59 years: 9% vs. 24% 60-69 years: 25% vs. 21% ≥70: 56% vs. 42% Male: 81% vs. 82% Race/ethnicity: Not reported Recurrent bladder cancer: All (recurrent only) Stage Ta: 69% vs. 64% Stage T1: 25% vs. 27% Stage unknown: 6% vs. 9% Functional status: Not reported

G1 = Grade 1; G2 = Grade 2; G3 = Grade 3; Gx = Grade unknown; MMC = Mytomycin C; pT1 = Tumor stage 1 determined by pathology; pTa = Tumor stage a determined by pathology; T1 = Tumor stage 1; Ta = Tumor stage a; Tis = carcinoma in situ; TURBT = transurethral resection of bladder tumor

Table 12 Summary of epirubicin study results

Author, Year | Interventions (number analyzed for recurrence) | Recurrence | Progression | Mortality
Ali-El-Dein, 1997^119^ (Journal of Urology) | A: Epirubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=64) B: Epirubicin, 80 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=68) C: Doxorubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=60) D: TURBT only. No adjuvant therapy. (n=61) | Recurrence: 25.0% (16/64) vs. 17.6% (12/68) vs. 36.7% (22/60) vs.65.6% (40/61); A, B, and C vs. D, p=0.0002; A and B vs. C, p=0.02; A vs. B, p>0.05. Mean time to first recurrence, months (95% CI): 16 (12.2-19.8) vs. 15.4 (11.4-19.4) vs. 18.9 (14.4-23.4) vs. 6.3 (5.2-7.4), A, B, and C vs. D, p<0.001; A and B vs. C, p=0.05; A vs. B, p=0.05 (all log-rank test) Recurrence rate/100 patient/months: 0.83 vs. 0.60 vs. 1.18 vs. 2.73, A, B, and C vs. D, p<0.001; A and B vs. C, p<0.05; A vs. B, p<0.05. | Progression: 10.9% (7/64) vs. 4.4% (3/68) vs. 10.0% (6/60) vs.8.2% (5/61). Mean interval to progression, months (95% CI): 31 (22-40) vs. 31 (18-44) vs. 33 (26-40) vs. 37 (30-44), log-rank test, p=0.6 (all log-rank test).
Ali-El-Dein, 1997^126^ (British Journal of Urology) | A: Epirubicin, 50 mg (in 50 mL normal saline). Single instillation immediately after TURBT. (n=55) B: Epirubicin, 50 mg (in 50 mL normal saline). Total 18 instillations: First at 7 to 14 days after TURBT, then once a week × 7, then once monthly × 10. (n=59) C: TURBT only. No adjuvant therapy. (n=54) | Recurrence: 23.6% (13/55) vs. 25.4% (15/59) vs. 51.8% (28/54); A vs. B vs. C, p=0.002; A and B vs. C, p<0.001; A vs. B, p=0.8. Mean interval to first recurrence, months: 16 vs. 18 vs. 6.9; A and B vs. C, p<0.05; A vs. B, p>0.05. Recurrence rate/100 patient/months: 0.79 vs. 0.84 vs. 2.01 | Progression: 5.5% (3/55) vs. 3.4% (2/59) vs. 9.3% (5/54), p=0.4
Berrum-Svennung, 2008^127^ | A: Epirubicin, 50 mg (in 50 mL saline). Single instillation within 6 hours after TURBT. (n=155) B: Placebo. Saline, 50 mL. Single instillation within 6 hours after TURBT. ( n=152) | Recurrence, during 2 years: 51.0% (79/155) vs. 62.5% (95/152); Mann-Whitney U test, p=0.04, log-rank test, p=0.022 | Progression (stage to muscle invasion): 2.6% (4/155) vs. 1.3% (2/152), (difference “not significant”).
Eto, 1994^195^ | A: Epirubicin, 30 mg (in 30 mL physiological saline). Total 19 instillations: 2 times/week for 4 weeks, then 1 time/month for 11 months. (n=60) B: Doxorubicin, 30 mg (in 30 mL physiological saline). Total 19 instillations: 2 times/week for 4 weeks, then 1 time/month for 11 months. (n=54) | Recurrence (at 1 year): 6.7% (4/60) vs. 13.0% (7/54) Recurrence free at 1 year, generalized Wilcoxon test, p=nonsignificant. Recurrence (at 2 years): 11.6% (7/60) vs. 18.5% (10/54) Recurrence free at 2 years, generalized Wilcoxon test, p=nonsignificant.
Gudjónsson, 2009^128^ | A: Epirubicin, 80 mg (in 30 mL saline). Single instillation within 24 hours of TURBT. (n=102) B: TURBT only. No adjuvant therapy. (n=117) | Recurrence: 62% (63/102) vs. 77% (90/117) Difference in Recurrence-free survival, log-rank test, p=0.016. Univariate HR (95% CI): 0.67 (0.49-0.93), p=0.017 Multivariate HR (95% CI): 0.56 (0.39-0.80), p=0.002 (adjusted for tumor multiplicity, number of recurrences per year, sex, age, and tumor grade).
Igawa, 1996^129^ | A: Epirubicin, 20 mg (in 40 mL saline). Total 24 instillations: First instillation within 2 weeks of TURBT, once a month × 24 months. (n=43) B: TURBT only. No adjuvant therapy. (n=32) | Recurrence: 60.5% (26/43) vs. 68.8% (22/32), p-value not reported. | Progression: 20.9% (9/43) vs. 3.1% (1/32), p=0.024
Liu, 2006^192^ | A: Epirubicin, 80 mg (in 40 mL normal saline). Single instillation within 6 hours of TURBT. (n=14) B: Epirubicin, 40 mg. Total 16 - 18 instillations: Every week for 6 ∼ 8 weeks, then every month for 10 months. (n=15) C: MMC, 40 mg. Total 16 - 18 instillations: Every week for 6 ∼ 8 weeks, then every month for 10 months. (n=15) | Recurrence: 35.7% (5/14) vs. 33.3% (5/15) vs. 40% (6/15), p>0.05 Recurrence-free at 1 year: 100% (14/14) vs. 86.7% (13/15) vs.93.3% (14/15) Recurrence-free at 2 years: 85.7% (12/14) vs. 80.0% (12/15) vs.66.7% (13/15) Recurrence-free at 3 years: 71.4% (10/14) vs. 73.3% (11/15) vs.80.0% (12/15) Recurrence-free at 5 years: 64.3% (9/14) vs. 66.7% (10/15) vs.60.0% (9/15) Mean interval to recurrence, months: 8 vs. 4 vs. 5
Melekos, 1992^130^ | A: Epirubicin, 50 mg (in 5 mL sterile saline). Total minimum 6 instillations for all patients: First instillation within 2 weeks after TURBT, one dose weekly × 6 weeks. Then, single dose given at each followup exam for patients who were recurrence-free during following 2 years (maximum 7 additional instillations). (n=43) B: TURBT only. No adjuvant therapy. (n=22) | Recurrence: 37.2% (16/43) vs. 54,5% (12/22), p>0.50 Recurrence-free survival (40 months), A>B, Mantel-Haenszel test, p=0.11 Relative recurrence rate: 0.81 vs. 1.46, p>0.05 Recurrence rate/100 patient-months: 1.4 vs. 2.6, p>0.10 Mean time to recurrence: 18.7 month vs. 12.2 months, p<0.02 | Progression (stage and/or grade): 9.3% (4/43) vs. 22.7% (5/22), p>0.30
Melekos, 1993^103^ | A. Epirubicin, 50 mg (in 50 mL saline). Total instillations variable: All patients received initial 6-week course, then maintenance therapy every 3 months for first 2 years then every 6 months if at high risk for recurrence and initially responsive to treatment then received a separate 4-week course at month 6 of followup. (n=67) B. TURBT only. No adjuvant therapy. (n=32) | Recurrence: 40% (27/67) vs. 59% (19/32) Interval before recurrence: 16 months vs. 11 months Progression: 9% vs. 22% Muscle invasion: 4% vs. 13% | Progression (stage or muscle invasion): 13% (9/67) vs. 34% (11/32)
Oosterlinck, 1993^131^ | A: Epirubicin, 80 mg (in 50 mL physiological solution). Single instillation minimum for each patient, within 6 hours after TURBT. For recurrence, repeat TURBT and repeat instillation for each recurrence until maximum of 3 additional instillations. (n=194) B: Placebo. Sterile water, 50 mL. Single instillation minimum for each patient, within 6 hours after TURBT. For recurrence, repeat TURBT and repeat instillation for each recurrence until maximum of 3 additional instillations. (n=205) | Recurrence: 29% (56/194) vs. 41% (84/205), log-rank test, p=0.02Recurrence rate/year: 0.17 vs. 0.32, p<0.0001 | Progression: 8.8% (17/194) vs. 7.3% (15/205), “no evidence of difference”, p-value not reported.
Rajala, 1999^133^ | A: Interferon-α-2b, 50 million units (in 100 mL physiological saline). Single intravesical instillation immediately after TURBT. (n=66) B: Epirubicin, 100 mg (in 100 mL physiological saline). Single intravesical instillation immediately after TURBT. (n=68) C: TURBT only. No adjuvant therapy. (n=66) | Recurrence: 63.7% (42/66) vs. 33.8% (23/68) vs. 60.6 (40/66)
Rajala, 2002^132^ | A: Interferon-α-2b, 50 million units (in 100 mL physiological saline). Single intravesical instillation immediately after TURBT. (n=66) B: Epirubicin, 100 mg (in 100 mL physiological saline). Single intravesical instillation immediately after TURBT. (n=68) C: TURBT only. No adjuvant therapy. (n=66) | Recurrence: 68.2% (45/66) vs. 45.6% (31/68) vs. 72.7 (48/66), p=0.002. Recurrence-free at 72 months: 31.4% vs. 50.8% vs. 23.7% Recurrence-free survival: B>A or C, log-rank test, p=0.002. Median time to first recurrence, months (95% CI): 12 (9-15) vs. [not attained] vs. 9 (5-13)
Saika, 2010^134^ | A. Epirubicin, 20 mg (in 40 mL physiological saline). Total 2 instillations: First immediately after (<1 hour) TURBT, second in the early morning of the following day. (n=79) B. Epirubicin, 50 mg (in 100 mL physiological saline). Total 2 instillations: First immediately after (<1 hour) TURBT, second in the early morning of the following day. (n=84) C. TURBT only. No adjuvant therapy. (n=77) | Median recurrence-free survival, months: 24 vs. 38 vs. 13; A vs. B, p=0.48; A vs. C, p=0.25; B vs. C, p=0.05 (all log-rank test). | Progression: 0.0% (0/83) vs. 1.1% (1/90) vs. 0.0% (0/84).
Shuin, 1994^196^ | A: Epirubicin, 30 mg (in 40 mL saline). Total 17 instillations: Timing of first not specified; every 2 weeks × 3 months, then every 4 weeks for remainder of 1 year. B: Doxorubicin, 30 mg (in 40 mL saline). Total 17 instillations: Timing of first not specified; every 2 weeks × 3 months, then every 4 weeks for remainder of 1 year. | Recurrence: 25% (8/32) vs. 27% (9/33), chi-square test, p=NS.Recurrence-free period, mean (range): 9.7 months (4 to 17) vs. 8.5 months (3 to 16), “no significant difference” (type of statistical testing and p-value not specified). | Progression: “There has been no case of grade G3 or invasive cancer in either group.”

CI = confidence interval; G3 = Grade 3; HR = hazard ratio; MMC = Mytomycin C; NS = not significant; TURBT = transurethral resection of bladder tumor

Table 15 Summary of results for intravesical therapy versus no intravesical therapy

Intravesical Therapy | All-Cause Mortality | Bladder Cancer-Specific Mortality | Bladder Cancer Recurrence | Bladder Cancer Progression
BCG | No trials | 1 trial, RR 0.62, 95% CI 0.32 to 1.19 | 3 trials, RR 0.56, 95% CI 0.43 to 0.71, I^2^=0% | 4 trials, RR 0.39, 95% CI 0.24 to 0.64, I^2^=40%
MMC | 1 trial, HR 1.17, 95% CI 0.89 to 1.53 | 1 trial, HR 0.71, 95% CI 0.34 to 1.46 | 8 trials, RR 0.71, 95% CI 0.57 to 0.89, I^2^=72% | 5 trials, RR 0.68, 95% CI 0.39 to 1.20, I^2^=0%
Doxorubicin | 2 trials, RR 1.83, 95% CI 0.78 to 4.28 and RR 0.93, 95% CI 73 to 1.18 | 2 trials, RR 2.35, 95% CI 0.25 to 21.6 and RR 0.97, 95% CI 0.54 to 1.76 | 10 trials, RR 0.80, 95% CI 0.72 to 0.88, I^2^=46% | 5 trials, RR 1.03, 95% CI 0.72 to 1.46, I^2^=0.0%
Epirubicin | No trials | No trials | 9 trials, RR 0.63, 95% CI 0.53 to 0.75, I^2^=64% | 8 trials, RR 0.79, 95% CI 0.48 to 1.30, I^2^=27%
Gemcitabine | 1 trial, RR 0.50, 95% CI 0.13 to 2.00 | 1 trial, RR 1.00, 95% CI 0.06 to 15.8 | 1 trial, RR 0.98, 95% CI 0.70 to 1.36 | 1 trial, RR 3.00, 95% CI 0.32 to 28.4
Interferon-alpha | 1 trial, RR 1.00, 95% CI 0.15 to 6.75 | 1 trial, RR 1.00, 95% CI 0.15 to 6.75 | 3 trials, RR 0.75, 95% CI 0.53 to 1.06, I^2^=50% | 2 trials, RR 0.33, 95% CI 0.14 to 0.76, I^2^=0%
Thiotepa | 1 trial, HR 0.99, 95% CI 0.56 to 1.82 | 1 trial HR 1.61, 95% CI 0.59 to 4.30 (multi-instillation regimen) and HR 1.73, 95% CI 0.65 to 4.63 (single dose) | 5 trials, RR 0.78, 95% CI 0.58 to 1.06, I^2^=69% | 1 trial, RR 0.92, 95% CI 0.13 to 6.36

BCG = bacillus Calmette Guérin; CI = confidence interval; HR = hazard ratio; RR = relative risk

#### BCG

Five trials (reported in 10 publications) randomized patients to BCG versus no intravesical therapy following TURBT (Table 6; Appendixes E2, F2).102-111 The dose of BCG ranged from 75 mg to 150 mg. All trials evaluated maintenance therapy with BCG, except for one trial that was limited to 6-week induction therapy.106

No trial evaluated effects of BCG versus no intravesical therapy on risk of all cause mortality. One trial found BCG associated with decreased risk of bladder cancer mortality, but the difference was not statistically significant (RR 0.62, 95% CI 0.32 to 1.19).102 BCG was associated with reduced risk of bladder cancer recurrence (3 trials, 29% vs. 50%, RR 0.56, 95% CI 0.43 to 0.71, I^2^=0%) (Figure 9)103,104,111 and progression (4 trials, 15% vs. 42%, RR 0.39, 95% CI 0.24 to 0.64, I^2^=40%) (Figure 10).103-106 One trial found BCG associated with a trend towards decreased risk of cystectomy versus no intravesical therapy, but the difference was not statistically significant (RR 0.61, 95% CI 0.33 to 1.14).106

Figure 9 Meta-analysis of bacillus Calmette-Guérin versus no intravesical therapy: Risk of recurrence

BCG = bacillus Calmette-Guérin; CI = confidence interval

Figure 9 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus no intravesical therapy: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 3 studies, with a pooled risk of 0.56 (95% confidence interval 0.43 to 0.71), and the overall I-squared value of 0.0 (p=0.989).

Figure 10 Meta-analysis of bacillus Calmette-Guérin versus no intravesical therapy: Risk of progression

BCG = bacillus Calmette-Guérin; CI = confidence interval

Figure 10 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus no intravesical therapy: risk of progression. The plot depicts a meta-analysis of the risk of progression of bladder cancer. The risk of progression values are represented by squares. Recurrence risk was reported or calculated for 4 studies, with a pooled risk of 0.39 (95% confidence interval 0.24 to 0.64), and the overall I-squared value of 39.7 (p=0.174).

All BCG trials that reported recurrence evaluated maintenance regimens. Statistical heterogeneity was present in the analysis of progression. Excluding one trial106 that evaluated an induction regimen (also the only trial to focus on treatment of recurrent cancer, RR 0.56, 95% CI 0.42 to 0.75) eliminated statistical heterogeneity, but resulted in a similar estimate (RR 0.27, 95% CI 0.15 to 0.48, I^2^=0%).

#### MMC

Nine trials (reported in 10 publications) evaluated MMC versus no intravesical therapy97,101,111-118 (Tables 7, 8; Appendixes E2, F2). The doses of MMC ranged from 5 mg to 40 mg. The number of instillations varied from one to 58: three trials evaluated a single instillation,114,117,118 two trials evaluated an induction regimen (8 instillations over 4 or 8 weeks),97,112,116 and 4 trials evaluated maintenance regimens (ranging from 5 instillations over 1 year to 38 instillations over 2 years).101,111-113,115,118 Duration of followup ranged from a mean of 35 months to a median of 94 months.

One trial found no difference between MMC administered as a single dose or as a maintenance regimen (5 instillations every 1 year) versus no intravesical therapy in risk of all cause-mortality (HR 1.17, 95% CI 0.89 to 1.53) or bladder cancer-specific mortality (HR 0.71, 95% CI 0.34 to 1.46).118

MMC was associated with decreased risk of bladder cancer recurrence versus no intravesical therapy (8 trials, RR 0.71, 95% CI 0.57 to 0.89, I^2^=72% ) (Figure 11).97,101,111,112,114-117 Results were very similar using the profile likelihood method (RR 0.71, 95% CI 0.52 to 0.91). Results favored MMC in all trials, including two trials of single dose therapy (RR 0.43, 95% CI 0.14 to 1.31),114,117 as well as in other stratified and sensitivity analyses. Restricting the analysis to trials of multiple MMC instillations gave results similar to the overall pooled estimate (6 trials, RR 0.80 95% CI 0.67 to 0.95, I^2^=50%).97,101,111,112,115,116 Findings were also consistent in a ninth trial that could not be pooled, which found MMC associated with greater recurrence-free survival over two years (log-rank test, p=0.01) and lower annual recurrence rate over two years (42% vs. 82%, p=0.001).118

Figure 11 Meta-analysis of MMC versus no intravesical therapy: Risk of recurrence

CI = confidence interval; MMC = Mitomycin C

Figure 11 is a forest plot titled meta-analysis of MMC versus no intravesical therapy: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 8 studies, with a pooled risk of 0.71 (95% confidence interval 0.57 to 0.889, and the overall I-squared value of 72.1 (p=0.001).

MMC was associated with lower risk than no intravesical therapy of bladder cancer progression, but the difference was not statistically significant (5 trials, RR 0.68, 95% CI 0.39 to 1.20, I^2^=0%) (Figure 12).97,113-115,117 Excluding two trials of single dose therapy resulted in a similar estimate (3 trials, RR 0.67, 95% CI 0.38 5to 1.20, I^2^=0%).114,117 One trial that did not provide poolable data also reported no statistically significant difference in risk of progression with either single dose or maintenance MMC.118

Figure 12 Meta-analysis of MMC versus no intravesical therapy: Risk of progression

CI = confidence interval; MMC = Mitomycin C

Figure 12 is a forest plot titled meta-analysis of MMC versus no intravesical therapy: risk of progression. The plot depicts a meta-analysis of the risk of progression of bladder cancer. The risk of progression values are represented by squares. Progression risk was reported or calculated for 5 studies, with a pooled risk of 0.68 (95% confidence interval 0.39 to 1.20), and the overall I-squared value of 0.0 (p=0.992).

#### Doxorubicin

Eleven trials (reported in 13 publications) evaluated doxorubicin versus no intravesical therapy95,101,112,113,115,116,119-125 (Tables 9, 10; Appendixes E2, F2). The doses of doxorubicin ranged from 10 mg to 80 mg; the most commonly studied doses were 20 mg, 30 mg, and 50 mg. The number of instillations varied from 1 to 58: 2 trials used a single instillation,95,125 1 trial used an induction regimen (8 instillations over 4 weeks),112,116 and 1 trial used a regimen of 6 instillations in the 2 weeks prior to TURBT.123 The remaining trials used maintenance regimens (ranging from 15 instillations over 1 year to 58 instillations over 2 years). Duration of followup for recurrence ranged from 6 months to a median of 5 years, with followup as long as 10.9 years for mortality.

Two trials found no clear differences between maintenance regimens of doxorubicin versus no intravesical therapy in risk of all-cause or bladder cancer-specific mortality after 10 years of followup. In one trial, doxorubicin was associated with increased risk of all-cause mortality (30% vs. 17%, RR 1.83, 95% CI 0.78 to 4.28) and disease-specific mortality (6.5% vs. 2.8%, RR 2.35, 95% CI 0.25 to 21.6), but estimates were imprecise and the differences were not statistically significant.120 A second trial found no differences between doxorubicin versus no intravesical therapy in all-cause mortality (54% vs. 58%; RR 0.93, 95% CI 0.73 to 1.18) or deaths due to bladder or other primary cancers (18% vs. 18%; RR 0.97, 95% CI 0.54 to 1.76).121

Doxorubicin was associated with decreased risk of bladder cancer recurrence versus no intravesical therapy (10 trials, RR 0.80, 95% CI 0.72 to 0.88, I^2^=46%%) (Figure 13).95,101,112,115,116,119-121,123,124 Results were similar using the profile likelihood method. Findings were also similar in sensitivity and stratified analyses. The only trial that found no difference in risk of recurrence used doses of doxorubicin (10 to 80 mg) that varied depending on the patient's bladder capacity (RR 0.94, 95% CI 0.79 to 1.13).115 Excluding one trial of single instillation therapy (RR 0.89, 95% CI 0.63 to 1.01)95 had no effect on the pooled estimate and did not reduce heterogeneity (9 trials, RR 0.79, 95% CI 0.71 to 0.87, I^2^=49%). One trial that did not provide poolable data also found a single instillation with doxorubicin associated with improved recurrence-free survival at a median followup of 41 months (log-rank test, p=0.0026).125

Figure 13 Meta-analysis of doxorubicin versus no intravesical therapy: Risk of recurrence

CI = confidence interval

Note: Akaza, 1987 (Study 2), Matsumura, 1992, Niijima, 1983 (Study 1) reported effects for two different regimens.

Figure 13 is a forest plot titled meta-analysis of doxorubicin versus no intravesical therapy: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 13 studies, with a pooled risk of 0.80 (95% confidence interval 0.72 to 0.88), and the overall I-squared value of 45.6 (p=0.037).

There was no difference between doxorubicin versus no intravesical therapy in risk of bladder cancer progression (5 trials, RR 1.03, 95% CI 0.72 to 1.46, I^2^=0.0%).113,115,119,120,122 Findings were similar in sensitivity and subgroup analyses.

#### Epirubicin

Ten trials (reported in 11 publications) evaluated epirubicin versus no intravesical therapy (Tables 11, 12; Appendixes E2, F2).103,119,126-134 The doses of epirubicin ranged from 20 mg to 100 mg, with 50 mg and 80 mg the most commonly studied dosages. The number of instillations varied from 1 to 24: 5 trials used a single instillation,126-128,131,132 1 trial evaluated 2 instillations over 2 days,134 2 trials used an induction regimen (6 instillations over 6 weeks) followed by up to 7 additional maintenance doses over 2 years for recurrence-free patients,103,130 and 3 trials used maintenance regimens (ranging from 18 instillations over 1 year to 24 instillations over 2 years).119,126,129 Duration of followup ranged from a median of 20 months to 72 months.

Epirubicin was associated with reduced risk of bladder cancer recurrence versus no intravesical therapy (9 trials, RR 0.63, 95% CI 0.53 to 0.75, I^2^=64%) (Figure 14).103,119,126-132 Findings were similar in sensitivity and stratified analyses. One trial which didn't report poolable data for recurrence reported longer median recurrence-free survival for epirubicin, 50 mg (2 instillations) compared with no adjuvant therapy (38 months vs. 13 months, log-rank test, p=0.05).134

Figure 14 Meta-analysis of epirubicin versus no intravesical therapy: Risk of recurrence

CI = confidence interval

Note: Ali-El-Dein, 1997 (Brittish J Urol), Ali-El-Dein, 1997 (J Urol) each reported effects for two different regimens.

Figure 14 is a forest plot titled meta-analysis of epirubicin versus no intravesical therapy: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 11 studies, with a pooled risk of 0.63 (95% confidence interval 0.53 to 0.75), and the overall I-squared value of 63.6 (p=0.002).

Epirubicin was also associated with reduced risk of bladder cancer progression versus no intravesical therapy, but the difference was not statistically significant (8 trials, RR 0.79, 95% CI 0.48 to 1.30, I^2^=27%) (Figure 15).103,119,126,127,129-131,134 In stratified analyses, there was no clear pattern to suggest that longer duration of therapy was associated with decreased risk of progression. An outlier trial found a maintenance regimen of epirubicin 20 mg (24 instillations over 2 years) associated with an increased risk in progression (21% [9/43] vs. 3% [1/32]; RR 6.70, 95% CI 0.89 to 50.22), though the difference was not statistically significant and the estimate was very imprecise.129

Figure 15 Meta-analysis of epirubicin versus no intravesical therapy: Risk of progression

CI = confidence interval

Note: Ali-El-Dein, 1997 (Brittish J Urol), Ali-El-Dein, 1997 (J Urol), Saika, 2010 each reported effects for two different regimens.

Figure 15 is a forest plot titled meta-analysis of epirubicin versus no intravesical therapy: risk of progression. The plot depicts a meta-analysis of the risk of progression of bladder cancer. The risk of progression values are represented by squares. Progression risk was reported or calculated for 11 studies, with a pooled risk of 0.79 (95% confidence interval 0.48 to 1.30), and the overall I-squared value of 27.4 (p=0.183).

No trial evaluated effects of intravesical epirubicin on overall or bladder cancer-specific mortality.

#### Gemcitabine

One trial (n=248) evaluated a single instillation of gemcitabine versus placebo (Tables 13, 14; Appendixes E2, F2).135 It found no difference between gemcitabine and placebo in risk of bladder cancer recurrence after 24 months (RR 0.98, 95% CI 0.70 to 1.36). Estimates for progression (RR 3.00, 95% CI 0.32 to 28.4), all-cause mortality (2.4% vs. 4.8%, RR 0.50, 95% CI 0.13 to 2.00), and bladder cancer-mortality (0.8% vs. 0.8%, RR 1.00, 95% CI 0.06 to 15.81) were very imprecise.

Table 13 Summary of gemcitabine, interferon, or thiotepa study characteristics

Intervention | Author, Year | Setting and Study Years | Interventions (number analyzed for recurrence) | Duration of Followup and Method | Population Characteristics by Treatment Group (age, race/ethnicity, sex, stage of disease, functional status)
Gemcitabine vs. no intravesical therapy | Bohle, 2009^135^ | Germany and Turkey Multicenter Study years: January 2004 - June 2005 | A: Gemcitabine (GEM), 2000 mg (in 100 mL saline (0.9% NaCl)), instilled over 30 - 40 minutes immediately after TUR, followed by continuous irrigation with saline for ≥20 hours. (n=124) B: Placebo (PBO), 100 mL saline (0.9% NaCl), instilled over 30 - 40 minutes immediately after TUR, followed by continuous irrigation with saline for ≥20 hours. (n=124) | Duration (median): 23.6 months (range: 0 - 46). Method: Cystoscopy at least at month 3 and month 6, and every 6 months thereafter. | Age, median (range): 65 years (24 - 89) vs. 67 years (39 - 87) Race/ethnicity: not reported Sex (male): 76.6% vs. 83.1% Recurrent bladder cancer: 24.2% vs. 21.0% Stage: pTa: 75.0% vs. 71.0%; pT1: 25.0% vs. 29.0% Functional Status (Karnofski score): score 90-100: 91.9% vs. 94.4%; score 80-85: 7.3% vs. 4.0%; score <80: 0.8% vs. 0.8%
Interferon vs. no intravesical therapy | Portillo, 1997^137^ | Spain Number of sites unclear 1990-1994 | A: Interferon-α-2b, 60 million units. (n=39) B: Placebo (double distilled water).(n=39) A and B: First instillation 2-3 weeks after TURBT; Once weekly × 12 weeks, then once monthly × 9 months | Duration: mean 43months. Method: Cystoscopy, cytology, laboratory blood tests, urinalysis every 3 months × 1 year, then every 4 months × 1 year, then every 6 months thereafter. | Age, mean: 64.9 years Race/ethnicity: not reported Sex (male): 87.2% (68/78) Recurrent bladder cancer: 19.1%, overall (not reported by group, p=NS) Stage and Grade: T1G1: 2.6% (1/39) vs. 12.8% (5/39); T1G2: 82.1% (32/39) vs. 61.5% (24/39); T1G3: 15.4% (6/39) vs. 25.6% (10/39) Functional Status: not reported
Interferon vs. no intravesical therapy | Stavropoulos, 2002^138^ | Greece Number of sites unclear Study years not reported | A. Interferon-γ, 21 MU in 50 mL saline weekly for 8 weeks. (n=26) B. No adjuvant treatment. TURBT alone.(n=28) | Duration: Mean: 12.1 months Method: Cystoscopy every 3 months for 15 months and every 6 months thereafter. | Mean age: 66 vs. 64 years Male: 88% (23/26) vs. 71% (20/28) Race/ethnicity: not reported Recurrent bladder cancer: 27% (7/26) vs. 29% (8/28) Stage Ta: 42% (11/26) vs. 64% (18/28) Stage T1: 58% (15/26) vs. 36% (10/28) Functional status: not reported
Thiotepa vs. no intravesical therapy | Burnand, 1976^96^ | UK Single center Study years not reported | A: Thiotepa, 90 mg (in 100 mL sterile water) immediately after TURBT (n=19) B: No adjuvant treatment. TURBT alone (n=32) | Duration: 2 to 5 years Method: Cystoscopy, interval not reported | Age, mean (years): 60 vs. 62 Sex (male): 84% vs. 84% Race/ethnicity: not reported Recurrent bladder cancer: Not reported Stage: Not reported
Thiotepa vs. no intravesical therapy | Hirao, 1992^139^ | Japan Single center 1986-1990 | A: Thiotepa, 30 mg (in 30 mL physiological saline), for a total of 32 instillations over a 2-year period. (n=45) B: No adjuvant therapy. TURBT only. (n=48) | Duration (mean): 19.6 ± 10.8 vs. 14.9 ± 10.7 months Method: Cystoscopy and urinary cytology every 3 months for 3 years, every 6 months thereafter “until at least 5 years”. | Age, mean years: 59.1 vs. 64.2 Race/ethnicity: not reported Sex (male): 73.1% vs. 76.5% Recurrent bladder cancer: not reported Stage: Ta: 31.1% vs. 41.7%; T1: 68.9% vs. 58.3% Functional Status: not reported
Thiotepa vs. no intravesical therapy | Medical Research Council Working Party on Urological Cancer, 1994^98^ Medical Research Council Working Party on Urological Cancer, 1985^99^ | UK Multicenter 1981 - 1984 | A: Thiotepa, 30 mg in 50 mL saline immediately following TURBT, then every 3 months for 1 year (n=122) B: Thiotepa , 30 mg in 50 mL saline immediately following TURBT (n=126) C: No adjuvant treatment. TURBT alone.(n=131) | Duration: median 8 years, 9 months Method: Cystoscopy every 3 months for one year, at least every 6 months for 2 years, then annually | Age: 51-59 years: 24% vs. 17% vs. 26%; 60-69 years: 37% vs. 43% vs. 31%; 70-79 years: 23% vs. 25% vs. 24% Sex: not reported Race/ethnicity: not reported Recurrent bladder cancer: All primary Ta: 76% vs. 72% vs. 78% T1: 15% vs. 18% vs. 14%
Thiotepa vs. no intravesical therapy | Schulman, 1978^100^ | Europe Multicenter 1975-1978 | A. Thiotepa 30 mg in 30 mL sterile water. First instillation 1 month after TURBT, then weekly for 4 weeks, then every 4 weeks for 11 months. (n=75) B. No adjuvant therapy. TURBT alone. (n=69) | Duration: average 10 months; some patients with followup as long as 2 years. Method: Followup with cystoscopy every 12 weeks for first and second year, | Age: not reported Sex: not reported Race/ethnicity: not reported Recurrent bladder cancer: 38.7% vs. 43.5% Stage: T1: 100%

BCG = bacillus Calmette-Guérin; CI = confidence interval; HR = hazard ratio; MMC = mytomycin C; RR = risk ratio

Table 14 Summary of gemcitabine, interferon, or thiotepa study results

Intervention | Author, Year | Interventions (number analyzed for recurrence) | Recurrence | Progression | Mortality
Gemcitabine vs. no intravesical therapy | Bohle, 2009^135^ | A: Gemcitabine (GEM), 2000 mg (in 100 mL saline (0.9% NaCl)), instilled over 30 - 40 minutes immediately after TUR, followed by continuous irrigation with saline for ≥20 hours. (n=124) B: Placebo (PBO), 100 mL saline (0.9% NaCl), instilled over 30 - 40 minutes immediately after TUR, followed by continuous irrigation with saline for ≥20 hours. (n=124) | Recurrence: 35.5% vs. 36.3% 12-month recurrence-free survival, HR (95% CI): G1/G2: 1.05 (0.69-1.59) G3: 0.48 (0.15-1.51) 12-month recurrence-free survival, according to receipt of concomitant BCG: With BCG: HR=1.44 (0.49-4.17) Without BCG: HR=0.88 (0.58-1.34) | Progression to muscle-invasive: 2.4% vs. 0.8% | Mortality, disease-specific: 0.8% vs. 0.8% Mortality, overall: 2.4% vs. 4.8%
Interferon vs. no intravesical therapy | Portillo, 1997^137^ | A: Interferon-α-2b, 60 million units. (n=39) B: Placebo (double distilled water).(n=39) A and B: First instillation 2-3 weeks after TURBT; Once weekly × 12 weeks, then once monthly × 9 months | Recurrence at 12 months: 28.2% (11/39) vs. 35.9% (14/39) Recurrence at mean followup of 43 months: 53.8% (21/39) vs. 51.3% (20/39), p=NS. Recurrence-free interval: 17 months vs. 9.6 months, p=NS | Progression (stage, grade, diffuse CIS, and/or metastasis): 7.7% (3/39) vs. 17.9% (7/39), p=NS | Mortality due to bladder cancer: 5.1% (2/39) vs. 5.1% (2/39), p=NS
Interferon vs. no intravesical therapy | Stavropoulos, 2002^138^ | A. Interferon-γ, 21 MU in 50 mL saline weekly for 8 weeks. (n=26) B. No adjuvant treatment. TURBT alone.(n=28) | Recurrence: 61.5% (16/26) vs. 85.7% (24/28); p=0.043 Median time to first recurrence:12.0 months vs. 7.5 months Disease-free survival, median months (95% CI): 12.0 (8.3-15.7) vs. 7.0 (4.4-9.6); log-rank test, p=0.024. | Progression to muscle-invasive disease: 3.8% (1/26) vs. 3.6% (1/28).
Thiotepa vs. no intravesical therapy | Burnand, 1976^96^ | A: Thiotepa, 90 mg (in 100 mL sterile water) immediately after TURBT (n=19) B: No adjuvant treatment. TURBT alone (n=32) | Recurrence: 58% vs. 97% at 2 to 5 years, RR 0.60 (95% CI 0.41 to 0.88) Time to recurrence (months): 2.20 vs. 2.66
Thiotepa vs. no intravesical therapy | Hirao, 1992^139^ | A: Thiotepa, 30 mg (in 30 mL physiological saline), for a total of 32 instillations over a 2-year period. (n=45) B: No adjuvant therapy. TURBT only. (n=48) | Recurrence at 3 years: 15% vs. 46%, p<0.05 Cumulative recurrence rate (CRR)*, all cases: 0.70 vs. 3.07 Cumulative recurrence rate (CRR): Ta: 0.97 vs. 2.03 T1: 0.55 vs. 3.80 G1: 1.33 vs. 1.92 G2: 0.64 vs. 3.99 Solitary: 0.77 vs. 2.44 Multiple: 0.48 vs. 4.86
Thiotepa vs. no intravesical therapy | Medical Research Council Working Party on Urological Cancer, 1994^98^ Medical Research Council Working Party on Urological Cancer, 1985^99^ | A: Thiotepa, 30 mg in 50 mL saline immediately following TURBT, then every 3 months for 1 year (n=122) B: Thiotepa , 30 mg in 50 mL saline immediately following TURBT (n=126) C: No adjuvant treatment. TURBT alone.(n=131) | Recurrence-free time at median 8.75 years: HR 1.09 (95% CI 0.96 to 1.56) for A vs. C, HR 1.11 (95% CI 0.78 to 1.5) for B vs. C Recurrence at 1 year: 51% (62/122) vs. 46% (58/126) vs. 40% (50/124), HR 1.15 (95% CI 0.76 to 1.79) for A vs. C, HR 1.27 (95% CI 0.81 to 1.89) for B vs. C | Failure-free (no progression or death from bladder cancer) at median 8.75 years: HR 1.75 (95% CI 0.79 to 3.85) for A vs. C, HR 1.59 (95% CI 0.68 to 3.70) for B vs. C | Mortality: 31% (38/122) vs. 29% (36/1216) vs. 31% (40/131) at median 8.75 years, HR 0.99 (95% CI 0.56 to 1.82) for A or B vs. C Bladder cancer mortality: 7.4% (9/122) vs. 7.9% (10/126) vs. 4.6% (6/131)
Thiotepa vs. no intravesical therapy | Schulman, 1978^100^ | A. Thiotepa 30 mg in 30 mL sterile water. First instillation 1 month after TURBT, then weekly for 4 weeks, then every 4 weeks for 11 months. (n=75) B. No adjuvant therapy. TURBT alone. (n=69) | Recurrence: 49.3% (37/75) vs. 52.2% (36/69) Recurrence rate/100 patient months: 6.93 vs. 9.97; p=0.04 Recurrence: Primary: 37.0% (17/46) vs. 41.0% (16/39) Recurrent: 69.0% (20/29) vs. 66.7% (20/30) Recurrence rate/100 patient months: Primary: 4.98 vs. 6.74 Recurrent: 9.33 vs. 14.19 | Progression of stage: 4.0% (3/75) vs. 5.8% (4/69) Progression of grade: 6.7% (5/75) vs. 7.2% (5/69) Progression of stage and grade: 2.7% (2/75) vs. 2.9% (2/69) Progression of stage: Primary: 0.0% (0/46) vs. 0.0% (0/39) Recurrent: 10.3% (3/29) vs. 13.3% (4/30) Progression of grade: Primary: 4.4% (2/46) vs. 0.0% (0/39) Recurrent: 10.3% (3/29) vs. 16.7% (5/30) Progression of stage and grade: Primary: 0.0% (0/46) vs. 0.0% (0/39) Recurrent: 6.9% (2/29) vs. 6.7% (2/30)

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C; RR = risk ratio

#### Interferon Alpha

Three trials (reported in 4 publications) evaluated interferon alpha versus no intravesical therapy (Tables 13, 14; Appendixes E2, F2).132,133,136,137 The doses of interferon alpha ranged from 40 million units (MU) to 80 MU. One trial evaluated a single instillation132,133 and two trials evaluated maintenance regimens (21 or 22 instillations over 1 year).136,137 Duration of followup ranged from 2 years to a median of 72 months.

One trial found no difference between interferon alpha and placebo in risk of overall and bladder cancer-specific mortality (5% [2/39] vs. 5% [2/39], RR 1.00, 95% CI 0.15 to 6.75).137

Interferon alpha was associated with decreased risk of bladder cancer recurrence versus no intravesical therapy, but the difference was not statistically significant (3 trials, RR 0.75, 95% CI 0.53 to 1.06, I^2^=50%) (Figure 16).132,136,137 Results were similar using the profile likelihood method. One trial found interferon alpha associated with decreased risk136 and two trials no effect.132,137 The trial that found interferon alpha associated with decreased risk of bladder cancer evaluated interferon alpha using doses of 40, 60, and 80 MU; only the 80 MU dose was associated with decreased risk of recurrence (RR 0.35, 95% CI 0.14 to 0.89).136 The other two trials evaluated doses of 60 MU or less and one132,133 evaluated single instillation therapy.

Figure 16 Meta-analysis of interferon alpha-2b versus no intravesical therapy: Risk of recurrence

CI = confidence interval

Figure 16 is a forest plot titled meta-analysis of interferon-alpha-2b versus no intravesical therapy: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 5 studies, with a pooled risk of 0.75 (95% confidence interval 0.53 to 1.06), and the overall I-squared value of 50.5 (p=0.089).

Interferon alpha was associated with lower risk of bladder cancer progression versus no intravesical therapy (2 trials, RR 0.33, 95% CI 0.14 to 0.76, I^2^=0.0%) (Figure 17).136,137

Figure 17 Meta-analysis of interferon alpha-2b versus no intravesical therapy: Risk of progression

CI = confidence interval

Figure 17 is a forest plot titled meta-analysis of interferon-alpha-2b versus no intravesical therapy: risk of progression. The plot depicts a meta-analysis of the risk of progression of bladder cancer. The risk of progression values are represented by squares. Progression risk was reported or calculated for 4 studies, with a pooled risk of 0.33 (95% confidence interval 0.14 to 0.76), and the overall I-squared value of 0.0 (p=0.721).

#### Interferon Gamma

One trial (n=54) found induction therapy (8 instillations over 8 weeks) with interferon-gamma 21 MU (8 instillations over 8 weeks) patients with recurrent and/or multiple TaG2, TaG3, or T1/G2-G3 tumors associated with decreased risk of bladder cancer recurrence versus no intravesical therapy (62% vs. 86%, RR 0.72, 95% CI 0.51 to 1.01) (Tables 13, 14; Appendixes E2, F2).138 There was no difference in risk of bladder cancer progression (3.8% vs. 3.6%, RR 1.08, 95% CI 0.07 to 16.4) after a median followup of 9 months, but the estimate was imprecise. The trial did not report mortality.

#### Thiotepa

Five trials (reported in 6 publications) evaluated thiotepa versus no intravesical therapy (Tables 13, 14; Appendixes E2, F2).96,98-100,139,140 The doses of thiotepa ranged from 30 mg to 90 mg, with the most commonly studied dose 30 mg. The number of instillations varied from 1 to 32: 2 trials used a single instillation96,98,99 and 4 trials used maintenance regimens (ranging from 5 instillations over 1 year to 32 instillations over 2 years).98-100,139,140 Duration of followup ranged from a mean of 14.9 months to a median of 8.75 years.

One trial found no difference between thiotepa 30 mg five instillations or single dose versus no intravescial therapy in risk of all-cause mortality (HR 0.99, 95% CI 0.56 to 1.82); estimates for bladder cancer-specific mortality favored no intravesical therapy, but were imprecise (HR 1.61 [95% CI 0.59 to 4.39] and HR 1.73 [95% CI 0.65 to 4.63] for multi-instillation and single dose regimens, respectively).98,99 Estimates for the combined outcome of bladder cancer progression or bladder cancer mortality were similar, but results were not reported separately for bladder cancer progression alone.

Thiotepa was associated with decreased risk of bladder cancer recurrence versus no intravesical therapy, but the difference was not statistically significant (5 trials, RR 0.78, 95% CI 0.58 to 1.06, I^2^=69%) (Figure 18).96,98,100,139,140 Results were similar using the profile likelihood method. Estimates from trials that evaluated a single instillation (2 trials, RR 0.83, 95% CI 0.44 to 1.56, I^2^=83%)96,98 and multiple instillations (4 trials, RR 0.74, 95% CI 0.49 to 1.12, I^2^=70%)99,100,139,140 were similar. Stratification according to duration of followup eliminated statistical heterogeneity. Trials with followup greater than 1 year found thiotepa associated with decreased risk of recurrence (3 trials that evaluated 4 regimens, RR 0.55, 95% CI 0.42 to 0.73, I^2^=0%),96,139,140 but there was no difference in trials that evaluated regimens at 1 year or less (2 trials that evaluated 3 regimens, RR 1.10, 95% CI 0.90 to 1.34, I^2^=0%).98,100 Other sensitivity and stratified analyses had no effect on pooled estimates.

Figure 18 Meta-analysis of thiotepa versus no intravesical therapy: Risk of recurrence

CI = confidence interval

Note: Koontz, 1981 and MRC, 1994 each reported effects for two different regimens.

Figure 18 is a forest plot titled meta-analysis of thiotepa versus no intravesical therapy: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 7 studies, with a pooled risk of 0.78 (95% confidence interval 0.58 to 1.06), and the overall I-squared value of 68.8 (p=0.004).

There was no difference in risk of bladder cancer progression of stage (4.0% vs. 5.8%, RR 0.69, 95% CI 0.16 to 2.97), grade (6.7% vs. 7.2%, RR 0.92, 95% CI 0.28 to 3.04), or both stage and grade (2.7% vs. 2.9%, RR 0.92, 95% CI 0.13 to 6.36) in one study.100

## Key Question 3a What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination?

### Key Points

#### BCG Versus MMC

- There were no differences between BCG versus MMC in risk of bladder cancer recurrence overall (10 trials, RR 0.95, 95% CI 0.81 to 1.11, I^2^=67%), but BCG was associated with decreased risk in the subgroup of trials that evaluated maintenance regimens (5 trials, RR 0.79, 95% CI 0.71 to 0.87, I^2^=0%). There was no difference in risk of all-cause (7 trials, RR 0.94, 95% CI 0.83 to 1.06, I^2^=0%) or bladder cancer-specific mortality (5 trials, RR 0.77, 95% CI 0.54 to 1.10, I^2^=0%), or progression (7 trials, RR 0.88, 95% CI 0.66 to 1.17, I^2^=18%) (SOE: moderate for all-cause mortality, bladder cancer-specific mortality, and progression; low for recurrence).
- There were no differences between BCG versus BCG plus MMC given sequentially in risk of all-cause (1 trial, RR 1.57, 95% CI 0.67 to 3.71) or bladder cancer-specific mortality (2 trials, RR 1.10, 95% CI 0.50 to 2.38, I^2^=17%), bladder cancer recurrence (4 trials, RR 1.03, 95% CI 0.70 to 1.52, I^2^=75%), progression (3 trials, RR 0.87, 95% CI 0.40 to 1.91, I^2^=22%), or cystectomy (4 trials, RR 0.87, 95% CI 0.41 to 1.84, I^2^=0%) (SOE: low for mortality, recurrence, progression, and cystectomy).
- There were no differences between BCG plus MMC administered sequentially versus MMC in risk of all-cause (2 trials, RR 1.53, 95% CI 0.72 to 1.74 and RR 0.95, 95% CI 0.71 to 1.30) or bladder cancer mortality (2 trials, RR 0.64, 95% CI 0.22 to 1.88 and RR 0.95, 95% CI 0.45 to 1.56), bladder cancer recurrence (2 trials, RR 0.88, 95% CI 0.75 to 1.03, I^2^=0%), or progression (2 trials, RR 0.82 [95% CI 0.40 to 1.68] and RR 1.28 [95% CI 0.35 to 4.61]) (SOE: low).

#### BCG Versus Doxorubicin

- BCG was associated with decreased risk of bladder cancer recurrence versus doxorubicin (2 trials [RR 0.31, 95% CI 0.16 to 0.61] and RR 0.75 [95% CI 0.64 to 0.88]), but there were no differences in risk of all-cause mortality (2 trials, RR 0.40 [95% CI 0.01 to 12] and RR 1.00 [95% CI 0.71 to 1.37]), bladder cancer progression (1 trial, RR 0.20, 95% CI 0.02 to 1.72) (SOE: low for mortality, recurrence progression, and cystectomy).

#### BCG Versus Epirubicin

- BCG was associated with reduced risk of bladder cancer recurrence versus epirubicin, but statistical heterogeneity was high (5 trials, RR 0.54, 95% CI 0.40 to 0.74, I^2^=76%). Estimates favored BCG for all-cause (3 trials, RR 0.72, 95% CI 0.44 to 1.19, I^2^=87%) and bladder cancer-specific mortality (3 trials, RR 0.72, 95% CI 0.25 to 2.08, I^2^=80%), and bladder cancer progression (5 trials, RR 0.60, 95% CI 0.36 to 1.01, I^2^=47%), but differences were not statistically significant (SOE: moderate for recurrence, low for all-cause mortality, bladder cancer-specific mortality, and progression).
- There was no difference between BCG versus BCG plus epirubicin administered sequentially in risk of bladder cancer recurrence (3 trials, RR 1.25, 95% CI 0.92 to 1.69, I^2^=0%). BCG was associated with increased risk of bladder cancer progression (3 trials, RR 1.92, 95% CI 0.73 to 5.07, I^2^=0%), but the difference was not statistically significant (SOE: low).
- One trial found no differences between BCG versus epirubicin plus interferon alpha-2b in risk of bladder cancer mortality (RR 0.79, 95% CI 0.32 to 1.63) or progression-free survival, though BCG was associated with decreased risk of bladder cancer recurrence (RR 0.66, 95% CI 0.51 to 0.85) (SOE: low).

#### BCG Versus Gemcitabine

- There were no differences between BCG versus gemcitabine in risk of all-cause mortality (1 trial, RR 1.20, 95% CI 0.04 to 34), progression (2 trials, RR 1.11 [95% CI 0.53 to 2.34] and RR 0.52 [95% CI 0.13 to 2.06]) or quality of life (1 trial) (SOE: low for mortality, quality of life, and progression).
- Evidence from three trials was insufficient to determine effects of BCG versus gemcitabine on risk of bladder recurrence, due to clinical heterogeneity and inconsistent findings (RR 1.67 [95% CI 1.21 to 2.29], RR 0.53 [95% CI 0.28 to 1.01], and RR 0.76 [95% CI 0.44 to 1.90]) (SOE: insufficient).
- There were no differences between BCG versus BCG plus gemcitabine administered sequentially in risk of bladder cancer recurrence (1 trial, RR 0.86, 95% CI 0.49 to 1.51) or progression (1 trial, RR 1.18, 95% CI 0.30 to 4.61) (SOE: low for progression and recurrence).

#### BCG Versus Interferon

- BCG was associated with reduced risk of bladder cancer recurrence versus interferon alpha-2a (1 trial, RR 0.57, 95% CI 0.39 to 0.82) but the difference in risk of bladder cancer progression was not statistically significant (1 trial, RR 0.69, 95% CI 0.25 to 1.92) (SOE: low for recurrence, and progression).
- In patients pretreated with MMC, BCG was associated with reduced risk of bladder cancer recurrence versus alternating BCG plus interferon alpha-2b (1 trial, RR 0.42, 95% CI 0.30 to 0.59) (SOE: low).
- Differences between BCG versus coadministration of BCG and interferon alpha-2b in risk of bladder cancer recurrence (1 trial, RR 0.88, 95% CI .71 to 1.08) or progression (1 trial, RR 0.76, 95% CI 0.17 to 3.30) did not reach statistical significance (SOE: low for recurrence and progression).

#### BCG Versus Thiotepa

- Two trials found maintenance therapy with BCG associated with decreased risk of recurrence versus thiotepa (RR 0.38 [95% CI 0.19 to 0.76] and RR 0.04 [95% CI 0.00 to 0.63]), but estimates for other outcomes were too imprecise to evaluate effects (SOE: low for recurrence, insufficient for progression, death, and cystectomy).

#### MMC Versus Doxorubicin

- There was no difference between MMC versus doxorubicin in risk of bladder cancer recurrence (6 trials, RR 1.00, 95% CI 0.82 to 1.22, I^2^=44%), but MMC was associated with a nonstatistically significant trends towards decreased risk of bladder cancer progression (4 trials, RR 0.63, 95% CI 0.37 to 1.08, I^2^=21%) (SOE: low).

#### MMC Versus Epirubicin

- There was no difference between MMC versus epirubicin in risk of bladder cancer recurrence in one trial (RR 1.16, 95% CI 0.52 to 2.58) (SOE: low).

#### MMC Versus Gemcitabine

- In one trial, MMC was associated with no difference in risk of bladder cancer progression (p=0.29). MMC was associated with increased risk of recurrence but the difference was not statistically significant (RR 1.64, 95% CI 0.64 to 4.19) (SOE: low).

#### MMC Versus Interferon Alpha

- One trial found no difference between MMC versus interferon alpha in risk of bladder cancer recurrence (RR 0.77, 95% CI 0.58 to 1.01) or bladder cancer progression (RR 1.38, 95% CI 0.49 to 3.88) (SOE: low).

#### MMC Versus Interferon Gamma

- MMC was associated with increased risk of bladder cancer recurrence versus interferon-gamma in one trial (RR 1.61, 95% CI 0.97 to 2.67) (SOE: low).

#### MMC Versus Thiotepa

- Two trials found no difference between MMC versus thiotepa in risk of recurrence (RR 1.76 [95% CI 0.36 to 8.70] and RR 1.14 [95% CI 0.60 to 2.16]) (SOE: low).

#### Doxorubicin Versus Epirubicin

- Doxorubicin was associated with increased risk of bladder cancer recurrence versus epirubicin (3 trials, RR 1.56, 95% CI 1.08 to 2.22, I^2^=0%); the difference in risk of progression was not statistically significant (1 trial, RR 1.32, 95% CI 0.50 to 3.47) (SOE: low for recurrence and progression).

#### Doxorubicin Versus Thiotepa

- There was no statistically significant difference between doxorubicin versus thiotepa in risk of bladder cancer recurrence (RR 1.22, 95% CI 0.76 to 1.94). Estimates from one trial for progression (RR 2.11, 95% CI 0.40 to 11.06), noncancer mortality (RR 0.35, 95% CI 0.01 to 8.45), and cancer-specific mortality (RR 3.17, 95% CI 0.13 to 76.1) were very imprecise (SOE: low for recurrence; SOE: insufficient for progression, noncancer mortality, and cancer-specific mortality).

#### Epirubicin Versus Interferon Alpha

- Epirubicin was associated with decreased risk of bladder cancer recurrence versus interferon alpha in one trial (RR 0.67, 95% CI 0.49 to 0.91) (SOE: low).

### Detailed Synthesis

Fifty-four trials (reported in 66 publications) compared effects of intravesical therapy using one drug versus another (Tables 6, 7, 8, 9, 10, 11, 12; Appendixes E3, F2).101,103,111-113,115,116,119,132,133,141-196 Fourteen trials evaluated BCG versus MMC,111,147-165 two trials BCG and MMC versus MMC,166-169 four trials BCG versus doxorubicin,170-172 nine trials BCG versus epirubicin,103,173-181 one trial BCG versus epirubicin plus interferon,182,183 four trials BCG versus gemcitabine,184-187 three trials BCG versus interferon alpha,188-190 and one trial BCG versus thiotepa.172 The comparison drugs were administered alone or as part of sequential therapy with BCG. Thirteen trials (reported in 15 publications) evaluated comparisons of intravesical therapies that did not involve BCG.112,113,115,116,119,132,133,141,191-196 Four trials evaluated MMC versus doxorubicin,112,113,115,116,191 one trial MMC versus epirubicin,192 one trial MMC versus interferon alpha,193 one trial MMC versus interferon-gamma,141 one trial MMC versus gemcitabine,194 three trials doxorubicin versus epirubicin,119,195,196 one trial doxorubicin versus thiotepa,172 and one trial epirubicin versus interferon alpha.132,133

Samples sizes ranged from 41 to 957 and duration of followup from 15 months to 9 years. Mean age ranged from 52.1 to 74 years and the proportion of patients who were male ranged from 55 to 97 percent. Five trials excluded patients with G3 tumors and 7 trials excluded patients with CIS lesions. In the other trials, the proportion with G3 tumors ranged from 0 to 73 percent and the proportion with CIS lesions ranged from 0 to 100 percent. Thirty-four trials focused on patients with primary tumors and 29 trials focused on patients with recurrent tumors. Two trials were rated high risk of bias,186,196 41 trials medium risk of bias,103,111-113,115,116,119,132,133,141,147-154,156-169,171-181,183,185,187-195 and 4 trials low risk of bias (Appendix F2).155,170,182,184 Two trials reported blinding of outcomes assessors;133 ,158 no trial blinded care provider or patients. Other methodological limitations included inadequate description of randomization and allocation concealment and high attrition or failure to report attrition. Results are summarized in Table 16.

Table 16 Summary of results for intravesical therapy head-to-head trials

Comparison | All-Cause Mortality | Bladder Cancer-Specific Mortality | Bladder Cancer Recurrence | Bladder Cancer Progression
BCG vs. MMC | 7 trials, RR 0.94, 95% CI 0.83 to 1.06, I^2^=0% | 5 trials, RR 0.77, 95% CI 0.54 to 1.10, I^2^=0% | 10 trials, RR 0.95, 95% CI 0.81 to 1.11, I^2^=67% | 7 trials, RR 0.88, 95% CI 0.66 to 1.17, I^2^=18%
BCG vs. BCG plus MMC given sequentially | 1 trial, RR 1.57, 95% CI 0.67 to 3.71 | 2 trials, RR 1.10, 95% CI 0.50 to 2.38, I^2^=17% | 4 trials, RR 1.03, 95% CI 0.70 to 1.52, I^2^=75% | 3 trials, RR 0.87, 95% CI 0.40 to 1.91, I^2^=22%
BCG plus MMC given sequentially vs. MMC | 2 trials, RR 1.53, 95% CI 0.72 to 1.74 and RR 0.95, 95% CI 0.71 to 1.30 | 2 trials, RR 0.64, 95% CI 0.22 to 1.88 and RR 0.95, 95% CI 0.45 to 1.56 | 2 trials, RR 0.88, 95% CI 0.75 to 1.03, I^2^=0% | 2 trials, RR 0.82, 95% CI 0.40 to 1.68 and RR 1.28, 95% CI 0.35 to 4.61
BCG vs. doxorubicin | 2 trials, RR 0.40, 95% CI 0.01 to 12 and RR 1.00, 95% CI 0.71 to 1.37 | No evidence | 2 trials, RR 0.31, 95% CI 0.16 to 0.6 and RR 0.75, 95% CI 0.64 to 0.88 | 1 trial, RR 0.20, 95% CI 0.02 to 1.72
BCG vs. epirubicin | 3 trials, RR 0.72, 95% CI 0.44 to 1.19, I^2^=87% | 3 trials, RR 0.72, 95% CI 0.25 to 2.08, I^2^=80% | 5 trials, RR 0.54, 95% CI 0.40 to 0.74, I^2^=76% | 5 trials, RR 0.60, 95% CI 0.36 to 1.01, I^2^=47%
BCG vs. BCG plus epirubicin given sequentially | No evidence | No evidence | 3 trials, RR 1.25, 95% CI 0.92 to 1.69, I^2^=0% | 3 trials, RR 1.92, 95% CI 0.73 to 5.07, I^2^=0%
BCG vs. gemcitabine | 1 trial, RR 1.20, 95% CI 0.04 to 34 | No evidence | 3 trials, RR 1.67, 95% CI 1.21 to 2.29; RR 0.53, 95% CI 0.28 to 1.01 and RR 0.76, 95% CI 0.44 to 1.90 | 2 trials, RR 1.11, 95% CI 0.53 to 2.34 and RR 0.52, 95% CI 0.13 to 2.06
BCG vs. BCG plus gemcitabine given sequentially | No evidence | No evidence | 1 trial, RR 0.86, 95% CI 0.49 to 1.51 | 1 trial, RR 1.18, 95% CI 0.30 to 4.61
BCG vs. Interferon alpha-2a | No evidence | No evidence | 1 trial, RR 0.57, 95% CI 0.39 to 0.82 | 1 trial, RR 0.69, 95% CI 0.25 to 1.92
BCG vs. alternating BCG and interferon alpha-2a | No evidence | No evidence | 1 trial, RR 0.42, 95% CI 0.30 to 0.59 | No evidence
BCG vs. coadministration of BCG and interferon alpha-2a | No evidence | No evidence | 1 trial, RR 0.88, 95% CI .71 to 1.08 | 1 trial, RR 0.76, 95% CI 0.17 to 3.30
BCG vs. thiotepa | No evidence | No evidence | 1 trial, RR 0.38, 95% CI 0.19 to 0.76 | 1 trial, RR 0.42, 95 5CI 0.19 to 0.76
MMC vs. doxorubicin | No evidence | No evidence | 4 trials, RR 1.02, 95% CI 0.86 to 1.21, I^2^=30% | 3 trials, RR 0.48, 95% CI 0.26 to 0.90, I^2^=53%
MMC vs. epirubicin | No evidence | No evidence | 1 trial, RR 1.16, 95% CI 0.52 to 2.58 | No evidence
MMC vs. gemcitabine | No evidence | No evidence | 1 trial, no difference (p=0.29) | 1 trial, RR 1.64, 95% CI 0.64 to 4.19
MMC vs. interferon alpha | No evidence | No evidence | 1 trial, RR 0.77, 95% CI 0.58 to 1.01 | 1 trial, RR 1.38, 95% CI 0.49 to 3.88
Doxorubicin vs. epirubicin | No evidence | No evidence | 3 trials, RR 1.56, 95% CI 1.08 to 2.22, I^2^=0% | 1 trial, RR 1.32, 95% CI 0.50 to 3.47
Doxorubicin vs. thiotepa | Not reported | 1 trial, RR 3.17, 95% CI 0.13 to 76.1 | 1 trial, RR 1.22, 95% CI 0.76 to 1.94 | 1 trial, RR 2.11, 95% CI 0.40 to 11.06
Epirubicin vs. interferon alpha | No evidence | No evidence | 1 trial, RR 0.67, 95% CI 0.49 to 0.91 | No evidence

BCG = bacillus Calmette Guérin; CI = confidence interval; MMC = Mitomycin C; RR = risk ratio

#### BCG Versus MMC

Ten trials (reported in 16 publications) randomized patients to BCG versus MMC111,147-161 and four trials randomized patients to BCG versus BCG plus MMC given sequentially (Table 6; Appendixes E3, F2).162-165 The dose of BCG ranged from 13.5 mg to 120 mg and the dose of MMC from 20 mg to 40 mg with the number of instillations ranging from 6 weekly instillations148,154 to 42 weekly instillations administered over 3 years.154 No trial compared single instillation therapy with BCG versus MMC and no trial of MMC utilized an “optimized” regimen.197,198

There was no difference between BCG versus MMC in risk of bladder cancer recurrence (10 trials, RR 0.95, 95% CI 0.81 to 1.11, I^2^=677%) (Figure 19).111,147,151,153-156,159,158,161 However, statistical heterogeneity was present. Stratification of trials according to whether they evaluated maintenance or induction regimens reduced statistical heterogeneity. BCG was associated with decreased risk of bladder cancer recurrence in trials that evaluated maintenance regimens (5 trials, RR 0.79, 95% CI 0.71 to 0.87, I^2^=0%),147,151,153,111,161 but not in trials that evaluated induction regimens (4 trials, RR 1.22, 95% CI 0.99 to 1.51, I^2^=50%).111,154,156,159

Figure 19 Meta-analysis of bacillus Calmette-Guérin versus MMC: Risk of recurrence

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C

Note: Witjes, 1996 and Ojea, 2007 each reported effects for two different regimens.

Figure 19 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus MMC: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 5 studies for induction, with a pooled risk of 1.27 (95% confidence interval 1.01 to 1.61), and the subtotal I-squared value of 55.0 (p=0.064). Recurrence risk was reported or calculated for 8 studies for maintenance, with a pooled risk of 0.79 (95% confidence interval 0.71 to 0.87) and the subtotal I-squared value of 0.00 (p=0.775). The overall pooled risk was 0.95 (95% confidence interval 0.81 to 1.11) and the overall I-squared value was 66.9 (p=0.000).

There were no differences between BCG versus MMC in all-cause (7 trials, RR 0.94, 95% CI 0.83 to 1.06, I^2^=0%) (Figure 20)147,151,153,155,157,159,161 or disease-specific mortality (5 trials, RR 0.77, 95% CI 0.54 to 1.10, I^2^=0%) (Figure 21).147,151,157,159,161 There were also no differences in risk of bladder cancer progression (Figure 22) (7 trials, RR 0.88, 95% CI 0.66 to 1.17, I^2^=18%).147,151,155-157,159,161 One trial (n=337) found no difference between BCG versus MMC in risk of cystectomy, but the estimate was very imprecise (RR 2.20, 95% CI 0.07 to 65).111

Figure 20 Meta-analysis of bacillus Calmette-Guérin versus MMC: Risk of mortality

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C

Note: Ojea, 2007 reported effects for two different regimens.

Figure 20 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus mitomycin C: risk of mortality. The plot depicts a meta-analysis of the risk of mortality. The risk of mortality values are represented by squares. Mortality risk was reported or calculated for 1 study for induction, with a risk of 0.91 (95% confidence interval 0.65 to 1.28). Mortality risk was reported or calculated for 7 studies for maintenance, with a pooled risk of 0.94 (95% confidence interval 0.82 to 1.08) and the subtotal I-squared value of 0.0 (p=0.628). The overall pooled risk was 0.94 (95% confidence interval 0.83 to 1.06) and the overall I-squared value was 0.0 (p=0.735).

Figure 21 Meta-analysis of bacillus Calmette–Guérin versus MMC: Risk of bladder cancer–specific mortality

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C

Note: Ojea, 2007 reported effects for two different regimens.

Figure 21 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus MMC: risk of bladder cancer-specific mortality. The plot depicts a meta-analysis of the risk of mortality. The risk of mortality values are represented by squares. Mortality risk was reported or calculated for 1 study for induction, with a risk of 1.52 (95% confidence interval 0.64 to 3.62. Mortality risk was reported or calculated for 5 studies for maintenance, with a pooled risk of 0.67 (95% confidence interval 0.45 to 0.99) and the subtotal I-squared value of 0.0 (p=0.934). The overall pooled risk was 0.77 (95% confidence interval 0.54 to 1.10) and the overall I-squared value was 0.0 (p=0.597).

Figure 22 Meta-analysis of bacillus Calmette-Guérin versus MMC: Risk of progression

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C

Note: Witjes, 1996 and Ojea, 2007 each reported effects for two different regimens.

Figure 22 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus mitomycin C: risk of progression. The plot depicts a meta-analysis of the risk of progression of bladder cancer. The risk of progression values are represented by squares. Progression risk was reported or calculated for 1 study for induction, with a risk of 1.77 (95% confidence interval 0.90 to 3.48). Progression risk was reported or calculated for 8 studies for maintenance, with a pooled risk of 0.77 (95% confidence interval 0.59 to 1.01) and the subtotal I-squared value of 0.0 (p=0.687). The overall pooled risk was 0.88 (95% confidence interval 0.66 to 1.17) and the overall I-squared value was 17.9 (p=0.283).

There were no differences between BCG versus BCG plus MMC given sequentially in risk of all-cause (1 trial, RR 1.57, 95% CI 0.67 to 3.71)164 or bladder cancer mortality (Figure 23) (2 trials, RR 1.10, 95% CI 0.50 to 2.38, I^2^=17%),163,164 bladder cancer recurrence (Figure 24) (4 trials, RR 1.03, 95% CI 0.70 to 1.52, I^2^=75%),162-165 progression (Figure 25) (3 trials, RR 0.87, 95% CI 0.40 to 1.91, I^2^=22%),162-164 or cystectomy (4 trials, RR 0.87, 95% CI 0.41 to 1.84, I^2^=0%).162-165

Figure 23 Meta-analysis of bacillus Calmette-Guérin versus bacillus Calmette–Guérin plus MMC: Risk of bladder cancer–specific mortality

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C

Figure 23 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus bacillus Calmette-Guérrin plus mitomycin C: risk of bladder cancer-specific mortality. The plot depicts a meta-analysis of the risk of mortality. The risk of mortality values are represented by squares. Mortality risk was reported or calculated for 2 studies for maintenance, with a pooled risk of 1.10 (95% confidence interval 0.50 to 2.38) and the overall I-squared value was 16.5 (p=0.274).

Figure 24 Meta-analysis of bacillus Calmette-Guérin versus bacillus Calmette-Guérin plus MMC: Risk of recurrence

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C

Figure 24 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus bacillus Calmette- Guérrin plus MMC: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 1 study for single, with a risk of 0.53 (95% confidence interval 0.21 to 1.37). Recurrence risk was reported or calculated for 3 studies for maintenance, with a pooled risk of 1.13 (95% confidence interval 0.75 to 1.68) and the subtotal I-squared value of 79.3 (p=0.008). The overall pooled risk was 1.03 (95% confidence interval 0.70 to 1.52) and the overall I-squared value was 74.8 (p=0.008).

Figure 25 Meta-analysis of bacillus Calmette-Guérin versus bacillus Calmette-Guérin plus MMC: Risk of progression

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C

Figure 25 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus bacillus Calmette- Guérrin plus MMC: risk of progression. The plot depicts a meta-analysis of the risk of progression of bladder cancer. The risk of progression values are represented by squares. Progression risk was reported or calculated for 1 study for single installation, with a risk of 0.96 (95% confidence interval 0.06 to 14.55). Progression risk was reported or calculated for 2 studies for multiple instillations, with a pooled risk of 1.02 (95% confidence interval 0.29 to 3.59) and the subtotal I-squared value of 60.5 (p=0.111). The overall pooled risk was 0.87 (95% confidence interval 0.40 to 1.91) and the overall I-squared value was 22.2 (p=0.276).

Statistical heterogeneity was present in the analysis of bladder cancer recurrence. Excluding one trial that compared BCG induction therapy for 6 weeks versus BCG induction therapy plus a single dose of perioperative MMC (RR 0.53, 95% CI 0.21 to 1.37)162 (rather than sequential regimens involving multiple doses of BCG and MMC) resulted in a similar estimate and did not reduce heterogeneity (RR 1.13, 95% CI 0.75 to 1.68, I^2^=79%). Estimates were also similar using the profile likelihood method, and other subgroup and other sensitivity analyses also did not reduce heterogeneity and resulted in similar findings.

#### BCG Plus MMC Versus MMC

Two trials (reported in four publications) compared MMC versus MMC and BCG given sequentially (Table 6; Appendixes E3, F2).166-169 The Finnbladder study enrolled 256 patients and reported results for patients with (27%) and without CIS separately.167-169 All patients received 5 instillations of MMC and were then randomized to 15 additional instillations of MMC versus alternating MMC and BCG instillations over 2 years. The second trial analyzed 182 patients, of whom 36 percent had CIS.166 Doses of BCG ranged from 50 mg to 75 mg and MMC dose from 20 mg to 40 mg. Patients received four instillations of MMC and were then randomized to 6 weekly instillations of BCG or MMC. Both trials were rated medium risk of bias.

One trial found no difference between BCG plus MMC given sequentially versus MMC alone in risk of all-cause (RR 1.53, 95% CI 0.72 to 1.74) or bladder cancer mortality (RR 0.64, 95% CI 0.22 to 1.88).166 The other trial, which only reported mortality in patients with CIS, also found no difference in risk of all-cause (RR 0.95, 95% CI 0.71 to 1.30) or bladder cancer mortality (RR 0.95, 95% CI 0.45 to 1.56).167

There was no difference between BCG plus MMC given sequentially versus MMC alone in risk of bladder cancer recurrence (Figure 26) (2 trials, RR 0.88, 95% CI 0.75 to 1.03, I^2^=0%).166-168 One trial found no difference between BCG plus MMC versus MMC alone in risk of bladder cancer progression (RR 0.82, 95% CI 0.40 to 1.68).159 The other trial also found no difference, but only reported data from the subgroup of patients with CIS (RR 1.28, 95% CI 0.35 to 4.61).167 This trial also found no difference between BCG plus MMC given sequentially versus MMC alone in risk of cystectomy (1 trial, RR 0.20, 95% CI 0.03 to 1.57).

Figure 26 Meta-analysis of bacillus Calmette-Guérin plus MMC versus MMC: Risk of recurrence

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C

Figure 26 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin plus MMC versus MMC: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 1 study for induction, with a risk of 0.85 (95% confidence interval 0.61 to 1.20). Recurrence risk was reported or calculated for 2 studies for maintenance, with a pooled risk of 0.88 (95% confidence interval 0.71 to 1.08) and the subtotal I-squared value of 27.9 (p=0.239). The overall pooled risk was 0.88 (95% confidence interval 0.75 to 1.03) and the overall I-squared value was 0.0 (p=0.490).

#### BCG Versus MMC Plus Doxorubicin

One small trial (n=27) of patients with CIS found no differences between BCG versus sequential therapy with MMC and doxorubicin in likelihood of complete response (RR 1.06, 95% CI 0.81 to 1.39), progression (RR 1.50, 95% CI 0.28 to 8.08), or bladder cancer mortality (RR 2.21, 95% CI 0.22 to 22.5), though estimates were imprecise.145 BCG was associated with decreased risk of recurrence after complete response (11% vs. 52%, RR 0.18, 95% CI 0.05 to 0.72)

#### BCG Versus Doxorubicin

Three trials randomized patients to BCG versus doxorubicin (Table 6; Appendixes E3, F2).170-172 The dose of BCG ranged from 80 mg to 150 mg and the dose of doxorubicin ranged from 20 mg to 50 mg. All trials administered maintenance therapy for patients randomized to doxorubicin, though treatment was limited to induction therapy in the BCG arm of one trial.170

One trial found no difference between BCG 150 mg versus doxorubicin in risk of all-cause mortality (all deaths were due to bladder cancer) after 3 years (RR 0.40, 95% CI 0.01 to 12), though the estimate was imprecise.172 A second trial, in which half of the patients had CIS, found no difference between BCG 120 mg versus doxorubicin in risk of all-cause mortality after 5 years (RR 1.00, 95% CI 0.71 to 1.37).171 Both trials found BCG associated with decreased risk of bladder cancer recurrence (13% vs. 43%, RR 0.31 [95% CI 0.16 to 0.61]172 and 61% vs. 81%, RR 0.75 [95% CI 0.64 to 0.88]).171 One trial found no difference between BCG versus doxorubicin in risk of bladder cancer progression (RR 0.20, 95% CI 0.02 to 1.72) or cystectomy (RR 0.26, 95% CI 0.03 to 2.46).172

#### BCG Versus Epirubicin

Six trials (reported in 7 publications) randomized patients to BCG versus epirubicin103,173-178 and three trials randomized patients to BCG versus BCG plus epirubicin given sequentially (3 studies) (Table 6; Appendixes E3, F2).179-181 The dose of BCG ranged from 50 mg to 150 mg and the dose of epirubicin from 40 mg to 80 mg. The number of bladder instillations ranged from 6 weekly instillations181 to 27 over 3 years.173

BCG was associated with decreased risk of all-cause (Figure 27) (3 trials, RR 0.72, 95% CI 0.44 to 1.19, I^2^=87%)173,174,177 and disease-specific mortality (Figure 28) (3 trials, RR 0.72, 95% CI 0.25 to 2.08,I^2^=80%)173,174,177 versus epirubicin, but the differences were not statistically significant. Estimates were similar using the profile likelihood method. Excluding the trial173 that used the lowest dose of BCG (50 mg, versus 81 mg in the other trials) reduced statistical heterogeneity for all-cause mortality (RR 0.92, 95% CI 0.67 to 1.25, I^2^=26%), but the difference remained nonstatistically significant. Other subgroup and sensitivity analyses did not reduce statistical heterogeneity or affect findings.

Figure 27 Meta-analysis of bacillus Calmette-Guérin versus epirubicin: All-cause mortality

BCG = bacillus Calmette-Guérin; CI = confidence interval

Figure 27 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus epirubin: all-cause mortality. The plot depicts a meta-analysis of the risk of mortality. The risk of mortality values are represented by squares. Moraltity risk was reported or calculated for 3 studies for maintenance, with a pooled risk of 0.72 (95% confidence interval 0.44 to 1.19) and the overall I-squared value was 86.7 (p=0.001).

Figure 28 Meta-analysis of bacillus Calmette-Guérin versus epirubicin: Bladder cancer–specific mortality

BCG = bacillus Calmette-Guérin; CI = confidence interval

Figure 28 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus epirubin: bladder cancer-specific mortality. The plot depicts a meta-analysis of the risk of mortality. The risk of mortality values are represented by squares. Moraltity risk was reported or calculated for 3 studies for maintenance, with a pooled risk of 0.72 (95% confidence interval 0.25 to 2.08) and the overall I-squared value was 80.3 (p=0.006).

BCG was associated with reduced risk of bladder cancer recurrence versus epirubicin (5 trials, 34% vs. 66%, RR 0.54, 95% CI 0.40 to 0.74, I^2^=76%) (Figure 29).103,173-176 The estimate was similar using the profile likelihood method. In stratified analyses, BCG was associated with reduced risk of recurrence in trials that excluded patients with CIS (3 trials, 33% vs. 73%, RR 0.44, 95% CI 0.36 to 0.53, I^2^=25%)173,174,176 but not in trials that included patients with CIS (2 trials, RR 0.80, 95% CI 0.60 to 1.07, I^2^=0%).103,175 Other subgroup and sensitivity analyses did not reduce statistical heterogeneity or affect findings.

Figure 29 Meta-analysis of bacillus Calmette-Guérin versus epirubicin: Risk of recurrence

BCG = bacillus Calmette-Guérin; CI = confidence interval; CIS = carcinoma in situ

Figure 29 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus epirubicin: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 2 studies with some CIS, with a risk of 0.80 (95% confidence interval 0.60 to 1.07), and subtotal I-squared value of 0.0 (p=0.987). Recurrence risk was reported or calculated for 3 studies with no CIS, with a pooled risk of 0.44 (95% confidence interval 0.36 to 0.534) and the subtotal I-squared value of 24.5 (p=0.226) The overall pooled risk was 0.54 (95% confidence interval 0.40 to 0.74) and the overall I-squared value was 76.0 (p=0.002).

BCG was also associated with decreased risk of bladder cancer progression versus epirubicin, though the difference was not quite statistically significant (5 trials, RR 0.60, 95% CI 0.36 to 1.01, I^2^=47%) (Figure 30).103,173-176 Estimates and findings were similar using the profile likelihood method. Statistical heterogeneity was reduced when one trial176 that used a lower dose of epirubicin (40 mg, versus 50 mg in the other trials) was excluded (4 trials, RR 0.70, 95% CI 0.48 to 1.02, I^2^=3%). This same trial also used the fewest number of scheduled epirubicin instillations (9 versus 11-27 in the other trials). Other sensitivity and subgroup estimates had little effect on findings.

Figure 30 Meta-analysis of bacillus Calmette-Guérin versus epirubicin: Risk of progression

BCG = bacillus Calmette-Guérin; CI = confidence interval

Figure 30 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus epirubicin: risk of progression. The plot depicts a meta-analysis of the risk of progression. The risk of progression values are represented by squares. Progression risk was reported or calculated for 4 studies with a 50 mg dose, with a risk of 0.70 (95% confidence interval 0.48 to 1.02), and the with a subtotal I-squared value of 3.3 (p=0.376). Recurrence risk was reported or calculated for 1 study with a 40 mg dose with a risk of 0.17 (95% confidence interval 0.05 to 0.60) and no I-squared value. The overall pooled risk was 0.60 (95% confidence interval 0.36 to 1.01) and the overall I-squared value was 46.9 (p=0.110).

There was no difference between BCG versus BCG plus epirubicin administered sequentially in risk of bladder cancer recurrence (Figure 31) (3 trials, RR 1.25, 95% CI 0.92 to 1.69, I^2^=0%). BCG was associated with increased risk of bladder cancer progression, but the difference was not statistically significant (3 trials, RR 1.92, 95% CI 0.73 to 5.07, I^2^=0%) (Figure 32).179-181 Excluding one trial179 of maintenance therapy with BCG versus maintenance therapy with BCG plus a single dose of perioperative epirubicin resulted in similar estimates. Trials did not report mortality.

Figure 31 Meta-analysis of bacillus Calmette-Guérin versus bacillus Calmette-Guérin plus epirubicin: Risk of recurrence

BCG = bacillus Calmette-Guérin; CI = confidence interval

Figure 31 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus bacillus Calmette-Guérrin plus epirubicin: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 1 study for induction, with a risk of 1.27 (95% confidence interval 0.32 to 4.98). Recurrence risk was reported or calculated for 2 studies for maintenance, with a pooled risk of 1.28 (95% confidence interval 0.86 to 1.92) and the subtotal I-squared value of 16.8 (p=0.273). The overall pooled risk was 1.25 (95% confidence interval 0.92 to 1.69) and the overall I-squared value was 0.0 (p=0.548).

Figure 32 Meta-analysis of bacillus Calmette-Guérin versus bacillus Calmette-Guérin plus epirubicin: Risk of progression

BCG = bacillus Calmette-Guérin; CI = confidence interval

Figure 32 is a forest plot titled meta-analysis of bacillus Calmette-Guérrin versus bacillus Calmette-Guérrin plus epirubicin: risk of progression. The plot depicts a meta-analysis of the risk of progression of bladder cancer. The risk of progression values are represented by squares. Progression risk was reported or calculated for 1 study for induction, with a risk of 1.90 (95% confidence interval 0.19 to 19.40). Progression risk was reported or calculated for 2 studies for maintenance, with a pooled risk of 1.93 (95% confidence interval 0.66 to 5.60) and the subtotal I-squared value of 0.0 (p=0.971). The overall pooled risk was 1.92 (95% confidence interval 0.73 to 5.07) and the overall I-squared value was 0.0 (p=0.999).

#### BCG Versus Epirubicin Plus Interferon

One trial (n=256) randomized patients with newly detected stage T1, G2-G3 bladder cancer to 2 mL of OncoTICE strain BCG versus epirubicin 50 mg plus 10 MU of interferon alpha-2b given together (Table 6; Appendixes E3, F2).182,183 Six weekly induction treatments were followed by maintenance therapy to 2 years. The trial was rated low risk of bias.

BCG was associated with reduced risk of bladder cancer recurrence (RR 0.66, 95% CI 0.51 to 0.85), cancer mortality at 5 years (RR 0.79, 95% CI 0.32 to 1.63), progression-free survival at 2 or 5 years, and risk of cystectomy at 2 years (RR 0.68, 95% CI 0.30 to 1.54)182,183 versus epirubicin plus interferon, but the only statistically significant difference was for bladder cancer recurrence.

#### BCG Versus Gemcitabine

Three trials randomized patients to BCG versus gemcitabine184-186 and one trial to BCG versus BCG plus gemcitabine administered sequentially (Table 6; Appendixes E3, F2).187 Two trials enrolled patients at high risk for bladder cancer recurrence (based on higher tumor grade, presence of CIS, recurrent tumors, and multiplicity of tumors),184,185 one enrolled patients at intermediate risk186 and one enrolled patients who were intermediate or high risk.187 The dose of BCG ranged from 27 mg to 81 mg. The dose of gemcitabine was 2000 mg in all studies, although the dose immediately after TURBT was 1000 mg in one study.187 The number of instillations ranged from 6 weekly instillations187 to 13 instillations over 3 years.185 The number of gemcitabine instillations ranged from 2^187^ to 15 to 18.^184,186^

One trial found no difference between BCG versus gemcitabine in all-cause mortality, but the estimate was very imprecise (RR 1.20, 95% CI 0.04 to 34).184 No trial reported bladder cancer specific mortality.

Three trials reported effects of BCG versus gemcitabine on risk of bladder cancer recurrence.184-186 Due to differences between trials in the populations and BCG doses evaluated, results were not pooled. One trial of patients with high risk Ta or T1 tumors found BCG 81 mg associated with increased risk of bladder cancer recurrence versus gemcitabine (RR 1.67, 95% CI 1.21 to 2.29)184 One trial of patients with high-risk T1 and/or G3 and/or CIS found no difference between BCG 50 mg and gemcitabine in risk of bladder cancer recurrence (RR 0.53, 95% CI 0.28 to 1.01)185 and one trial of patients with Ta tumors without CIS or G3 disease found no difference between BCG 27 mg versus gemcitabine (RR 0.76, 95% CI 0.44 to 1.90).186

Two trials found no difference between BCG versus gemcitabine in risk of bladder cancer progression (RR 1.11 [95% CI 0.53 to 2.34]184 and RR 0.52 [95% CI 0.13 to 2.06]).186 One trial found no difference between BCG versus gemcitabine on all quality of life dimensions as measured by the EORTC-QLQ-C30^199^ or the EORTC QLQ-BLS24,^186^ with the exception that emotional functioning decreased slightly in the BCG group but improved in the gemcitabine group (p=0.03 for difference in a multivariate analysis).186

No trial of BCG versus BCG plus gemcitabine administered sequentially evaluated effects on mortality. One trial (n=87) found no difference between BCG versus BCG plus gemcitabine given sequentially in risk of bladder cancer recurrence (RR 0.86, 95% CI 0.49 to 1.51) or progression (RR 1.18, 95% CI 0.30 to 4.61).187

#### BCG Versus Interferon

One trial randomized patients to BCG versus interferon alpha-2a,188 one trial randomized patients to BCG versus alternating BCG plus interferon alpha-2b,189 and one trial to BCG versus combination therapy with BCG plus interferon alpha-2b (Table 6; Appendixes E3, F2).190 One trial administered five bladder instillations of 40 mg of MMC to all patients prior to randomization to continued BCG or BCG and interferon alpha-2b administered sequentially.189 The dose of BCG ranged from 16.6 mg to 150 mg and the dose of interferon from 50 mg to 54 MU. Interferon instillations ranged from six over 1 year alternating with BCG189 to 24 given in addition to BCG over 3 years.190 Up to 17 interferon instillations were given over 9 months in the trial of BCG versus interferon given alone.188

One trial found BCG associated with reduced risk of recurrence versus interferon alpha-2a alone (39% vs. 69%, RR 0.57, 95% CI 0.39 to 0.82).188 There were no statistically significant differences in risk of bladder cancer progression (RR 0.69, 95% I 0.25 to 1.92) or cystectomy (RR 4.82, 95% CI 0.25 to 94), but estimates were imprecise.

One trial found BCG associated with lower risk of bladder cancer recurrence versus alternating BCG plus interferon alfa-2b (28% vs. 68%, 1 trial, RR 0.42, 95% CI 0.30 to 0.59).189 All patients received MMC prior to randomization to BCG or alternating BCG plus interferon alfa-2b.

A third trial found no difference in risk of bladder cancer recurrence between BCG versus the combination of BCG plus interferon alfa-2b in patients who did not receive pretreatment with MMC (RR 0.88, 95% CI .71 to 1.08).190 Patients received up to 24 instillations. The dose of BCG was approximately 50 mg during induction and 16.6 mg in the maintenance phase.

No trial of BCG versus regimens involving interferon evaluated mortality.

#### BCG Versus Thiotepa

Two trials randomized patients to BCG versus thiotepa (Table 6; Appendixes E3, F2).142,172 One trial initially enrolled patients (n=123) with Ta or T1 tumors but later restricted enrollment to T1 tumors due to the low probability of recurrence with Ta disease.172 BCG-Pasteur 150 mg or thiotepa 50 mg was administered weekly for 4 weeks, then monthly for 11 months. The other trial (n=46) randomized patients with recent recurrence (up to stage T1) to 6 × 10^9^ CFUs BCG-TICE versus thiotepa 60 mg weekly for 6 weeks, followed by maintenance therapy for a total of 2 years.142 Both trials found BCG associated with reduced risk of bladder cancer recurrence versus thiotepa (13% vs. 36%, RR 0.38 [95% CI 0.19 to 0.76]172 and 0% vs. 47%, RR 0.04 [95% CI 0.00 to 0.63]142). Estimates for other outcomes, including progression, death, and cystectomy, were too imprecise to evaluate effects.

#### MMC Versus Doxorubicin

Six trials (reported in seven publications) evaluated MMC versus doxorubicin (Tables 7, 8; Appendixes E3, F2).101,112,113,115,116,144,191 Three trials evaluated an MMC dose of 20 mg,112,113,116,191 one trial evaluated a dose of 30 mg,101 and in two trials doses ranged from 5 mg to 40 mg depending on the patient's bladder capacity.115,144 In one trial, the doxorubicin dose ranged from 50 to 100 mg depending on the patient's bladder capacitiy.144 In the other trials, doxorubicin doses ranged from 10 to 80 mg. Five trials101,112,113,115,144,191 evaluated maintenance regimens (range 15 to 42 instillations) and one trial evaluated an induction regimen (8 doses over 4 weeks).112,116 Duration of followup ranged from a median of 15 months to a mean of 60 months.

There was no difference between MMC versus doxorubicin in risk of bladder cancer recurrence (6 trials, RR 1.00, 95% CI 0.82 to 1.22, I^2^=44%) (Figure 33).112,115,116,191 Findings were similar in a subgroup analysis restricted to five trials that evaluated maintenance therapy regimens (RR 0.88, 95% CI 0.69 to 1.11, I^2^=27%).101,112,115,144,191 MMC was also associated with a decreased risk of bladder cancer progression versus doxorubicin that did not reach statistical significance (4 trials, RR 0.63, 95% CI 0.37 to 1.08, I^2^=20%).113,115,144,191 No trial evaluated effects on overall or bladder cancer-specific mortality.

Figure 33 Meta-analysis of MMC versus doxorubicin: Risk of recurrence

BCG = bacillus Calmette-Guérin; CI = confidence interval; MMC = Mitomycin C

Note: Akaza, 1987 (Study 2) and Niijima, 1983 (Study 1) each reported effects for two different regimens and Huland, 1990 reported effects for three different regimens.

Figure 33 is a forest plot titled meta-analysis of MMC versus doxorubicin: risk of recurrence. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 10 studies, with a pooled risk of 1.00 (95% confidence interval 0.82 to 1.22) and the overall I-squared value was 44.5 (p=0.063).

#### MMC Versus Epirubicin

One small (n=44) trial evaluated MMC versus epirubicin in patients with single G1 or G2 tumors without CIS (Tables 7, 8; Appendixes E3, F2).192 It found no difference in risk of bladder cancer recurrence at 5 years between maintenance therapy with MMC 40 mg (16 to 18 instillations over 1 year) versus either a single 80 mg dose of epirubicin (40% [6/15] vs. 36% [5/14]; RR 1.12, 95% CI 0.44 to 2.86) or maintenance therapy with epirubicin 40 mg (40% [6/15] vs. 33% [5/15]; RR 1.20, 95% CI 0.47 to 3.10). The trial did not evaluate bladder cancer progression or mortality.

#### MMC Versus Gemcitabine

One trial (n=109) evaluated induction therapy with MMC versus gemcitabine in patients with recurrent G1-G3 tumors (Tables 7, 8; Appendixes E3, F2).194 At a median followup of 36 months, there was no difference between MMC versus gemcitabine in risk of bladder cancer recurrence (p=0.29), but MMC was associated with lower likelihood of recurrence-free survival (log-rank test, p=0.0021). MMC was also associated with increased risk of bladder cancer progression, but the difference was not statistically significant (18% [10/55] vs. 11% [6/54]; RR 1.64, 95% CI 0.64 to 4.19). The trial did not assess mortality.

#### MMC Versus Interferon Alpha

One trial (n=287) evaluated induction therapy with MMC versus interferon-alpha for primary G1 or G2 tumors without CIS (Tables 7, 8; Appendixes E3, F2).193 It found MMC associated with lower risk of bladder cancer recurrence than interferon-alpha 50 MU after 42 months of followup (37% [52/141] vs. 48% [70/146]; RR 0.77, 95% CI 0.58 to 1.01). MMC was associated with increased risk of bladder cancer progression, but the difference was not statistically significant (6% [8/141] vs. 4% [6/146], RR 1.38, 95% CI 0.49 to 3.88).193 The trial did not assess effects on mortality.

#### MMC Versus Interferon Gamma

One trial (n=123) evaluated maintenance therapy (20 instillations over 1 year) with MMC 40 mg versus interferon-gamma 15 MU for primary G2 tumors (CIS excluded) (Tables 7, 8; Appendixes E3, F2).141 MMC was associated with higher risk of recurrence after a median of 2 years followup [43% (27/63) vs. 27% (16/60); RR 1.61, 95% CI 0.97 to 2.67]. The trial did not assess effects on bladder cancer progression or mortality.

#### MMC Versus Thiotepa

Two trials compared maintenance therapy with MMC 40 mg versus thiotepa 60 mg.143,146 One trial (n=47) of patients with recurrent or multiple bladder cancers (excluding Tis) reported no clear differences in risk of recurrence (RR 1.76, 95% CI 0.36 to 8.70) or progression (RR 2.64, 95% CI 0.30 to 23.6), but estimates were very imprecise.143 Another trial (n=83) of patients with Ta or Tis lesions (not necessarily recurrent or multiple) found no difference in risk of recurrence (33% vs. 29%, RR 1.14, 95% CI 0.60 to 2.16).146

#### Doxorubicin Versus Epirubicin

Three trials evaluated doxorubicin versus epirubicin (Tables 9, 10; Appendixes E3, F2).119,195,196 Doses of doxorubicin were 30 to 50 mg and doses of epirubicin 30 to 80 mg. All trials evaluated maintenance regimens.

Doxorubicin was associated with higher risk of recurrence versus epirubicin (3 trials, RR 1.56, 95% CI 1.08 to 2.22, I^2^=0.0).119,195,196 One trial found no difference between maintenance therapy with doxorubicin 50 mg versus epirubicin 50 mg (RR 0.91, 95% CI 0.33 to 2.57) or epirubicin 80 mg (RR 2.08, 95% CI 1.13 to 3.83) in risk of bladder cancer progression119 and another trial reported no instances of progression in either treatment group.196 None of the trials evaluated effects on mortality.

#### Doxorubicin Versus Thiotepa

One trial (n=109) evaluated maintenance therapy (15 instillations over 1 year) with doxorubicin 50 mg versus thiotepa 50 mg in patients with G1-G3 NMIBC (Tables 9, 10; Appendixes E3, F2).172 There were no statistically significant differences in risk of bladder cancer recurrence (43% [23/53] vs. 36% [20/56]; RR 1.22, 95% CI 0.76 to 1.94) progression (8% [4/53] vs. 4% [2/56]; RR 2.11, 95% CI 0.40 to 11.06), noncancer mortality (0% [0/53] vs. 2% [1/56]; RR 0.35, 95% CI 0.01 to 8.45) or cancer-specific mortality (2% [1/53] vs. 0% [0/56]; RR 3.17, 95% CI 0.13 to 76.07) after a median followup of 36 months, though estimates were very imprecise.

#### Epirubicin Versus Interferon Alpha

One trial (n=134) evaluated a single instillation of epirubicin 100 mg versus interferon-alpha 50 MU for primary G1-G3 tumors (Tables 11, 12; Appendixes E3, F2).132,133 Epirubicin was associated with decreased risk of bladder cancer recurrence (46% [31/68] vs. 68% [45/66]; RR 0.67, 95% CI 0.49 to 0.91). Effects on bladder cancer progression or mortality were not reported.

## Key Question 3b Does the comparative effectiveness differ according to tumor characteristics, such as stage, grade, size, multiplicity, whether the tumor is primary or recurrent, or molecular/genetic markers?

### Key Points

- There were no clear differences in estimates of effectiveness of intravesical therapies in subgroups defined by tumor stage, grade, size, multiplicity, recurrence status, or DNA policy (SOE: low for stage, grade, tumor multiplicity, primary versus recurrent DNA ploidy).

### Detailed Synthesis

Evidence on how estimates of comparative effectiveness of intravesical therapies vary in subgroups defined by tumor characteristics was limited. There were no clear differences in estimates of effectiveness in subgroups defined by tumor stage,103,106,112,119,130,132,133,136,137,139, 172,180,191,193-195 presence or absence of CIS,152,159,171,172 tumor grade,103,112,119,130,132,133,135-137,139,155,172,173,188,191,194,195 tumor multiplicity,101,103,119,128,130,132,133,135,139,172,180,188,194,195 tumor size,180,188,194 primary versus recurrent tumor,100,103,112,119,122,124,128,130-133,135,180,191,194,195 or DNA ploidy.180 The trials evaluated various intravesical therapies, comparisons, and outcomes (recurrence, progression, mortality). Risk estimates were generally similar across subgroups or were imprecise, with overlapping confidence intervals.

## Key Question 3c Does the comparative effectiveness differ according to patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities?

### Key Points

- No trial evaluated how estimates of effectiveness of intravesical therapy vary in subgroups defined by patient characteristics such as age, sex, race/ethnicity, performance status, and comorbidities (SOE: insufficient).
- In patients with recurrence or progression following prior BCG therapy, one trial found maintenance therapy with gemcitabine associated with decreased risk of recurrence versus repeat treatment with BCG, and one trial found MMC maintenance therapy associated with lower likelihood of disease-free survival than gemcitabine; estimates for progression were imprecise (SOE: low).

No trial evaluated how estimates of effectiveness of intravesical therapy vary in subgroups defined by patient characteristics such as age, sex, race/ethnicity, performance status, and comorbidities. Most trials of patients with recurrent bladder cancer did not specify whether patients had received prior intravesical therapy or the type of intravesical therapy received.109,149,165,168,179,180,188,189,196 One trial of patients with high-risk Ta or T1 NMIBC (based on the European Organization for Research and Treatment of Cancer Scoring System) who failed BCG therapy found a gemcitabine maintenance regimen with gemcitabine (2000 mg) associated with decreased risk of recurrence versus BCG-Connaught (81 mg) (53% vs. 88%, RR 0.60, 95% CI 0.44 to 0.82), though there was no difference in risk of progression (33% vs. 38%) and only one death was recorded.184 Another trial (n=109) of patients with progression or relapse after intravesical therapy (83% BCG) found an MMC maintenance regimen associated with lower likelihood of disease-free survival (p=0.0021) than gemcitabine, though differences in recurrence rate (1.72 vs. 1.26 per 100 patient-months, p=0.31) and progression (18% vs. 11%, RR 1.64, 95% CI 0.64 to 4.19) were not statistically significant.194

## Key Question 3d Does the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents differ according to dosing frequency, duration of treatment, and/or the timing of administration relative to TURBT?

### Key Points

#### BCG

- Six trials found no clear differences between standard and lower doses of BCG in risk of recurrence, progression, or bladder cancer mortality, including in patients with higher-risk NMIBC, though there was some inconsistency between trials. Standard therapy was associated with increased risk of local and systemic adverse events versus lower dose BCG in most trials (SOE: low).
- Three trials of responders to BCG induction therapy found no clear differences between maintenance versus no maintenance therapy in risk of all-cause mortality (3 trials, RR 0.90, 95% CI 0.72 to 1.11) or bladder cancer mortality (2 trials, RR 1.14, 95% CI 0.24 to 5.40), though maintenance therapy was associated with decreased risk of recurrence (RR 0.76 [95% CI 0.65 to 0.88] and RR 0.16 [95% CI 0.02 to 1.21]) (SOE: low).
- Two of three trials found more prolonged courses of BCG associated with decreased risk of bladder cancer recurrence versus induction therapy in patients with higher-risk NMIIBC, but increased risk of adverse events (SOE: low).
- One trial found BCG TICE associated with lower likelihood of 5-year recurrence-free survival versus BCG Connaught (48% vs. 74%, p=0.01) and one trial found BCG TICE associated with lower likelihood of 5-year recurrence-free survival versus BCG RIVM (36% vs. 54%, p=0.07). Four trials that compared non-TICE BCG strains found no differences (SOE: low).

#### MMC

- One trial of patients with NMIBC (not selected for being at higher risk) found no clear differences between MMC 40 mg single instillation versus five instillations in risk of recurrence, progression, or mortality. The single instillation was associated with lower risk of local adverse events (SOE: low).
- One trial of patients with higher-risk NMIBC found MMC 20 mg induction therapy for 6 weeks associated with higher risk of recurrence than maintenance therapy. There were no clear differences in risk of adverse events (SOE: low).
- Two trials of MMC maintenance regimens in patients with NMIBC not selected for being at higher risk found some evidence that a higher total number of instillations and increased frequency during initial therapy were associated with lower risk of recurrence and progression, and might be associated with lower risk of local adverse events (SOE: low)
- One trial found no difference between “optimized” versus nonoptimizied administration of intravesical MMC in risk of recurrence in patients with low-risk NMIBC, but one other trial of patients with higher-risk NMIBC found optimized administration associated with lower risk of recurrence and increased risk of local adverse events (SOE: low).

#### Doxorubicin

- Two trials of patients with NMIBC not selected for being at higher risk found no differences between doxorubicin 30 mg and 20 mg given as short (8 week) or long (2 years) regimens in risk of recurrence or progression, with no differences in adverse events (SOE: low).
- Two trials of patients with NMIBC not selected for being at higher risk found no clear differences between doxorubicin induction therapy and induction plus maintenance in risk of recurrence, progression, or mortality, with no differences in adverse events (SOE: low).
- Two trials of doxorubicin found no clear benefits associated with administration prior to TURBT or multiple instillations immediately after TURBT, with some evidence of increased adverse events with multiple immediate post-TURBT instillations (SOE: low).

#### Epirubicin

- Three trials of epirubicin found no clear evidence that higher doses are associated with reduced risk of recurrence or progression versus lower doses, with no differences in adverse events (SOE: moderate).
- Three trials found no clear difference between single instillation epirubicin and multiple instillations in patients with low- or high-risk NMIBC in risk of recurrence, progression, or bladder cancer mortality, with some evidence of lower risk of local adverse events (SOE: moderate).
- Two trials found no clear differences between epirubicin maintenance therapy and induction without maintenance in risk of recurrence or progression, including one trial of patients with higher-risk NMIBC. There were no differences in risk of local adverse events (SOE: moderate).
- Five trials that evaluated different epirubicin regimens that included maintenance therapy found some evidence that more intensive therapy is associated with decreased risk of recurrence, but results were inconsistent. There was no difference in risk of adverse events (SOE: low).

#### Thiotepa

- Two trials found no clear differences between thiotepa 30 mg and 60 mg for maintenance or for treatment of incompletely resected NMIBC or CIS (SOE: low).

#### Interferon Alpha-2b

- Four trials found higher doses of interferon alfa-2b associated with improved outcomes related to recurrence, progression, or resolution of bladder cancer marker lesions versus lower doses, but most estimates were imprecise and did not reach statistical significance. There were no clear differences in risk of local or systemic adverse events (SOE: low).

#### Multiple Drugs

- One trial found no difference between initiation of intravesical therapy (9 instillations over 6 months) with MMC or doxorubicin 50 mg on the day of TURBT versus 1 to 2 weeks after TURBT in risk of recurrence, progression, or mortality; or between maintenance beyond 6 months versus no additional maintenance therapy. There were no clear differences in local or systemic adverse events (SOE: low).

### Detailed Synthesis

Fifty-three trials in 57 publications of intravesical therapy compared different doses or instillation regimens of the same drug or different BCG strains (Tables 17, 18; Appendixes E4, F2).112,113,116,118,119,123,126,134,136,140,148,151,154,156,157,176,191,192,197,198,200-236 Eleven trials in 12 publications evaluated comparisons involving BCG,148,151,156,176,200,201,204-211,215,218,222,223, 226,228,230,233,237 seven trials evaluated MMC,118,154,191,197,198,212,213,232 five trials in six publications evaluated doxorubicin,112,113,116,123,214,231,236 13 trials evaluated epirubicin,119,126,134,192,216,219,220, 224,225,227,229,234,235 two trials in one publication evaluated thiotepa,140 and three trials evaluated interferon alpha-2b.136,203,217,221 Sample sizes ranged from 34 to 1,355 and duration of followup from 4 weeks to 9 years. Twenty-four trials were conducted in the United States or Europe.118,136,140,148,151,154,156,191,197,212,214,216,217,221-224,228,230-232,234 Thirty-eight trials were rated medium risk of bias112,113,116,118,119,123,126,134,136,140,148,151,154,156,176,191,192,197,212,214-217,219-225,227-229,231-236 and four trials high risk of bias.198,218,226,230 No trial reported blinding of patients or care providers to the treatment regimen received. Only five trials118,134,176,215,233 reported in adequate detail use of an appropriate randomization method and only one trial221 reported assessment of outcomes blinded to the treatment received. Additional methodological shortcomings in the trials rated high risk of bias included use of sequential allocation218,226 and reporting of only interim results.230

Table 17 Study characteristics for trials comparing doses, duration, and timing of administration

Trial Type | Author, Year Setting Study Years | Inclusion Criteria | Interventions | Number Randomized/Analyzed | Duration and Method of Followup
BCG Trials | Badalament, 1987^200^ USA Single center 1981-1984 | Recurrent Ta, T1, or Tis bladder cancer without immediate indication for cystectomy who underwent BCG induction therapy | A: BCG Pasteur strain 120 mg (in 50 mL sterile saline) weekly for 6 weeks starting at 2-3 weeks after TURBT, then monthly B: BCG Pasteur strain 120 mg (in 50 mL sterile saline) weekly for 6 weeks | 93/unclear | Duration, median 22 months (range 3 to 44 months) Method: Cystoscopy 3-5 weeks after induction, then every 3 months, with cytology
BCG Trials | Fellows, 1994^201^ UK Multicenter 1988-1991 | Histologically proven recurrent multiple pTa/pT1 bladder tumors difficult to control endoscopically | A: BCG Evans strain (1-5 × 109 CFU) B: BCG Pasteur strain (1-3 × 109 CFU) 6 weekly instillations | 99/97 | Duration: 3 months Method: Cystoscopy 3 months after start of BCG
BCG Trials | Gruenwald, 1997^215^ Israel Single center 1992-1994 | Multifocal (≥3) tumors of any stage or grade, ≥3 recurrences within 12 months (regardless of stage), concomitant Tis, stage T1, or grade G3 | A: Pasteur strain BCG 120 mg/50 mL saline (begun within 1 month after TURBT, once weekly for 6 weeks) B: Pasteur strain BCG 120 mg/50 mL saline (begun within 1 month after TURBT, once weekly for 12 weeks) | 89/89 | Duration, median: 29 months Method: Cystoscopy and cytology every 3 months during year 1, every 6 months during year 2
BCG Trials | Hinotsu, 2011^176^ Japan Multicenter 2004-2006 | Recurrent or multiple tumors with confirmed Ta or T1 transitional cell carcinoma; must have 1 of the following: (a) at least 3 tumors (b) recurrence is at least the third such event or with recurrence diagnosed within 12 months from previous TURBT for NMIBC | Within 1 month of TURBT: A. BCG 81 mg (Connaught strain) in 40 mL saline weekly for 6 weeks then once weekly for 3 weeks at 3, 6, 12,and 18 months from start of induction therapy B. BCG 81 mg (Connaught strain) in 40 mL saline weekly for 6 weeks C. Epirubicin 40 mg in 40 mL saline twice at 1-week interval and then 7 times at 2-week intervals | 116/110 | Duration, median: 2 years Method: Cystoscopy and cytology every 3 months for 3 years then every 6 months
BCG Trials | Inamoto, 2013^204^ Japan Single center 2008-2009 | Histologically proven, single or multiple, primary or recurrent, stage Ta, T1, grades 1-3 urothelial carcinoma of the bladder, or carcinoma in situ. | A: Tokyo 172 strain BCG 40mg in 40 mL of saline B: Connaaught strain BCG 81 mg in 40 mL of saline Given for six consecutive weeks starting 14 days after TURBT | 38/38 | Duration: Median followup: 16.4 months vs. 16.5 months Method: Cystoscopy and urine cytology every 3 months
BCG Trials | Irie, 2003^218^ Japan Single center 1996-2001 | Superficial papillary bladder cancer, no prior BCG or chemotherapeutic agents, stage Ta or T1 | A. BCG (Tokyo 172 strain) 40 mg/40 mL saline, 6 instillations weekly starting 7-50 days after TURBT B: BCG (Tokyo 172 strain) 80 mg/40 mL saline, 6 instillations weekly starting 7-50 days after TURBT | Not Reported/80 | Duration, mean: 27.5 months in 40 mg group and 20 months in 80 mg group Method: Cystoscopy and cytology every 3 months for 2 years, then every 6 months
BCG Trials | Koga, 2010^205^ Japan Multicenter 2002-2005 | Histologically-confirmed Ta, T1 transitional cell carcinoma or CIS of bladder, responded to induction therapy | BCG 80 mg (Tokyo strain) within 4 weeks of biopsy or TURBT and repeated weekly for 8 weeks; patients with complete response were randomized to: A. BCG 80 mg (Tokyo strain) within 3 months of randomization followed by instillations at 3, 6, and 9 months B. No BCG | 53/51 | Duration: Median followup: 27 vs. 29 months Method: Cytology and cystoscopy 2 months after randomization and then every 3 months for 3 years and thereafter every 6 months
BCG Trials | Lamm, 2000^206^ USA Multicenter 1986-1989 Lerner, 2007^207^ | Histologically confirmed transitional cell carcinoma of the bladder within 6 months before enrollment; papillary tumors Ta or T1; 2 tumors (primary and recurrent or 2 recurrences) within 1 year, 3 or more within the most recent 6 months and/or CIS, responded to induction therapy with BCG | At least 1 week following TURBT patients received BCG 81 mg (Connaught strain) in 50.5 mL saline and simultaneous percutaneous BCG 0.5 cc (10^7 CFU) to inner thigh weekly for 6 weeks, responders randomized to: A. BCG intravesically and percutaneously 3 successive weekly treatments at 3 months, 6 months and every 6 months to 3 years B. No BCG | 550/384 | Duration: Median followup: 120 months Method: Cytology and cystoscopy every 3 months for 2 years then every 6 months for 2 years then yearly
BCG Trials | Martinez-Pineiro, 2002^222^ Spain Multicenter 1991-1992 | Primary or r4ecurrent TaG2/3 or T1G1-3 bladder cancer with or without CIS; primary Tis; recurrent TaG1 cancers | A: BCG Connaught strain 81 mg, 12 instillations (starting 7 to 14 days after TURBT, once weekly for 6 weeks, then once every 2 weeks for 12 weeks) B: BCG Connaught strain 27 mg, 12 instillation (starting 7 to 14 days after TURBT, once weekly for 6 weeks, then once every 2 weeks for 12 weeks) | 500/499 | Duration, median: 69 months Method: Not reported
BCG Trials | Martinez-Pineiro, 2005^223^ Spain Multicenter 1995-1999 | T1G3 and Tis bladder cancer | A: BCG Connaught strain 81 mg, 12 instillations (starting 7 to 14 days after TURBT, once weekly for 6 weeks, then once every 2 weeks for 12 weeks) B: BCG Connaught strain 27 mg, 12 instillation (starting 7 to 14 days after TURBT, once weekly for 6 weeks, then once every 2 weeks for 12 weeks) | 155/ 155 | Duration, median: 61 months Method: Not reported
BCG Trials | Morales, 1992^226^ Canada Single center 1979-1988 | Tis or T1 transitional cell carcinoma of the bladder with residual neoplasm; in patients with recurrences must have had a least 2 histologically documented but completely ablated tumors on 2 separate cystoscopic studies in the last 12 months | A: Armand Frappier BCG 60 mg weekly for 6 weeks B: Armand Frappier BCG 120 mg weekly for 6 weeks | 97/97 | Duration, mean: 21 months Method: Cystoscopy at 4, 12, and 24 weeks, then at 6 to 12 months
BCG Trials | Mukherjee, 1992^208^ UK Single center 1984- unclear end date | Multiple recurrent superficial bladder tumors that were increasingly difficult to keep under endoscopic control | A: BCG Glaxo strain (1.2 × 109 CFU) B: BCG Pasteur strain (1.2 × 109 CFU) 6 weekly instillations, followed by either monthly instillations if there was a complete response or 6-weeks if there was a partial or no response. | 21/21 | Duration: mean 60 months Method: Cystoscopy 3 months after final instillation, and then according to clinical criteria
BCG Trials | Oddens, 2013^228^ Europe Multicenter 1997-2005 | Solitary T1G3 or multiple Ta-T1, G1-3 urothelial carcinoma of the bladder | A: BCG (OncoTICE strain) 5 × 10^8^ CFU at 1/3 dose, 15 instillations (started within 14 days after TURBT, one weekly for 6 weeks, then 3 weekly instillations at months 3 ,6, and 12) B: BCG full dose, 15 instillations (started within 14 days after TURBT, one weekly for 6 weeks, then 3 weekly instillations at months 3 ,6, and 12) C: BCG at 1/3 dose, 27 instillations (started within 14 days after TURBT, one weekly for 6 weeks, then 3 weekly instillations at months 3 ,6,12, 18, 24, 30, and 36) D: BCG full dose, 27 instillations (started within 14 days after TURBT, one weekly for 6 weeks, then 3 weekly instillations at months 3 ,6,12, 18, 24, 30, and 36) | 1805/ 1355 | Duration, median: 7.1 years Method: Cystoscopy and cytology every 3 months for 3 years, then every 6 months
BCG Trials | Ojea, 2007^151^ Spain Multicenter 1995-1998 | Intermediate risk with stages TaG2 and T1G1-2 superficial bladder tumors without carcinoma in situ | 14-21 days after transurethral resection with histological confirmation of bladder cancer, patients received 6 weekly instillations then another 6 instillations one every 2 weeks; if a recurrence was diagnosed a further TURBT was performed and the treatment continued A. BCG 27 mg (Connaught strain) B. BCG 13.5 mg (Connaught strain) C. MMC: 30 mg | 430/397 | Duration, median: 57 months vs. 61 months vs. 53 months Method: Cystoscopy every 3 months during first year and then every 4 months for the next 4 years
BCG Trials | Pagano, 1995^230^ Bassi, 1992^262^ (Abstract of interim results) Italy Single center 1990 | Multiple papillary tumors (Ta-T1) and CIS | 6-week course of intravesical therapy: A. Pasteur strain BCG 75 mg B. Pasteur strain BCG 150 mg | Not Reported/138 | Duration: Not reported Method: Not reported
BCG Trials | Palou, 2001^209^ Spain, England Multicenter 1989-1995 | Primary or relapsing stage Ta or T1 grade 3 superficial bladder tumors with or without associated CIS or isolated CIS or associated with grade 2 superficial bladder tumors, responded to induction therapy with BCG | Initial treatment with 6 weekly instillations of BCG 81 mg (Connaught strain); if relapse then 6 additional weekly instillations; if disease free then randomized to: A. BCG 81 mg (Connaught) 6 weekly instillations every 6 months for 2 years B. No further treatment | 131/126 | Duration: Median followup 78 months Method: Alternating cytology and cystoscopy every 3 months for 2 years and then cytology and cystoscopy every 6 months
BCG Trials | Rentsch, 2014^210^ Switzerland Single center 1998-2010 | High risk NMIBC (any high-grade tumor, any low-grade tumor with more than two recurrences within 2 years, or carcinoma in situ) | A: BCG Connaught (6.6-19.2 × 108 CFU) B: BCG Tice (2-8 × 108 CFU) 6 weekly intravesical instillations | 142/131 | Duration: Median 47.6 vs. 51.4 months Method: Cystoscopy and cytology at 3- month intervals for the first 3 years, then at 6-month intervals for the following 2 years. Urography or CT scan at 1 and 3 years after BCG.
BCG Trials | Sengiku, 2013^233^ Japan Single center 2004-2012 | Stage Ta/T1 or Tis, multiple tumors and recurrence-free period of 3 months or less | At least 2 weeks after removing as much of visible lesion as possible by TURBT, patients received weekly up to 8 times: A. BCG 80 mg (Tokyo strain) in 40 mL saline B. BCG 81 mg (Connaught strain) in 40 mL saline | 178/129 | Method: Cystoscopy and urine cytology every 3 months for first 2 years and every 3-6 months thereafter
BCG Trials | Witjes, 1993^148^ Witjes, 1996^156^ Vegt, 1995^211^ The Netherlands Multicenter 1987-1990 | Histologically proven papillary pTa-pT1 transitional cell transitional cell carcinoma of the bladder with or without CIS | A. MMC 30 mg in 50 mL saline once a week for 4 weeks and thereafter once a month for 5 months. If a superficial recurrence or persistent CIS after 6 months, 3 additional monthly instillations given B. BCG-Tice C. BCG RIVM BCG 5×108 bacilli in 50 mL saline, administered once a week for 6 weeks. At the time of first superficial recurrence or persistent CIS at 3 or 6 months, a second 6 week course with BCG instillations was given after complete TURBT or biopsy. | 469/437 | Duration, median: 32 months Method: Cystoscopy every 3 months for 2 years, every 4 months in years 3 and 4 and every 6 months thereafter
MMC Trials | Au, 2001^197^ USA, Europe, and Canada Multicenter 1992-2000 | Transitional cell carcinoma of bladder at high risk for recurrence based on 1) two or more episodes of Ta, Tis, or T1 cancers, 2) multifocal (≥3 papillary tumors or Tis involving ≥25% of bladder surface and/or in two or more biopsy sites), 3) tumors >5 cm, G3, or DNA aneuploidy | A: MMC 40 mg/20 mL sterile water, 6 instillations (once weekly for 6 weeks), optimized by instruction to refrain from fluids for 8 hour prior to and during instillations, oral doses of 1.3 g sodium bicarbonate the night before, Foley to empty bladder prior to instillation for post void residual <10 mL B: MMC 20 mg/20 mL sterile water, 6 instillations (once weekly for 6 weeks), without additional optimization measures | 230/201 | Duration: 5 years Method: Cystoscopy and cytology every 3 months for 2 years, every 6 months for years 3-5, and once yearly thereafter
MMC Trials | Colombo, 2012^213^ Italy Single center 2010-2011 | Recurrent, single, small (<1.5 cm) bladder cancers following TURBT of low-grade NMIBC | A: Mitomycin C (MMC), 40 mg (in 40 mL saline) three instillations per week for 2 weeks, prior to TURBT B: Mitomycin C (MMC), 40 mg (in 40 mL saline) one instillation per week for 6 weeks, prior to TURBT | 54/54 | Duration, 9 to 11 days following end of instillations Method: Cystoscopy with 14 days of completion of therapy
MMC Trials | Ersoy, 2013^198^ Turkey Single center 2006- 2010 | Primary low-risk NMIBC. Stage Ta, Grade G1. Solitary tumor; Size <3 cm. | A: MMC, 40 mg (in 40 mL sterile saline) intravesical; infusion within 6 hours of TURBT; MMC retained in bladder for 2 hours. B: Urinary alkalinization prior to MMC instillation: Sodium bicarbonate, 1.3 g, orally × 3 doses (night before TURBT, morning of TURBT, 30 minutes prior to MMC). MMC, 40 mg (in 40 mL sterile saline) intravesical; infusion within 6 hours of TURBT; MMC retained in bladder for 2 hours. C: No drugs given in the first 6 hours after TURBT. | 53/49 | Duration, median: A vs. B vs. C: 51 vs. 50 vs. 54 months, p=0.815 Method: Cystoscopy: month 3, month 12, then annually for 5 years.
MMC Trials | Friedrich, 2007^154^ Germany Multicenter 1995-2002 | Patients with primary transitional cell carcinoma of the bladder or patients with tumor recurrence after TURBT without prior adjuvant; histopathologic evaluation of their completely resected tumor revealed an intermediate risk pTaG1 tumor (size >3 cm, recurrent or multifocal tumor) or pTaG2 up to pT1 tumor (G1-3). Patients with T1G3 tumor were eligible in case of a unifocal small tumor (≤2.5 cm). | A. MMC 20 mg, 6 weekly instillations B. BCG RIVM 2 × 10^8 CFU, 6 weekly instillations C. MMC 20 md, 6 weekly instillations followed by monthly instillations of MMC 20 mg for 3 years | 495/ 495 | Duration, median: 2.9 years Method: Cytology and cystoscopy every 3 months in the first 2 years and every 6 months thereafter
MMC Trials | Fukui, 1992^202^ Japan Single center 1986-1989 | Ta, T1, or Tis transitional cell carcinoma of the bladder who had complete response to 5 weeks induction therapy with sequential MMC and adriamycin | A: MMC 20 mg (in 20 mL saline) on day 1 and adriamycin 40 mg (in 20 mL saline) on day 2 for 5 weeks, followed by maintenance therapy once monthly for 12 months B: MMC 20 mg (in 20 mL saline) on day 1 and adriamycin 40 mg (in 20 mL saline) on day 2 for 5 weeks, No maintenance therapy | 51/51 | Duration: Unclear Method: Cystoscopy and urine cytology every 3 months
MMC Trials | Huland, 1990^191^ Germany Multicenter 1983 - 1985 | Superficial bladder carcinoma (primary or recurrent). Stages Ta, T1 or Tis; Grade G1, G2 or G3. CIS. Single or multiple tumors. | A: MMC, 20 mg/20 mL. Total 42 instillations. Every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. B: MMC, 20 mg/20 mL. Total 42 instillations. Every week × 8 weeks, then every 4 weeks for rest of 1st year and 2 additional years. C: MMC, 20 mg/20 mL. Total 20 instillations. Every week × 20 weeks. D: Doxorubicin, 50 mg/50 mL. Total 42 instillations. Every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. For all groups: Instillations started 4 to 6 weeks after discharge from hospital. | 477/419 | Duration, mean: A vs. B vs. C vs. D: 26.7 vs. 27.4 vs. 26.7 vs. 30.2 months Method: Cystoscopy every 3 months.
MMC Trials | Schwaibold, 1997^232^ Germany Single center 1983-1987 | Ta, T1, or Tis transitional cell carcinoma of the bladder | A: MMC 20 mg/20 mL saline, 42 instillations (every 2 weeks for 1 year, every 4 weeks for 1 year, every 3 months for 1 year) B: MMC 20 mg/20 mL saline, 42 instillation (every week for 8 weeks, every 4 weeks for 44 weeks and 2 additional years) C: MMC 20 mg/20 mL saline, 20 instillations (every week for 20 weeks) D: Doxorubicin 50 mg/50 mL saline, 42 instillations (same schedule as A) | 477/ 419 | Duration, median: 57 months Method: Cystoscopy every 3 months
MMC Trials | Tolley, 1996^118^ United Kingdom Multicenter 1984 - 1986 | Patients with newly diagnosed stage Ta or T1 transitional cell carcinoma of the bladder; Grades 1 -3. | A: MMC 20 mg/20 mL saline, 42 instillations (every 2 weeks for 1 year, every 4 weeks for 1 year, every 3 months for 1 year) B: MMC 2 mg/20 mL saline, 42 instillation (every week for 8 weeks, every 4 weeks for 44 weeks and 2 additional years) C: MMC 20 mg/20 mL saline, 20 instillations (every week for 20 weeks) D: Doxorubicin 50 mg/50 mL saline, 42 instillations (same schedule as A) | 452/452 | Duration, median: 57 months Method: Cystoscopy every 3 months
Doxorubicin Trials | Akaza, 1987^112^ Japan Unclear if single or multicenter 1982-1985 | Histologically proven superficial bladder cancer (primary only). Stages Ta or T1; Grade G1 or G2. Absence of tumor after TURBT. | A: Doxorubicin, 30 mg (in 30 mL saline). B: Doxorubicin, 20 mg (in 40 mL saline). C: MMC: 20 mg (in 40 mL saline). D: No adjuvant treatment. TURBT alone. For A, B, and C: First instillation within 1 week of TURBT. Once weekly × 2 weeks, then once every 2 weeks × 14 week, then once monthly × 8 months, then once every 3 month × 1 year (Total: 21 doses over 2 years) | 665/607 | Duration: 3.5 years, maximum; Mean, median not reported Method: Cystoscopy and urinary cytology studies at 12-week intervals throughout study period
Doxorubicin Trials | Flamm, 1990^214^ Austria Single center 1979-1981 | Primary or recurrent transitional cell carcinoma of the bladder, otherwise not specified | A: Doxorubicin 50 mg/50 mL saline weekly for 6 weeks, then monthly for 2 years B: Doxorubicin 50 mg/50 mL saline weekly for 6 weeks | 160/146 | Duration: 5 years Method: Cystoscopy every 3 months for 2 years, then every 6 months
Doxorubicin Trials | Matsumura, 1992^123^ Japan Multicenter 1987-1989 | Ta, T1, or Tis transitional cell carcinoma of the bladder; primary with multiple lesions or recurrent with one or more lesions | A: Doxorubicin 20 mg/40 mL saline, 21 instillations (following TURBT, once weekly for 2 weeks, then every 2 weeks for 14 weeks, once monthly for 8 months, and once every three months for 1 year) B: Doxorubicin 20 mg/40 mL saline, 6 instillations (over 2 weeks prior to TURBT) C: No doxorubicin | 443/284 | Duration, median: 240 days Method: Not reported
Doxorubicin Trials | Niijima, 1983^116^ Japan Multicenter 1980 – 1985 | Histologically proven superficial bladder cancer (primary or recurrent). Stages Ta or T1; Grade not specified. Absence of tumor after TURBT. | A: Doxorubicin, 30 mg (in 30 mL saline). B: Doxorubicin, 20 mg (in 40 mL saline). C: MMC: 20 mg (in 40 mL saline). D: No adjuvant treatment. TURBT alone. For A, B, and C: First instillation within 1 week of TURBT. Twice weekly × 4 weeks (Total: 8 doses) | 707/575 | Duration: 5 years, maximum; Mean/Median not reported Method: Cystoscopy and urinary cytology studies at 12-week intervals during the observation period.
Doxorubicin Trials | Rubben, 1988^231^ Germany Single center 1979-1981 | Primary or recurrent NMIBC, any grade | A: Doxorubicin 50 mg/50 mL saline, 13 instillations (2 hours prior to TURBT, then twice weekly for 6 weeks) B: Doxorubicin 50 mg/50 mL saline, 28 instillations (2 hours prior to TURBT, then twice weekly for 6 weeks, twice monthly for 4.5 months, once monthly for 6 months) C: No intravesical therapy | 965/834 | Duration: Mean, median not reported Method: Cystoscopy and cytology every 3 months for 2 years, then every 6 months
Doxorubicin Trials | Ueda, 1992^236^ Japan Multicenter 1984-1986 | Ta and T1 transitional cell carcinoma of bladder | A: Doxorubicin 30 mg/30 mL saline, 19 instillations (immediately and 2 days after TURBT, then weekly for 2 weeks, every 2 weeks for 14 weeks, monthly for 8 months) B: Doxorubicin 30 mg/30 mL saline, 19 instillations (immediately and 2 days after TURBT, then weekly for 2 weeks, every 2 weeks for 14 weeks, monthly for 8 months) plus 5-fluorouracil 200 mg/day starting at 1 week C: Doxorubicin 30 mg/30 mL saline, 17 instillations (starting 7 days after TURBT weekly for 2 weeks, every 2 weeks for 14 weeks, monthly for 8 months) | 275/187 | Duration, mean: 31 months Method: Cystoscopy at 4 weeks then every 3 months
Epirubicin Trials | Ali-El-Dein, 1997^119^ (J Urol) Egypt Single center 1991 – 1995 | TCC of the bladder (primary or recurrent). Stages Ta or T1; Associated CIS or other dysplastic mucosal changes; Grade G1 - G3. Rapid recurrence within 6 months of initial resection; Multicentricity; Positive posterior urethral biopsy and/or positive postoperative urinary cytology (only 2 patients with positive posterior urethral biopsy, who underwent resection of multiple tumors to provide bladder neck incompetence and sufficient contact of drug with prostatic urethra). | A: Epirubicin, 50 mg (in 50 mL normal saline). B: Epirubicin, 80 mg (in 50 mL normal saline). C: Doxorubicin, 50 mg (in 50 mL normal saline). D: No adjuvant treatment. TURBT alone. For Groups A - C: First instillation 7 to 14 days after TURBT. Retained intravesically for 2 hours; Instillations once a week × 8 weeks, then once monthly to complete 1 year of treatment. | 253/ 253 | Duration, mean: 30.1 months Method: Cystourethroscopy, urine cytology, and flow cytometry every 3 months during first 2 years, and every 6 months thereafter.
Epirubicin Trials | Ali-El-Dein, 1997^126^ (British J Urol) Egypt Single center 1992 – 1996 | TCC of the bladder (primary or recurrent). G2 or G3, multiple recurrent, pT1, aneuploidy, or ≥3 cm; pTa if multiple, large (≥3 cm), recurrent and/or grade 2-3 tumors. | A: Epirubicin, 50 mg (in 50 mL normal saline); Single instillation immediately after TURBT. Retained intravesically for 2 hours. B: Epirubicin, 50 mg (in 50 mL normal saline); Initial instillation 1 - 2 weeks after TURBT. Retained intravesically for 2 hours; Then, instillations once a week × 7, then once monthly × 10 to complete 1 year of treatment. C: No adjuvant treatment. TURBT alone. | 179/168 | Duration, mean: 32.2 months Method: Cysto-urethroscopy, cytology, and DNA flow cytometry 8 weeks after resection, then every 3 months during first 2 years, and every 6 months thereafter during the next 2 years.
Epirubicin Trials | Hendricksen, 2008^216^ the Netherlands Multicenter 1998-2004 | ≤85 years of age, solitary T1 tumor, or multiple primary or recurrent T1 or Ta G1-G3 urothelial cell carcinoma of the bladder in whom complete TURBT was possible | A. Epirubicin 50 mg/50 mL saline, 9 instillations over 6 months (once weekly for 4 weeks started within 2 weeks of TURBT, then once monthly for 5 months) B. Epirubicin 50 mg/50 mL saline, 10 instillations over 6 months (within 48 hours of TURBT, once weekly for 4 weeks starting within 2 weeks of TURBT, once monthly for 5 months) C: Epirubicin 50 mg/50 mL saline, 11 instillations over 12 months (once weekly for 4 weeks starting within 2 weeks of TURBT, once monthly for 5 months, once every three months for 6 months) | 1000/731 | Duration, median (A and B, not reported for C): 7 years Method: Cystoscopy every 3 months for a year, then every 6 months for a year, annually thereafter.
Epirubicin Trials | Koga, 2004^219^ Japan Multicenter 1993-1995 | New, untreated transitional cell carcinoma of the bladder, Ta or T1 disease, no residual tumor based on cystoscopy and cytology | A: Epirubicin 30 mg/30 mL saline 19 times (within 24 hours of TURBT, then 2-3 days, 1 week, and 2 weeks after TURBT, then once every 2 weeks for 12 weeks, then once a month for 9 months) B: Epirubicin 30 mg/30 mL saline 9 times (within 24 hours of TURBT, then 2-3 days, 1 week, and 2 weeks after TURBT, then once every 2 weeks for 10 weeks) | 171/150 | Duration, median: 30.6 months Method: Cytology every month, cystoscopy every 3 months for 2 years, then every 6 months
Epirubicin Trials | Kuroda, 2004^220^ Japan Multicenter 1994-1996 | Primary or recurrent superficial transitional cell carcinoma of the bladder (Ta or T1, G1 or G2) | A. Epirubicin 20 mg/40 mL saline, 17 instillations over 12 months (starting about 7 days after TURBT, once weekly for 2 weeks, once every other week for 14 weeks, once a month for 8 months) B: Epirubicin 30 mg/40 mL saline, 12 instillations over 12 months (starting about 7 days after TURBT, once weekly for 2 weeks, once every other week for 14 weeks, once a month for 3 months) C: Epirubicin 40 mg/40 mL saline, 9 instillations over 4 months (starting about 7 days after TURBT, once weekly for 2 weeks, once every other week for 14 weeks) | 622/614 | Duration, median: 3.5 years Method: Cystoscopy every 3 months
Epirubicin Trials | Liu, 2006^192^ China Unclear if single or multicenter 1997 – 1998 | Superficial bladder carcinoma (primary or recurrent). Stages Ta or T1; Grade G1 or G2 | A: Epirubicin, 80 mg (in 40 mL normal saline). Single intravesical instillation within 6 hours of TURBT. B: Epirubicin, 40 mg, intravesical instillation every week for 6 ∼ 8 weeks, then every month for 10 months. C: MMC, 40 mg, intravesical instillation every week for 6 ∼ 8 weeks, then every month for 10 months. | 47/44 | Duration: All patients followed-up for 5 years until June 2003. Method: Cystoscopy and urinary cytology every 3 months × 2 years, then every 6 months × 3 years.
Epirubicin Trials | Masters, 1999^224^ UK Multicenter 1991-1993 | Primary or recurrent Ta or T1 bladder cancer | A: Epirubicin 50 mg/50 mL saline, 5 instillations (starting 10-14 days after TURBT, every 3 months for 12 months) B: Epirubicin 100 mg/50 mL saline, 5 instillations (starting 10-14 days after TURBT, every 3 months for 12 months) First 102 patients had a marker tumor left after initial TURBT (0.5 cm) | 126/122 | Duration: 834 vs. 774 days Method: Cystoscopy every 3 months
Epirubicin Trials | Mitsumori, 2004^225^ Japan Multicenter 1998-2001 | Recurrent or primary Ta or T1 bladder cancer | A: Epirubicin 30 mg/40 mL saline, 6 instillations (starting 1 week after TURBT once every 2 weeks for 12 weeks, total 180 mg) B: Epirubicin 30 mg/40 mL saline, 6 instillations (3 instillations within first 5-7 days after TURBT, then once every 2 weeks for 6 weeks, total 180 mg) C: Epirubicin 30 mg/40 mL saline, 12 instillations (starting 1 week after TURBT, once weekly for 12 weeks, total 360 mg) D: Epirubicin 30 mg/40 mL saline, 12 instillations (3 instillations within first 5-7 days after TURBT, then once weekly for 9 weeks, total 360 mg) | 91/69 | Duration, median: 13.3 months Method: Cystoscopy and urine cytology every 3 months for 3 years, then every 6 months
Epirubicin Trials | Nomata, 2002^227^ Japan Multicenter 1995-1998 | Ta or T1/G1 or G2 transitional cell carcinoma of the bladder, ECOG performance status 0 or 1, age 20 to 80 years, post TURBT with no evidence of residual cancer based on cytological evaluation of voided urine | A. Epirubicin 30 mg/30 mL saline 19 times over 1 year (once weekly for 4 weeks, then every 2 weeks for 4 months) B. Epirubicin 30 mg/30 mL saline 12 times over 5 months (once weekly for 4 weeks, then every 2 weeks for 4 months, then once per month for 7 months) | 138/125 | Duration, median: 18.1 months Method: Cystoscopy every 3 months
Epirubicin Trials | Okamura, 1998^229^ Japan Multicenter 1991-1993 | Ta-T1 papillary bladder cancer resectable by TURBT, ECOG performance status 0 or 1, age <85 years; primary or recurrent bladder cancer if recurrence-free interval >1 year | A: Epirubicin 40 mg/40 mL saline 17 times (within 24 hours of TURBT, during first week, once weekly for 4 weeks, then once monthly for 11 months) B: Epirubicin 40 mg/40 mL saline 6 times (within 24 hours of TURBT, during first week, then once weekly for 4 weeks) | 148/138 | Duration, median: 29.6 months Cystoscopy and cytology at 4 weeks, then every 3 months
Epirubicin Trials | Saika, 2010^134^ Japan Multicenter 1995 – 2001 | Transitional cell carcinoma of the bladder (primary or recurrent). Stages Ta or T1; Grade G1, G2, or G3. Age ≥20 years. | A. Epirubicin, 20 mg (in 40 mL physiological saline). Two intravesical infusions, one immediately after (<1 hour) TURBT and one in the early morning of the following day, retained in bladder for 1 hour. B. Epirubicin, 50 mg (in 100 mL physiological saline). Same procedure as A. C. No adjuvant therapy. TURBT only. | 303/240 | Duration, median: Overall: 44 months; A vs. B vs. C: 44 vs. 46 vs. 42 Method: Cystoscopy every 3 months for 2 years and every 6 months thereafter.
Epirubicin Trials | Serretta, 2010^234^ Italy Multicenter 2002-2003 | Multiple and recurrent Ta tumors; recurrent, single or multiple T1 tumors | A: Epirubicin 80 mg/50 mL saline, 16 instillations (within 6 hours of TURBT, then once weekly for 5 weeks, once weekly for 10 months) B: Epirubicin 80 mg/50 mL saline, 6 instillations (within 6 hours of TURBT, then once weekly for 5 weeks) | 482/395 | Duration, median: 48 months Method: Cystoscopy and cytology every 3 months for 2 years, then 6 months from years 3 to 5
Epirubicin Trials | Turkeri, 2010^235^ Turkey Multicenter 2002-2004 | Primary bladder tumor, ≤3 lesions, Ta (G2 or G3) or T1 (G1 or G2) | A: Epirubicin 100 mg within 6 hours after TURBT B: Epirubicin 100 mg within 6 hours and 12-hours after TURBT | 299/143 | Duration, mean: 16.9 months Method: Cystoscopy every 3 months for 1 year, then every 6 months during years 2 and 3, then once yearly
Gemcitabine Trials | Gardmark, 2007^157^ Japan Single center 1986-1989 | Recurrent multiple Ta G1/2 bladder cancer, with all lesions except one marker lesion resected | A: Gemcitabine 2000 mg (in 100 mL saline) once weekly for 6 weeks B: Gemcitabine 2000 mg (in 100 mL saline) twice weekly for 3 weeks C: Gemcitabine 2000 mg (in 100 mL saline) single instillation | 32/30 | Duration: 9 weeks after initial instillation Method: Cystoscopy
Thiotepa Trials | Koontz, 1981^140^ (prophylaxis) USA Multicenter 1974-1977 | Multifocal NMIBC or bladder cancer on ≥3 occasions in last 18 months; clinical assessment that prophylaxis warranted (2 tumors within 6 months); or complete response to thiotepa | A: Thiotepa 30 mg/30 mL distilled water (once every 4 weeks for maximum 2 years) B: Thiotepa 60 mg/60 mL distilled water (once every 4 weeks for maximum 2 years) C: No thiotepa | 95/93 (30 responders from Koontz 1981 thiotepa treatment trial enrolled) | Duration, median: 15 months Method: Cystoscopy every 3 months
| Koontz, 1981^140^ (treatment) USA Multicenter 1974-1977 | Incompletely resected NMIBC (single or multiple) or Tis or carcinoma on random biopsy | A: Thiotepa 30 mg/30 mL distilled water (once weekly for 4 weeks, repeated after 4 weeks) B: Thiotepa 60 mg/60 mL distilled water (once weekly for 4 weeks, repeated after 4 weeks) | 101/95 | Duration: 4 weeks after 2 4-week treatment courses Method: Cystoscopy at 4 weeks after fourth instillation and 4 weeks after eight instillation
Interferon alpha-2b Trials | Giannakopoulos, 1998^136^ Greece Unclear if single or multicenter Study years not reported | Superficial transitional cell carcinoma (TCC) of the bladder (primary or recurrent). Stages Ta or T1; Grade G2. | A: No adjuvant treatment. TURBT alone. B: Interferon-α-2b (interferon-α-2b), 40 MU (in 50 mL normal saline). C: Interferon-α-2b (interferon-α-2b), 60 MU (in 50 mL normal saline). D: Interferon-α-2b (interferon-α-2b), 80 MU (in 50 mL normal saline). For Groups B - D: First instillation after histological verification of stage and grade; 48 - 72 hours after TURBT. Retained intravesically for 1 hour; patient position changed every 15 minutes. Instillations once a week × 2 months, then once every 15 days × 4 months, then once monthly × 6 months. | 89/89 | Duration: 36 months Method: Cystoscopy and urine cytology, every 3 months for 18 months, and every 6 months thereafter.
Interferon alpha-2b Trials | Glashan, 1990^203^ USA, Europe, Australia, Canada Multicenter 1985-1988 | Carcinoma in situ of the bladder and positive post-biopsy cytology | A: Interferon α-2b 100 million units (in 30 mL sterile water) B: Interferon α-2b 10 million units (in 30 mL sterile water) First instillation within 1 month of positive cytology, administered once weekly for 12 weeks, then monthly through one year | 85/80 | Duration: 36 months Method: Cystoscopy and cytology every 3 months
Interferon alpha-2b Trials | Hoeltl, 1991^217^ Austria Single center Study years not reported | Primary G1 or G2 papillary transitional cell carcinoma of bladder stages Ta, T1, or TIS or recurrent G1/Ta or T1 bladder cancer; Karnofsky performance status ≥50% | A: Interferon alfa-2b 100 × 10^6^ IU (100 MU)/30 mL sterile water (once weekly for 10 weeks, then once monthly for 1 year total of therapy) B: Interferon alfa-2b 10 × 10^6^ IU (10 MU)/30 mL sterile water (starting within 36 hours of TURBT, once weekly for 10 weeks, then once monthly for 1 year total of therapy) C: Ethoglucid 1.13 g/100 mL sterile water (once weekly for 10 weeks, then once monthly for 1 year total of therapy) | 44/34 | Duration, mean: 36.5 months Method: Cystoscopy and urine cytology every 3 months for 1 year, then every 6 months
Interferon alpha-2b Trials | Malmström, 2002^221^ Europe Multicenter Study years: not reported | Histologically confirmed TCC of the bladder (primary or recurrent). Multiple tumors only. Stages Ta or T1; Grade G1 or G2. Karnofsky performance status >70%; No other malignancy within 5 years of the study, except nonmelanoma skin cancer; Age ≥18 years; Not pregnant and on appropriate birth control. | A: Interferon-α, 30 MU (in 30 mL sterile water). Retained in bladder × 2 hours; patient moved from side to side every 30 minutes. First instillation 1 to 2 weeks after TURBT or biopsy, then weekly × 12 weeks. B: Interferon-α, 50 MU (in 30 mL sterile water). Same procedure as A. C: Interferon-α, 80 MU (in 30 mL sterile water). Same procedure as A. D: MMC, 40 mg (in 40 mL sterile water). Retained in bladder × 2 hours; patient moved from side to side every 30 min. First instillation 1 to 2 weeks after TURBT or biopsy, then weekly × 8 weeks. | 115/110 | Method: followup at 9 weeks and 13 weeks for all treatment groups and at 9 weeks only for control group. Cystoscopy at week 9 for both groups.
Multiple Drugs | Bouffioux, 1995^212^ Europe Multicenter 1983-1986 | Completely resectable, Ta or T1 (0 or A), papillary transitional cell carcinoma of the bladder (single or multiple, primary or recurrent), previous intravesical treatment with cytotoxic drugs other than MMC allowed if >3 months prior | Initial randomization: A. MMC 30 mg/50 mL saline or doxorubicin 50 mg, 9 instillations starting on day of TURBT (once weekly for 4 weeks, then once monthly for 5 months) B. MMC 30 mg/50 mL saline or doxorubicin 50 mg, 9 instillations, starting between days 7 and 15 after TURBT (once weekly for 4 weeks, then once monthly for 5 months) Second randomization at 6 months: A: Continued instillations once a month for 6 months, total 15 B: No maintenance | 965/834 | Duration, average: 2.75 to 6.5 years (varied by outcome) Method: Cystoscopy every 3 months during year 1, every 4 months during year 2, every 6 months thereafter

BCG = bacillus Calmette-Guérin; BCG RIVM = RIVM strain of bacillus Calmette- Guérin; BCG-Tice = bacillus Calmette-Guérin Tice strain; CIS = carcinoma in situ; CFU = Colony Forming Unit; ECOG = Eastern Cooperative Oncology Group; G1 = Grade 1; G2 = Grade 2; G3 = Grade 3; MMC = Mitomycin C; MU = million units; NMIBC = non–muscle-invasive bladder cancer; pT1 = Tumor stage 1 determined by pathology; pTa = Tumor stage a determined by pathology; T1 = Tumor stage 1; Ta = Tumor stage a; TCC = transitional cell carcinoma; Tis = carcinoma in situ; TURBT = transurethral resection of the bladder tumor

Table 18 Results summary for trials comparing dosages, duration, and timing of administration

Intervention | Author, Year Setting Study Years | Interventions | Progression | Recurrence | Mortality | Adverse Events
BCG Trials | Badalament, 1987^200^ USA Single center 1981-1984 | A: BCG Pasteur strain 120 mg (in 50 mL sterile saline) weekly for 6 weeks starting at 2-3 weeks after TURBT, then monthly B: BCG Pasteur strain 120 mg (in 50 mL sterile saline) weekly for 6 weeks | Progression: 26% (12/47) vs. 20% (9/46) at median 22 months, RR 1.31 (95% CI 0.61 to 2.80) | | Mortality: 0% (0/47) vs. 0% (0/46) at median 22 months | Only reported for maintenance arm Discontinued due to adverse events: 45% (21/47) Dysuria: 89% (42/47) Frequency/urgency: 85% (40/47) Hematuria: 57% (27/47) Fever/chills: 43% (20/47) Flu-like symptoms: 13% (6/47) Suprapubic pain: 6% (3/47)
BCG Trials | Fellows, 1994^201^ UK Multicenter 1988-1991 | A: BCG Evans strain (1-5 × 109 CFU) B: BCG Pasteur strain (1-3 × 109 CFU) 6 weekly instillations | Responders at three months (marker tumor response and no new tumors): 12/51 vs. 18/43, p=0.064 | | | Severe AEs: Frequency: 4/51 vs. 5/46 Dysuria: 2/51 vs. 2/46 Hematuria: 1/51 vs. 2/46 Fever/Malaise: 2/51 vs. 1/46 Joint pain: 1/51 vs. 0/46 Hepatic dysfunction: 0/51 vs. 0/46
BCG Trials | Gruenwald, 1997^215^ Israel Single center 1992-1994 | A: Pasteur strain BCG 120 mg/50 mL saline (begun within 1 month after TURBT, once weekly for 6 weeks) B: Pasteur strain BCG 120 mg/50 mL saline (begun within 1 month after TURBT, once weekly for 12 weeks) | Progression: 5.0% (2/40) vs. 10% (3/30), RR 0.50 (95% CI 0.09 to 2.81) | Percent recurrence-free: 55% (22/40) vs. 70% (21/30) (p>0.05); adjusted OR 2.17 for B vs. A (95% CI 0.9 to 5.22) (adjusted for stage and number of recurrences) Time to recurrence: 12.3 vs. 12.9 months Recurrence: 20% (8/40) vs. 13% (4/30) at 1 year, RR 1.5 (95% CI 0.50 to 4.5); 45% (18/40) vs. 30% (9/30) at 2 years, RR 1.5 (95% CI 0.79 to 2.86) | Bladder cancer and all-cause mortality: 5.0% (2/40) vs. 3.3% (1/30), RR 1.5 (95% CI 0.14 to 16) | Dysuria or frequency: 30% (12/40) vs. 40% (12/30) Hemorrhagic cystitis: 7.5% (3/40) vs. 13% (4/30) Fever (mild): 22% (9/40) vs. 30% (9/30) Severe side effects: 2.5% (1/40) vs. 6.7% (2/30)
BCG Trials | Hinotsu, 2011^176^ Japan Multicenter 2004-2006 | Within 1 month of TURBT: A. BCG 81 mg (Connaught strain) in 40 mL saline weekly for 6 weeks then once weekly for 3 weeks at 3, 6, 12,and 18 months from start of induction therapy B. BCG 81 mg (Connaught strain) in 40 mL saline weekly for 6 weeks C. Epirubicin 40 mg in 40 mL saline twice at 1-week interval and then 7 times at 2-week intervals | Progression at time of recurrence: 0% (0/41) vs. 7.1% (3/42), RR 0.15 (0.01 to 2.7) | Recurrence: 12% (5/41) vs. 33% (14/42), RR 0.37 (95% CI 0.14 to 0.92) | Recurrence-free survival: 85% vs. 65% (p=0.02) | Urinary frequency: 93% (39/42) vs. 71% (30/42), RR 1.3 (95% CI 1.1 to 1.6) Dysuria: 93% (39/42) vs. 69% (29/42), RR 1.3 (95% CI 1.1 to 1.7) Hematuria: 93% (39/42) vs. 71% (30/42), RR 1.3 (95 %CI 1.1 to 1.6) Fever: 43% (18/42) vs. 26% (11/42), RR 1.6 (95% CI 0.88 to 3.0)
BCG Trials | Inamoto, 2013^204^ Japan Single center 2008-2009 | A: Tokyo 172 strain BCG 40mg in 40 mL of saline B: Connaaught strain BCG 81 mg in 40 mL of saline Given for six consecutive weeks starting 14 days after TURBT | | Recurrence-free survival: 72.2% vs. 83.5%, log rank p=0.698 | | All AEs: 14/18 (77%) vs. 14/20 (70%), p=0.7718 AEs in more than 10% of patients: Pollakisuria: 3/18 (16.7%) vs. 6/20 (31.6%), p=0.5637 Hematuria: 4/18 (22.2%) vs. 1/20 (5.3%), 0.0833 Miction pain: 4/18 (22.2%) vs. 1/20 (5.3%), p=0.0455 Fever: 2/18 (11.1%) vs. 7/20 (36.8%)
BCG Trials | Irie, 2003^218^ Japan Single center 1996-2001 | A. BCG (Tokyo 172 strain) 40 mg/40 mL saline, 6 instillations weekly starting 7-50 days after TURBT B: BCG (Tokyo 172 strain) 80 mg/40 mL saline, 6 instillations weekly starting 7-50 days after TURBT | Progression: 5.0% (2/40) vs. 6.4% (2/31), RR 0.78 (95% CI 0.12 to 5.20) | Recurrence: 28% (11/40) vs. 16% (5/31), RR 1.71 (95% CI 0.66 to 4.40) | Not reported | Discontinuation of treatment due to adverse effects: 2% (1/40) vs. 21% (8/39), RR 0.12 (95% CI 0.02 to 0.93) Fever: 6% (2/35) vs. 13% (5/39), RR 0.45 (95% CI 0.09 to 2.15) Bladder irritability: 27% (10/37) vs. 53% (20/38), RR 0.51 (95% CI 0.28 to 0.94) Macroscopic hematuria: 9% (3/34) vs. 23% (7/30), RR 0.38 (95% CI 0.11 to 1.33)
BCG Trials | Koga, 2010^205^ Japan Multicenter 2002-2005 | BCG 80 mg (Tokyo strain) within 4 weeks of biopsy or TURBT and repeated weekly for 8 weeks; patients with complete response were randomized to: A. BCG 80 mg (Tokyo strain) within 3 months of randomization followed by instillations at 3, 6, and 9 months B. No BCG | Progression: 0 vs. 1 (4%) | Recurrence: 1 (4%) vs. 7 (26%), p=0.078 | Mortality: 2 (8%) vs. 2 (7%) Died due to bladder cancer: 0 vs. 1 (4%) | Dysuria: 17% vs. not reported
BCG Trials | Lamm, 2000^206^ USA Multicenter 1986-1989 Lerner, 2007^207^ | At least 1 week following TURBT patients received BCG 81 mg (Connaught strain) in 50.5 mL saline and simultaneous percutaneous BCG 0.5 cc (10^7 CFU) to inner thigh weekly for 6 weeks, responders randomized to: A. BCG intravesically and percutaneously 3 successive weekly treatments at 3 months, 6 months and every 6 months to 3 years B. No BCG | | | 5 year survival: 83% vs. 78% | 2 BCG related deaths
BCG Trials | Martinez-Pineiro, 2002^222^ Spain Multicenter 1991-1992 | A: BCG Connaught strain 81 mg, 12 instillations (starting 7 to 14 days after TURBT, once weekly for 6 weeks, then once every 2 weeks for 12 weeks) B: BCG Connaught strain 27 mg, 12 instillation (starting 7 to 14 days after TURBT, once weekly for 6 weeks, then once every 2 weeks for 12 weeks) | Progression: 12% (29/252) vs. 13% (33/247), RR 0.86 (95% CI 0.54 to 1.37) Progression-free survival (B vs. A): HR 1.17 (95% CI 0.71 to 1.93) Cystectomy: 4.8% (12/252) vs. 6.1% (15/247), RR 0.78 (95% CI 0.37 to 1.64) | Recurrence: 28% (71/252) vs. 31% (76/247), RR 0.92 (95% CI 0.70 to 1.20) Disease-free interval (B vs. A): HR 1.09 (95% CI 0.79 to 1.51) | All-cause mortality: 20% (51/252) vs. 22% (55/247), RR 0.93 (95% CI 0.66 to 1.31) Survival time (B vs. A): HR 1.08 (95% CI 0.74 to 1.58) Bladder cancer mortality: 7.9% (20/252) vs. 7.3% (18/247), RR 1.09 (95% CI 0.59 to 2.01) Cancer-free survival (B vs. A): HR 1.25 (95% CI 0.53 to 2.94) | Local side effects: 67% (168/252) vs. 55% (135/247), RR 1.22 (95% CI 1.06 to 1.41) Severe (grade 3 or 4) local side effects: 18% (44/252) vs. 6.5% (16/247), RR 2.70 (95% CI 1.56 to 4.65) Systemic side effects: 32% (80/252) vs. 15% (38/247), RR 2.06 (95% CI 1.46 to 2.91) Severe systemic side effects: 3.6% (9/252) vs. 4.4% (11/247), RR 0.80 (95% CI 0.34 to 1.90) Withdrawal due to side effects: 9.1% (23/252) vs. 4.0% (10/247), RR 2.25 (95% CI 1.10 to 4.64)
BCG Trials | Martinez-Pineiro, 2005^223^ Spain Multicenter 1995-1999 | A: BCG Connaught strain 81 mg, 12 instillations (starting 7 to 14 days after TURBT, once weekly for 6 weeks, then once every 2 weeks for 12 weeks) B: BCG Connaught strain 27 mg, 12 instillation (starting 7 to 14 days after TURBT, once weekly for 6 weeks, then once every 2 weeks for 12 weeks) | Progression: 24% (20/82) vs. 26% (19/73), RR 0.94 (95% CI 0.54 to 1.61) Progression-free survival (B vs. A): HR 1.08 (95% CI 0.58 to 2.03) Cystectomy: 8.4% (7/82) vs. 9.5% (7/73), RR 0.89 (95% CI 0.33 to 2.42) | Recurrence: 39% (32/82) vs. 45% (33/73), RR 0.86 (95% CI 0.60 to 1.25) Disease-free interval (B vs. A): HR 1.23 (95% CI 0.75 to 2.00) Cancer-free survival (B vs. A): HR 1.25 (95% CI 0.53 to 2.94) | All-cause mortality: 29% (24/82) vs. 29% (21/73), RR 1.01 (95% CI 0.62 to 1.67) Bladder cancer mortality: 12% (10/82) vs. 15% (11/73), RR 0.81 (95% CI 0.36 to 1.79) | Local side effects: 70% (57/82) vs. 48% (35/72), RR 1.43 (95% CI 1.08 to 1.89) Severe (grade 3 or 4) local side effects: 20% (16/82) vs. 11% (8/73), RR 1.78 (95% CI 0.81 to 3.92) Systemic side effects: 16% (13/82) vs. 5.5% (4/73), RR 2.89 (95% CI 0.99 to 8.48) Severe systemic side effects: 0% (0/82) vs. 1.4% (1/73), RR 0.30 (95% CI 0.01 to 7.18) Withdrawal due to side effects: 12.2% (10/83) vs. 9.6% (7/73), RR 1.26 (95% CI 0.50 to 3.13)
BCG Trials | Morales, 1992^226^ Canada Single center 1979-1988 | A: Armand Frappier BCG 60 mg weekly for 6 weeks B: Armand Frappier BCG 120 mg weekly for 6 weeks | | Recurrence-free: 37% (18/49) vs. 67% (32/48), RR 0.55 (95% CI 0.36 to 0.84) | | Side effects (not otherwise defined): 12% (6/49) vs. 33% (16/48), RR 0.37 (95% CI 0.16 to 0.86)
BCG Trials | Mukherjee, 1992^208^ UK Single center 1984- unclear end date Kaisary, 1987^238^ | A: BCG Glaxo strain (1.2 × 109 CFU) B: BCG Pasteur strain (1.2 × 109 CFU) 6 weekly instillations, followed by either monthly instillations if there was a complete response or 6-weeks if there was a partial or no response. | At 5 years: Complete response: 5/12 vs. 4/9 Failures: 7/12 vs. 5/9 | At 5-year followup the Pasteur strain group was 1.12 times more likely to be free of disease than the Glaxo group, not statistically significant. | | Most patients complained of hematuria and dysuria
BCG Trials | Oddens, 2013^228^ Europe Multicenter 1997-2005 | A: BCG (OncoTICE strain) 5 × 10^8^ CFU at 1/3 dose, 15 instillations (started within 14 days after TURBT, one weekly for 6 weeks, then 3 weekly instillations at months 3 ,6, and 12) B: BCG full dose, 15 instillations (started within 14 days after TURBT, one weekly for 6 weeks, then 3 weekly instillations at months 3 ,6, and 12) C: BCG at 1/3 dose, 27 instillations (started within 14 days after TURBT, one weekly for 6 weeks, then 3 weekly instillations at months 3 ,6,12, 18, 24, 30, and 36) D: BCG full dose, 27 instillations (started within 14 days after TURBT, one weekly for 6 weeks, then 3 weekly instillations at months 3 ,6,12, 18, 24, 30, and 36) | Progression to ≥T2: 7.6% (26/341) vs. 9.1% (31/339) vs. 8.9% (30/337) vs. 6.5% (22/338) Distant metastasis: 4.4% (15/341) vs. 4.7% (16/339) vs. 5.3% (18/337) vs. 5.3% (18/338) | Recurrence: 49% (168/341) 43% (145/339) vs. 43% (145/337) vs. 39% (131/338) Percent recurrence-free at 5 years: 54% vs. 59% vs. 63% vs. 64% (unable to reject null hypothesis of inferiority of 1/3 dose or 1 year of treatment; >10% decrease was only observed for A vs. D, HR 0.75, 95% CI 0.59 to 0.94); 59% vs. 62% for A or C (1/3 dose) vs. B or D (full dose) (p=0.09); 57% for A or B (1 year maintenance) vs. 63% for C or D (3 years maintenance) (p=0.06) | Mortality: 24% (83/341) vs. 26% (88/339) vs. 30% (101/337) vs. 29% (97/338) Bladder cancer mortality: 3.8% (13/341) vs. 5.9% (20/339) vs. 5.0% (17/337) vs. 5.3% (18/338) | Systemic or local side effects within first year: 7.2% (24/334) vs. 7.0% (23/329) vs. 5.3% (7/323) vs. 5.5% (18/330) Systemic or local side effects after the first year: 0% (0/334) vs. 0% (0/329) vs. 2.8% (9/323) vs. 3.6% (12/330) No differences for A or C vs. B or D, or A or B vs. C or D
BCG Trials | Ojea, 2007^151^ Spain Multicenter 1995-1998 | 14-21 days after transurethral resection with histological confirmation of bladder cancer, patients received 6 weekly instillations then another 6 instillations one every 2 weeks; if a recurrence was diagnosed a further TURBT was performed and the treatment continued A. BCG 27 mg (Connaught strain) B. BCG 13.5 mg (Connaught strain) C. MMC: 30 mg | Progression: 10% (14/142) vs. 13% (18/139), RR 0.76 (95% CI 0.39 to 1.47) Time to progression (B vs. A): HR 1.16 (95% CI 0.57 to 2.34) | Recurrence: 27% (38/142) vs. 36% (50/139), RR 0.74 (95% CI 0.52 to 1.06) Disease-free interval (B vs. A): HR 1.35, (95% CI 0.89 to 2.06), adjusted HR 1.49 (95% CI 0.97 to 2.28) Recurrence rate: 0.58 vs. 0.74 per 100 patient-months | A vs. B All-cause mortality: 9.2% (13/142) vs. 12% (17/139), RR 0.75 (95% CI 0.38 to 1.48) Bladder cancer death: 2.1% (3/142) vs. 3.6% (5/139), RR 0.59 (95% CI 0.14 to 2.41) Cancer-specific survival time (B vs. A): HR 1.60 (95% CI 0.38 to 6.72) | A vs. B Withdrawals due to AE: Not reported Local toxicity 65% vs. 64% Systemic toxicity: 11% vs. 11%
BCG Trials | Pagano, 1995^230^ Bassi, 1992^262^ (Abstract of interim results) Italy Single center 1990 | 6-week course of intravesical therapy: A. Pasteur strain BCG 75 mg B. Pasteur strain BCG 150 mg | | | Disease free survival Ta: no difference between doses (p=0.55) Disease free survival CIS: favors the low dose group (p<0.001) Disease free survival T1: number of patients enrolled to date does not allow a statistical conclusion (p=0.07) | Withdrawals due to AE: Not reported Fever: 18 vs. 33, p<0.05 Cystitis: 32 vs. 57, p<0.05 Macroscopic hematuria: 13 vs. 26, p<0.05
BCG Trials | Palou, 2001^209^ Spain, England Multicenter 1989-1995 | Initial treatment with 6 weekly instillations of BCG 81 mg (Connaught strain); if relapse then 6 additional weekly instillations; if disease free then randomized to: A. BCG 81 mg (Connaught) 6 weekly instillations every 6 months for 2 years B. No further treatment | Progression: 3 vs. 2 | Tumor-free: 53 vs. 46 Superficial relapse: 10 (15%) vs. 16 (26%), p=0.07 | Mortality: 11 vs. 8 Died of bladder cancer: 3 vs. 2 | Discontinued instillations due to side effects: 32 in BCG maintenance group; number in control group not reported
BCG Trials | Rentsch, 2014^210^ Switzerland Single center 1998-2010 | A: BCG Connaught (6.6-19.2 × 108 CFU) B: BCG Tice (2-8 × 108 CFU) 6 weekly intravesical instillations | 5- year progression-free survival: 94.1% (95% CI 87.8-100%) vs. 87.9 (95% CI 76.5-100), p=0.3442 | 5- year recurrence-free survival: 74% (95% CI 39.1-63.3 months) vs. 48% (95% CI 35.5-65.1 months), p=0.0108 | Overall survival: 84.9% (95% CI 75.5-95.5) vs. 93.6 (95% CI 85.2-100), p=0.2652 Disease-specific survival: 93% (95% CI 86.5-100) vs. 100% (100-100), no p-value reported | Side effects caused by BCG: 20/71 vs. 25/60, p=0.09
BCG Trials | Sengiku, 2013^233^ Japan Single center 2004-2012 | At least 2 weeks after removing as much of visible lesion as possible by TURBT, patients received weekly up to 8 times: A. BCG 80 mg (Tokyo strain) in 40 mL saline B. BCG 81 mg (Connaught strain) in 40 mL saline | | Percent recurrence-free: 73% vs. 69% at 2 years, 62% vs. 56% at 5 years (p=0.75) | | Withdrawals due to AE: 7 (8%) vs. 9 (10%) Fever AE or complication events: 12 vs. 10 Cystitis AE or complication events: 33 vs. 28 Hematuria AE or complication events: 8 vs. 12
BCG Trials | Witjes, 1993^148^ Witjes, 1996^156^ Vegt, 1995^211^ The Netherlands Multicenter 1987-1990 | A. MMC 30 mg in 50 mL saline once a week for 4 weeks and thereafter once a month for 5 months. If a superficial recurrence or persistent CIS after 6 months, 3 additional monthly instillations given B. BCG-Tice C. BCG RIVM BCG 5×108 bacilli in 50 mL saline, administered once a week for 6 weeks. At the time of first superficial recurrence or persistent CIS at 3 or 6 months, a second 6 week course with BCG instillations was given after complete TURBT or biopsy. | Progression: 5% (7) vs. 6% (8) | B vs. C % Recurrence-free, all papillary tumors 1 year: 68% vs. 69% 2 year: 54% vs. 62% 5 year: 36% vs. 54% (log-rank, p=0.07) Recurrence: 64% (75/117) vs. 46% (62/134), RR 1.39 (95% CI 1.10 to 1.74) | | B vs. C Drug-induced cystitis: 30% (42/140) vs. 32% (48/149) Drug-induced cystitis requiring treatment delay or discontinuation: 1.4% (2/140) vs. 2.0% (3/149) Systemic side-effects: 27% (38/140) vs. 18% (27/149) Systemic side-effects requiring treatment delay or discontinuation: 4.3% (6/140) vs. 2.0% (3/149) Withdrawals due to AE: 14 (total across 3 arms) Intercurrent death=10 (total across 3 arms)
MMC Trials | Au, 2001^197^ USA, Europe, and Canada Multicenter 1992-2000 | A: MMC 40 mg/20 mL sterile water, 6 instillations (once weekly for 6 weeks), optimized by instruction to refrain from fluids for 8 hour prior to and during instillations, oral doses of 1.3 g sodium bicarbonate the night before, Foley to empty bladder prior to instillation for post void residual <10 mL B: MMC 20 mg/20 mL sterile water, 6 instillations (once weekly for 6 weeks), without additional optimization measures | | Percent recurrence-free at 5 years: 41% vs. 25% Recurrences: 51% (61/119) vs. 66% (73/111), RR 0.78 (95% CI 0.63 to 0.97) Time to recurrence (median, months): 29 vs. 12 (p=0.005) | | Discontinuation of treatment due to adverse events: 1.8% vs. 1.9% Dysuria: 33% vs. 18%, RR 1.86 (95% CI 1.15 to 3.02) Cystitis: 23% vs. 16%, RR 1.46 (95% CI 0.84 to 2.53) Urinary frequency: 24% vs. 31% Urinary urgency: 22% vs. 26% Hematuria: 26% vs. 23% Fever: 3.6% vs. 4.7% Fatigue: 18% vs. 19% Nausea: 10% vs. 8.5%
MMC Trials | Colombo, 2012^213^ Italy Single center 2010-2011 | A: Mitomycin C (MMC), 40 mg (in 40 mL saline) three instillations per week for 2 weeks, prior to TURBT B: Mitomycin C (MMC), 40 mg (in 40 mL saline) one instillation per week for 6 weeks, prior to TURBT | Complete response (absence of residual tumor on histology): 70% (19/27) vs. 44% (12/27), RR 1.58 (95% CI 0.97 to 2.58) Progession: 0% (0/27) vs. 0% (0/27) | | | Grade 3 or 4 systemic toxicity or discontinuation due to systemic toxicity: No cases Urinary frequency: 69% vs. 67% Chemical cystitis: 42% vs. 47% Urinary incontinence: 15% vs. 27% Hematuria: 31% vs. 52% Lower urinary tract pain: 38% vs. 29%
MMC Trials | Ersoy, 2013^198^ Turkey Single center 2006- 2010 | A: MMC, 40 mg (in 40 mL sterile saline) intravesical; infusion within 6 hours of TURBT; MMC retained in bladder for 2 hours. B: Urinary alkalinization prior to MMC instillation: Sodium bicarbonate, 1.3 g, orally × 3 doses (night before TURBT, morning of TURBT, 30 minutes prior to MMC). MMC, 40 mg (in 40 mL sterile saline) intravesical; infusion within 6 hours of TURBT; MMC retained in bladder for 2 hours. C: No drugs given in the first 6 hours after TURBT. | | A vs. B Recurrence free at 1 year: 100% vs. 86.7%, p=0.132 Recurrence free at 3 years: 100% vs. 79.4%, p=0.132 Recurrence free at 5 years: 100% vs. 79.4%, p=0.173 Mean time to recurrence, months (95% CI): not reported vs. 34.8 (28.5-41.1) | | Not reported
MMC Trials | Friedrich, 2007^154^ Germany Multicenter 1995-2002 | A. MMC 20 mg, 6 weekly instillations B. BCG RIVM 2 × 10^8 CFU, 6 weekly instillations C. MMC 20 md, 6 weekly instillations followed by monthly instillations of MMC 20 mg for 3 years | | A vs. C Recurrence: 26% (46/179) vs10% (16/153), RR 2.5 (95% CI 1.5 to 4.2) Percent recurrence-free at 2 years: 71% (126/179) vs. 88% (135/153) Percent recurrence-free at 3 years:69% (123/179) vs. 86% (132/153) (log-rank test, p=0.0006) Recurrence-free interval: Adjusted HR 0.38 (95% CI 0.21 to 0.69) for C vs. A after adjustment for facility, primary/recurrent, stage/grade | | Withdrawals due to AE: 0 vs. 3 vs. 8 Dysuria: 12% vs. 20% Hematuria: 1% vs. 9% Fever: 2% vs. 2%
MMC Trials | Fukui, 1992^202^ Japan Single center 1986-1989 | A: MMC 20 mg (in 20 mL saline) on day 1 and adriamycin 40 mg (in 20 mL saline) on day 2 for 5 weeks, followed by maintenance therapy once monthly for 12 months B: MMC 20 mg (in 20 mL saline) on day 1 and adriamycin 40 mg (in 20 mL saline) on day 2 for 5 weeks, No maintenance therapy | Progression: 12% (3/25) vs. 3.8% (1/26), RR 3.12 (95% CI 0.35 to 28.0) Progression, according to stage: Ta or Ta: 0% (0/13) vs. 0% (0/15) Tis: 25% (3/12) vs. 9.1% (1/11) | Recurrence: 36% (9/25) vs. 65% (17/26), RR 0.55 (95% CI 0.30 to 1.0) Nonrecurrence, according to stage: Ta or T1: 59% vs. 38% (p>0.05) Tis: 73% vs. 24% (p<0.05) Recurrence, according to stage: Ta or T1: 38% (5/13) vs. 60% (9/15) Tis: 33% (4/12) vs. 73% (8/11)
MMC Trials | Huland, 1990^191^ Germany Multicenter 1983 - 1985 | A: MMC, 20 mg/20 mL. Total 42 instillations. Every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. B: MMC, 20 mg/20 mL. Total 42 instillations. Every week × 8 weeks, then every 4 weeks for rest of 1st year and 2 additional years. C: MMC, 20 mg/20 mL. Total 20 instillations. Every week × 20 weeks. D: Doxorubicin, 50 mg/50 mL. Total 42 instillations. Every 2 weeks × 1 year, then every 4 weeks × 1 year, then every 3 months × 1 year. For all groups: Instillations started 4 to 6 weeks after discharge from hospital. | Progression of stage: 2.9% (6/209) vs. 1.0% (1/96) vs. 5.3% (4/75) Progression of grade: 1.9% (4/209) vs. 1.0% (1/96) vs. 4.0% (3/75) | A vs. B vs. C Recurrence: 15.3% (32/209) vs. 9.4% (9/96) vs. 17.3% (13/75) Recurrence per 100 patient-months: 0.68 vs. 0.49 vs. 0.65 | | A vs. B vs. C Chemical cystitis: 25% vs. 12% vs. 18% Allergy: 2% vs. 2% vs. 1% Other: 6% vs. 4% vs. 10% Total: 33% vs. 18% vs. 29%
MMC Trials | Schwaibold, 1997^232^ Germany Single center 1983-1987 | A: MMC 20 mg/20 mL saline, 42 instillations (every 2 weeks for 1 year, every 4 weeks for 1 year, every 3 months for 1 year) B: MMC 20 mg/20 mL saline, 42 instillation (every week for 8 weeks, every 4 weeks for 44 weeks and 2 additional years) C: MMC 20 mg/20 mL saline, 20 instillations (every week for 20 weeks) D: Doxorubicin 50 mg/50 mL saline, 42 instillations (same schedule as A) | Progression: 12% (24/209) vs. 5.2% (5/96) vs. 6.7% (5/75) vs. 18% (7/39) (p=0.01 for overall treatment effect in Cox proportional hazards model adjusted for number of prior recurrences, grade/Tis, recurrent cancer); RR for B vs. A 0.06, 95% CI 0.01 to 0.51 | A vs. B vs. C vs. D Recurrence: 24% (51/209) vs. 18% (17/96) vs. 20% (15/75) vs. 31% (12/39) (p=0.21 for overall treatment effect in Cox proportional hazards model adjusted for number of prior recurrences, and grade/Tis); RR for B vs. A 0.53, 95% CI 0.29 to 0.96) | | Not reported
MMC Trials | Tolley, 1996^118^ United Kingdom Multicenter 1984 - 1986 | A: MMC 20 mg/20 mL saline, 42 instillations (every 2 weeks for 1 year, every 4 weeks for 1 year, every 3 months for 1 year) B: MMC 2 mg/20 mL; saline, 42 instillation (every week for 8 weeks, every 4 weeks for 44 weeks and 2 additional years) C: MMC 20 mg/20 mL saline, 20 instillations (every week for 20 weeks) D: Doxorubicin 50 mg/50 mL saline, 42 instillations (same schedule as A) | Progression-free interval, group comparisons, HR 0.97 (95% CI 0.46 to 2.06) | A vs. B Recurrence at 24 months: 42% vs. 31% (p=0.14) Recurrence-free interval, group comparisons, HR 0.74 (95% CI 0.51 to 1.06) | All-cause mortality: 33.6% (50/149) vs. 42.5% (62/146), RR 0.79 (95% CI 0.59 to 1.1) Bladder cancer mortality: 5.4% (8/149) vs. 5.5% (8/146), RR 0.98 (95% CI 0.38 to 2.5) | A vs. B (none reported for C) Dysuria and frequency: 0% (0/149) vs. 6.2% (9/146), RR 0.05 (95% CI 0.003 to 0.88) Delayed healing of biopsy site: 0.7% (1/149) vs. 4.1% (6/146) Chemical cystitis was not reported as a side effect by any patient in either group.
Doxorubicin Trials | Akaza, 1987^112^ Japan Unclear if single or multicenter 1982-1985 | A: Doxorubicin, 30 mg (in 30 mL saline). B: Doxorubicin, 20 mg (in 40 mL saline). C: MMC: 20 mg (in 40 mL saline). D: No adjuvant treatment. TURBT alone. For A, B, and C: First instillation within 1 week of TURBT. Once weekly × 2 weeks, then once every 2 weeks × 14 week, then once monthly × 8 months, then once every 3 month × 1 year (Total: 21 doses over 2 years) | Progression (in stage, grade, or both): 43.2% (19/44) vs. 31.0% (13/42) vs. 26.8% (11/41) vs. 38.7% (12/31); RR 1.40 (95% CI 0.79 to 2.45) for A vs. B | A vs. B vs. C vs. D Recurrence-free survival rate at 1 year: 74.8% vs. 75.0 vs. 76.3% vs. 66.7% Recurrence-free survival rate at 2 years: 62.3% vs. 59.1 vs. 62.3% vs. 51.8% Recurrence-free survival at 1260 days, generalized Wilcoxon test: A>D, p<0.05 B>D, p<0.05 C>D, p<0.05 Long-term (median, 6.6 years) followup in subgroup of 158 patients Recurrence/year (number of recurrences/total observation period: 0.473 vs. 0.512 vs. 0.472 vs. 0.510 | | A vs. B vs. C (not reported for group D) Pollakiuria: 16% vs. 18.7% vs. 23.8% Dysuria: 25.6% vs. 25.2% vs. 27.0% Hematuria: 13.6% vs. 7.3% vs. 11.1% Pyuria: 10.4% vs. 10.6% vs. 19.8% “No significant systemic side effects” A vs. B vs. C (not reported for group D) Pollakiuria: 16% vs. 18.7% vs. 23.8% Dysuria: 25.6% vs. 25.2% vs. 27.0% Hematuria: 13.6% vs. 7.3% vs. 11.1% Pyuria: 10.4% vs. 10.6% vs. 19.8% “No significant systemic side effects”
Doxorubicin Trials | Flamm, 1990^214^ Austria Single center 1979-1981 | A: Doxorubicin 50 mg/50 mL saline weekly for 6 weeks, then monthly for 2 years B: Doxorubicin 50 mg/50 mL saline weekly for 6 weeks | Progression: 19% (13/70) vs. 20% (15/76), RR 0.94 (95% CI 0.48 to 1.8) | Recurrence: 47% (33/70) vs. 42% (32/76), RR 1.1 (95% CI 0.78 to 1.6) Time to first recurrence (months): 16 vs. 13 (p=0.78) Recurrence rate: 1.7 vs. 1.4 per 100 patient-months (p>0.1) | All-cause mortality: 21% (15/70) vs. 24% (18/76), RR 0.90 (95% CI 0.49 to 1.7) Bladder cancer mortality: 13% (9/70) vs. 13% (10/76), RR 0.95 (95% CI 0.41 to 2.2) | Chemical cystitis: 12.8% vs. 11.8%
Doxorubicin Trials | Matsumura, 1992^123^ Japan Multicenter 1987-1989 | A: Doxorubicin 20 mg/40 mL saline, 21 instillations (following TURBT, once weekly for 2 weeks, then every 2 weeks for 14 weeks, once monthly for 8 months, and once every three months for 1 year) B: Doxorubicin 20 mg/40 mL saline, 6 instillations (over 2 weeks prior to TURBT) C: No doxorubicin | | Percent recurrence-free at 1 year: 63.8% vs. 49.0% (p>0.05 for A vs. B) Percent recurrence-free at 2 years: 38.2% vs. 18.8% (p<0.05 for A vs. B) | | A vs. B Urinary frequency: 10.3% (13/126) vs. 17.3% (13/75) Pain on urination: 10.3% (13/126) vs. 12.0% (9/75) Dysuria: 3.2% (4/126) vs. 4.0% (3/75) Hematuria: 4.0% (5/126) vs. 8.0% (6/75) Pyuria: 4.0% (5/126) vs. 9.3% (7/75)
Doxorubicin Trials | Niijima, 1983^116^ Japan Multicenter 1980 – 1985 | A: Doxorubicin, 30 mg (in 30 mL saline). B: Doxorubicin, 20 mg (in 40 mL saline). C: MMC: 20 mg (in 40 mL saline). D: No adjuvant treatment. TURBT alone. For A, B, and C: First instillation within 1 week of TURBT. Twice weekly × 4 weeks (Total: 8 doses) | | Primary tumor: Recurrence-free survival rate at 1 year (A vs. B vs. C vs. D): 73.1% vs. 76.6% vs. 84.0% vs. 70% Recurrence-free survival at 1800 days, generalized Wilcoxon test: B>D, p<0.05 C>D, p<0.01 Comparisons not reported for other treatment group comparisons. Recurrent tumor: Recurrence-free survival at 1800 days, generalized Wilcoxon test: A>D; B>D; C>D; differences reported as nonsignificant, no p - values reported. | | A vs. B vs. C (not reported for group D) Pollakiuria: 33.8% vs. 28.3% vs. 33.1% Dysuria: 36.9% vs. 27.5% vs. 27.4% Hematuria: 20.0% vs. 11.6% vs. 9.7% Pyuria: 23.8% vs. 19.6% vs. 8.9% “No significant systemic side effects”
Doxorubicin Trials | Rubben, 1988^231^ Germany Single center 1979-1981 | A: Doxorubicin 50 mg/50 mL saline, 13 instillations (2 hours prior to TURBT, then twice weekly for 6 weeks) B: Doxorubicin 50 mg/50 mL saline, 28 instillations (2 hours prior to TURBT, then twice weekly for 6 weeks, twice monthly for 4.5 months, once monthly for 6 months) C: No intravesical therapy | | Recurrence rate (per 100 patient-months) (p>0.05 in all subgroups) Primary: 2.5 vs. 2.4 vs. 2.3 Recurrent: 2.6 vs. 2.8 vs. 3.9 Solitary: 1.8 vs. 3.0 vs. 2.0 Multiple: 3.6 vs. 3.6 vs. 4.6 <3 cm: 1.9 vs. 3.4 vs. 2.9 >3 cm: 2.7 vs. 2.9 vs. 2.6 Tis negative: 2.3 vs. 3.1 vs. 2.2 Tis positive: 3.2 vs. 3.2 vs. 4.4 | | Systemic side effects: None observed Local side effects resulting in incomplete treatment: 11% vs. 33% vs. 11%
Doxorubicin Trials | Ueda, 1992^236^ Japan Multicenter 1984-1986 | A: Doxorubicin 30 mg/30 mL saline, 19 instillations (immediately and 2 days after TURBT, then weekly for 2 weeks, every 2 weeks for 14 weeks, monthly for 8 months) B: Doxorubicin 30 mg/30 mL saline, 19 instillations (immediately and 2 days after TURBT, then weekly for 2 weeks, every 2 weeks for 14 weeks, monthly for 8 months) plus 5-fluorouracil 200 mg/day starting at 1 week C: Doxorubicin 30 mg/30 mL saline, 17 instillations (starting 7 days after TURBT weekly for 2 weeks, every 2 weeks for 14 weeks, monthly for 8 months) | | | Percent recurrence-free at 36 months: 79.4% vs. 73.7% vs. 67.6% vs. 63.1% (NS); 76.4% vs. 65.4% for A + B vs. C +D (p>0.05) | Bladder irritation: 48% (24/50) vs. 55% (30/55) vs. 26% (15/58) vs. 26% (16/61) Bladder irritation resulting in withdrawal: 8% (4/50) vs. 5% (3/55) vs. 2% (1/58) vs. 3% (2/61) Hematuria and bladder calculi: 0 vs. 0 vs. 0 vs. 2% (1/61)
Epirubicin Trials | Ali-El-Dein, 1997^119^ (J Urol) Egypt Single center 1991 - 1995 | A: Epirubicin, 50 mg (in 50 mL normal saline). B: Epirubicin, 80 mg (in 50 mL normal saline). C: Doxorubicin, 50 mg (in 50 mL normal saline). D: No adjuvant treatment. TURBT alone. For Groups A - C: First instillation 7 to 14 days after TURBT. Retained intravesically for 2 hours; Instillations once a week × 8 weeks, then once monthly to complete 1 year of treatment. | Progression: 10.9% (7/64) vs. 4.4% (3/68), RR 2.5 (95% CI 0.67 to 9.2) Mean interval to progression, months (95% CI): 31 (22-40) vs. 31 (18-44) | A vs. B Recurrence: 25.0% (16/64) vs. 17.6% (12/68), RR 1.42 (95% CI 0.73 to 2.76) Mean time to first recurrence, months (95% CI): 16 (12.2-19.8) vs. 15.4 (11.4-19.4). Recurrence rate per 100 patient-months: 0.83 vs. 0.60, p<0.05. | | A vs. B vs. C (No data for group D) Any adverse event: 15.6% (10/64) vs. 23.5% (16/68) Adverse events per Number of instillations: 7.3% (88/1199) vs. 8.7% (111/1280) Systemic toxicity: 0.0% (0/10) vs. 0.0% (0/16) Mild toxicity: 50.0% (5/10) vs. 68.8% (11/16) Severe toxicity (i.e., requiring permanent or temporary discontinuation of treatment): 20.0% (2/10) vs. 12.5% (2/16) Contracted bladder: 10.0% (1/10) vs. 6.3% (1/16) Hematuria: 10.0% (1/10) vs. 12.5% (2/16) UTI: 10.0% (1/10) vs. 0.0% (0/16)
Epirubicin Trials | Ali-El-Dein, 1997^126^ (British J Urol) Egypt Single center 1992 - 1996 | A: Epirubicin, 50 mg (in 50 mL normal saline); Single instillation immediately after TURBT. Retained intravesically for 2 hours. B: Epirubicin, 50 mg (in 50 mL normal saline); Initial instillation 1 - 2 weeks after TURBT. Retained intravesically for 2 hours; Then, instillations once a week × 7, then once monthly × 10 to complete 1 year of treatment. C: No adjuvant treatment. TURBT alone. | Progression: 5.5% (3/55) vs. 3.4% (2/59) | A vs. B Recurrence: 23.6% (13/55) vs. 25.4% (15/59), p=0.8. Mean interval to first recurrence, months: 16 vs. 18 Recurrence rate per 100 patient-months: 0.79 vs. 0.84 | | A vs. B Any adverse event: 21.8% (12/55) vs. 25.4% (15/59), p=0.8. Mild toxicity: 75.0% (9/12) vs. 66.7% (10/15) , p=0.8. Severe toxicity (i.e., requiring permanent or temporary discontinuation of treatment): 25.0% (3/12) vs. 33.3% (5/15) , p=0.7. Contracted bladder: 0.0% (0/12) vs. 6.7% (1/15) Hematuria: 16.7% (2/12) vs. 20.0% (3/15) UTI: 8.3% (1/12) vs. 6.7% (1/15) No patients with systemic toxicity.
Epirubicin Trials | Hendricksen, 2008^216^ the Netherlands Multicenter 1998-2004 | A. Epirubicin 50 mg/50 mL saline, 9 instillations over 6 months (once weekly for 4 weeks started within 2 weeks of TURBT, then once monthly for 5 months) B. Epirubicin 50 mg/50 mL saline, 10 instillations over 6 months (within 48 hours of TURBT, once weekly for 4 weeks starting within 2 weeks of TURBT, once monthly for 5 months) C: Epirubicin 50 mg/50 mL saline, 11 instillations over 12 months (once weekly for 4 weeks starting within 2 weeks of TURBT, once monthly for 5 months, once every three months for 6 months) | % progression-free at 5 years: 90.0% vs. 87.7% vs, 88.2% (p=0.593, log-rank) | Percent recurrence-free at 5 years: 44.4% vs. 42.7% vs. 45.0% (p=0.712, log-rank) | | Therapy stopped or delayed due to side effects: 15% (39/266) vs. 22% (62/286) vs. 22% (61/277) Chemical cystitis: 32% (84/266) vs. 33% (95/286) vs. 24% (66/277) Hematuria: 13% (36/266) vs. 19% (54/286) vs. 11% (30/277) Systemic side effects: 13% (35/266) vs. 14% (40/286) vs. 14% (37/277)
Epirubicin Trials | Koga, 2004^219^ Japan Multicenter 1993-1995 | A: Epirubicin 30 mg/30 mL saline 19 times (within 24 hours of TURBT, then 2-3 days, 1 week, and 2 weeks after TURBT, then once every 2 weeks for 12 weeks, then once a month for 9 months) B: Epirubicin 30 mg/30 mL saline 9 times (within 24 hours of TURBT, then 2-3 days, 1 week, and 2 weeks after TURBT, then once every 2 weeks for 10 weeks) | | Percent recurrence-free at 3 years: 85.2% vs. 63.9% (p=0.005) Recurrence: 13.0% (10/77) vs. 31.5% (23/77); unadjusted HR 0.39 (0.18 to 0.82), adjusted HR 0.36 (0.17 to 0.78) (adjusted for multiplicity and tumor stage) | | Severe local toxicity: 5.2% (4/77) vs. 8.2% (6/73), RR 0.63 (95% CI 0.19 to 2.15) Discontinuation due to pain: 1.3% (1/77) vs. 0% (0/73) Systemic toxicity (fatigue, low grade fever): 0% (0/77) vs. 2.7% (2/73) Macrohematuria (mild, moderate, severe): 30% (23/77) vs. 16% (12/73) Dysuria (mild, moderate, severe): 38% (29/77) vs. 37% (27/73) Frequency (mild, moderate, severe): 32% (25/77) vs. 30% (22/73)
Epirubicin Trials | Kuroda, 2004^220^ Japan Multicenter 1994-1996 | A. Epirubicin 20 mg/40 mL saline, 17 instillations over 12 months (starting about 7 days after TURBT, once weekly for 2 weeks, once every other week for 14 weeks, once a month for 8 months) B: Epirubicin 30 mg/40 mL saline, 12 instillations over 12 months (starting about 7 days after TURBT, once weekly for 2 weeks, once every other week for 14 weeks, once a month for 3 months) C: Epirubicin 40 mg/40 mL saline, 9 instillations over 4 months (starting about 7 days after TURBT, once weekly for 2 weeks, once every other week for 14 weeks) | | Percent recurrence-free at 1 year: 67% vs. 73% vs. 74% Percent recurrence-free at 2 years: 49% vs. 55% vs. 60% Percent recurrence-free at 4 years: 36% vs. 46% vs. 44% Time to recurrence (median, days): 688 vs. 1007 vs. 1186 (p=0.04 for dose-response) | Mortality: 5.4% (11/205) vs. 6.4% (13/204) vs. 8.8% (18/205); RR 0.84 (95% CI 0.39 to 1.8) for A vs. B, RR 0.61 (95% CI 0.30 to 1.3) for A vs. C, and RR 0.73 (95% CI 0.37 to 1.4) for B vs. C Bladder cancer mortality: 1.5% (3/205) vs. 1.5% (3/204) vs. 2.4% (5/205), RR 1.0 (95% CI 0.20 to 4.9) for A vs. B, 0.60 (95% CI 0.15 to 2.5) for A vs. C, and RR 0.60 (95% CI 0.15 to 2.5) for B vs. C | Frequency (mild, moderate, severe): 22% vs. 35% vs. 29% Pain on urination (mild, moderate, severe): 21% vs. 32% Vs. 30% Dysuria (mild, moderate, severe): 12% vs. 17% vs. 15% Hematuria (mild, moderate, severe): 19% vs. 25% vs. 20%
Epirubicin Trials | Liu, 2006^192^ China Unclear if single or multicenter 1997 - 1998 | A: Epirubicin, 80 mg (in 40 mL normal saline). Single intravesical instillation within 6 hours of TURBT. B: Epirubicin, 40 mg, intravesical instillation every week for 6 ∼ 8 weeks, then every month for 10 months. C: MMC, 40 mg, intravesical instillation every week for 6 ∼ 8 weeks, then every month for 10 months. | | A vs. B Tumor-free survival at 1 year: 100% (14/14) vs. 86.7% (13/15), RR 1.15 (95% CI 0.91 to 1.44) Tumor-free survival at 2 years: 85.7% (12/14) vs. 80.0% (12/15), RR 1.07 (95% CI 0.77 to 1.49) Tumor-free survival at 3 years: 71.4% (10/14) vs. 73.3% (11/15), RR 0.89 (95% CI 0.59 to 1.35) Tumor-free survival at 5 years: 64.3% (9/14) vs. 66.7% (10/15), RR 0.96 (95% CI 0.57 to 1.64) Mean interval to recurrence, months: 8 vs. 4 vs. 5 Recurrence rate: 35.7% (5/14) vs. 33.3% (5/15), RR 1.07 (95% CI 0.39 to 2.92) | | A vs. B Any side effect: 13.6% vs. 53.3% Dysuria or urinary frequency/urgency: 6.3% (1/16) vs. 13.3% (2/15) Stricture of urethra: 0% (0/16) vs. 6.7% (1/15) No systemic adverse events
Epirubicin Trials | Masters, 1999^224^ UK Multicenter 1991-1993 | A: Epirubicin 50 mg/50 mL saline, 5 instillations (starting 10-14 days after TURBT, every 3 months for 12 months) B: Epirubicin 100 mg/50 mL saline, 5 instillations (starting 10-14 days after TURBT, every 3 months for 12 months) First 102 patients had a marker tumor left after initial TURBT (0.5 cm) | | Recurrence: 44% (27/61) vs. 56% (34/61), HR 0.68 (95% CI 0.41 to 1.13) Recurrence rate: 0.52 vs. 0.58 per patient-year, RR 0.90 (0.58 to 1.52) | | UTI: 31% (19/61) vs. 21% (13/61), RR 1.46 (95% CI 0.79 to 2.69) Bladder spasm: 15% (9/61) vs. 44% (27/61), RR 0.33 (95% CI 0.17 to 0.65) Withdrawal or incomplete therapy due to adverse events: 11% (7/61) vs. 23% (14/61), RR 0.50 (95% CI 0.22 to 1.15)
Epirubicin Trials | Mitsumori, 2004^225^ Japan Multicenter 1998-2001 | A: Epirubicin 30 mg/40 mL saline, 6 instillations (starting 1 week after TURBT once every 2 weeks for 12 weeks, total 180 mg) B: Epirubicin 30 mg/40 mL saline, 6 instillations (3 instillations within first 5-7 days after TURBT, then once every 2 weeks for 6 weeks, total 180 mg) C: Epirubicin 30 mg/40 mL saline, 12 instillations (starting 1 week after TURBT, once weekly for 12 weeks, total 360 mg) D: Epirubicin 30 mg/40 mL saline, 12 instillations (3 instillations within first 5-7 days after TURBT, then once weekly for 9 weeks, total 360 mg) | | Recurrence rates A vs. B vs. C vs. D: 30% (6/20) vs. 25% (6/24) vs. 8.3% (1/12) vs. 0% (0/10) at 6 months, 50% (10/20) vs. 35% (8/23) vs. 45% (4/9) vs. 12% (1/8) at 12 months (p=0.04 for A vs. D with log-rank test, otherwise p>0.05) A or B (180 mg) vs. C or D (360 mg): 27% (12/44) vs. 5% (1/22) at 6 months; 42% (18/43) vs. 29% (5/17) at 12 months (p=0.01, log-rank test) A or C (starting 1 week after TURBT) vs. B or D (early instillations): 22% (7/32) vs. 18% (6/34) at 6 months; 48% (14/29) vs. 29% (9/31) at 12 months (p=0.36, log-rank test) In multivariate regression, total dose (180 vs. 360 mg, AOR 0.32, 95% CI 0.11 to 0.92) and urine cytology (I-II vs. III-IVAOR 3.11, 95% CI 1.08 to 8.94) independent predictors for local recurrence; delayed vs. early not significant (AOR 0.91, 95% CI 0.37 to 2.23) | | Side effects (irritated bladder, UTI, or hematuria): 23% (5/22) vs. 24% (6/25) vs. 25% (3/12) vs. 40% (4/10) (P>0.05)
Epirubicin Trials | Nomata, 2002^227^ Japan Multicenter 1995-1998 | A. Epirubicin 30 mg/30 mL saline 19 times over 1 year (once weekly for 4 weeks, then every 2 weeks for 4 months) B. Epirubicin 30 mg/30 mL saline 12 times over 5 months (once weekly for 4 weeks, then every 2 weeks for 4 months, then once per month for 7 months) | | Percent recurrence-free at 3 years: 48.5% vs. 55.1% (p>0.05) | | Urinary frequency (grade 1-3): 33% (18/55) vs. 20% (11/55) Dysuria (grade 1-3): 31% (17/55) vs. 21% (15/70) Macroscopic hematuria (grade 1-3): 42% (23/55) vs. 36% (25/70)
Epirubicin Trials | Okamura, 1998^229^ Japan Multicenter 1991-1993 | A: Epirubicin 40 mg/40 mL saline 17 times (within 24 hours of TURBT, during first week, once weekly for 4 weeks, then once monthly for 11 months) B: Epirubicin 40 mg/40 mL saline 6 times (within 24 hours of TURBT, during first week, then once weekly for 4 weeks) | % disease progression at 3 years: 2.9% (2/69) vs. 1.4% (1/69) | Percent recurrence-free at 3 years: 75.1% vs. 77.2% (p=0.62) Time to first recurrence (mean, months): 36.0 vs. 36.9 | | Dysuria: 7.2% overall Macroscopic hematuria: 0.7% overall Withdrawal due to adverse events: 1.4% (2/138) Local toxicity: No difference between groups
Epirubicin Trials | Saika, 2010^134^ Japan Multicenter 1995 - 2001 | A. Epirubicin, 20 mg (in 40 mL physiological saline). Two intravesical infusions, one immediately after (<1 hour) TURBT and one in the early morning of the following day, retained in bladder for 1 hour. B. Epirubicin, 50 mg (in 100 mL physiological saline). Same procedure as A. C. No adjuvant therapy. TURBT only. | Progression: 0.0% (0/83) vs. 1.1% (1/90), RR 0.36 (95% CI 0.01 to 8.74) | A vs. B Median recurrence-free survival, months: 24 vs. 38 (p>0.05) | | A vs. B Bladder Grade 1 irritabilities (e.g., micturition pain and/or frequency): 22.9% vs. 35.6%; p=0.106 Grade 1 anemia: 2.4% (2/83) vs.2.2% (2/90) Grade 1 serum transaminases elevation: 1.2% (1/83) vs. 3.3% (3/90) Grade 1 leukopenia: 0.0% (0/83) vs.1.1% (1/90)
Epirubicin Trials | Serretta, 2010^234^ Italy Multicenter 2002-2003 | A: Epirubicin 80 mg/50 mL saline, 16 instillations (within 6 hours of TURBT, then once weekly for 5 weeks, once weekly for 10 months) B: Epirubicin 80 mg/50 mL saline, 6 instillations (within 6 hours of TURBT, then once weekly for 5 weeks) | Progression to muscle-invasive: 2.9% (7/245) vs. 1.3% (3/237) | Percent recurrence-free at 3 months: 98.4% (182/185) vs. 94.8% (199/210) (p=0.06) Percent recurrence-free at 6 months: 95.1% (174/183) vs. 87.3% (157/180) (p=0.004) Percent recurrence-free at 12 months: 86.7% (143/165) vs. 79.1% (136/172) (p=0.03) Percent recurrence-free at 18 months: 77.8% (105/135) vs. 68.1% (98/144) (p=0.03) Percent recurrence-free at 24 months: 70.2% (87/124) vs. 63.0% (85/135) (p=0.11) Percent recurrence-free at 36 months: 62.1% (72/116) vs. 54.4% (69/127) (p=0.11) Percent recurrence-free at 48 months: 50.5% (48/95) vs. 45.9% (51/111) (p=0.26) Time to recurrence (median, months): 17 vs. 12 (p=0.10) | | Serious adverse events: 0.2% overall Chemical cystitis with discontinuation of treatments: 0.4% overall Fever: 2.2% overall Dysuria and urgency resulting in treatment interruption: 7.1% overall Hematuria: 2.9% overall Treatment postponement: 15.7% overall
Epirubicin Trials | Turkeri, 2010^235^ Turkey Multicenter 2002-2004 | A: Epirubicin 100 mg within 6 hours after TURBT B: Epirubicin 100 mg within 6 hours and 12-hours after TURBT | Progression: 1.5% (1/68) vs. 4.0% (3/75), RR 0.37 (95% CI 0.04 to 3.45) | Recurrence rates: 14.7% vs. 21.3%, adjusted HR 0.67 (95% CI 0.30 to 1.51) (adjusted for grade, stage, solitary vs. multiple, age <70 vs. ≥70 years) | Recurrence-free survival (months): 10.3 vs. 10.5 months (p=0.47, log-rank) Disease-free survival (months): 14.9 vs. 15.5 months | Not reported
Gemcitabine Trials | Gardmark, 2007^157^ Japan Single center 1986-1989 | A: Gemcitabine 2000 mg (in 100 mL saline) once weekly for 6 weeks B: Gemcitabine 2000 mg (in 100 mL saline) twice weekly for 3 weeks C: Gemcitabine 2000 mg (in 100 mL saline) single instillation | A vs. B vs. C Complete response (complete disappearance of marker lesion and no new tumor): 44% (4/9) vs. 40% (4/10) vs. 10% (1/10)
Thiotepa Trials | Koontz, 1981^140^ (prophylaxis) USA Multicenter 1974-1977 | A: Thiotepa 30 mg/30 mL distilled water (once every 4 weeks for maximum 2 years) B: Thiotepa 60 mg/60 mL distilled water (once every 4 weeks for maximum 2 years) C: No thiotepa | | Percent recurrence-free at 12 months: 63% vs. 69% vs. 40% (p=0.02 for A or B vs. C) | | Leukopenia (WBC <3000): 0% (0/23) vs. 4.3% (1/23) vs. 0% (0/47) Thrombocytopenia (platelets <100,000): 0% (0/23) vs. 4.3% (1/23) vs. 0% (0/47) UTI: 0% (0/23) vs. 17% (4/23) vs. 0% (0/47)
Thiotepa Trials | Koontz, 1981^140^ (treatment) USA Multicenter 1974-1977 | A: Thiotepa 30 mg/30 mL distilled water (once weekly for 4 weeks, repeated after 4 weeks) B: Thiotepa 60 mg/60 mL distilled water (once weekly for 4 weeks, repeated after 4 weeks) | Success (slight or moderate reduction of tumor, or complete remission): 70% (35/50) vs. 58% (26/45), RR 1.21, 95% CI 0.89 to 1.65 after first course; 48% (24/50) vs. 47% (21/45), RR 1.03, 95% CI 0.67 to 1.57) after second course | | | Leukopenia (WBC <3000): 2.0% (1/50) vs. 13% (6/45), RR 0.15 (95% CI 0.02 to 1.20) Thrombocytopenia (platelets <100,000): 6.0% (3/50) vs. 0% (0/45) UTI: 2.0% (1/50) vs. 2.2% (1/45)
Interferon alpha-2b Trials | Giannakopoulos, 1998^136^ Greece Unclear if single or multicenter Study years not reported | A: No adjuvant treatment. TURBT alone. B: Interferon-α-2b (interferon-α-2b), 40 MU (in 50 mL normal saline). C: Interferon-α-2b (interferon-α-2b), 60 MU (in 50 mL normal saline). D: Interferon-α-2b (interferon-α-2b), 80 MU (in 50 mL normal saline). For Groups B - D: First instillation after histological verification of stage and grade; 48 - 72 hours after TURBT. Retained intravesically for 1 hour; patient position changed every 15 minutes. Instillations once a week × 2 months, then once every 15 days × 4 months, then once monthly × 6 months. | Progression: 13.6% (3/22) vs. 4.2% (1/24) vs. 4.3% (1/23); B vs. C, p=NS, B vs. D, p=NS; C vs. D, p=NS | B vs. C vs. D Recurrence: 36.4% (8/22) vs. 29.2% (7/24) vs. 21.7% (5/23); Differences between B, C, and D, p>0.10. Recurrence rate per 100 patient-months: 1.19 vs. 0.88 vs. 0.63; B vs. C, p=“significant”, B vs. D, p=“significant”; C vs. D, p=0.026. | Recurrence-free survival time, months (mean): 21.4 vs. 26.1 vs. 30.0; B vs. C, p=0.02, B vs. D, p<0.01; C vs. D, p=NS. | No side effects of the drugs were noted. No adverse reactions noted. Five patients (groups not reported) developed fevers and were found to have urinary tract infections.
Interferon alpha-2b Trials | Glashan, 1990^203^ USA, Europe, Australia, Canada Multicenter 1985-1988 | A: Interferon α-2b 100 million units (in 30 mL sterile water) B: Interferon α-2b 10 million units (in 30 mL sterile water) First instillation within 1 month of positive cytology, administered once weekly for 12 weeks, then monthly through one year | | | | Flu-like symptoms: 14% (8/47) vs. 8% (3/38), RR 2.2 (95% CI 0.61 to 7.57) Withdrawal due to adverse events: None
Interferon alpha-2b Trials | Hoeltl, 1991^217^ Austria Single center Study years not reported | A: Interferon alfa-2b 100 × 10^6^ IU (100 MU)/30 mL sterile water (once weekly for 10 weeks, then once monthly for 1 year total of therapy) B: Interferon alfa-2b 10 × 10^6^ IU (10 MU)/30 mL sterile water (starting within 36 hours of TURBT, once weekly for 10 weeks, then once monthly for 1 year total of therapy) C: Ethoglucid 1.13 g/100 mL sterile water (once weekly for 10 weeks, then once monthly for 1 year total of therapy) | Progression (recurrence of G2 or G3 cancer, ≥T2, or metastatic): 36.4% (4/11) vs. 7.7% (1/13), RR 4.7 (95% CI 0.62 to 36) | A vs. B Recurrence rate: 2.76 vs. 4.4 per 100 months Percent recurrence-free: 54.5% (6/11) vs. 46.2% (6/13), RR 1.2 (95% CI 0.53 to 2.62) Time to recurrence (mean, months): 22.4 vs. 22.2 | | A vs. B Local toxicity (chemocystitis, dysuria): 0% (0/11) vs. 0% (0/13) Systemic side effects: None observed
Interferon alpha-2b Trials | Malmström, 2002^221^ Europe Multicenter Study years: not reported | A: Interferon-α, 30 MU (in 30 mL sterile water). Retained in bladder × 2 hours; patient moved from side to side every 30 min. First instillation 1 to 2 weeks after TURBT or biopsy, then weekly × 12 weeks. B: Interferon-α, 50 MU (in 30 mL sterile water). Same procedure as A. C: Interferon-α, 80 MU (in 30 mL sterile water). Same procedure as A. D: MMC, 40 mg (in 40 mL sterile water). Retained in bladder × 2 hours; patient moved from side to side every 30 min. First instillation 1 to 2 weeks after TURBT or biopsy, then weekly × 8 weeks. | A vs. B vs. C Complete response (macroscopic disappearance of marker lesion): 19% (5/27) vs. 30% (8/27) vs. 26% (7/27) at 9 weeks; 19% (5/27) vs. 33% (9/27) vs. 41% (11/27) at 13 weeks (p>0.05 for all comparisons) | | | A vs. B vs. C vs. D Adverse events reported: 37% (10/27) vs. 37% (10/27) vs. 48% (13/27) vs. 55% (16/29) Adverse events with frequency ≥10%, reported by treatment group: A: None B: Fever (11%); Pain (11%) C: Fever (11%); Pain (15%); Micturition frequency (11%) D: Pain (10%); Dysuria (10%); Hematuria (14%); Micturition disorder (14%); Micturition frequency (28%); UTI (10%)
Multiple Drugs | Bouffioux, 1995^212^ Europe Multicenter 1983-1986 | Initial randomization: A. MMC 30 mg/50 mL saline or doxorubicin 50 mg, 9 instillations starting on day of TURBT (once weekly for 4 weeks, then once monthly for 5 months) B. MMC 30 mg/50 mL saline or doxorubicin 50 mg, 9 instillations, starting between days 7 and 15 after TURBT (once weekly for 4 weeks, then once monthly for 5 months) Second randomization at 6 months: A: Continued instillations once a month for 6 months, total 15 B: No maintenance | Early vs. delayed treatment Progression to invasive bladder cancer: 11% (40/374) vs. 10% (38/378) after 6.5 years Distant metastasis: 6% (24/412) vs. 6% (17/412) Second primary: 7% (28/412) vs. 6% (25/412) Maintenance vs. no maintenance Progression to invasive bladder cancer: 9% (26/303) vs. 8% (25/314) Distant metastasis: 4% (12/304) vs. 4% (13/314) Second primary: 5% (15/304) vs. 7% (21/314) (p=0.41) | Early vs. delayed treatment Time to first recurrence: 43% (161/374) vs. 49% (187/378) after 2.75 years (p=0.18, log-rank test) Recurrence rate: 0.27 vs. 0.33 (p=0.08) Maintenance vs. no maintenance Time to first recurrence: 43% (130/303) vs. 50% (156/314) after 3 years (p=0.20, log-rank test) Recurrence rate: 0.23 vs. 0.28 (p=0.20) | Early vs. delayed treatment Mortality: 19% (78/412) vs. 21% (86/412) (p=0.60) Maintenance vs. no maintenance Mortality: 17% (53/304) vs. 20% (63/314) | Early vs. delayed Chemical cystitis requiring delay or discontinuation of therapy: 3% vs. 0% with MMC, 2.2% vs. 0.5% with doxorubicin Systemic toxicity requiring discontinuation of instillations: 1.8% with MMC, 0.8% with doxorubicin

AE = adverse event; AOR = adjusted odds ratio; BCG = bacillus Calmette-Guérin; BCG RIVM = RIVM strain of bacillus Calmette- Guérin; BCG-Tice = bacillus Calmette-Guérin Tice strain; CFU = colony forming unit; CI = confidence interval; CIS = carcinoma in situ; G2 = Grade 2 ; G3 = Grade 3; HR = hazard ratio; IU = international unit; MMC = Mitomycin C; MU = million units; NS = not significant; OR = odds ratio; RR = risk ratio; T1 = Tumor stage 1; T2 = tumor stage 2; Ta = Tumor stage a; Tis = carcinoma in situ; TURBT = transurethral resection of the bladder tumor; UTI = urinary tract infection; WBC = white blood cell count

#### BCG

##### Comparisons of Different Doses

Seven trials (reported in eight publications) compared different doses of intravesical BCG.151,218,222,223,226,228,230,237 The trials varied with regard to the BCG strain, dose comparisons, and populations evaluated. Most trials found no clear differences between standard and lower doses of BCG in risk of recurrence and other outcomes, though there was some inconsistency across studies.

Three trials compared different doses of intravesical Connaught strain BCG.151,222,223 In all three trials, BCG was administered as 12 instillations over 5 to 6 months. One trial (n=499) found no differences between standard (81 mg) and reduced (27 mg) dose Connaught strain BCG in risk of recurrence (28% vs. 31%, RR 0.92, 95% CI 0.70 to 1.20), progression (12% vs. 13%, RR 0.86, 95% CI 0.54 to 1.37), or bladder cancer mortality (7.9% vs. 7.3%, RR 1.09, 95% CI 0.59 to 2.01) after a median of 69 months.222 In the subgroup of patients with high-risk (T1G3, Tis, ≥2 prior relapses, multifocal, or ≥3 cm) tumors, there was a nonstatistically significant trend favoring standard (81 mg) dose therapy (30% vs. 37%, RR 0.80, 95% CI 0.60 to 1.08), but the estimate was imprecise and there were baseline differences in risk markers. In addition, a subsequent randomized trial (n=155) that focused on patients with higher-risk NMIBC (T1G3 and Tis) found no differences between standard dose versus 27 mg in risk of recurrence (39% vs. 45%, RR 0.86, 95% CI 0.60 to 1.25), progression (24% vs. 26%, RR 0.94, 95% CI 0.54 to 1.61), or bladder cancer mortality (12% vs. 15%, RR 0.81, 95% CI 0.36 to 1.79) after a median followup of 60 months.223 The third trial, which enrolled patients with intermediate-risk (TaG2 or T1/G1-2 without CIS) tumors, found no statistically significant differences between one-third dose (27 mg) and one-sixth dose (13.5 mg) in risk of recurrence (27% vs. 36%, RR 0.74, 95% CI 0.52 to 1.06), progression (10% vs. 13%, RR 0.76, 95% CI 0.39 to 1.47), or bladder cancer mortality (2.1% vs. 3.6%, RR 0.59, 95% CI 0.14 to 2.41), though trends favored the higher dose group.151

Four trials evaluated dose comparisons involving other BCG strains.218,226,228,230 One trial, which did not focus on high-risk NMIBC, found no differences between low (40 mg) versus standard (80 mg) dose Tokyo 172 strain BCG (6 instillations over 6 weeks) in risk of recurrence (28% vs. 16%, RR 1.71, 95% CI 0.66 to 4.40) or progression (5.0% vs. 6.4%, RR 0.78, 95% CI 0.12 to 5.20) after about 2 years followup.218 The other three trials focused on treatment of higher-risk NMIBC. The largest trial (n=1805) enrolled patients with solitary T1G3 or multiple Ta-T1/G1-G3 tumors.228 It found no differences between one third versus full dose OncoTICE strain BCG (administered as 15 instillations over 12 months or 27 instillations over 36 months) in the likelihood of remaining recurrence-free at 5 years (59% vs. 62%, p=0.09), progression, or mortality. However, the one-third dose/1 year regimen was associated with decreased likelihood of remaining disease-free versus the full dose/3 year regimen (HR 0.75, 95% CI 0.59 to 0.94). Benefits of three years of full-dose therapy were limited to high-risk patients (HR for recurrence 1.61, 95% CI 1.13 to 2.30). One trial (n=97) of patients with residual T1 or Tis tumors or a history of multiple recurrences found low-dose Armand Frappier BCG (60 mg) associated with lower likelihood of remaining recurrence-free (37% vs. 67%, RR 0.55, 95% CI 0.36 to 0.84) than standard dose therapy (each administered once weekly for 6 weeks) after a mean duration of followup of 21 months.226 The other trial (n=183), which enrolled patients with multiple Ta/T1 tumors or CIS, found low-dose (75 mg) Pasteur strain BCG more effective than standard (150 mg) dose (6 weeks induction with 2 years maintenance) in time to recurrence (p=0.0009 overall), but there was no difference in risk of tumor progression (9% in both groups).230 In addition, only interim results have been published from this trial.

In most trials, standard dose BCG therapy was consistently associated with increased risk of local and systemic adverse events versus reduced doses.218,222,223,226 However, the largest trial found no clear differences between standard versus 1/3 dose BCG in local or systemic adverse events, or in risk of discontinuation due to adverse events.228,237 One trial found no differences between 27 (1/3 dose) versus 13.5 mg (1/6 dose) in local or systemic adverse events.151

##### Comparisons of Different Instillation Regimens

Six trials (reported in seven publications) compared induction therapy with BCG for 6 to 8 weeks versus more prolonged courses.176,200,205-207,209,215 Three trials randomized responders to BCG induction therapy (dose 80 to 81 mg) to maintenance therapy versus no maintenance therapy.205-207,209 Maintenance therapy ranged from 3 additional instillations over 9 months to 21 additional instillations over 3 years. There was no difference between maintenance therapy versus no maintenance therapy in risk of all-cause mortality (3 trials, RR 0.90, 95% CI 0.72 to 1.11, I^2^=0%),205,206,209 bladder cancer mortality (2 trials, RR 1.14, 95% CI 0.24 to 5.40, I^2^=0%),205,209 or progression (2 trials, RR 0.85, 95% CI 0.69 to 1.04).205,206 Two trials each found maintenance therapy associated with decreased risk of recurrence (RR 0.76 [95% CI 0.65 to 0.88]206 and RR 0.16 [95% CI 0.02 to 1.21]205), but there was statistical heterogeneity and the pooled estimate was imprecise, with a nonstatistically significant effect (RR 0.49, 95% CI 0.12 to 1.93, I^2^=56%). None of the trials reported risk of adverse events with maintenance therapy versus no maintenance therapy.

Three other trials randomized patients with high-risk (recurrent or multifocal) NMIBC to maintenance versus induction therapy with BCG, prior to determining response to induction therapy.176,200,215 In one trial (n=83), maintenance therapy with Connaught strain BCG 81 mg (6 weeks induction followed by once weekly instillations for 3 weeks at 3, 6, 12, and 18 months) was associated with lower risk of recurrence (12% vs. 33%, RR 0.37, 95% CI 0.14 to 0.92) than induction therapy alone after a median followup of 2 years.176 In another trial (n=70), a 12-week course of Pasteur strain BCG 120 mg was associated with a trend towards decreased risk of recurrence versus a 6-week course after 2 years, but the difference was not statistically significant (30% vs. 45%, RR 0.67, 95% CI 0.35 to 1.27).215 The third trial found no difference between monthly maintenance therapy with Pasteur strain BCG 120 mg versus a 6-week course of therapy in disease-free interval after a median followup of 22 months.200 One trial176 found no difference in risk of progression (0% vs. 6.1%, RR 0.15, 95% CI 0.01 to 2.7), one trial215 found no differences in risk of mortality or radical cystectomy, and one trial reported no difference in risk of progression (there were no deaths),200 but estimates were imprecise. Two trials reported risk of harms with maintenance versus induction therapy. In both trials, more prolonged courses of BCG therapy were associated with increased risk of local adverse events versus 6-week induction regimens, with no clear differences in systemic or serious adverse events.176,215 In the trial of 18 months maintenance versus 6 weeks of induction therapy, rates of urinary frequency were 93 versus 71 percent (RR 1.3, 95% CI 1.1 to 1.6), dysuria 93 versus 69 percent (RR 1.3, 95% CI 1.1 to 1.7), hematuria 93 versus 71 percent (RR 1.3, 95% CI 1.1 to 1.6), and fever 43 versus 26 percent (RR 1.6, 95% CI 0.88 to 3.0).176 In the trial of 12 versus 6 weeks of BCG, there were fewer adverse events and differences were not statistically significant.215

One trial of patients with solitary T1G3 or multiple Ta-T1/G1-G3 tumors found no difference between OncoTICE strain BCG (1/3 or full dose) administered as 15 instillations over 12 months versus 27 instillations over 36 months in the likelihood of remaining recurrence-free at 5 years (57% vs. 63%, p=0.06).228 There were also no differences in risk of progression or mortality. There were no differences in risk of local or systemic adverse events.228,237

##### Comparisons of Different BCG Strains

Six trials (reported in eight publications) compared outcomes of 6 to 8 weeks of intravesical therapy with one BCG strain versus another.148,156,201,204,208,210,211,233,238 The largest trial (n=437) found BCG TICE associated with lower likelihood of remaining recurrence-free after 5 years (36% vs. 54%, log-rank p=0.07) in patients with papillary NMIBC (not selected for being higher risk), though the difference was not statistically significant.148,156,211 There was no difference in risk of progression (5% vs. 6%) or local or systemic side adverse events. The differences also were not statistically significant when analyses were restricted to patients with G3 tumors or CIS. Another trial (n=142) found BCG TICE associated with lower likelihood of 5-year recurrence-free survival versus BCG Connaught (48% vs. 74%, p=0.01) in higher-risk patients (high-grade tumors, low-grade tumor with multiple recurrences, or CIS), though there were no difference in progression-free or overall survival.210 BCG TICE was also associated with higher risk of dysuria (30% vs. 13%, p=0.02), though there was no difference in risk of any harm.

Four other trials found no differences between non-TICE BCG strains.201,204,208,233,238 Two trials focused on patients with multiple recurrent tumors and two included patients with CIS. One trial (n=129)233 found no difference between BCG Tokyo versus BCG Connaught in likelihood of 5-year recurrence-free survival (62% vs. 56%, p=0.74). A smaller trial (n=38) also found no differences between low-dose BCG Tokyo versus regular dose BCG Connaught in likelihood of complete response (72% vs. 75%) at median followup of 16.5 months or in likelihood of 1-year recurrence-free survival (p=0.69).204 One trial (n=94)201 found no difference between BCG Evans versus BCG Pasteur in marker tumor clearance or development of new tumors after 3 months. Another trial found no difference between BCG Evans (Glaxo) versus BCG Pasteur in likelihood of a complete response at 1 year (42% vs. 44%), but enrolled a very small sample (n=21).208,238 There were no differences in risk of adverse events in any of these BCG comparisons.

#### MMC

##### Comparisons of Different Instillation Regimens

One trial (n=295) of patients with NMIBC (not selected for being at higher risk) found no clear differences between MMC 40 mg single instillation within 24 hours of TURBT versus 5 instillations in risk of recurrence at 24 months (42% vs. 31%, p=0.14), progression-free interval (HR 0.97, 95% CI 0.46 to 2.06), all-cause mortality (34% vs. 42%, RR 0.79, 95% CI 0.59 to 1.1), or bladder cancer mortality (5.4% vs. 5.5%, RR 0.98, 95% CI 0.38 to 2.5).118 The single instillation was associated with lower risk of dysuria or frequency (0% vs. 6.2%, RR 0.05, 95% CI 0.003 to 0.88).

One trial (n=332) of patients with higher-risk NMIBC (based on higher stage, higher grade, multifocality, and recurrence) found MMC 20 mg induction therapy for 6 weeks associated with higher risk of recurrence than induction plus maintenance therapy for 3 years (26% vs. 10%, RR 2.5, 95% CI 1.5 to 4.2).154 There were no clear difference in risk of adverse events.

Two trials compared MMC regimens that varied in both the number and frequency of instillations in patients with NMIBC who were not selected for being at higher risk. One trial (n=380) found that regimens of MMC 20 mg that involved more intensive induction (weekly for 8 weeks followed by maintenance for a total of 3 years or weekly for 20 weeks) were associated with lower risk of recurrence and progression than regimen involving less intensive (biweekly for 1 year, followed by maintenance for a total of 3 years) induction (18% and 20% vs. 24% for recurrence and 5.2% and 6.7% vs. 12% for progression, respectively).232 Effects were more pronounced in patients with recurrent than with primary bladder cancer. Adverse events were not reported. Another trial found that a more intensive and prolonged course of MMC 20 mg (induction with 8 weekly instillations, with a total of 42 instillations over 3 years) was associated with lower risk of recurrence and stage progression than the same number of instillations over 3 years with a less intense induction (biweekly for the first year) or a course involving 20 weekly instillations (recurrence 9.4% vs. 15% and 17%; stage progression 1.0% vs. 2.9% and 5.3%), and a lower risk of chemical cystitis (12% vs. 25% and 18%).191

One trial (n=54) of MMC (40 mg) for patients with recurrent, single, small (<1.5 cm) NMIBC found 3 instillations per week for 2 weeks prior to TURBT associated with higher likelihood of complete response (absence of residual tumor) versus a once weekly instillation for 6 weeks prior to TURBT, though the difference was not statistically significant (70% vs. 44%, RR 1.58, 95% CI 0.97 to 2.56).213 There were no cases of progression. There were no differences in risk of urinary frequency, chemical cystitis, or hematuria.

##### “Optimized” Versus Nonoptimized Administration

Two trials compared “optimized” administration of intravesical MMC (through alkalinization of urine) versus instillation without additional optimization.197,198 One of the trials also optimized MMC administration by restricting fluids and emptying the bladder prior to instillation, and administering at a higher dose and concentration (40 mg in 20 mL versus 20 mg in 20 mL).197 The first trial (n=26), which evaluated single-dose MMC for low-risk NMIBC (Ta, G1, solitary, <3 cm), found no difference between optimized and standard administration of a single dose of MMC, with no cases of recurrence in the standard therapy group after a median duration of followup of 51 months.198 However, a trial (n=201) of high-risk NMIBC found optimized therapy associated with lower risk of recurrence (51% vs. 66%; RR 0.78, 95% CI 0.63 to 0.97) and time to recurrence (median 29 vs. 12 months, p=0.005) after 5 years of followup. Benefits were not observed in patients with prior intravesical therapy, but were observed across other subgroups defined by tumor multifocality, stage, grade, and papillary lesion type. Optimized therapy was associated with increased risk of dysuria (33% vs. 18%, RR 1.86, 95% CI 1.15 to 3.02), with no difference in risk of other local or systemic adverse events and no difference in risk of discontinuation due to adverse events (1.8% vs. 1.9%).

#### Doxorubicin

##### Comparisons of Different Doses

Two trials found no differences between regimens involving doxorubicin 30 mg versus 20 mg in patients with NMIBC not selected for being at higher risk. One trial (n=368) of short-term therapy (eight instillations over 4 weeks) found no differences between doses in recurrence-free survival at 540 days (57% vs. 52% for 30 mg vs. 20 mg doses, respectively) or at 1800 days.112,116 The other trial (n=345), which evaluated longer-term therapy (21 instillations over 2 years), found no difference in recurrence-free survival (62% vs. 59%) at 2 years.112,113 In a subgroup of patients with long-term followup data (median 6.6 years) it also found no difference in risk of progression (43% vs. 31%) or recurrence rate (0.473 vs. 0.512 per year). In both trials, there were no clear differences in local adverse events and no systemic adverse events were reported.

##### Comparisons of Different Instillation Regimens

Two trials found no clear differences between doxorubicin induction therapy and induction plus maintenance in patients with NMIBC not selected for being at higher risk. One trial (n=146) found no difference between doxorubicin 50 mg maintenance therapy for 2 years versus induction therapy for 6 weeks without maintenance in risk of recurrence (47% vs. 42%, RR 1.1, 95% CI 0.78 to 1.6), progression (19% vs. 20%, RR 0.94, 95% CI 0.48 to 1.8), or bladder cancer mortality (13% vs. 13%, RR 0.95, 95% CI 0.41 to 2.2) after 5 years.214 There were also no clear difference in risk of recurrence in subgroups stratified by primary or recurrent, solitary or multiple, or Ta vs. T1 cancers. Rates of local adverse events (chemical cystitis) were similar (13% vs. 12%). The other trial (n=220) found no differences between doxorubicin 50 mg given as 13 instillations over 6 weeks versus 28 instillations over 6 months in recurrence rate (25 vs. 2.3 per 100 patient-months), progression (16% vs. 11%, p>0.35), or bladder cancer mortality (5.3% vs. 1.8%).231

Two trials of doxorubicin involved comparisons regarding timing of therapy.123 One trial (n=306) of patients with higher-risk NMIBC (multiple or recurrent lesions) found maintenance therapy with doxorubicin 20 mg (21 instillations over 2 years) associated with higher likelihood of remaining recurrence-free at 2 years (38% vs. 19%, p<0.05) than 6 instillations administered in the 2 weeks prior to TURBT, with no post-TURBT therapy.123 There were no differences in risk of local adverse events. The other trial (n=187), which did not focus on higher-risk NMIBC, evaluated four regimens of doxorubicin 30 mg involving early initiation (two instillations in first 2 days, followed by 17 instillations over 1 year) versus no early instillation (17 instillations over 1 year, starting 7 days after TURBT), with or without 5-fluorouracil.236 As no effects of 5-fluorouracil on outcomes were observed, these groups were combined for the analyses. The trial found no overall difference between the early and delayed initiation groups in likelihood of remaining recurrence-free at 36 months (76% vs. 65%, p>0.05), though estimates favored the early initiation groups at some earlier time points and in patient subgroups with primary tumors, Ta, <1 cm lesions, G1 lesions, G2 lesions, and multiple tumors. Risk of bladder irritation was greater with the early instillation regimens (48-55% vs. 26%), but there was no difference in risk of bladder irritation resulting in withdrawal (5-8% vs. 2-3%).

#### Epirubicin

##### Comparisons of Different Doses

Three trials compared regimens involving different doses of intravesical epirubicin.119,134,224 Overall there was no clear pattern that higher doses of epirubicin are associated with improved outcomes. One trial (n=132) of patients with higher-risk NMIBC found no statistically significant differences between epirubicin 50 mg vs. 80 mg, given as ∼19 instillations over 1 year, in risk of recurrence (25% vs. 18%; RR 1.42, 95% CI 0.73 to 2.76), time to first recurrence (mean 16 vs. 15 months), or risk of progression (11% vs. 4.4%, RR 2.5, 95% CI 0.67 to 9.2) after a mean followup of 30 months, though trends favored higher-dose therapy.126 Lower-dose therapy was associated with a higher recurrence rate (0.83 vs. 0.60 per 100 patient-months, p<0.05). Two other trials evaluated patients with NMIBC not selected for being at higher risk.134,224 One trial (n=54) found no differences between epirubicin 50 mg vs. 100 mg (administered as 5 instillations over 1 year) in risk of recurrence (44% vs. 56%, HR 0.68, 95% CI 0.41 to 1.13) or recurrence rate (0.52 vs. 0.58 per patient-year, p>0.05) after mean followup of about 2 years.224 The other trial (n=163) found no differences between epirubicin 20 mg vs. 50 mg (administered as 2 instillations, one immediately after TURBT and one the following day) in duration of recurrence-free survival (mean 24 vs. 38 months, p>0.05) or risk of progression (0% vs. 1.1%) after a median followup duration of 44 months.134 One of the trials found lower-dose therapy associated with lower risk of bladder spasm (15% vs. 44%, RR 0.33, 95% CI 0.17 to 0.65);224 otherwise there were no clear differences in risk of local or systemic adverse events.

##### Comparisons of Different Instillation Regimens

Three trials compared epirubicin single instillation therapy with multiple instillations.119,192,235 One trial (n=143) of patients with low-risk NMIBC found no difference between a single instillation of epirubicin 100 mg within 6 hours of TURBT versus an additional instillation at 12 hours in risk of recurrence (15% vs. 21%, adjusted HR 0.67, 95% CI 0.30 to 1.51) or progression (1.5% vs. 4.0%, RR 0.37, 95% CI 0.04 to 3.45) after a mean followup duration of 16.9 months.235 Another trial (n=44) of patients with Ta-T1/G1-G2 NMIBC found no differences between a single intravesical instillation of epirubicin 80 mg given within 6 hours of TURBT versus maintenance therapy with epirubicin 40 mg over about 1 year in risk or recurrence (36% vs. 33%, RR 1.07, 95% CI 0.39 to 2.92) or tumor-free survival (64% vs. 67%, RR 0.96, 95% CI 0.57 to 1.64) through 5 years.192 Although the single instillation regimen was associated with lower risk of any side effect, there were no clear differences in risk of specific local adverse events and no systemic adverse events were recorded. The other trial (n=114), which evaluated patients with higher-risk NMIBC, found no difference between a single instillation of epirubicin 50 mg immediately after TURBT versus treatments initiated after 1 to 2 weeks and continued for 1 year (18 instillations) in risk of recurrence (24% vs. 25%), time to first recurrence (16 vs. 18 months), or risk of progression (5.5% vs. 3.4%) after a mean duration of followup of 32 months.119 There were also no clear differences in risk of recurrence in subgroups stratified by tumor stage, grade, or lesion size, though results favored delayed maintenance therapy for G3 lesions (53% vs. 20%, RR 2.63, 95% CI 0.88 to 7.89). There were no differences in risk of adverse events, including adverse events requiring temporary or permanent discontinuation of therapy.

Two trials evaluated epirubicin maintenance therapy versus induction without maintenance.229,234 One trial (n=395) of patients with higher-risk, non-G3 NMIBC (multiple or recurrent tumors) found no clear differences between epirubicin 80 mg maintenance therapy (16 instillations over 1 year) versus induction without maintenance (6 instillations over 6 weeks) in remaining recurrence-free at 48 months (50% vs. 46%, p=0.26) or in risk of progression to MIBC (2.9% vs. 1.3%).234 One trial (n=138) of patients with papillary NMIBC found no difference between epirubicin 40 mg induction therapy (6 instillations over 5 weeks) versus maintenance therapy (17 instillations over 1 year) in likelihood of remaining recurrence-free at 3 years (75% vs. 77%, p=0.62) or likelihood of progression (2.9% vs. 1.4%).229 Both trials found no differences in risk of local adverse events.

Five trials compared different epirubicin regimens that included maintenance therapy.216,219,220,225,227 One trial (n=269) of patients with multiple or recurrent Ta or T1 tumors or a solitary T1 tumor found no differences in likelihood of remaining recurrence- or progression-free at 5 years between epirubicin 50 mg administered as nine instillations over 6 months versus the same regimen plus an additional instillation within 48 hours of TURBT or the same regimen plus two additional maintenance instillations through 1 year.216 One trial (n=150) of patients with Ta or T1 NMIBC (not selected for being at higher risk) found epirubicin 30 mg administered as 19 instillations over 1 year associated with lower risk of recurrence than nine instillations over 3 months (13% vs. 32%, HR 0.39, 95 % CI 0.18 to 0.82) after a median followup of 31 months.219 A trial (n=125) of patients with Ta-T1/G1-G2 NMIBC found no difference between epirubicin 30 mg administered as 19 instillations over 1 year versus 12 instillations over 5 months in likelihood of remaining recurrence-free at 3 years (48% vs. 55%, p>0.05).227 Another trial of patients with Ta-T1/G1-G2 NMIBC compared epirubicin 20 mg administered as 17 instillations over 12 months (total dose 340 mg), 30 mg given in 12 instillations over 7 months (total dose 360 mg), and 40 mg given in nine instillations over 4 months (total dose 360 mg).220 The median time to recurrence was 688, 1007, and 1186 days, respectively (p=0.04 for dose/intensity response). There were no differences in mortality or bladder cancer mortality. A trial (n=69) of patients with Ta-T1/G1-G3 NMIBC compared four 12-week regimens involving epirubicin 30 mg that varied in the total dose administered (180 vs. 360 mg) and method of initiating therapy (once every 2 weeks starting 1 week after TURBT versus 3 instillations within the first 5-7 days after TURBT).225 It found no difference between regimens based on the intensity of instillation, but the lower-dose regimens were associated with higher risk of recurrence at 12 months (42% vs. 29%, p=0.01). In all five trials, risk of local and systemic adverse events were similar across regimens.

#### Gemcitabine

##### Comparisons of Different Instillation Regimens

One small trial (n=32) of recurrent multiple Ta, G1 or G2 bladder cancers was too underpowered to determine if there were differences between gemcitabine 2000 mg once weekly for 6 weeks, twice weekly for 3 weeks, or a single instillation in likelihood of experiencing a complete response (disappearance of marker lesion and no new tumor, 44% vs. 40% vs. 10%).157

#### Thiotepa

##### Comparisons of Different Doses

Two trials (reported in the same publication) compared different doses of thiotepa.140 One trial (n=46) of patients with multifocal or recurrent NMIBC, or who had experienced a complete response to thiotepa, found no difference between maintenance therapy with thiotepa 30 mg versus 60 mg (once every 4 weeks for up to 2 years) in likelihood of being recurrence-free at 12 months (63% vs. 69%).140 There were no differences in risk of adverse events. Another trial (n=95) of patients with incompletely resected NMIBC or CIS found no difference between thiotepa 30 mg versus 60 mg in likelihood of success (reduction in tumor or remission) following two courses of therapy (48% vs. 47%, RR 1.03, 95% CI 0.67 to 1.57).140 There was no difference in risk of adverse events, though the lower-dose regimen was associated with a trend towards decreased risk of leukopenia (2.0% vs. 13%, RR 0.15, 95% CI 0.02 to 1.20).

#### Interferon Alpha-2b

##### Comparisons of Different Doses

Four trials compared different doses of intravesical interferon alpha-2b.136,203,217,221 Two trials compared 100 MU versus 10 MU (once weekly for 10 or 12 weeks, then once monthly for a total of 1 year),203,217 one trial compared 80, 50, and 40 MU (weekly for 12 weeks),221 and one trial compared 80, 60, and 40 MU (once weekly for 2 months, then once every 2 weeks for 4 months, then once monthly).136 One trial focused on patients with Tis lesions and the others included patients with Ta and T1 tumors.203 Although the trials generally found higher doses of interferon alfa-2b associated with improved outcomes related to recurrence, progression, or resolution of bladder cancer marker lesions, most differences were not statistically significant, due to small sample sizes (n ranged from 24 to 89) with imprecise estimates. One trial found a statistically significant dose-dependent difference in recurrence rate with 80, 60, and 40 MU (1.19 vs. 0.88 vs. 0.63 per 100 patient-months, respectively).136 The trial of patients with Tis found 100 MU associated with increased likelihood of a complete response (resolution of Tis, negative cytology, and no transitional cell carcinomas; 21% vs. 2.1% at 21 months, RR 10.0, 95% CI 1.33 to 75.0) and decreased risk of progression (13% vs. 37%, RR 0.35, 95% CI 0.15 to 0.82), with no difference in risk of cystectomy (15% vs. 18%, RR 0.81, 95% CI 0.31 to 2.10).203 There were no clear differences in risk of local or systemic adverse events, including flu-like symptoms.136,203,217,221

#### Multiple Drugs

One trial found no difference between initiation of intravesical therapy (9 instillations over 6 months) with MMC 30 mg or doxorubicin 50 mg on the day of TURBT versus 1 to 2 weeks after TURBT in risk of recurrence (43% vs. 49% after 2.75 years, p=0.18), progression to invasive bladder cancer (11% vs. 10%), or mortality (19% vs. 21%, p=0.60).212 The trial also randomized patients after 6 months to maintenance therapy for an additional 6 months or no maintenance. It found no differences in risk of recurrence (43% vs. 50% after 3 years, p=0.20), progression (9% vs. 8%), or mortality (17% vs. 20%). However, in a multivariate model that adjusted for prognostic factors, patients who received delayed therapy and no maintenance had a higher rate of recurrence than the other patients. Rates of local and systemic side effects were low, with no clear differences between regimens.

One trial of responders to 5-week induction therapy with sequential mitomycin and doxorubicin found maintenance therapy through 12 months associated with decreased risk of recurrence versus no maintenance therapy that was of borderline statistical significance (36% vs. 65%, RR 0.55, 95% CI 0.30 to 1.0).202 The estimate for risk of progression was very imprecise (RR 3.12, 95% CI 0.35 to 28.0).

## Key Question 4 For patients with high-risk non–muscle-invasive bladder cancer treated with TURBT, what is the effectiveness of external beam radiation therapy (either alone or with systemic chemotherapy/immunotherapy) for decreasing mortality or improving other outcomes compared with intravesical chemotherapy/immunotherapy alone or cystectomy?

### Key Points

- One randomized trial of patients with T1G3 bladder cancer found no effects of radiation therapy versus no radiotherapy (unifocal disease and no CIS) or radiation therapy versus intravesical therapy (multifocal disease or CIS) in recurrence-free survival (HR 0.94, 95% CI 0.67 to 1.30), progression-free interval (HR 1.07, 95% CI 0.65 to 1.74), progression-free survival (HR 1.35, 95% CI 0.92 to 1.98), or overall survival (HR 1.32, 95% CI 0.86 to 2.04) after 5 years (SOE: low).

### Detailed Synthesis

One randomized trial (rated medium risk of bias) compared external beam radiation therapy versus no radiation therapy in patients with NMIBC (Appendixes E5, F2).239 Patients with T1G3 lesions and unifocal disease without CIS were randomized to radiation therapy (60 Gy in 30 fractions during 6 weeks or equivalent) versus no radiotherapy (group 1, n=77) and patients with multifocal disease or CIS were randomized to radiation therapy versus intravesical therapy (group 2, n=133). Radiation therapy was associated with no effects on recurrence-free survival (HR 0.94, 95% CI 0.67 to 1.30), progression-free interval (HR 1.07, 95% CI 0.65 to 1.74), progression-free survival (HR 1.35, 95% CI 0.92 to 1.98), or overall survival (HR 1.32, 95% CI 0.86 to 2.04) after 5 years. The rate of progression to muscle invasive disease was high (∼32% overall). There was no evidence of an interaction between effects of radiotherapy and the patient group. Rates of cystectomy were similar (14% vs. 16%), and there was no clear difference in risk of long-term adverse events.

One cohort study of T1G3 patients found that patients who underwent radiotherapy plus TURBT had lower likelihood of progression than those who underwent TURBT alone, but there was no difference compared with TURBT + intravesical therapy, and the study did not attempt to adjust for potential confounders (Appendixes E5, F3).240

## Key Question 5 In surveillance of patients treated for non–muscle-invasive bladder cancer, what is the effectiveness of various urinary biomarkers to decrease mortality or improve other outcomes compared with other urinary biomarkers or standard diagnostic methods (cystoscopy, cytology, and imaging)?

### Key Points

- No study evaluated the effectiveness of urinary biomarkers to decrease mortality or improve other outcomes compared with standard diagnostic methods or other urinary biomarkers (SOE: insufficient).

### Detailed Synthesis

No study evaluated the effectiveness of urinary biomarkers to decrease mortality or improve other outcomes compared with standard diagnostic methods or other urinary biomarkers.

## Key Question 5a Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers?

### Key Points

- No evidence (SOE: insufficient).

## Key Question 5b Does the comparative effectiveness differ according to the treatment used (i.e., specific chemotherapeutic or immunotherapeutic agents and/or TURBT)?

### Key Points

- No evidence (SOE: insufficient).

## Key Question 5c Does the comparative effectiveness differ according to the length of surveillance intervals?

### Key Points

- No evidence (SOE: insufficient).

## Key Question 5d Does the comparative effectiveness differ according to patient characteristics, such as age, sex, or race/ethnicity?

### Key Points

- No evidence (SOE: insufficient).

## Key Question 6 For initial diagnosis or surveillance of patients treated for non–muscle-invasive bladder cancer, what is the effectiveness of blue light or other methods of augmented cystoscopy compared with standard cystoscopy for recurrence rates, progression of bladder cancer, mortality, or other clinical outcomes?

### Key Points

- There was no difference between fluorescent versus white light cystoscopy in risk of mortality (3 trials, RR 1.28, 95% CI 0.55 to 2.95, I^2^=41%) (SOE: low).
- Fluorescent cystoscopy with 5-ALA or hexaminolevulinate (HAL) was associated with decreased risk of bladder cancer recurrence versus white light cystoscopy at short-term (<3 months, 9 trials, RR 0.58, 95% CI 0.36 to 0.94, I^2^=75%), intermediate-term (3 months to <1 year, 5 trials, RR 0.67, 95% CI 0.51 to 0.88, I^2^=35%), and long-term followup (≥1 year, 11 trials, RR 0.81, 95% CI 0.68 to 0.98, I^2^=64%), but findings were inconsistent and potentially susceptible to performance bias (due to failure to blind the initial cystoscopy) and publication bias (SOE: low).
- There was no difference between fluorescent versus white light cystoscopy in risk of progression to muscle invasive bladder cancer (9 trials, RR 0.78, 95% CI 0.55 to 1.12, I^2^=0%) (SOE: moderate).
- Narrow band imaging was associated with lower risk of bladder cancer recurrence at 3 months (3.9% vs. 17%, OR 0.62, 95% CI 0.41 to 0.92) and at 12 months (OR 0.24, 95% 0.07 to 0.81) in one trial (SOE: low).

### Detailed Synthesis

Fourteen trials (reported in 19 publications) evaluated clinical outcomes of augmented (fluorescent or narrow band imaging) cystoscopy versus standard white light cystoscopy (Table 19; Appendix E6).241-259 Thirteen trials evaluated fluorescent cystoscopy following instillation of the photosensitizer 5-ALA, which is not commercially available (6 studies),241,246,252,256,257,259 or HAL (7 studies).245,247,248,250,251,255,258 One trial evaluated narrow band imaging.254 Sample sizes ranged from 44 to 551 and duration of followup from 6 weeks to 60 months. Mean age of participants ranged from 60 to 70 years of age and participants were predominantly male, except in the trial of narrow band imaging (∼80% female). One trial was conducted in the United States, Canada, and Europe;249,258 the remainder were conducted in Europe. One trial restricted enrolment to patients with new bladder cancer;255 the other trials included patients with either new or recurrent bladder cancer or did not specify whether patients had new or recurrent bladder cancer. In all studies, patients underwent TURBT and intravesical therapy protocols varied. Followup analyses were restricted to patients with NMIBC (Ta, T1, and in some cases CIS) on initial cystoscopy. Followup was performed with fluorescent light cystoscopy in one trial;256 in the other trials followup was performed with white light cystoscopy or the method was not reported. Three trials were rated high risk of bias and the other 11 medium risk of bias (Appendix F2). Only one trial described an adequate randomization method,254 four trials reported adequate allocation concealment,247,248,255,257 and four trials reported followup cystoscopic examinations blinded to initial cystoscopy method.247,248,257,259 All trials except for one used an unblinded design. It evaluated cystoscopic examination with white light and fluorescent cystoscopy blinded to instillation of fluorescent photosensitizer versus placebo, which could reduce performance bias.259 In one other trial, patients were initially randomized to no HAL versus HAL and all underwent white light cystoscopy; the HAL group subsequently underwent a second randomization to fluorescent cystoscopy versus no fluorescent cystoscopy.258 Although this design may reduce performance bias related to performance of the initial white light cystoscopy, the second cystoscopic examination was still unblinded. Four trials reported high attrition252,257-259 and one trial did not report attrition.

Table 19 Fluorescent cystoscopy study characteristics

Author, Year | Setting and Study Years | Interventions (number analyzed for recurrence) | Duration of Followup and Cystoscopic Followup Method | Population Characteristics by Treatment Group (age, race/ethnicity, sex, stage of disease, functional status)
Babjuk, 2005^241^ | Czech Republic Single center 2001-2003 | A: White light and 5-ALA fluorescent cystoscopy with TURBT (n=60) B: White light cystoscopy with TURBT (n=62) All patients with G1 or G2 tumors received adjuvant intravesical therapy; all patients with G3 tumors received intravesical BCG | Duration: 24 months Method: White light cystoscopy | Age (mean): 68 vs. 70 years Male: 72% vs. 63% Stage: 63% vs. 60% Ta, 37% vs. 40% T1 Grade: 50% vs. 53% G1, 40% vs. 35% G2, 10% vs. 11% G3
Dragoescu, 2011^245^ | Romania Single center 2009 | A: White light and HAL fluorescent cystoscopy with TURBT (n=22) B: White light cystoscopy with TURBT (n=22) All patients received postoperative intravesical epirubicin (Farmorubicin) and additional therapy based on risk group | Duration: 12 months Method: not reported | Age (mean): 59 vs. 62 years Male: 78% Stage: 22% vs. 18% Ta, 78% vs. 82% T1 Grade: 32% vs. 27% G1, 55% vs. 64% G2, 14% vs. 9.1% G3
Filbeck, 2002^246^ (also Denzinger 2007a243, Denzinger 2007b244) | Germany Single center 1997-2000 | A: White light and 5-ALA fluorescent cystoscopy with TURBT (n=88) B: White light cystoscopy with TURBT (n=103) All patients received intravesical prophylaxis based on AUA guidelines according to number of tumors, stage, and grade | Duration, mean: 21 months Method not reported | Age (median): 68 vs. 70 years Sex: Not reported Race/ethnicity: Not reported Smoker: Not reported Recurrent bladder cancer: 31% vs. 18% (p=0.06) Stage: 42% vs. 41% pTaG1, 31% vs. 28% pTaG2, 2.3% vs. 1.0% pTaG3, 7.9% vgs. 13% pT1G2, 11.4% vs. 11.7% pT1G3, 5.7% vs. 4.9% CIS Risk group: 35% vs. 48% low, 46% vs. 34% intermediate, 19% vs. 18% high
Geavlete, 2010^247^ | Romania Single center 2007-2009 | A: White light and HAL fluorescent cystoscopy with TURBT (n=223) B: White light cystoscopy (n=223) All patients received single, immediate postoperative MMC instillation | Duration: 6 weeks Method: White light cystoscopy | Age (mean): 64 years (overall) Male: 73% (overall) Race/ethnicity: Not reported Smoker: Not reported Recurrent bladder cancer: Not reported Stage: 10% vs. 8.1% CIS, 51% vs. 47% pTa, 17% vs. 17% pT1, 14% vs. 15% MIBC Grade (for Ta and T1 tumors): 40% vs. 40% G1, 41% vs. 41% G2, 19% vs. 19% G3
Geavlete, 2011^248^ | Romania Single center Study years not reported | A: White light and HAL fluorescent cystoscopy with TURBT (n=125) B: White light cystoscopy and TURBT (n=114) All patients received single, immediate postoperative MMC instillation | Duration: 2 years Method: White light cystoscopy | Age (mean): 67 years (overall) Male: 74% (overall) Stage: 11% vs. 8.3% CIS, 45% vs. 41% pTa, 19% vs. 18% pT1 Grade: Not reported
Hermann, 2011^250^ | Denmark Multicenter Study years not reported | A: White light and HAL fluorescent cystoscopy with TURBT (n=59) B: White light cystoscopy (n=74) No patient received intravesical therapy immediately after TURBT, 3 patients in each arm had previously received MMC and 21 patients BCG (10 in arm A and 11 in arm B) | Duration: 12 months Method: White light cystoscopy | Age (mean): 71 vs. 69 years Male: 75% Race/ethnicity: Not reported Smoker: Not reported Recurrent bladder cancer: Not reported Stage and grade: 84% vs. 90% Ta low grade, 12% vs. 6% Ta high grade, 0% T1 low grade, 2% vs. 4% T1 high grade
Karaolides, 2012^251^ | Greece Single center 2008-2010 | A: White light and HAL fluorescent cystoscopy with TURBT (n=41) B: White light cystoscopy with TURBT (n-45) Patients with moderate and high risk tumors received epirubicin 6 weeks after TURBT, or BCG | Duration: 18 months Method: White light cystoscopy | Age (mean): 66 vs. 64 years Male: 80% vs. 89% Race/ethnicity: Not reported Smoker: Not reported Recurrent bladder cancer: 29% vs. 24% Tumor stage and grade: 12% vs. 6.7% CIS, 22% vs. 31% high grade, 63% vs. 60% low grade, 2.4% vs. 2.2% low malignant potential
Kriegmair, 2002^252^ | Austria Multicenter 1997-1998 | A: White light and 5-ALA fluorescent cystoscopy with TURBT (n=52) B: White light cystoscopy with TURBT (n=49) Additional treatments not reported | Duration: 10 to 14 days Method: not reported | Age (mean): 69 vs. 70 years Male: 82% vs. 70% Stage: 4.6% vs. 6.2% CIS, 55% vs. 47% Ta, 18% vs. 20% T1, 7.7% vs. 16% T2 Grade: 32% vs. 12% G1, 32% vs. 42% G2, 9.2% vs. 12% G3
Naselli, 2012^254^ Italy | Italy Multicenter 2009-2010 | A: Narrow band imaging cystoscopy and TURBT (n=76) B: White light cystoscopy and TURBT (n=72) Additional treatments not reported | Duration: 1 year Method: White light cystoscopy | Age (mean): 71 vs. 72 years Male: 16% vs. 24% Stage: 76% vs. 72% Ta or CIS, 24% vs. 28% T1 Grade: 51% vs. 57% low, 49% vs. 43% high (including CIS)
O'Brien, 2013^255^ | UK Single center 2005-2010 | A: HAL fluorescent cystoscopy with TURBT (n=86) B: White light cystoscopy with TURBT (n=82) All patients received single shot intravesical MMC, BCG for grade tumors or CIS | Duration: 12 months Method: not reported | Age (mean): 68 vs. 68 years Male: 74% vs. 73% Stage and grade: 57% vs. 50% G1pTa or G2 (low grade) pTa/pT1; 17% vs. 13% G2 (high grade) pTa or G3pTa; 25% vs. 36% G2 (high grade) pTa or G3pT1; 14% vs. 26% secondary CIS
Riedl, 2001^256^ (also Daniltchenko, 2005^242^) | Germany Multicenter 1998-2000 | A: 5-ALA fluorescent cystoscopy with TURBT (n=51) B: White light cystoscopy with TURBT (n=51) MMC for pTa and pT1G1-2, BCG for pT1G3, CIS, and failed MMC | Duration: 60 months (median 42 vs. 39 months) Method: ALA fluorescent cystoscopy at 6 weeks | Age (mean): 70 vs. 67 years Male: 71% vs. 73% Stage: 78% vs. 78% Ta, 22% vs. 22% T1 Grade: 18% vs. 14% G1, 69% vs. 76% G2, 14% vs. 9.8% G3
Schumacher, 2010^257^ | Sweden Multicenter 2002-2005 | A: White light and 5-ALA fluorescent cystoscopy with TURBT (n=141) B: White light cystoscopy with TURBT (n=138)Patients received BCG for CIS, pTaG3, and pT1G2-3 starting 4 weeks after TURBT | Duration: 12 months Method: White light cystoscopy | Age (mean): 70 vs. 69 years Male: 73% vs. 75% Stage and grade: 0.7% vs. 4.3% CIS, 55% vs. 48% pTaG1-2, 12% vs. 10% pTaG3 or pT1G1-2, 4.3% vs. 5.1% pT1G3, 0.7% vs. 3.6% pT2
Stenzl, 2010^258^ (also Grossman 2012^249^) | USA, Canada, and Europe Multicenter Study years not reported | A: White light cystoscopy following instillation of HAL, followed by second randomization: a: Fluorescent cystoscopy and TURBT (n=271) b: TURBT without fluorescent cystoscopy (excluded from recurrence analysis, n unclear) B: White light cystoscopy and TURBT (n=280) Intravesical BCG for high grade T1 or CIS | Duration: 9 months, additional followup to median of 53-55 months Method: White light cystoscopy | Age (mean): 68 vs. 70 years Male: 78% vs. 79% Stage: 72% vs. not reported Ta, 17% vs. not reported T1, 11% vs. not reported CIS Grade: Not reported
Stenzl, 2011^259^ | Italy Multicenter 2009-2010 | A: White light and fluorescent cystoscopy with TURBT following instillation of 5-ALA (n=183) B: White light and fluorescent cystoscopy with TURBT following instillation of placebo (n=176) CIS, pTaG3, or pT1G2-3 received BCG 4 weeks after TURBT | Duration: 12 months Method: White light cystoscopy | Age (mean): 66 years (overall) Male: 72% (overall) Stage and grade: 33% vs. 28% pTaG1, 19% vs. 20% pTaG2, 1.1% vs. 0% pTaG3, 1.1% vs. 0.6% pT1G1, 8.7% vs. 8.5% pT1G2, 10% vs. 31% pT1G3, 5.5% vs. 4.5% pT2, 1.6% vs. 1.7% isolated CIS

5-ALA = 5-aminolevulinic acid; AUA = American Urological Association; BCG = bacillus Calmette-Guérin; CIS = carcinoma in situ; G1 = Grade 1; G2 = Grade 2; G3 = Grade 3; HAL = hexaminolevulinate; MMC = Mitomycin C; pT1 = Tumor stage 1 determined by pathology; pTa = Tumor stage a determined by pathology; T1 = Tumor stage 1; Ta = Tumor stage a; TURBT = transurethral resection of the bladder tumor

Fluorescent cystoscopy was associated with decreased risk of bladder cancer recurrence versus white light cystoscopy at short-term (<3 months, 9 trials, RR 0.58, 95% CI 0.36 to 0.94, I^2^=75%, Figure 34),241,245,247,248,251,252,255,256,259 intermediate-term (3 months to <1 year, 5 trials, RR 0.67, 95% CI 0.51 to 0.88, I^2^=35%, Figure 35),245,248,250,256,258 and long-term followup (≥1 year, 11 trials, RR 0.81, 95% CI 0.68 to 0.98, I^2^=64%, Figure 36) (Table 20).241,245,246,248,250,251, 255-259 Estimates were similar in sensitivity analysis using the profile likelihood method. Statistical heterogeneity was not reduced and estimates were similar when trials were stratified according to the photosensitizer used (5-ALA or HAL), risk of bias (medium or high), or masking of followup cystoscopy to the initial cystoscopy method. Results were also similar in an analysis restricted to recurrence assessed at around 1 year (9 to 16 months) (9 trials, RR 0.80, 95% CI 0.63 to 1.02, I^2^=69%).241,245,248,250,251,255,257-259 For short-term recurrence, two outlier trials reported point estimates that favored white light cystoscopy. One of the trials was the only one in which the initial cystoscopy was blinded to use of a photosensitizer (patients randomized to identical 5-ALA and placebo solutions and all underwent cystoscopy using fluorescent light) (RR 1.37, 95% CI 0.90 to 2.09).259 It also reported an estimate that favored white-light cystoscopy for long-term recurrence (RR 1.20, 95% 0.94 to 1.52). The other trial was the only one that restricted inclusion to patients with new bladder cancer (RR 1.16, 95% CI 0.61 to 2.19).255 Although all patients in this trial, including those with low-risk lesions, received single-shot intravesical MMC, other trials that reported more favorable effects of fluorescent cystoscopy on risk of recurrence also administered intravesical therapy in patients with low-risk lesions.241,245-247,256

Figure 34 Meta-analysis of fluorescent cystoscopy versus white light cystoscopy: Risk of bladder cancer recurrence at short term (<3 months) followup

ALA = aminolevulinic acid; CI = confidence interval; HAL = hexaminolevulinate

Figure 34 is a forest plot titled meta-analysis of fluorescent cystoscopy versus white light cystoscopy: risk of bladder cancer recurrence at short term (<3 months) followup. The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares in each graph. Recurrence risk was reported or calculated for 4 studies for ALA, with a pooled risk of 0.65 (95% confidence interval 0.32 to 1.31), and the subtotal I-squared value of 85.9 (p=0.000). Recurrence risk was reported or calculated for 5 studies for HAL, with a pooled risk of 0.52 (95% confidence interval 0.27 to 0.97) and the subtotal I-squared value of 50.2 (p=0.091). The overall pooled risk was 0.58 (95% confidence interval 0.36 to 0.94) and the overall I-squared value was 75.4 (p=0.001).

Figure 35 Meta-analysis of fluorescent cystoscopy versus white light cystoscopy: Risk of bladder cancer recurrence at intermediate term (3 months to <1 year)

CI = confidence interval; HAL = hexaminolevulinate

Figure 35 is a forest plot titled meta-analysis of fluorescent cystoscopy versus white light cystoscopy: risk of bladder cancer recurrence at intermediate term (3 months to <1 year). The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares in each graph. Recurrence risk was reported or calculated for 1 study for ALA, with a risk of 0.56 (95% confidence interval 0.34 to 0.91).Recurrence risk was reported or calculated for 4 studies for HAL, with a pooled risk of 0.70 (95% confidence interval 0.52 to 0.95) and the subtotal I-squared value of 30.2 (p=0.231). The overall pooled risk was 0.67 (95% confidence interval 0.51 to 0.88) and the overall I-squared value was 35.0 (p=0.188).

Figure 36 Meta-analysis of fluorescent cystoscopy versus white light cystoscopy: Risk of bladder cancer recurrence at long term (≥1 year)

ALA = aminolevulinic acid; CI = confidence interval; HAL = hexaminolevulinate

Figure 36 is a forest plot titled meta-analysis of fluorescent cystoscopy versus white light cystoscopy: risk of bladder cancer recurrence at long term (≥1 year). The plot depicts a meta-analysis of the risk of recurrence of bladder cancer. The risk of recurrence values are represented by squares. Recurrence risk was reported or calculated for 5 studies for ALA, with a pooled risk of 0.86 (95% confidence interval 0.68 to 1.08), and the subtotal I-squared value of 65.3 (p=0.021). Recurrence risk was reported or calculated for 6 studies for HAL, with a pooled risk of 0.74 (95% confidence interval 0.53 to 1.03) and the subtotal I-squared value of 69.5 (p=0.006). The overall pooled risk was 0.81 (95% confidence interval 0.68 to 0.98) and the overall I-squared value was 64.1 (p=0.002).

Table 20 Fluorescent cystoscopy results summary

Type | Author, Year | Interventions (number analyzed for recurrence) | Recurrence | Progression | Mortality
5-ALA fluorescent cystoscopy | Babjuk, 2005^241^ | A: White light and 5-ALA fluorescent cystoscopy with TURBT (n=60) B: White light cystoscopy with TURBT (n=62) | Short-term: 8.3% (5/60) vs. 37% (23/62) Long-term: 60% (36/60) vs. 73% (45/62) | 8.3% (5/60) vs. 8.1% (5/62) | Not reported
5-ALA fluorescent cystoscopy | Filbeck, 2002^246^ (also Denzinger 2007a, Denzinger 2007b) | A: White light and 5-ALA fluorescent cystoscopy with TURBT (n=88) B: White light cystoscopy with TURBT (n=103) Progression analysis restricted to patients with T1 high grade lesions on initial cystoscopy | Long-term: 20% (18/88) vs. 42% (43/103) | 19% (4/21) vs. 12% (3/25) | Not reported
5-ALA fluorescent cystoscopy | Kriegmair, 2002^252^ | A: White light and 5-ALA fluorescent cystoscopy with TURBT (n=52) B: White light cystoscopy with TURBT (n=49) | Short-term: 52% (27/52) vs. 54% (26/49) | Not reported | Not reported
5-ALA fluorescent cystoscopy | Riedl, 2001^256^ (also Daniltchenko, 2005^242^) | A: 5-ALA fluorescent cystoscopy with TURBT (n=51) B: White light cystoscopy with TURBT (n=51) | Short-term: 20% (10/51) vs. 47% (24/51) Intermediate term: 29% (15/51) vs. 53% (27/51) Long-term: 59% (30/51) vs. 75% (38/51) | 7.8% (4/51) vs. 18% (9/51) | Not reported
5-ALA fluorescent cystoscopy | Schumacher, 2010^257^ | A: White light and 5-ALA fluorescent cystoscopy with TURBT (n=141) B: White light cystoscopy with TURBT (n=138) | Long-term: 45% (63/141) vs. 44% (61/138) | 9.2% (13/141) vs. 11% (15/138) | 3.5% (5/141) vs. 2.9% (4/138)
5-ALA fluorescent cystoscopy | Stenzl, 2011^259^ | A: White light and fluorescent cystoscopy with TURBT following instillation of 5-ALA (n=183) B: White light and fluorescent cystoscopy with TURBT following instillation of placebo (n=176) | Short-term: 65% (24/37) vs. 47% (17/36) Long-term: 31% (57/183) vs. 26% (45/176) | 7.7% (14/183) vs. 8.5% (15/176) | Not reported
HAL fluorescent cystoscopy | Dragoescu, 2011^245^ | A: White light and HAL fluorescent cystoscopy with TURBT (n=22) B: White light cystoscopy with TURBT (n=22) | Short-term: 4.5% (1/22) vs. 14% (3/22) Intermediate-term: 9.1% (2/22) vs. 23% (5/22) Long-term: 18% (4/22) vs. 45% (10/22) | 4.5% (1/22) vs. 9.1% (2/22) | Not reported
HAL fluorescent cystoscopy | Geavlete, 2010^247^ | A: White light and HAL fluorescent cystoscopy with TURBT (n=223) B: White light cystoscopy (n=223) | Short-term: 11% (8/72) vs. 31% (20/64) | Not reported | Not reported
HAL fluorescent cystoscopy | Geavlete, 2011^248^ | A: White light and HAL fluorescent cystoscopy with TURBT (n=125) B: White light cystoscopy and TURBT (n=114) | Short-term: 7.2% (9/125) vs. 16% (18/114) Intermediate term: 12% (15/125) vs. 22% (25/114) Long-term: 31% (39/125) vs. 46% (52/114) | 2.4% (3/125) vs. 4.4% (5/114) at 1 year, 4% (5/125) vs. 7% (8/114) at 2 years | Not reported
HAL fluorescent cystoscopy | Hermann, 2011^250^ | A: White light and HAL fluorescent cystoscopy with TURBT (n=59) B: White light cystoscopy (n=74) | Intermediate-term: 17% (10/59) vs. 31% (23/74) Long-term: 31% (18/59) vs. 47% (35/74) | Not reported | Not reported
HAL fluorescent cystoscopy | Karaolides, 2012^251^ | A: White light and HAL fluorescent cystoscopy with TURBT (n=41) B: White light cystoscopy with TURBT (n-45) | Short-term: 2.4% (1/41) vs. 13% (6/45) Long-term: 17% (7/41) vs. 40% (18/45) | 0% (0/41) vs. 4.4% (2/45) | Not reported
HAL fluorescent cystoscopy | O'Brien, 2013^255^ | A: HAL fluorescent cystoscopy with TURBT (n=86) B: White light cystoscopy with TURBT (n=82) | Short-term: 20% (17/86) vs. 17% (14/82) Long-term: 31% (27/86) vs. 35% (29/82) | Not reported | 5.4% (7/129) vs. 0.8% (1/120)
HAL fluorescent cystoscopy | Stenzl, 2010^258^ (also Grossman 2012^249^) US, Canada, and Europe | A: White light cystoscopy following instillation of HAL, followed by second randomization: a: Fluorescent cystoscopy and TURBT (n=271) b: TURBT without fluorescent cystoscopy (excluded from recurrence analysis, n unclear) B: White light cystoscopy and TURBT (n=280) | Intermediate-term: 47% (128/271) vs. 56% (157/280) Long-term: 38% (97/255) vs. 32% (83/261) | 1.8% (5/271) vs. 2.5% (7/280) | Mortality: 1.4% (5/365) vs. 1.4% (5/361) at 9 months, 14% (39/271) vs. 16% (44/280) at median 53 to 55 months Bladder cancer mortality: 2.2% (6/271) vs. 2.9% (8/280)

5-ALA = 5-aminolevulinic acid; AUA = American Urological Association; BCG = bacillus Calmette Guérin; CI = confidence interval; CIS = carcinoma in situ; G1 = Grade 1; G2 = Grade 2; G3 = Grade 3; HAL = hexaminolevulinate; HR = hazard ratio; ITT = intention to treat; MMC = Mitomycin C; OR = odds ratio; pTa = Tumor stage a determined by pathology; T1 = Tumor stage 1; Ta = Tumor stage a; TURBT = transurethral resection of the bladder tumor

One other trial (n=604) did not meet inclusion criteria because it was published only as an abstract, but also reported results inconsistent with overall pooled estimates.260 It found no differences between fluorescent versus white light cystoscopy in risk for recurrence at short-term (29% vs. 29%) or long-term (24-month) followup (18% vs. 19%). Followup was performed with fluorescent cystoscopy.

There was no difference between fluorescent versus white light cystoscopy in risk of progression to muscle-invasive bladder cancer (9 trials, RR 0.78, 95% CI 0.55 to 1.12, I^2^=0%, Figure 37).241,245,246,248,251,256-259 Estimates were similar in analyses stratified by the photosensitizer used, risk of bias, masking of the followup cystoscopy to the initial cystoscopy method, or duration of followup (9-18 months versus >24 months). Results were also similar when the one trial that performed followup using fluorescent cystoscopy was excluded.256

Figure 37 Meta-analysis of fluorescent cystoscopy versus white light cystoscopy: Risk of progression to muscle-invasive bladder cancer

ALA = aminolevulinic acid; CI = confidence interval; HAL = hexaminolevulinate

Figure 37 is a forest plot titled meta-analysis of fluorescent cystoscopy versus white light cystoscopy: risk of progression to muscle invasive bladder cancer. The risk of progression values are represented by squares. Progression risk was reported or calculated for 5 studies for ALA, with a pooled risk of 0.86 (95% confidence interval 0.57 to 1.28), and the subtotal I-squared value of 0.0 (p=0.695). Recurrence risk was reported or calculated for 4 studies for HAL, with a pooled risk of 0.59 (95% confidence interval 0.29 to 1.22) and the subtotal I-squared value of 0.0 (p=0.898). The overall pooled risk was 0.78 (95% confidence interval 0.55 to 1.12) and the overall I-squared value was 0.0 (p=0.892).

There was no difference between fluorescent versus white light cystoscopy in risk of mortality, though this outcome was only reported in three trials and the estimate was imprecise (RR 1.28, 95% CI 0.55 to 2.95, I^2^=41%, Figure 38).255,257,258 Stratification by the photosensitizer used, the duration of followup, and risk of bias did not reduce statistical heterogeneity. There was also no difference between fluorescent versus white light cystoscopy in risk of mortality when the one trial256 that performed followup using fluorescent cystoscopy was excluded, or when the analysis was performed using the profile likelihood method.

Figure 38 Meta-analysis of fluorescent cystoscopy versus white light cystoscopy: Risk of mortality

ALA = aminolevulinic acid; CI = confidence interval; HAL = hexaminolevulinate

Figure 38 is a forest plot titled meta-analysis of fluorescent cystoscopy versus white light cystoscopy: risk of mortality. The risk of mortality values are represented by squares. Mortality risk was reported or calculated for 1 study for ALA, with a risk of 1.22 (95% confidence interval 0.34 to 4.46). Mortality risk was reported or calculated for 2 studies for HAL, with a pooled risk of 1.87 (95% confidence interval 0.29 to 12.22) and the subtotal I-squared value of 70.6 (p=0.065). The overall pooled risk was 1.28 (95% confidence interval 0.55 to 2.95) and the overall I-squared value was 42.8 (p=0.174).

One trial evaluated outcomes following use of narrow band imaging versus white light cystoscopy. It found narrow band imaging associated with lower risk of bladder cancer recurrence at 3 months (3.9% vs. 17%, OR 0.62, 95% CI 0.41 to 0.92) and at 12 months (OR 0.24, 95% 0.07 to 0.81).254 It did not report effects of narrow band imaging on risk of bladder cancer progression or mortality.

## Key Question 7 What are the comparative adverse effects of various tests for diagnosis and post-treatment surveillance of bladder cancer, including urinary biomarkers, cytology, and cystoscopy?

### Key Points

- Urinary biomarkers miss 23 to 42 percent of patients with bladder cancer and are incorrectly positive in 11 to 28 percent of patients without bladder cancer, but no study directly measured effects of inaccurate diagnosis on clinical outcomes (SOE: insufficient).
- There were no clear differences between fluorescent cystoscopy versus white light cystoscopy in risk of false-positives in two trials (SOE: low).
- There were no clear differences between fluorescent cystoscopy versus white light cystoscopy in risk of renal and genitourinary adverse events in two trials (SOE: low).

### Detailed Synthesis

Urinary biomarkers are associated with potential harms as a result of false-negative tests (which could result in a failure to perform cystoscopy and diagnosis bladder cancer when it is present) or false-positive tests (which could result in unnecessary cystoscopy when bladder cancer is absent). As presented in Key Question 1, the sensitivity of urinary biomarkers ranged from 0.58 to 0.77, meaning that 23 to 42 percent of cancers were missed, and the specificity ranged from 0.72 to 0.89, meaning that 11 to 28 percent of patients without bladder cancer had incorrectly positive tests. However, no study directly measured the clinical consequences of false-negative or false-positives in terms of clinical outcomes such as morbidity, mortality, quality of life due to delayed diagnosis, or complications related to unnecessary cystoscopy.

Harms were not well reported in 13 trials of fluorescent cystoscopy versus white light cystoscopy. Seven trials did not report adverse events at all; two others reported no complications associated with intravesical instillation of the photosensitizer HAL but did not describe methods used to identify adverse events.248,255 Two trials found no clear difference in risk of false-positives with HAL fluorescent cystoscopy versus white light cystoscopy (25% vs. 16%, RR 1.51, 95% CI 0.88 to 2.57 and 10% vs. 12%, RR 0.80, 95% CI 0.62 to 1.04).250,258 There were also no clear differences between fluorescent cystoscopy versus white light cystoscopy in risk of renal and genitourinary adverse events257,258 or serious adverse events.258,259 One trial found no difference between narrow band imaging versus white light cystoscopy in risk of false-positives.254

## Key Question 8 What are the comparative adverse effects of various treatments for non–muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT?

### Key Points

#### Intravesical Therapy Versus No Intravesical Therapy

- Four trials of BCG vs. no intravesical therapy reported granulomatous cystitis or irritative symptoms in 27 to 84 percent of patients, macroscopic hematuria in 21 to 72 percent, and fever in 27 to 44 percent. Harms were not reported in patients who did not receive intravesical therapy (SOE: low).
- Evidence on harms associated with non-BCG intravesical therapies versus no intravesical therapy was very limited, though some trials reported an increased risk of local adverse events. Evidence was insufficient to determine effects of non-BCG intravesical therapies versus no intravesical therapy on risk of systemic adverse events (SOE: low for local adverse events, insufficient for systemic adverse events).

#### BCG Versus MMC

- BCG was associated with increased risk of any local adverse event (2 trials, RR 2.01, 95% CI 1.59 to 2.54, I^2^=0%), granulomatous cystitis (5 trials, RR 1.71, 95% CI 1.22 to 2.41, I^2^=58%), dysuria (3 trials, 48% vs. 32%, RR 1.23, 95% CI 1.03 to 1.46, I^2^=34%), and hematuria (6 trials, RR 1.78, 95% CI 1.24 to 2.56, I^2^=62%) versus MMC (SOE: low for local adverse events and dysuria; moderate for granulomatous cystitis and hematuria).
- BCG was associated with increased risk of any systemic adverse event (2 trials, RR 2.01, 95% CI 1.59 to 2.54, I^2^=0%) and fever (4 trials, RR 4.51, 95% CI 2.31 to 8.82, I^2^=25%) versus MMC (SOE: low for systemic adverse events and fever).
- There was no difference between BCG versus MMC in risk of discontinuation of instillations (4 trials, RR 1.26, 95% CI 0.39 to 4.01, I^2^=70%) (SOE: low).
- BCG was associated with increased risk of discontinuation of instillations versus BCG plus MMC given sequentially (1 trial, RR 4.06, 95% CI 2.09 to 7.86) (SOE: low).

#### BCG Plus MMC Versus MMC

- There was no difference between sequentially administered BCG plus MMC and MMC alone in local adverse events (1 trial, RR 1.36, 95% CI 0.60 to 3.08) or risk of cystitis (1 trial, RR 1.30, 95% CI 0.88 to 1.93) (SOE: low for local adverse events and cystitis).
- There was no difference between BCG and MMC given sequentially and MMC used alone in systemic adverse events (1 trial, RR 1.07, 95% CI 0.63 to 1.84) but BCG plus MMC was associated with increased risk of fever (1 trial, 12% vs. 3%, RR 3.75, 95% CI 1.08 to 13) (SOE: low for systemic adverse events and fever).
- There was no difference between alternating BCG plus MMC and MMC alone in risk of discontinuation of instillations in patients with CIS (1 trial, RR 0.54, 95% CI 0.16 to 1.84) or in patients with Ta or T1 tumors (1 trial, RR 0.93, 95% CI 0.52 to 1.65) (SOE: low).

#### BCG Versus Doxorubicin

- BCG was associated with increased risk of cystitis versus doxorubicin (1 trial, RR 17, 95% CI 1 to 289), but there was insufficient evidence to determine effects on dysuria (3 trials, data not pooled) and hematuria (2 trials, data not pooled) due to small numbers of trials with inconsistent results (SOE: low for cystitis; insufficient for dysuria and hematuria).

#### BCG Versus Epirubicin

- BCG was associated with increased risk of local side effects (1 trial, RR 3.28, 95% CI 1.26 to 8.53), granulomatous cystitis (4 trials, RR 1.86, 95% CI 1.35 to 2.56, I^2^=65%), dysuria (1 trial, RR 2.43, 95% CI 1.13 to 5.24), hematuria (4 trials, RR 1.77, 95% CI 1.41 to 2.22, I^2^=0%) and fever (2 trials, RR 9.73, 95% CI 2.72 to 35,I 2=0%) versus epirubicin alone, but results were mixed for discontinuation of intravesical therapy (2 trials, data not pooled) (SOE: low for local side effects, dysuria; granulomatous cystitis, hematuria, and fever; insufficient for discontinuation of instillations).
- BCG was associated with increased risk of systemic adverse events (1 trial, RR 5.97, 95% CI 2.18 to 16), granulomatous cystitis (1 trial, RR 2.28, 95% CI 1.46 to 3.54) and discontinuation of instillations (1 trial, RR 4.56, 95% CI 1.35 to 15) versus sequentially administered BCG and epirubicin, but there was no difference in risk of dysuria (1 trial, RR 1.22, 95% CI 0.56 to 2.66), hematuria (2 trials, RR 2.27, 95% CI 0.86 to 6.00, I^2^=0%) or fever (2 trials, RR 2.09, 95% CI 0.48 to 9.02, I^2^=0%) (SOE: low for systemic adverse events, granulomatous cystitis, discontinuation of instillations, dysuria, hematuria, and fever).

#### BCG Versus Gemcitabine

- There were no differences between BCG and gemcitabine in risk of local adverse events requiring postponement or discontinuation of intravesical therapy (1 trial, RR 1.33, 95% CI 0.32 to 5.49), systemic adverse events (1 trial, RR 0.50, 95% CI 0.10 to 2.5), dysuria (2 trials, RR 1.51, 95% CI 0.92 to 2.50, I^2^=0%), or hematuria (2 trials, RR 4.62, 95% CI 0.78 to 27, I^2^=29%), but BCG was associated with increased risk of fever (2 trials, RR 6.24, 95% CI 1.03 to 38, I^2^=5%) (SOE: low for local and systemic adverse events, dysuria, hematuria, and fever).
- One trial found no difference between BCG versus BCG plus gemcitabine given sequentially in risk of dysuria (RR 0.92, 95% CI 0.52 to 1.65) or hematuria (RR 0.30, 95% CI 0.08 to 1.09) (SOE: low).

#### BCG Versus Interferon

- BCG was associated with increased risk of dysuria versus interferon alpha-2a (1 trial, RR 84, 95% CI 5.29 to 1319) but no difference in risk of fever (1 trial, RR 4.82, 95% CI 0.25 to 94) (SOE: low for dysuria and fever).
- BCG was associated with increased risk of constitutional symptoms (1 trial, RR 1.63, 95% CI 1.12 to 2.38) and fever (1 trial, RR 2.26, 95% CI 1.30 to 3.95) versus coadministration of BCG and interferon alpha-2b (SOE: low for constitutional symptoms and fever).

#### BCG Versus Thiotepa

- BCG was associated with increased risk of bladder irritability (1 trial, RR 2.93, 95% CI 1.45 to 5.90), cystitis (1 trial, RR 18, 95% CI 1.11 to 306), and fever (1 trial, RR 8.36, 95% CI 0.47 to 150) versus thiotepa (SOE: low for dysuria, cystitis and fever).

#### MMC Versus Doxorubicin

- Evidence was insufficient to determine effects of MMC versus doxorubicin on risk of local adverse events, based on inconsistent results from six trials (SOE: insufficient).

#### MMC Versus Epirubicin

- One small trial found no difference between MMC versus epirubicin 80 mg in risk of urinary symptoms (SOE: low).

#### MMC Versus Interferon Alpha

- One trial found MMC associated with greater risk of hematuria versus interferon alpha (RR 2.00, 95% CI 1.09 to 3.65), decreased risk of fever (RR 0.13, 95% CI 0.03 to 0.55), and no difference in risk of dysuria or urinary frequency (SOE: low).

#### MMC Versus Gemcitabine

- One trial found MMC associated with increased risk of chemical cystitis versus gemcitabine (RR 3.93, 95% CI 1.17 to 13.14), with no difference in risk of dysuria or hematuria. (SOE: low).

#### Doxorubicin Versus Epirubicin

- Doxorubicin was associated with increased risk of chemical cystitis versus epirubicin (1 trial, RR 1.85, 95% CI 1.13 to 3.03), with no clear difference in risk of dysuria or urinary frequency (2 trials) or hematuria (3 trials, RR 1.53, 95% CI 0.50 to 4.66, I^2^=0%) (SOE: low for chemical cystitis, urinary frequency, and hematuria).

#### Doxorubicin Versus Thiotepa

- One trial found no difference between doxorubicin versus thiotepa in risk of bladder irritability (RR 0.92, 95% CI 0.36 to 2.37) (SOE: low).

#### Epirubicin Versus Interferon Alpha

- One trial found no difference between epirubicin versus interferon alpha in risk of dysuria or fever (SOE: low).

### Detailed Synthesis

#### Intravesical Drugs Versus No Intravesical Therapy

Eight trials evaluated harms of intravesical therapy versus no intravesical therapy.117,131,133,135-138,140 One trial evaluated MMC,117 two trials epirubicin,131,133 two trials interferon alpha,136,137 one trial interferon-gamma,138 one trial thiotepa,140 and one trial gemcitabine.135 Reporting of harms was suboptimal and focused primarily on local adverse events.

#### BCG

Trials of BCG versus no intravesical therapy only reported harms in patients receiving BCG. Granulomatous cystitis or irritative vesical symptoms were reported in 27^110^ to 84 percent104 of patients, macroscopic hematuria in 21^104^ to 72 percent,205 and fever from 27^104^ to 44 percent.109

#### MMC

One trial (n=121) found no difference between a single instillation of MMC 40 mg versus TURBT alone in risk of chemical cystitis [3.5% (2/57) vs. 1.6% (1/64)].117

#### Doxorubicin

No study evaluated harms of doxorubicin versus no intravesical therapy.

#### Epirubicin

One trial found single instillation epirubicin 80 mg (up to 4 repeat instillations for recurrence) associated with increased risk of chemical cystitis versus placebo (12% vs. 1.9%; RR 6.29, 95% CI 2.22 to 17.8).131 A second trial of single instillation epirubicin 100 mg versus no intravesical therapy also reported imprecise estimates and no statistically significant differences in risk of dysuria (5.9% [4/68] vs. 0.0% [0/66]; RR 8.74, 95% CI 0.48 to 159) or fever (0.0% [0/68] vs. 0.9% [1/66]; RR 0.32, 95% CI 0.01 to 7.80).133

#### Gemcitabine

One trial (n=328) found no difference between a single instillation of gemcitabine 2000 mg versus placebo risk of experiencing at least one adverse event (30% vs. 26%; RR 1.11, 95% CI 0.79 to 1.57) or fever (1.2% [2/166] vs. 0.6% [1/162]).135

#### Interferon Alpha

One trial (n=78) found no difference between interferon alpha versus no intravesical therapy in risk of urinary tract infection (23.3% vs. 16.7%, p=NS).137 Another trial (n=89) of maintenance therapy with three different doses of interferon alpha (40, 60, and 80 MU) versus no intravesical therapy reported high fever related to urinary tract infections in five patients, but did not specify treatment groups.136

#### Interferon Gamma

One trial (n=54) of induction therapy with interferon-gamma 21 MU (8 instillations over 8 weeks) versus no intravesical therapy reported no withdrawals from treatment due to adverse events, though harms were otherwise poorly reported.138

#### Thiotepa

One trial (n=93) evaluated a maintenance regimen with thiotepa 60 or 30 mg versus no intravesical therapy.140 Urinary tract symptoms were reported in 17 percent (4/23) of patients randomized to thiotepa 60 mg (2 patients with UTI and 2 with dysuria and urinary frequency) but no patients in the other groups (0% [0/23] vs. 0% [0/47]).140

#### Intravesical Drugs Versus Intravesical Drugs

Fifteen trials evaluated harms of one drug administered for intravesical therapy versus another. Six trials evaluated MMC vs. doxorubicin,101,112,115,116,144,191 one trial MMC vs. epirubicin,192 two trials MMC vs. interferon alpha,193,221 one trial MMC vs. gemcitabine,194 three trials doxorubicin vs. epirubicin,119,195,196 one trial doxorubicin vs. thiotepa,172 and one trial epirubicin vs. interferon alpha.133 Evaluation of harms was generally suboptimal and inconsistently reported.

##### BCG Versus MMC

BCG was associated with increased risk of any local adverse event versus MMC when each was administered alone (2 trials, 40% vs. 20%, RR 2.01, 95% CI 1.59 to 2.54, I^2^=0%).151,156 Regarding specific local adverse events, BCG was also associated with increased risk of granulomatous cystitis (5 trials, 31% vs. 19%, RR 1.71, 95% CI 1.22 to 2.41, I^2^=58%),111,153,155,156,160 dysuria (3 trials, 48% vs. 32%, RR 1.23, 95% CI 1.03 to 1.46, I^2^=34%),147,152,154 and hematuria (36% vs. 18%, 6 trials, RR 1.78, 95% CI 1.24 to 2.56, I^2^=62%).111,147,152-154,155 Estimates were similar using the profile likelihood method. For granulomatous cystitis, excluding one trial160 that administered nine instillations of MMC (versus 12 to 38 instillations in the other trials) reduced statistical heterogeneity, though the pooled estimate was similar (4 trials, RR 2.01, 95% CI 1.56 to 2.59, I^2^=0%). Other sensitivity and subgroup analyses had little effect on findings.

BCG was also associated with increased risk of any systemic adverse event (3 trials, 14% vs. 4%, RR 2.93, 95% CI 1.80 to 4.78, I^2^=0%)151,156,160 and fever (4 trials, 18% vs. 3%, RR 4.51, 95% CI 2.31 to 8.82,I^2^=25%).147,152,153,155

There was no difference between BCG versus MMC alone in risk of discontinuation of further bladder instillations (4 trials, RR 1.26, 95% CI 0.39 to 4.01, I^2^=70%), though statistical heterogeneity was present.149,152,153,160 BCG was associated with reduced risk of discontinuation in one trial that did not include patients with grade 3 tumors,(4% vs. 24%, RR 0.18, 95% CI 0.04 to 0.78)153 but was associated with increased risk of discontinuation in the three trials that included patients with grade 3 tumors (9% vs. 4%, RR 1.88, 95% CI 1.05 to 3.38, I^2^=0%).149,152,160

No trial of BCG versus sequential BCG plus MMC evaluated risk of local or systemic adverse events. One trial (n=304) found BCG associated with increased risk of discontinuation of bladder instillations versus sequential BCG plus MMC (26% vs. 6%, RR 4.06, 95% CI 2.09 to 7.86)163

##### BCG Plus MMC Versus MMC

One trial (n=182) found no difference between BCG plus MMC administered sequentially versus MMC alone in risk of experiencing any local adverse event (RR 1.36, 95% CI 0.60 to 3.08) or granulomatous cystitis (RR 1.30, 95% CI 0.88 to 1.93).166 There was also no difference in risk of any systemic adverse event (1 trial, RR 1.07, 95% CI 0.63 to 1.84). Although BCG plus MMC was associated with increased risk of fever (1 trial, 12% vs. 3%, RR 3.75, 95% CI 1.08 to 13), the estimate was very imprecise.

One other trial (n=256) found no difference between alternating BCG plus MMC versus MMC alone in risk of discontinuation of intravesical therapy in patients with CIS (RR 0.54, 95% CI 0.16 to 1.84)169 or in patients with Ta or T1 tumors (RR 0.93, 95% CI 0.52 to 1.65).168

##### BCG Versus Doxorubicin

One trial found BCG associated with increased risk of cystitis versus doxorubicin, but the estimate was very imprecise (RR 17, 95% CI 1 to 289).172 Findings for dysuria were mixed, with one trial finding decreased risk with BCG (RR 0.49, 95% CI 0.30 to 0.82),170 one trial finding increased risk with BCG (RR 3.16, 95% CI 1.50 to 6.67),172 and one trial finding no difference (RR 1.24, 95% CI 0.99 to 1.56).171 The three trials differed in the dose of BCG (80 mg to 150 mg) and doxorubicin administered (20 mg to 50 mg). The trial that found BCG associated with decreased risk of dysuria used the lowest doses of both BCG and doxorubicin.

Effects on risk of systemic adverse events were also inconsistent. One trial found BCG associated with decreased risk of hematuria versus doxorubicin (RR 0.50, 95% CI 0.43 to 0.85),170 but a second trial found no difference (RR 1.36, 95% CI 0.95 to 1.95).171 One trial found BCG associated with increased risk of fever versus doxorubicin (RR 5.03, 95% CI 2.75 to 9.19),171 but a second trial found no difference (RR 0.82, 95% CI 0.64 to 1.05).170

##### BCG Versus Epirubicin

One trial found BCG associated with increased risk of any local side effect versus epirubicin when each was administered alone (20% vs. 6%, RR 3.28, 95% CI 1.26 to 8.53).177 BCG was also associated with increased risk of granulomatous cystitis (4 trials, 48% vs. 28%, RR 1.86, 95% CI 1.35 to 2.56, I^2^=65%),103,175,177,178 dysuria (1 trial, 24% vs. 10%, RR 2.43, 95% CI 1.13 to 5.24),177 and hematuria (4 trials, 33% vs. 19%, RR 1.77, 95% CI 1.41 to 2.22, I^2^=0%).103,175,177,178 For granulomatous cystitis, the estimate was similar using the profile likelihood method and subgroup analyses did not impact findings.

BCG was associated with increased risk of fever versus epirubicin when each was administered alone (2 trials, 16% vs. 1%, RR 9.73, 95% CI 2.72 to 35, I^2^=0%).103,177 One trial found BCG associated with increased risk of discontinuation of intravesical therapy (32% vs. 10%, RR 3.29, 95% CI 1.58 to 6.83),177 though another trial found no difference (RR 0.95, 95% CI 0.85 to 1.05).178

BCG was associated with increased risk of granulomatous cystitis versus sequentially-administered BCG plus epirubicin (1 trial, 62% vs. 27%, RR 2.28, 95% CI 1.46 to 3.54),180 but there was no difference in risk of dysuria (1 trial, RR 1.22, 95% CI 0.56 to 2.66)181 or hematuria (2 trials, RR 2.27, 95% CI 0.86 to 6.00, I^2^=0%).180,181

BCG was associated with increased risk of any systemic adverse event versus alternating BCG plus epirubicin (1 trial, 36% vs. 6%, RR 5.97, 95% CI 2.18 to 16),180 but there was no difference in risk of fever (2 trials, RR 2.09, 95% CI 0.48 to 9.02, I^2^=0%).180,181 One trial found BCG associated with increased risk of discontinuation of intravesical therapy versus alternating BCG plus epirubicin (21% vs. 5%, RR 4.56, 95% CI 1.35 to 15).180

##### BCG Versus Epirubicin Plus Interferon

One trial found BCG associated with increased likelihood of discontinuation of intravesical therapy versus the combination of epirubicin plus interferon, but the estimate was imprecise (9% vs. 2%, RR 5.41, 95% CI 1.23 to 24).182 There was no difference in frequency of subjective urinary problems (specific adverse events and rates not reported).

##### BCG Versus Gemcitabine

One trial found no difference between BCG versus gemcitabine in risk of local adverse events requiring postponement or discontinuation of intravesical therapy (RR 1.33, 95% CI 0.32 to 5.49).185 Two trials found no difference between BCG versus gemcitabine in risk of dysuria (RR 1.51, 95% CI 0.92 to 2.50, I^2^=0%) or hematuria (RR 4.62, 95% CI 0.78 to 27, I^2^=29%).184,186 No trial reported risk of granulomatous cystitis.

One trial found no difference between BCG versus gemcitabine in risk of any systemic adverse event (RR 0.50, 95% CI 0.10 to 2.5).185 Two trials found BCG associated with increased risk of fever, though the estimate was imprecise (RR 6.24, 95% CI 1.03 to 38, I^2^=5%).184,186

One trial found no difference between BCG versus BCG plus gemcitabine given sequentially in risk of dysuria (RR 0.92, 95% CI 0.52 to 1.65) or hematuria (RR 0.30, 95% CI 0.08 to 1.09).187 No cases of fever were reported.187

##### BCG Versus Interferon

One trial of BCG versus interferon alpha-2a found BCG associated with increased risk of dysuria (85% vs. 0%, RR 84, 95% CI 5.29 to 1319) and fever, but estimates were extremely imprecise (RR 4.82, 95% CI 0.25 to 94).188

One trial found BCG associated with increased risk of constitutional symptoms (18% vs. 11%, RR 1.63, 95% CI 1.12 to 2.38) and fever (11% vs. 5%, RR 2.26, 95% CI 1.30 to 3.95) versus BCG coadministered with interferon alpha-2b.190

##### BCG Versus Thiotepa

One trial found BCG was associated with increased risk of bladder irritability (42% vs. 13%, RR 2.93, 95% CI 1.45 to 5.90), cystitis (16% vs. 0%, RR 18, 95% CI 1.11 to 306), and fever (7% vs. 0%, RR 8.36, 95% CI 0.47 to 150) versus thiotepa.172 No patient randomized to thiotepa reported cystitis or fever, resulting in very wide confidence intervals.

##### MMC Versus Doxorubicin

Six trials reported inconsistent effects of MMC versus doxorubicin administered as induction or maintenance therapy in risk of dysuria or chemical cystitis.101,112,115,116,144,191 Two trials found MMC was associated with decreased risk of chemical cystitis versus doxorubicin (8.9% vs. 22%, RR 0.41 [95% CI 0.22 to 0.75]116 and 21% vs. 48%, RR 0.31 [95% CI 0.23 to 0.42]),191 but one trial found MMC associated with a nonstatistcially significant increased risk of chemical cystitis (19% vs. 13%, RR 1.44, 95% CI 0.32 to 6.54).144 Three trials found no statistically significant differences in risk of dysuria or urinary frequency,112,115,116 three trials found no difference in risk of hematuria,112,116,144 and one trial found no difference in risk of bladder irritability.144 Data were not poolable because event rates and sample sizes were not reported in all trials.

##### MMC Versus Epirubicin

One small trial (n=44) found no difference between maintenance therapy with MMC 40 mg and a single instillation or maintenance therapy with epirubicin 80 mg in risk of urinary symptoms (13% [2/15] vs. 7% [1/14] vs. 13% [2/15], respectively).192

##### MMC Versus Interferon Alpha

One trial (n=287) found induction therapy with MMC 40 mg associated with higher risk of hematuria versus interferon alpha (19% vs. 9.8%; RR 2.00, 95% CI 1.09 to 3.65).193 There were no statistically significant differences in risk of dysuria (46% vs. 43%) or urinary frequency (47% vs. 41%). MMC was associated with lower risk of fever (1.4% vs. 11% ; RR 0.13, 95% CI 0.03 to 0.55). No patient in either group had to be withdrawn due to adverse effects. Another trial of induction regimens found no difference between MMC versus interferon alpha in risk of bladder pain (10% vs. 15%), though MMC was associated with increased risk of urinary frequency (28% vs. 11%, p not reported).221 There were no clear differences in risk of withdrawal due to adverse events.

##### MMC Versus Interferon Gamma

No study evaluated harms of MMC versus interferon-gamma.

##### MMC Versus Gemcitabine

One trial (n=109) found induction therapy with MMC associated with increased risk of chemical cystitis versus gemcitabine (21% vs. 6%; RR 3.93, 95% CI 1.17 to 13.14).194 There were no statistically significant differences in risk of dysuria (20% vs. 9%) or hematuria (7% vs. 4%). Treatment was delayed due to local adverse effects (not specified) in 10 percent of MMC patients and 5 percent of gemcitabine patients.

##### Doxorubicin Versus Epirubicin

One trial found maintenance therapy with doxorubicin associated with increased risk of chemical cystitis versus epirubicin (35% vs. 19%; RR 1.85, 95% CI 1.13 to 3.03).119 Three patients (5%) in the doxorubicin group experienced systemic side effects (one case each of thrombocytopenia, hypersensitivity reaction, and fever). Two trials of maintenance therapy found no clear differences in disk of dysuria, or urinary frequency.195 There was also no difference in risk of hematuria (3 trials, RR 1.53, 95% CI 0.50 to 4.66; I^2^=0.0).119,195,196

##### Doxorubicin Versus Thiotepa

One trial (n=109) found no difference between maintenance therapy with doxorubicin versus thiotepa in risk of bladder irritability (13% vs. 14%; RR 0.92, 95% CI 0.36 to 2.37).172 Other harms were not reported

##### Epirubicin Versus Interferon Alpha

One trial (n=134) found no difference between a single instillation of epirubicin versus interferon alpha in risk of dysuria (5.9% [4/68] vs. 1.5% [1/66]) or fever (0.0% [0/68] vs. 6.1% [4/66]).133 Other harms were not reported.

## Key Question 8a How do adverse effects of treatment vary by patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease?

### Key Points

- No study evaluated how harms of treatment vary in subgroups defined by patient characteristics such as age, sex, race/ethnicity, performance status, or medical comorbidities (SOE: insufficient).