# References

1 Siegel R, Ma J, Zou Z, et al. (2014). Cancer statistics, 2014. CA Cancer J for Clin.
2 U.S. Cancer Statistics Working Group. (2013). United States Cancer Statistics: 1999-2009 Incidence and Mortality Web-based Report.
3 National Cancer Institute. Surveillance, Epidemiology and End Results Program: Turning Cancer Data Into Discovery. Browse the SEER Cancer Statistics Review (CSR) 1975-2009.
4 James AC, Gore JL. (2013). The costs of non-muscle invasive bladder cancer. Urol Clin North Am.
5 American Cancer Society. Bladder Cancer; Early Detection, Diagnosis, and Staging Topics.
6 Kaufman DS, Shipley WU, Feldman AS. (2009). Bladder cancer. Lancet.
7 American Cancer Society. (2013). Bladder Cancer; Survival rates for bladder cancer by stage.
8 Babjuk M, Burger M, Zigeuner R, et al. (2013). EAU guidelines on non-muscle-invasive urothelial carcinoma of the bladder: update 2013. Eur Urol.
9 Cancer Research UK. (2013). Bladder cancer stage and grade.
10 American Cancer Society. (2014). Society AC, editor. How is bladder cancer staged?.
11 American Cancer Society. Bladder Cancer; How is bladder cancer diagnosed?.
12 Herman MP, Svatek RS, Lotan Y, et al. (2008). Urine-based biomarkers for the early detection and surveillance of non-muscle invasive bladder cancer. Minerva Urologica e Nefrologica.
13 Hall MC, Chang SS, Dalbagni G, et al. (2007). Guideline for the management of nonmuscle invasive bladder cancer (stages Ta, T1, and Tis): 2007 update. J Urol.
14 Babjuk M, Oosterlinck W, Sylvester R, et al. (2011). EAU guidelines on non-muscle-invasive urothelial carcinoma of the bladder, the 2011 update. Eur Urol.
15 Agency for Healthcare Research and Quality. (2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
16 Whiting PF, Rutjes AWS, Westwood ME, et al. (2011). QUADAS-2: A Revised Tool for the Quality Assessment of Diagnostic Accuracy Studies. Ann Intern Med.
17 Altman DG, Bland JM. (1994). Diagnostic tests 3: receiver operating characteristic plots. BMJ.
18 Zweig MH, Campbell G. (1993). Receiver-operating characteristic (ROC) plots: a fundamental evaluation tool in clinical medicine. Clin Chem.
19 U.S. Preventive Services Task Force. (2008). U.S. Preventive Services Task Force Procedure Manual.
20 Agency for Healthcare Research and Quality. (2012). Methods Guide for Medical Test Reviews.
21 Fu R, Gartlehner G, Grant M, et al. (2013). Conducting quantitative synthesis when comparing medical interventions. Agency for Healthcare Research and Quality, editor. Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
22 Chu H, Cole SR. (2006). Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. J Clin Epidemiol.
23 Zwinderman AH, Bossuyt PM. (2008). We should not pool diagnostic likelihood ratios in systematic reviews. Stat Med.
24 Trikalinos TA, Balion CM, Coleman CI, et al. (2012). Chapter 8: meta-analysis of test performance when there is a “gold standard”. J Gen Intern Med.
25 Chappell FM, Raab GM, Wardlaw JM. (2009). When are summary ROC curves appropriate for diagnostic meta-analyses?. Stat Med.
26 Takwoingi Y, Leeflang MM, Deeks JJ. (2013). Empirical evidence of the importance of comparative studies of diagnostic test accuracy. Ann Intern Med.
27 Fu R, Gartlehner G, Grant M, et al. (2011). Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
28 Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. BMJ.
29 Cornell JE, Mulrow CD, Localio R, et al. (2014). Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med.
30 Chahal R, Darshane A, Browning AJ, et al. (2001). Evaluation of the clinical value of urinary NMP22 as a marker in the screening and surveillance of transitional cell carcinoma of the urinary bladder. Eur Urol.
31 Feil G, Zumbragel A, Paulgen-Nelde HJ, et al. (2003). Accuracy of the ImmunoCyt assay in the diagnosis of transitional cell carcinoma of the urinary bladder. Anticancer Res.
32 Friedrich MG, Hellstern A, Hautmann SH, et al. (2002). Clinical use of urinary markers for the detection and prognosis of bladder carcinoma: a comparison of immunocytology with monoclonal antibodies against Lewis X and 486p3/12 with the BTA STAT and NMP22 tests. J Urol.
33 Giannopoulos A, Manousakas T, Gounari A, et al. (2001). Comparative evaluation of the diagnostic performance of the BTA stat test, NMP22 and urinary bladder cancer antigen for primary and recurrent bladder tumors. J Urol.
34 Gibanel R, Ribal MJ, Filella X, et al. (2002). BTA TRAK urine test increases the efficacy of cytology in the diagnosis of low-grade transitional cell carcinoma of the bladder. Anticancer Res.
35 Grossman HB, Messing E, Soloway M, et al. (2005). Detection of bladder cancer using a point-of-care proteomic assay. JAMA.
36 Grossman HB, Soloway M, Messing E, et al. (2006). Surveillance for recurrent bladder cancer using a point-of-care proteomic assay. JAMA.
37 Gudjonsson S, Isfoss BL, Hansson K, et al. (2008). The value of the UroVysion assay for surveillance of non-muscle-invasive bladder cancer. Eur Urol.
38 Gupta NP, Sharma N, Kumar R. (2009). Nuclear matrix protein 22 as adjunct to urine cytology and cystoscopy in follow-up of superficial TCC of urinary bladder. Urology.
39 Gutierrez Banos JL, Rebollo Rodrigo MH, Antolin Juarez FM, et al. (2001). NMP 22, BTA stat test and cytology in the diagnosis of bladder cancer: a comparative study. Urol Int.
40 Halling KC, King W, Sokolova IA, et al. (2002). A comparison of BTA stat, hemoglobin dipstick, telomerase and Vysis UroVysion assays for the detection of urothelial carcinoma in urine. J Urol.
41 Ianari A, Sternberg CN, Rossetti A, et al. (1997). Results of Bard BTA test in monitoring patients with a history of transitional cell cancer of the bladder. Urology.
42 Irani J, Desgrandchamps F, Millet C, et al. (1999). BTA stat and BTA TRAK: A comparative evaluation of urine testing for the diagnosis of transitional cell carcinoma of the bladder. Eur Urol.
43 Karnwal A, Venegas R, Shuch B, et al. (2010). The role of fluorescence in situ hybridization assay for surveillance of non-muscle invasive bladder cancer. Can J Urol.
44 Leyh H, Hall R, Mazeman E, et al. (1997). Comparison of the Bard BTA test with voided urine and bladder wash cytology in the diagnosis and management of cancer of the bladder. Urology.
45 Leyh H, Mazeman E. (1997). Bard BTA test compared with voided urine cytology in the diagnosis of recurrent bladder cancer. Eur Urol.
46 Lodde M, Mian C, Negri G, et al. (2003). Role of uCyt+ in the detection and surveillance of urothelial carcinoma. Urology.
47 Lotan Y, Capitanio U, Shariat SF, et al. (2009). Impact of clinical factors, including a point-of-care nuclear matrix protein-22 assay and cytology, on bladder cancer detection. BJU International.
48 Messing EM, Teot L, Korman H, et al. (2005). Performance of urine test in patients monitored for recurrence of bladder cancer: a multicenter study in the United States. J Urol.
49 Mian C, Lodde M, Haitel A, et al. (2000). Comparison of two qualitative assays, the UBC rapid test and the BTA stat test, in the diagnosis of urothelial cell carcinoma of the bladder. Urology.
50 Mian C, Pycha A, Wiener H, et al. (1999). Immunocyt: a new tool for detecting transitional cell cancer of the urinary tract. J Urol.
51 Nasuti JF, Gomella LG, Ismial M, et al. (1999). Utility of the BTA stat test kit for bladder cancer screening. Diag Cytopathol.
52 O'Sullivan P, Sharples K, Dalphin M, et al. (2012). A multigene urine test for the detection and stratification of bladder cancer in patients presenting with hematuria. J Urol.
53 Paoluzzi M, Cuttano MG, Mugnaini P, et al. (1999). Urinary dosage of nuclear matrix protein 22 (NMP22) like biologic marker of transitional cell carcinoma (TCC): a study on patients with hematuria. Archivio Italiano di Urologia, Andrologia.
54 Pfister C, Chautard D, Devonec M, et al. (2003). Immunocyt test improves the diagnostic accuracy of urinary cytology: results of a French multicenter study. J Urol.
55 Placer J, Espinet B, Salido M, et al. (2002). Clinical utility of a multiprobe FISH assay in voided urine specimens for the detection of bladder cancer and its recurrences, compared with urinary cytology. Eur Urol.
56 Pode D, Shapiro A, Wald M, et al. (1999). Noninvasive detection of bladder cancer with the BTA stat test. J Urol.
57 Ponsky LE, Sharma S, Pandrangi L, et al. (2001). Screening and monitoring for bladder cancer: refining the use of NMP22. J Urol.
58 Quek P, Chin CM, Lim PHC. (2002). The role of BTA stat in clinical practice. Annals of the Academy of Medicine, Singapore.
59 Raitanen MP, Leppilahti M, Tuhkanen K, et al. (2001). Routine follow-up cystoscopy in detection of recurrence in patients being monitored for bladder cancer. Annales Chirurgiae et Gynaecologiae.
60 Saad A, Hanbury DC, McNicholas TA, et al. (2002). A study comparing various noninvasive methods of detecting bladder cancer in urine. BJU International.
61 Sanchez-Carbayo M, Urrutia M, Silva JM, et al. (2001). Comparative predictive values of urinary cytology, urinary bladder cancer antigen, CYFRA 21-1 and NMP22 for evaluating symptomatic patients at risk for bladder cancer. J Urol.
62 Sarosdy MF, Schellhammer P, Bokinsky G, et al. (2002). Clinical evaluation of a multi-target fluorescence in situ hybridization assay for detection of bladder cancer. J Urol.
63 Sawczuk IS, Bagiella E, Sawczuk AT, et al. (2000). Clinical application of NMP22 in the management of transitional cell carcinoma of the bladder. Cancer Detect Prev.
64 Schamhart DH, de Reijke TM, van der Poel HG, et al. (1998). The Bard BTA test: its mode of action, sensitivity and specificity, compared to cytology of voided urine, in the diagnosis of superficial bladder cancer. Eur Urol.
65 Serretta V, Lo Presti D, Vasile P, et al. (1998). Urinary NMP22 for the detection of recurrence after transurethral resection of transitional cell carcinoma of the bladder: experience on 137 patients. Urology.
66 Shariat SF, Marberger MJ, Lotan Y, et al. (2006). Variability in the performance of nuclear matrix protein 22 for the detection of bladder cancer. J Urol.
67 Sharma S, Zippe CD, Pandrangi L, et al. (1999). Exclusion criteria enhance the specificity and positive predictive value of NMP22 and BTA stat. J Urol.
68 The United Kingdom and Eire Bladder Tumour Antigen Study Group. (1997). The use of the bladder-tumour associated analyte test to determine the type of cystoscopy in the follow-up of patients with bladder cancer. BJU.
69 Thomas L, Leyh H, Marberger M, et al. (1999). Multicenter trial of the quantitative BTA TRAK assay in the detection of bladder cancer. Clin Chem.
70 van der Poel HG, van Balken MR, Schamhart DH, et al. (1998). Bladder wash cytology, quantitative cytology, and the qualitative BTA test in patients with superficial bladder cancer. Urology.
71 Varella-Garcia M, Akduman B, Sunpaweravong P, et al. (2004). The UroVysion fluorescence in situ hybridization assay is an effective tool for monitoring recurrence of bladder cancer. Urol Oncol.
72 Witjes JA, van der Poel HG, van Balken MR, et al. (1998). Urinary NMP22 and karyometry in the diagnosis and follow-up of patients with superficial bladder cancer. Eur Urol.
73 Zippe C, Pandrangi L, Potts JM, et al. (1999). NMP22: a sensitive, cost-effective test in patients at risk for bladder cancer. Anticancer Res.
74 Cha EK, Tirsar LA, Schwentner C, et al. (2012). Immunocytology is a strong predictor of bladder cancer presence in patients with painless hematuria: a multicentre study. Eur Urol.
75 Horstmann M, Patschan O, Hennenlotter J, et al. (2009). Combinations of urine-based tumour markers in bladder cancer surveillance. Scand J Urol Nephrol.
76 Junker K, Fritsch T, Hartmann A, et al. (2006). Multicolor fluorescence in situ hybridization (M-FISH) on cells from urine for the detection of bladder cancer. Cytogenet Genome Res.
77 Leyh H, Marberger M, Conort P, et al. (1999). Comparison of the BTA stat test with voided urine cytology and bladder wash cytology in the diagnosis and monitoring of bladder cancer. Eur Urol.
78 Olsson H, Zackrisson B. (2001). ImmunoCyt a useful method in the follow-up protocol for patients with urinary bladder carcinoma. Scand J Urol Nephrol.
79 Piaton E, Daniel L, Verriele V, et al. (2003). Improved detection of urothelial carcinomas with fluorescence immunocytochemistry (uCyt assay) and urinary cytology: results of a French Prospective Multicenter Study. Laboratory Investigation.
80 Raitanen MP, Hellstrom P, Marttila T, et al. (2001). Effect of intravesical instillations on the human complement factor H related protein (BTA stat) test. Eur Urol.
81 Schmitz-Drager B, Tirsar LA, Schmitz-Drager C, et al. (2007). Immunocytology in the assessment of patients with painless gross haematuria. BJU International.
82 Schmitz-Drager BJ, Beiche B, Tirsar LA, et al. (2007). Immunocytology in the assessment of patients with asymptomatic microhaematuria. Eur Urol.
83 Serretta V, Pomara G, Rizzo I, et al. (2000). Urinary BTA-stat, BTA-trak and NMP22 in surveillance after TUR of recurrent superficial transitional cell carcinoma of the bladder. Eur Urol.
84 Song M-J, Lee H-M, Kim S-H. (2010). Clinical usefulness of fluorescence in situ hybridization for diagnosis and surveillance of bladder cancer. Cancer Genet Cytogenet.
85 Sullivan PS, Nooraie F, Sanchez H, et al. (2009). Comparison of ImmunoCyt, UroVysion, and urine cytology in detection of recurrent urothelial carcinoma: a “split-sample” study. Cancer.
86 Tetu B, Tiguert R, Harel F, et al. (2005). ImmunoCyt/uCyt+ improves the sensitivity of urine cytology in patients followed for urothelial carcinoma. Mod Pathol.
87 Toma MI, Friedrich MG, Hautmann SH, et al. (2004). Comparison of the ImmunoCyt test and urinary cytology with other urine tests in the detection and surveillance of bladder cancer. World J Urol.
88 Vriesema JL, Atsma F, Kiemeney LA, et al. (2001). Diagnostic efficacy of the ImmunoCyt test to detect superficial bladder cancer recurrence. Urology.
89 Wiener HG, Mian C, Haitel A, et al. (1998). Can urine bound diagnostic tests replace cystoscopy in the management of bladder cancer?. J Urol.
90 Sylvester RJ, van der Meijden AP, Oosterlinck W, et al. (2006). Predicting recurrence and progression in individual patients with stage Ta T1 bladder cancer using EORTC risk tables: a combined analysis of 2596 patients from seven EORTC trials. Eur Urol.
91 Fernandez-Gomez J, Madero R, Solsona E, et al. (2009). Predicting nonmuscle invasive bladder cancer recurrence and progression in patients treated with bacillus Calmette-Guerin: the CUETO scoring model. J Urol.
92 van Rhijn BW, Zuiverloon TC, Vis AN, et al. (2010). Molecular grade (FGFR3/MIB-1) and EORTC risk scores are predictive in primary non-muscle-invasive bladder cancer. Eur Urol.
93 Fernandez-Gomez J, Madero R, Solsona E, et al. (2011). The EORTC tables overestimate the risk of recurrence and progression in patients with non-muscle-invasive bladder cancer treated with bacillus Calmette-Guerin: external validation of the EORTC risk tables. Eur Urol.
94 Ather MH, Zaidi M. (2009). Predicting recurrence and progression in non-muscle-invasive bladder cancer using European organization of research and treatment of cancer risk tables. Urol J.
95 Abrams PH, Choa RG, Gaches CG, et al. (1981). A controlled trial of single dose intravesical adriamycin in superficial bladder tumours. BJU.
96 Burnand KG, Boyd PJ, Mayo ME, et al. (1976). Single dose intravesical thiotepa as an adjuvant to cystodiathermy in the treatment of transitional cell bladder carcinoma. BJU.
97 Kim HH, Lee C. (1989). Intravesical mitomycin C instillation as a prophylactic treatment of superficial bladder tumor. J Urol.
98 MRC. (1994). The effect of intravesical thiotepa on tumour recurrence after endoscopic treatment of newly diagnosed superficial bladder cancer. A further report with long-term follow-up of a Medical Research Council randomized trial. Medical Research Council Working Party on Urological Cancer, Subgroup on Superficial Bladder Cancer. BJU.
99 MRC Working Party. (1985). The effect of intravesical thiotepa on the recurrence rate of newly diagnosed superficial bladder cancer. An MRC Study. MRC Working Party on Urological Cancer. BJU.
100 Schulman C, Sylvester R, Robinson M, et al. (1978). Adjuvant therapy of T1 bladder carcinoma: preliminary results of an EORTC randomized study. Recent results in cancer research. Fortschritte der Krebsforschung. Progres dans les recherches sur le cancer.
101 Tsushima T, Matsumura Y, Ozaki Y, et al. (1987). Prophylactic intravesical instillation therapy with adriamycin and mitomycin C in patients with superficial bladder cancer. Cancer Chemother Pharmacol.
102 Herr HW, Schwalb DM, Zhang ZF, et al. (1995). Intravesical bacillus Calmette-Guerin therapy prevents tumor progression and death from superficial bladder cancer: ten-year follow-up of a prospective randomized trial. J Clin Oncol.
103 Melekos MD, Chionis HS, Paranychianakis GS, et al. (1993). Intravesical 4'-epi-doxorubicin (epirubicin) versus bacillus Calmette-Guerin. A controlled prospective study on the prophylaxis of superficial bladder cancer. Cancer.
104 Melekos MD. (1990). Intravesical Bacillus Calmette-Guerin prophylactic treatment for superficial bladder tumors: results of a controlled prospective study. Urol Int.
105 Pagano F, Bassi P, Milani C, et al. (1991). A low dose bacillus Calmette-Guerin regimen in superficial bladder cancer therapy: is it effective?. J Urol.
106 Herr HW, Laudone VP, Badalament RA, et al. (1988). Bacillus Calmette-Guerin therapy alters the progression of superficial bladder cancer. J Clin Oncol.
107 Herr HW. (1997). Tumour progression and survival in patients with T1G3 bladder tumours: 15-year outcome. BJU.
108 Cookson MS, Herr HW, Zhang ZF, et al. (1997). The treated natural history of high risk superficial bladder cancer: 15-year outcome. J Urol.
109 Pinsky CM, Camacho FJ, Kerr D, et al. (1985). Intravesical administration of bacillus Calmette-Guerin in patients with recurrent superficial carcinoma of the urinary bladder: report of a prospective, randomized trial. Cancer Treat Rep.
110 Pagano F, Bassi P, Milani C, et al. (1990). Low Dose BGC therapy in superficial bladder cancer; a clinicopathological perspective. Edinburgh, editor. Immunotherapy of urological tumours.
111 Krege S, Giani G, Meyer R, et al. (1996). A randomized multicenter trial of adjuvant therapy in superficial bladder cancer: transurethral resection only versus transurethral resection plus mitomycin C versus transurethral resection plus bacillus Calmette-Guerin. Participating Clinics. J Urol.
112 Akaza H, Isaka S, Koiso K, et al. (1987). Comparative analysis of short-term and long-term prophylactic intravesical chemotherapy of superficial bladder cancer. Prospective, randomized, controlled studies of the Japanese Urological Cancer Research Group. Cancer Chemother Pharmacol.
113 Akaza H, Koiso K, Kotake T, et al. (1992). Long-term results of intravesical chemoprophylaxis of superficial bladder cancer: experience of the Japanese Urological Cancer Research Group for Adriamycin. Cancer Chemother Pharmacol.
114 De Nunzio C, Carbone A, Albisinni S, et al. (2011). Long-term experience with early single mitomycin C instillations in patients with low-risk non-muscle-invasive bladder cancer: prospective, single-centre randomised trial. World J Urol.
115 Gustafson H, Wijkstrom H, Nyman C, et al. (1991). Prophylactic instillation therapy of superficial bladder cancer. A randomized study comparing mitomycin C and adriamycin with special reference to DNA ploidy. Scand J Urol Nephrol Suppl.
116 Niijima T, Koiso K, Akaza H. (1983). Randomized clinical trial on chemoprophylaxis of recurrence in cases of superficial bladder cancer. Cancer Chemother Pharmacol.
117 Solsona E, Iborra I, Ricos JV, et al. (1999). Effectiveness of a single immediate mitomycin C instillation in patients with low risk superficial bladder cancer: short and long-term followup. J Urol.
118 Tolley DA, Parmar MK, Grigor KM, et al. (1996). The effect of intravesical mitomycin C on recurrence of newly diagnosed superficial bladder cancer: a further report with 7 years of follow up. J Urol.
119 Ali-el-Dein B, el-Baz M, Aly AN, et al. (1997). Intravesical epirubicin versus doxorubicin for superficial bladder tumors (stages pTa and pT1): a randomized prospective study. J Urol.
120 Cheng CW, Chan PS, Chan LW, et al. (2005). 17-year follow-up of a randomized prospective controlled trial of adjuvant intravesical doxorubicin in the treatment of superficial bladder cancer. International Braz J Urol.
121 Kurth K, Tunn U, Ay R, et al. (1997). Adjuvant chemotherapy for superficial transitional cell bladder carcinoma: long-term results of a European Organization for Research and Treatment of Cancer randomized trial comparing doxorubicin, ethoglucid and transurethral resection alone. J Urol.
122 Kurth KH, Schroder FH, Tunn U, et al. (1984). Adjuvant chemotherapy of superficial transitional cell bladder carcinoma: preliminary results of a European organization for research on treatment of cancer. Randomized trial comparing doxorubicin hydrochloride, ethoglucid and transurethral resection alone. J Urol.
123 Matsumura Y, Akaza H, Isaka S, et al. (1992). The 4th study of prophylactic intravesical chemotherapy with adriamycin in the treatment of superficial bladder cancer: the experience of the Japanese Urological Cancer Research Group for Adriamycin. Cancer Chemother Pharmacol.
124 Obata K, Ohashi Y, Akaza H, et al. (1994). Prophylactic chemotherapy with intravesical instillation of adriamycin and oral administration of 5-fluorouracil after surgery for superficial bladder cancer. The Japanese Urological Cancer Research Group for Adriamycin. Cancer Chemother Pharmacol.
125 Okamura K, Ono Y, Kinukawa T, et al. (2002). Randomized study of single early instillation of (2″R)-4′-O-tetrahydropyranyl-doxorubicin for a single superficial bladder carcinoma. Cancer.
126 Ali-el-Dein B, Nabeeh A, el-Baz M, et al. (1997). Single-dose versus multiple instillations of epirubicin as prophylaxis for recurrence after transurethral resection of pTa and pT1 transitional-cell bladder tumours: a prospective, randomized controlled study. BJU.
127 Berrum-Svennung I, Granfors T, Jahnson S, et al. (2008). A single instillation of epirubicin after transurethral resection of bladder tumors prevents only small recurrences. J Urol.
128 Gudjonsson S, Adell L, Merdasa F, et al. (2009). Should all patients with non-muscle-invasive bladder cancer receive early intravesical chemotherapy after transurethral resection? The results of a prospective randomised multicentre study. Eur Urol.
129 Igawa M, Urakami S, Shirakawa H, et al. (1996). Intravesical instillation of epirubicin: effect on tumour recurrence in patients with dysplastic epithelium after transurethral resection of superficial bladder tumour. BJU.
130 Melekos MD, Dauaher H, Fokaefs E, et al. (1992). Intravesical instillations of 4-epi-doxorubicin (epirubicin) in the prophylactic treatment of superficial bladder cancer: results of a controlled prospective study. J Urol.
131 Oosterlinck W, Kurth KH, Schroder F, et al. (1993). A prospective European Organization for Research and Treatment of Cancer Genitourinary Group randomized trial comparing transurethral resection followed by a single intravesical instillation of epirubicin or water in single stage Ta, T1 papillary carcinoma of the bladder. J Urol.
132 Rajala P, Kaasinen E, Raitanen M, et al. (2002). Perioperative single dose instillation of epirubicin or interferon-alpha after transurethral resection for the prophylaxis of primary superficial bladder cancer recurrence: a prospective randomized multicenter study--FinnBladder III long-term results. J Urol.
133 Rajala P, Liukkonen T, Raitanen M, et al. (1999). Transurethral resection with perioperative instilation on interferon-alpha or epirubicin for the prophylaxis of recurrent primary superficial bladder cancer: a prospective randomized multicenter study--Finnbladder III. J Urol.
134 Saika T, Tsushima T, Nasu Y, et al. (2010). Two instillations of epirubicin as prophylaxis for recurrence after transurethral resection of Ta and T1 transitional cell bladder cancer: a prospective, randomized controlled study. World J Urol.
135 Bohle A, Leyh H, Frei C, et al. (2009). Single postoperative instillation of gemcitabine in patients with non-muscle-invasive transitional cell carcinoma of the bladder: a randomised, double-blind, placebo-controlled phase III multicentre study. Eur Urol.
136 Giannakopoulos S, Gekas A, Alivizatos G, et al. (1998). Efficacy of escalating doses of intravesical interferon alpha-2b in reducing recurrence rate and progression in superficial transitional cell carcinoma. BJU.
137 Portillo J, Martin B, Hernandez R, et al. (1997). Results at 43 months' follow-up of a double-blind, randomized, prospective clinical trial using intravesical interferon alpha-2b in the prophylaxis of stage pT1 transitional cell carcinoma of the bladder. Urology.
138 Stavropoulos NE, Hastazeris K, Filiadis I, et al. (2002). Intravesical instillations of interferon gamma in the prophylaxis of high risk superficial bladder cancer--results of a controlled prospective study. Scand J Urol Nephrol.
139 Hirao Y, Okajima E, Ozono S, et al. (1992). A prospective randomized study of prophylaxis of tumor recurrence following transurethral resection of superficial bladder cancer--intravesical thio-TEPA versus oral UFT. Cancer Chemother Pharmacol.
140 Koontz WW, Prout GR, Smith W, et al. (1981). The use of intravesical thio-tepa in the management of non-invasive carcinoma of the bladder. J Urol.
141 Giannopoulos A, Constantinides C, Fokaeas E, et al. (2003). The immunomodulating effect of interferon-gamma intravesical instillations in preventing bladder cancer recurrence. Clinical Cancer Research.
142 Brosman SA. (1982). Experience with bacillus Calmette-Guerin in patients with superficial bladder carcinoma. J Urol.
143 Flanigan RC, Ellison MF, Butler KM, et al. (1986). A trial of prophylactic thiotepa or mitomycin C intravesical therapy in patients with recurrent or multiple superficial bladder cancers. J Urol.
144 Jauhiainen. (1987). Instillation of mitomycin C and doxorubicin in the prevention of recurrent superficial (Ta-T1) bladder cancer. BJU.
145 Sekine H, Ohya K, Kojima SI, et al. (2001). Equivalent efficacy of mitomycin C plus doxorubicin instillation to bacillus Calmette-Guerin therapy for carcinoma in situ of the bladder. Int J Urol.
146 Zincke H, Benson RC, Hilton JF, et al. (1985). Intravesical thiotepa and mitomycin C treatment immediately after transurethral resection and later for superficial (stages Ta and Tis) bladder cancer: a prospective, randomized, stratified study with crossover design. J Urol.
147 Lamm DL, Blumenstein BA, David Crawford E, et al. (1995). Randomized intergroup comparison of bacillus calmette-guerin immunotherapy and mitomycin C chemotherapy prophylaxis in superficial transitional cell carcinoma of the bladder a southwest oncology group study. Urol Oncol.
148 Witjes JA, vd Meijden AP, Witjes WP, et al. (1993). A randomised prospective study comparing intravesical instillations of mitomycin-C, BCG-Tice, and BCG-RIVM in pTa-pT1 tumours and primary carcinoma in situ of the urinary bladder. Dutch South-East Cooperative Urological Group. EJC.
149 Rintala E, Jauhiainen K, Alfthan O, et al. (1991). Intravesical chemotherapy (mitomycin C) versus immunotherapy (bacillus Calmette-Guerin) in superficial bladder cancer. Eur Urol.
150 DeBruyne FM, van der Meijden AP, Geboers AD, et al. (1988). BCG (RIVM) versus mitomycin intravesical therapy in superficial bladder cancer. First results of randomized prospective trial. Urology.
151 Ojea A, Nogueira JL, Solsona E, et al. (2007). A multicentre, randomised prospective trial comparing three intravesical adjuvant therapies for intermediate-risk superficial bladder cancer: low-dose bacillus Calmette-Guerin (27 mg) versus very low-dose bacillus Calmette-Guerin (13.5 mg) versus mitomycin C. Eur Urol.
152 Lundholm C, Norlen BJ, Ekman P, et al. (1996). A randomized prospective study comparing long-term intravesical instillations of mitomycin C and bacillus Calmette-Guerin in patients with superficial bladder carcinoma. J Urol.
153 Mangiarotti B, Trinchieri A, Del Nero A, et al. (2008). A randomized prospective study of intravesical prophylaxis in non-musle invasive bladder cancer at intermediate risk of recurrence: mitomycin chemotherapy vs BCG immunotherapy. Archivio Italiano di Urologia, Andrologia.
154 Friedrich MG, Pichlmeier U, Schwaibold H, et al. (2007). Long-term intravesical adjuvant chemotherapy further reduces recurrence rate compared with short-term intravesical chemotherapy and short-term therapy with Bacillus Calmette-Guerin (BCG) in patients with non-muscle-invasive bladder carcinoma. Eur Urol.
155 Di Stasi SM, Giannantoni A, Stephen RL, et al. (2003). Intravesical electromotive mitomycin C versus passive transport mitomycin C for high risk superficial bladder cancer: a prospective randomized study. J Urol.
156 Witjes WP, Witjes JA, Oosterhof GO, et al. (1996). Update on the Dutch Cooperative Trial: mitomycin versus bacillus Calmette-Guerin-Tice versus bacillus Calmette-Guerin RIVM in the treatment of patients with pTA-pT1 papillary carcinoma and carcinoma in situ of the urinary bladder. Dutch South East Cooperative Urological Group. Semin Urolo Oncol.
157 Gardmark T, Jahnson S, Wahlquist R, et al. (2007). Analysis of progression and survival after 10 years of a randomized prospective study comparing mitomycin-C and bacillus Calmette-Guerin in patients with high-risk bladder cancer. BJU International.
158 Malmstrom PU, Wijkstrom H, Lundholm C, et al. (1999). 5-year followup of a randomized prospective study comparing mitomycin C and bacillus Calmette-Guerin in patients with superficial bladder carcinoma. Swedish-Norwegian Bladder Cancer Study Group. J Urol.
159 Witjes JA, v d Meijden AP, Collette L, et al. (1998). Long-term follow-up of an EORTC randomized prospective trial comparing intravesical bacille Calmette-Guerin-RIVM and mitomycin C in superficial bladder cancer. EORTC GU Group and the Dutch South East Cooperative Urological Group. European Organisation for Research and Treatment of Cancer Genito-Urinary Tract Cancer Collaborative Group. Urology.
160 DeBruyne FMJ, van der Meijden PM, Witjes JA, et al. (1992). Bacillus Calmette-Guérin versus mitomycin intravesical therapy in superficial bladder cancer: Results of randomized trial after 21 months of follow-up. Urology.
161 Jarvinen R, Kaasinen E, Sankila A, et al. (2009). Long-term efficacy of maintenance bacillus Calmette-Guerin versus maintenance mitomycin C instillation therapy in frequently recurrent TaT1 tumours without carcinoma in situ: a subgroup analysis of the prospective, randomised FinnBladder I study with a 20-year follow-up. Eur Urol.
162 Gulpinar O, Halilioglu AH, Gokce MI, et al. (2012). The value of perioperative mitomycin C instillation in improving subsequent bacillus calmette-guerin instillation efficacy in intermediate and high-risk patients with non-muscle invasive bladder cancer: a prospective randomized study. International Braz J Urol.
163 Kaasinen E, Wijkstrom H, Malmstrom PU, et al. (2003). Alternating mitomycin C and BCG instillations versus BCG alone in treatment of carcinoma in situ of the urinary bladder: a nordic study. Eur Urol.
164 Oosterlinck W, Kirkali Z, Sylvester R, et al. (2011). Sequential intravesical chemoimmunotherapy with mitomycin C and bacillus Calmette-Guerin and with bacillus Calmette-Guerin alone in patients with carcinoma in situ of the urinary bladder: results of an EORTC genito-urinary group randomized phase 2 trial (30993). Eur Urol.
165 Mohsen MAE, Shelbaia A, Ghobashy SE, et al. (2010). Sequential chemoimmunotherapy using mitomycin followed by bacillus Calmette-Guerin (MCC + BCG) versus single-agent immunotherapy (BCG) for recurrent superficial bladder tumors. UroToday International Journal.
166 Witjes JA, Caris CT, Mungan NA, et al. (1998). Results of a randomized phase III trial of sequential intravesical therapy with mitomycin C and bacillus Calmette-Guerin versus mitomycin C alone in patients with superficial bladder cancer. J Urol.
167 Jarvinen R, Kaasinen E, Rintala E, et al. (2012). Long-term results of maintenance treatment of mitomycin C or alternating mitomycin C and bacillus Calmette-Guerin instillation therapy of patients with carcinoma in situ of the bladder: a subgroup analysis of the prospective FinnBladder 2 study with a 17-year follow-up. Scand J Urol Nephrol.
168 Rintala E, Jauhiainen K, Kaasinen E, et al. (1996). Alternating mitomycin C and bacillus Calmette-Guerin instillation prophylaxis for recurrent papillary (stages Ta to T1) superficial bladder cancer. Finnbladder Group. J Urol.
169 Rintala E, Jauhiainen K, Rajala P, et al. (1995). Alternating mitomycin C and bacillus Calmette-Guerin instillation therapy for carcinoma in situ of the bladder. The Finnbladder Group. J Urol.
170 Hinotsu S, Akaza H, Isaka S, et al. (2006). Sustained prophylactic effect of intravesical bacille Calmette-Guerin for superficial bladder cancer: a smoothed hazard analysis in a randomized prospective study. Urology.
171 Lamm DL, Blumenstein BA, Crawford ED, et al. (1991). A randomized trial of intravesical doxorubicin and immunotherapy with bacille Calmette-Guerin for transitional-cell carcinoma of the bladder. NEJM.
172 Martinez-Pineiro JA, Jimenez Leon J, Martinez-Pineiro L, et al. (1990). Bacillus Calmette-Guerin versus doxorubicin versus thiotepa: a randomized prospective study in 202 patients with superficial bladder cancer. J Urol.
173 Sylvester RJ, Brausi MA, Kirkels WJ, et al. (2010). Long-term efficacy results of EORTC genito-urinary group randomized phase 3 study 30911 comparing intravesical instillations of epirubicin, bacillus Calmette-Guerin, and bacillus Calmette-Guerin plus isoniazid in patients with intermediate- and high-risk stage Ta T1 urothelial carcinoma of the bladder. Eur Urol.
174 Cheng CW, Chan SFP, Chan LW, et al. (2005). Twelve-year follow up of a randomized prospective trial comparing bacillus Calmette-Guerin and epirubicin as adjuvant therapy in superficial bladder cancer. IJU.
175 Melekos MD, Zarakovitis I, Dandinis K, et al. (1996). BCG versus epirubicin in the prophylaxis of multiple superficial bladder tumours: results of a prospective randomized study using modified treatment schemes. Int Urol Nephrol.
176 Hinotsu S, Akaza H, Naito S, et al. (2011). Maintenance therapy with bacillus Calmette-Guerin Connaught strain clearly prolongs recurrence-free survival following transurethral resection of bladder tumour for non-muscle-invasive bladder cancer. BJU International.
177 de Reijke TM, Kurth KH, Sylvester RJ, et al. (2005). Bacillus Calmette-Guerin versus epirubicin for primary, secondary or concurrent carcinoma in situ of the bladder: results of a European Organization for the Research and Treatment of Cancer--Genito-Urinary Group Phase III Trial (30906). J Urol.
178 van der Meijden AP, Brausi M, Zambon V, et al. (2001). Intravesical instillation of epirubicin, bacillus Calmette-Guerin and bacillus Calmette-Guerin plus isoniazid for intermediate and high risk Ta, T1 papillary carcinoma of the bladder: a European Organization for Research and Treatment of Cancer genito-urinary group randomized phase III trial. J Urol.
179 Cai T, Nesi G, Tinacci G, et al. (2008). Can early single dose instillation of epirubicin improve bacillus Calmette-Guerin efficacy in patients with nonmuscle invasive high risk bladder cancer? Results from a prospective, randomized, double-blind controlled study. J Urol.
180 Ali-El-Dein B, Nabeeh A, Ismail EH, et al. (1999). Sequential bacillus Calmette-Guerin and epirubicin versus bacillus Calmette-Guerin alone for superficial bladder tumors: a randomized prospective study. J Urol.
181 Bilen CY, Ozen H, Aki FT, et al. (2000). Clinical experience with BCG alone versus BCG plus epirubicin. IJU.
182 Duchek M, Johansson R, Jahnson S, et al. (2010). Bacillus Calmette-Guerin is superior to a combination of epirubicin and interferon-alpha2b in the intravesical treatment of patients with stage T1 urinary bladder cancer. A prospective, randomized, Nordic study. Eur Urol.
183 Hemdan T, Johansson R, Jahnson S, et al. (2014). 5-Year outcome of a randomized prospective study comparing bacillus Calmette-Guerin with epirubicin and interferon-alpha2b in patients with T1 bladder cancer. J Urol.
184 Di Lorenzo G, Perdona S, Damiano R, et al. (2010). Gemcitabine versus bacille Calmette-Guerin after initial bacille Calmette-Guerin failure in non-muscle-invasive bladder cancer: a multicenter prospective randomized trial. Cancer.
185 Porena M, Del Zingaro M, Lazzeri M, et al. (2010). Bacillus Calmette-Guerin versus gemcitabine for intravesical therapy in high-risk superficial bladder cancer: a randomised prospective study. Urol Int.
186 Gontero P, Oderda M, Mehnert A, et al. (2013). The impact of intravesical gemcitabine and 1/3 dose Bacillus Calmette-Guerin instillation therapy on the quality of life in patients with nonmuscle invasive bladder cancer: results of a prospective, randomized, phase II trial. J Urol.
187 Cho DY, Bae JH, Moon DG, et al. (2009). The effects of intravesical chemoimmunotherapy with gemcitabine and Bacillus Calmette-Guerin in superficial bladder cancer: a preliminary study. J Int Med Res.
188 Jimenez-Cruz JF, Vera-Donoso CD, Leiva O, et al. (1997). Intravesical immunoprophylaxis in recurrent superficial bladder cancer (Stage T1): multicenter trial comparing bacille Calmette-Guerin and interferon-alpha. Urology.
189 Kaasinen E, Rintala E, Pere AK, et al. (2000). Weekly mitomycin C followed by monthly bacillus Calmette-Guerin or alternating monthly interferon-alpha2B and bacillus Calmette-Guerin for prophylaxis of recurrent papillary superficial bladder carcinoma. J Urol.
190 Nepple KG, Lightfoot AJ, Rosevear HM, et al. (2010). Bacillus Calmette-Guerin with or without interferon alpha-2b and megadose versus recommended daily allowance vitamins during induction and maintenance intravesical treatment of nonmuscle invasive bladder cancer. J Urol.
191 Huland H, Kloppel G, Feddersen I, et al. (1990). Comparison of different schedules of cytostatic intravesical instillations in patients with superficial bladder carcinoma: final evaluation of a prospective multicenter study with 419 patients. J Urol.
192 Liu B, Wang Z, Chen B, et al. (2006). Randomized study of single instillation of epirubicin for superficial bladder carcinoma: long-term clinical outcomes. Cancer Investigation.
193 Boccardo F, Cannata D, Rubagotti A, et al. (1994). Prophylaxis of superficial bladder cancer with mitomycin or interferon alfa-2b: results of a multicentric Italian study. J Clin Oncol.
194 Addeo R, Caraglia M, Bellini S, et al. (2010). Randomized phase III trial on gemcitabine versus mytomicin in recurrent superficial bladder cancer: evaluation of efficacy and tolerance. J Clin Oncol.
195 Eto H, Oka Y, Ueno K, et al. (1994). Comparison of the prophylactic usefulness of epirubicin and doxorubicin in the treatment of superficial bladder cancer by intravesical instillation: a multicenter randomized trial. Kobe University Urological Oncology Group. Cancer Chemother Pharmacol.
196 Shuin T, Kubota Y, Noguchi S, et al. (1994). A phase II study of prophylactic intravesical chemotherapy with 4′-epirubicin in recurrent superficial bladder cancer: comparison of 4′-epirubicin and adriamycin. Cancer Chemother Pharmacol.
197 Au JL, Badalament RA, Wientjes MG, et al. (2001). Methods to improve efficacy of intravesical mitomycin C: results of a randomized phase III trial. JNCI.
198 Ersoy H, Yaytokgil M, Karakoyunlu AN, et al. (2013). Single early instillation of mitomycin C and urinary alkalinization in low-risk non-muscle-invasive bladder cancer: a preliminary study. Drug Des Devel Ther.
199 Aaronson NK, Ahmedzai S, Bergman B, et al. (1993). The European Organization for Research and Treatment of Cancer QLQ-C30: a quality-of-life instrument for use in international clinical trials in oncology. JNCI.
200 Badalament RA, Herr HW, Wong GY, et al. (1987). A prospective randomized trial of maintenance versus nonmaintenance intravesical bacillus Calmette-Guerin therapy of superficial bladder cancer. J Clin Oncol.
201 Fellows GJ, Parmar MK, Grigor KM, et al. (1994). Marker tumour response to Evans and Pasteur bacille Calmette-Guerin in multiple recurrent pTa/pT1 bladder tumours: report from the Medical Research Council Subgroup on Superficial Bladder Cancer (Urological Cancer Working Party). BJU.
202 Fukui I, Kihara K, Sekine H, et al. (1992). Intravesical combination chemotherapy with mitomycin C and doxorubicin for superficial bladder cancer: a randomized trial of maintenance versus no maintenance following a complete response. Cancer Chemother Pharmacol.
203 Glashan RW. (1990). A randomized controlled study of intravesical alpha-2b-interferon in carcinoma in situ of the bladder. J Urol.
204 Inamoto T, Ubai T, Nishida T, et al. (2013). Comparable effect with minimal morbidity of low-dose Tokyo 172 strain compared with regular dose Connaught strain as an intravesical bacillus Calmette-Guerin prophylaxis in nonmuscle invasive bladder cancer: Results of a randomized prospective comparison. Urol Ann.
205 Koga H, Ozono S, Tsushima T, et al. (2010). Maintenance intravesical bacillus Calmette-Guerin instillation for Ta, T1 cancer and carcinoma in situ of the bladder: randomized controlled trial by the BCG Tokyo Strain Study Group. IJU.
206 Lamm DL, Blumenstein BA, Crissman JD, et al. (2000). Maintenance bacillus Calmette-Guerin immunotherapy for recurrent TA, T1 and carcinoma in situ transitional cell carcinoma of the bladder: a randomized Southwest Oncology Group Study. J Urol.
207 Lerner SP, Tangen CM, Sucharew H, et al. (2007). Patterns of recurrence and outcomes following induction bacillus Calmette-Guerin for high risk Ta, T1 bladder cancer. JUrol.
208 Mukherjee A, Persad R, Smith PJ. (1992). Intravesical BCG treatment for superficial bladder cancer: long-term results using two different strains of BCG. BJU.
209 Palou J, Laguna P, Millan-Rodriguez F, et al. (2001). Control group and maintenance treatment with bacillus Calmette-Guerin for carcinoma in situ and/or high grade bladder tumors. J Urol.
210 Rentsch CA, Birkhauser FD, Biot C, et al. (2014). Bacillus Calmette-Guerin strain differences have an impact on clinical outcome in bladder cancer immunotherapy. Eur Urol.
211 Vegt PD, Witjes JA, Witjes WP, et al. (1995). A randomized study of intravesical mitomycin C, bacillus Calmette-Guerin Tice and bacillus Calmette-Guerin RIVM treatment in pTa-pT1 papillary carcinoma and carcinoma in situ of the bladder. J Urol.
212 Bouffioux C, Kurth KH, Bono A, et al. (1995). Intravesical adjuvant chemotherapy for superficial transitional cell bladder carcinoma: results of 2 European Organization for Research and Treatment of Cancer randomized trials with mitomycin C and doxorubicin comparing early versus delayed instillations and short-term versus long-term treatment. European Organization for Research and Treatment of Cancer Genitourinary Group. J Urol.
213 Colombo R, Rocchini L, Suardi N, et al. (2012). Neoadjuvant short-term intensive intravesical mitomycin C regimen compared with weekly schedule for low-grade recurrent non-muscle-invasive bladder cancer: preliminary results of a randomised phase 2 study. Eur Urol.
214 Flamm J. (1990). Long-term versus short-term doxorubicin hydrochloride instillation after transurethral resection of superficial bladder cancer. Eur Urol.
215 Gruenwald IE, Stein A, Rashcovitsky R, et al. (1997). A 12 versus 6-week course of bacillus Calmette-Guerin prophylaxis for the treatment of high risk superficial bladder cancer. J Urol.
216 Hendricksen K, Witjes WPJ, Idema JG, et al. (2008). Comparison of three schedules of intravesical epirubicin in patients with non-muscle-invasive bladder cancer. Eur Urol.
217 Hoeltl W, Hasun R, Albrecht W, et al. (1991). How effective is topical alpha-2b interferon in preventing recurrence of superficial bladder cancer?. BJU.
218 Irie A, Uchida T, Yamashita H, et al. (2003). Sufficient prophylactic efficacy with minor adverse effects by intravesical instillation of low-dose bacillus Calmette-Guerin for superficial bladder cancer recurrence. IJU.
219 Koga H, Kuroiwa K, Yamaguchi A, et al. (2004). A randomized controlled trial of short-term versus long-term prophylactic intravesical instillation chemotherapy for recurrence after transurethral resection of Ta/T1 transitional cell carcinoma of the bladder. J Urol.
220 Kuroda M, Niijima T, Kotake T, et al. (2004). Effect of prophylactic treatment with intravesical epirubicin on recurrence of superficial bladder cancer--The 6th Trial of the Japanese Urological Cancer Research Group (JUCRG): a randomized trial of intravesical epirubicin at dose of 20mg/40ml, 30mg/40ml, 40mg/40ml. Eur Urol.
221 Malmstrom P-U. (2002). A randomized comparative dose-ranging study of interferon-alpha and mitomycin-C as an internal control in primary or recurrent superficial transitional cell carcinoma of the bladder. BJU International.
222 Martinez-Pineiro JA, Flores N, Isorna S, et al. (2002). Long-term follow-up of a randomized prospective trial comparing a standard 81 mg dose of intravesical bacille Calmette-Guerin with a reduced dose of 27 mg in superficial bladder cancer. BJU International.
223 Martinez-Pineiro JA, Martinez-Pineiro L, Solsona E, et al. (2005). Has a 3-fold decreased dose of bacillus Calmette-Guerin the same efficacy against recurrences and progression of T1G3 and Tis bladder tumors than the standard dose? Results of a prospective randomized trial. J Urol.
224 Masters JR, Popert RJ, Thompson PM, et al. (1999). Intravesical chemotherapy with epirubicin: a dose response study. J Urol.
225 Mitsumori K, Tsuchiya N, Habuchi T, et al. (2004). Early and large-dose intravesical instillation of epirubicin to prevent superficial bladder carcinoma recurrence after transurethral resection. BJU International.
226 Morales A, Nickel JC, Wilson JW. (1992). Dose-response of bacillus Calmette-Guerin in the treatment of superficial bladder cancer. J Urol.
227 Nomata K, Noguchi M, Kanetake H, et al. (2002). Intravesical adjuvant chemotherapy for superficial transitional cell bladder carcinoma: results of a randomized trial with epirubicin comparing short-term versus long-term maintenance treatment. Cancer Chemother Pharmacol.
228 Oddens J, Brausi M, Sylvester R, et al. (2013). Final results of an EORTC-GU cancers group randomized study of maintenance bacillus Calmette-Guerin in intermediate- and high-risk Ta, T1 papillary carcinoma of the urinary bladder: one-third dose versus full dose and 1 year versus 3 years of maintenance. Eur Urol.
229 Okamura K. (1998). A randomized study of short- versus long-term intravesical epirubicin instillation for superficial bladder cancer. Eur Urol.
230 Pagano F, Bassi P, Piazza N, et al. (1995). Improving the efficacy of BCG immunotherapy by dose reduction. Eur Urol.
231 Rubben H, Lutzeyer W, Fischer N, et al. (1988). Natural history and treatment of low and high risk superficial bladder tumors. J Urol.
232 Schwaibold H, Pichlmeier U, Klingenberger HJ, et al. (1997). Long-term follow-up of cytostatic intravesical instillation in patients with superficial bladder carcinoma. Is short-term, intensive instillation better than maintenance therapy?. Eur Urol.
233 Sengiku A, Ito M, Miyazaki Y, et al. (2013). A prospective comparative study of intravesical bacillus Calmette-Guerin therapy with the Tokyo or Connaught strain for nonmuscle invasive bladder cancer. J Urol.
234 Serretta V, Morgia G, Altieri V, et al. (2010). A 1-year maintenance after early adjuvant intravesical chemotherapy has a limited efficacy in preventing recurrence of intermediate risk non-muscle-invasive bladder cancer. BJU International.
235 Turkeri L, Tanidir Y, Cal C, et al. (2010). Comparison of the efficacy of single or double intravesical epirubicin instillation in the early postoperative period to prevent recurrences in non-muscle-invasive urothelial carcinoma of the bladder: prospective, randomized multicenter study. Urol Int.
236 Ueda T, Naito S, Iguchi A, et al. (1992). Adjuvant chemotherapy with early intravesical instillation of adriamycin and long-term oral administration of 5-fluorouracil in superficial bladder cancer. The Kyushu University Urological Oncology Group. Cancer Chemother Pharmacol.
237 Brausi M, Oddens J, Sylvester R, et al. (2014). Side effects of Bacillus Calmette-Guerin (BCG) in the treatment of intermediate- and high-risk Ta, T1 papillary carcinoma of the bladder: results of the EORTC genito-urinary cancers group randomised phase 3 study comparing one-third dose with full dose and 1 year with 3 years of maintenance BCG. Eur Urol.
238 Kaisary AV. (1987). Intravesical BCG Therapy in the Management of Multiple Superficial Bladder Carcinoma Comparison between Glaxo and Pasteur Strains. BJU.
239 Harland SJ, Kynaston H, Grigor K, et al. (2007). A randomized trial of radical radiotherapy for the management of pT1G3 NXM0 transitional cell carcinoma of the bladder. J Urol.
240 Mulders PF, Hoekstra WJ, Heybroek RP, et al. (1994). Prognosis and treatment of T1G3 bladder tumours. A prognostic factor analysis of 121 patients. Dutch South Eastern Bladder Cancer Study Group. EJC.
241 Babjuk M, Soukup V, Petrik R, et al. (2005). 5-aminolaevulinic acid-induced fluorescence cystoscopy during transurethral resection reduces the risk of recurrence in stage Ta/T1 bladder cancer. BJU International.
242 Daniltchenko DI, Riedl CR, Sachs MD, et al. (2005). Long-term benefit of 5-aminolevulinic acid fluorescence assisted transurethral resection of superficial bladder cancer: 5-year results of a prospective randomized study. J Urol.
243 Denzinger S, Burger M, Walter B, et al. (2007). Clinically relevant reduction in risk of recurrence of superficial bladder cancer using 5-aminolevulinic acid-induced fluorescence diagnosis: 8-year results of prospective randomized study. Urology.
244 Denzinger S, Wieland WF, Otto W, et al. (2007). Does photodynamic transurethral resection of bladder tumour improve the outcome of initial T1 high-grade bladder cancer? A long-term follow-up of a randomized study. BJU International.
245 Dragoescu O, Tomescu P, Panus A, et al. (2011). Photodynamic diagnosis of non-muscle invasive bladder cancer using hexaminolevulinic acid. Rom J Morphol Embryol.
246 Filbeck T, Pichlmeier U, Knuechel R, et al. (2002). Clinically relevant improvement of recurrence-free survival with 5-aminolevulinic acid induced fluorescence diagnosis in patients with superficial bladder tumors. J Urol.
247 Geavlete B, Jecu M, Multescu R, et al. (2010). HAL blue-light cystoscopy in high-risk nonmuscle-invasive bladder cancer--re-TURBT recurrence rates in a prospective, randomized study. Urology.
248 Geavlete B, Multescu R, Georgescu D, et al. (2011). Treatment changes and long-term recurrence rates after hexaminolevulinate (HAL) fluorescence cystoscopy: does it really make a difference in patients with non-muscle-invasive bladder cancer (NMIBC)?. BJU International.
249 Grossman HB, Stenzl A, Fradet Y, et al. (2012). Long-term decrease in bladder cancer recurrence with hexaminolevulinate enabled fluorescence cystoscopy. J Urol.
250 Hermann GG, Mogensen K, Carlsson S, et al. (2011). Fluorescence-guided transurethral resection of bladder tumours reduces bladder tumour recurrence due to less residual tumour tissue in Ta/T1 patients: a randomized two-centre study. BJU International.
251 Karaolides T, Skolarikos A, Bourdoumis A, et al. (2012). Hexaminolevulinate-induced fluorescence versus white light during transurethral resection of noninvasive bladder tumor: does it reduce recurrences?. Urology.
252 Kriegmair M, Zaak D, Rothenberger KH, et al. (2002). Transurethral resection for bladder cancer using 5-aminolevulinic acid induced fluorescence endoscopy versus white light endoscopy. J Urol.
253 Mostafid H, Bunce C. (2009). Improved detection and reduced early recurrence of non-muscle-invasive bladder cancer using hexaminolaevulinate fluorescence cystoscopy: results of a multicentre prospective randomized study (PC B305). BJU International.
254 Naselli A, Introini C, Timossi L, et al. (2012). A randomized prospective trial to assess the impact of transurethral resection in narrow band imaging modality on non-muscle-invasive bladder cancer recurrence. Eur Urol.
255 O'Brien T, Ray E, Chatterton K, et al. (2013). Prospective randomized trial of hexylaminolevulinate photodynamic-assisted transurethral resection of bladder tumour (TURBT) plus single-shot intravesical mitomycin C vs conventional white-light TURBT plus mitomycin C in newly presenting non-muscle-invasive bladder cancer. BJU International.
256 Riedl CR, Daniltchenko D, Koenig F, et al. (2001). Fluorescence endoscopy with 5-aminolevulinic acid reduces early recurrence rate in superficial bladder cancer. J Urol.
257 Schumacher MC, Holmang S, Davidsson T, et al. (2010). Transurethral resection of non-muscle-invasive bladder transitional cell cancers with or without 5-aminolevulinic Acid under visible and fluorescent light: results of a prospective, randomised, multicentre study. Eur Urol.
258 Stenzl A, Burger M, Fradet Y, et al. (2010). Hexaminolevulinate guided fluorescence cystoscopy reduces recurrence in patients with nonmuscle invasive bladder cancer. J Urol.
259 Stenzl A, Penkoff H, Dajc-Sommerer E, et al. (2011). Detection and clinical outcome of urinary bladder cancer with 5-aminolevulinic acid-induced fluorescence cystoscopy : A multicenter randomized, double-blind, placebo-controlled trial. Cancer.
260 Alken P, Siegsmund M, Gromoll-Berbmann K, et al. (2007). A randomised controlled multicenter trial to compare the effects of transurethral detection and resection of bladder carcinomas under 5-ALA induced fluorescence light to conventional white light [abstract 593]. Eur Urol Suppl.
261 Tolley DA, Hargreave TB, Smith PH, et al. (1988). Effect of intravesical mitomycin C on recurrence of newly diagnosed superficial bladder cancer: interim report from the Medical Research Council Subgroup on Superficial Bladder Cancer (Urological Cancer Working Party). Br Med J (Clin Res Ed).
262 Bassi P. (1992). Dose Response of Bacillus Calmette-Guerin (BCG) in superficial bladder cancer: a phase III randomized tial low-dose vs standard-dose BCG regimen. J Urol.
263 Lotan Y, Roehrborn CG. (2003). Sensitivity and specificity of commonly available bladder tumor markers versus cytology: results of a comprehensive literature review and meta-analyses. Urology.
264 van Rhijn BW, van der Poel HG, van der Kwast TH. (2005). Urine markers for bladder cancer surveillance: a systematic review. Eur Urol.
265 Hajdinjak T. (2008). UroVysion FISH test for detecting urothelial cancers: meta-analysis of diagnostic accuracy and comparison with urinary cytology testing. Urol Oncol.
266 Burger M, Grossman HB, Droller M, et al. (2013). Photodynamic diagnosis of non-muscle-invasive bladder cancer with hexaminolevulinate cystoscopy: a meta-analysis of detection and recurrence based on raw data. Eur Urol.
267 Kausch I, Sommerauer M, Montorsi F, et al. (2010). Photodynamic diagnosis in non-muscle-invasive bladder cancer: a systematic review and cumulative analysis of prospective studies. Eur Urol.
268 Shelley MD, Kynaston H, Court J, et al. (2001). A systematic review of intravesical bacillus Calmette-Guerin plus transurethral resection vs transurethral resection alone in Ta and T1 bladder cancer. BJU International.
269 Han RF, Pan JG. (2006). Can intravesical bacillus Calmette-Guerin reduce recurrence in patients with superficial bladder cancer? A meta-analysis of randomized trials. Urology.
270 Sylvester RJ, Oosterlinck W, van der Meijden APM. (2004). A single immediate postoperative instillation of chemotherapy decreases the risk of recurrence in patients with stage Ta T1 bladder cancer: a meta-analysis of published results of randomized clinical trials. J Urol.
271 Abern MR, Owusu RA, Anderson MR, et al. (2013). Perioperative intravesical chemotherapy in non-muscle-invasive bladder cancer: a systematic review and meta-analysis. JNCCN.
272 Perlis N, Zlotta AR, Beyene J, et al. (2013). Immediate post-transurethral resection of bladder tumor intravesical chemotherapy prevents non-muscle-invasive bladder cancer recurrences: an updated meta-analysis on 2548 patients and quality-of-evidence review. Eur Urol.
273 Malmstrom P-U, Sylvester RJ, Crawford DE, et al. (2009). An individual patient data meta-analysis of the long-term outcome of randomised studies comparing intravesical mitomycin C versus bacillus Calmette-Guerin for non-muscle-invasive bladder cancer. Eur Urol.
274 Shang PF, Kwong J, Wang ZP, et al. (2011). Intravesical Bacillus Calmette-Guerin versus epirubicin for Ta and T1 bladder cancer. Cochrane Database Syst Rev.
275 Shelley MD, Jones G, Cleves A, et al. (2012). Intravesical gemcitabine therapy for non-muscle invasive bladder cancer (NMIBC): a systematic review. BJU International.
276 Sylvester RJ, Oosterlinck W, Witjes JA. (2008). The schedule and duration of intravesical chemotherapy in patients with non-muscle-invasive bladder cancer: a systematic review of the published results of randomized clinical trials. Eur Urol.
277 Babjuk M, Bohle A, Burger E, et al. (2014). Guidelines on Non-muscle-invasive Bladder Cancer (Ta, T1 and CIS).
278 Lijmer JG, Bossuyt PM, Heisterkamp SH. (2002). Exploring sources of heterogeneity in systematic reviews of diagnostic tests. Stat Med.
279 Gatsonis C, Paliwal P. (2006). Meta-analysis of diagnostic and screening test accuracy evaluations: methodologic primer. AJR Am J Roentgenol.
280 Macaskill P, Gatsonis C, Deeks JJ, et al. (2010). Chapter 10. Analysing and presenting results, version 1.0. Deeks JJ, Bossuyt PM, Gatsonis C, editors. Cochrane Handbook for Systematic Reviews of Diagnostic Test Accuracy: The Cochrane Collaboration.
281 Deeks JJ, Macaskill P, Irwig L. (2005). The performance of tests of publication bias and other sample size effects in systematic reviews of diagnostic test accuracy was assessed. J Clin Epidemiol.
282 Song F, Khan KS, Dinnes J, et al. (2002). Asymmetric funnel plots and publication bias in meta-analyses of diagnostic accuracy. Int J Epidemiol.