# Methods

This comparative effectiveness review (CER) follows the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter AHRQ Methods Guide).15 All methods were determined a priori.

## Topic Development and Refinement

AHRQ initially received this topic as a nomination via the Effective Healthcare Web site (http://www.effectivehealthcare.ahrq.gov/index.cfm/submit-a-suggestion-for-research/). The Scientific Resource Center developed preliminary Key Questions based on input from the topic nominator. The Evidence-based Practice Center revised the Key Questions and developed eligibility criteria to identify the populations, interventions, comparators, outcomes, timing, and study designs (PICOTS) of interest. The Evidence-based Practice Center further refined the Key Questions and PICOTS based on input from interviews with eight Key Informants. Key Informants included experts in urology (including experts in urinary biomarkers and urologic oncology), medical oncology, and radiation oncology, as well as patient representatives and payers. Key Informants disclosed financial and other conflicts of interest prior to participation. The AHRQ Task Order Officer and the investigators reviewed the disclosures and determined that the Key Informants had no conflicts of interest that precluded participation. The Key Questions were posted for public comment from February 6, 2014 through February 26, 2014, and comments were received from four individuals.

After reviewing the public comments and obtaining additional input from a Technical Expert Panel (TEP) convened for this report, the research team revised the Key Questions. The TEP consisted of eight experts, specializing in urology (including urinary biomarkers and urologic oncology), radiation oncology, and medical oncology. The procedure for reviewing potential conflicts of interests of TEP members was similar to the procedure used for the Key Informants. The research team developed the final protocol with input from the TEP and AHRQ and was posted on the AHRQ Web site on July 21, 2014 (www.effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=1940). The protocol was also registered in the PROSPERO international database of prospectively registered systematic reviews.

## Searching for the Evidence

A research librarian experienced in conducting literature searches for CERs searched in Ovid MEDLINE (January 1990–October 2014), Cochrane Central Register of Controlled Trials (through September 2014), Cochrane Database of Systematic Reviews (through September 2014), Health Technology Assessment (through 3^rd^ Quarter, 2014), National Health Sciences Economic Evaluation Database (through 3^rd^ Quarter, 2014), and Database of Abstracts of Reviews of Effects (through 3^rd^ Quarter, 2014) to capture both published and grey literature. See Appendix A for the full search strategies. We searched for unpublished studies in clinical trial registries (ClinicalTrials.gov, Current Controlled Trials, ClinicalStudyResults.org and the WHO International Clinical Trials Registry Platform) and regulatory documents ( Drugs@FDA.gov and FDA Medical Devices Registration and Listing). Reference lists of relevant studies and previous systematic reviews were hand-searched for additional studies, including studies published prior to 1990. Scientific information packets were solicited from drug and device manufacturers and via a notice published in the Federal Register that invited interested parties to submit relevant published and unpublished studies using the publicly accessibly AHRQ Effective Health Care online scientific information packet portal.

Library searches were updated while the draft report was posted for public comment. Literature identified during the update search was assessed following the same process of dual review as for studies identified during the initial searches. New literature identified for inclusion was incorporated before the final submission of the report.

## Study Selection

We developed criteria for inclusion and exclusion of studies based on the Key Questions and PICOTS approach, in accordance with the AHRQ Methods Guide.15 Inclusion and exclusion criteria are summarized below and available in more detail in Appendix B. Abstracts were reviewed by two investigators, and all citations deemed appropriate for inclusion by at least one of the reviewers was retrieved. Two investigators independently reviewed all full-text articles for inclusion. Discrepancies were resolved by discussion and consensus. A list of the included studies can be found in Appendix C; excluded studies and primary reason for exclusion can be found in Appendix D.

### Population and Condition of Interest

For Key Questions related to diagnosis, we included studies of adults with signs or symptoms of possible bladder cancer (e.g., macroscopic or microscopic hematuria, irritative voiding symptoms) or undergoing surveillance following treatment for bladder cancer. For Key Questions related to treatment of non–muscle-invasive bladder cancer (NMIBC), we included studies of adults with NMIBC (defined as TNM stages Ta, Tis, or T1; N0; M0) undergoing treatment. Key Question 4 focused on adults with high-risk NMIBC.

### Interventions, Comparisons, and Study Designs of Interest

We included studies of US Food and Drug Administration (FDA)-approved urinary biomarkers for the diagnosis of bladder cancer (quantitative or qualitative NMP22, qualitative or quantitative BTA, FISH, and ImmunoCyt^™^) or available in the United States and classified as a Laboratory Developed Test by the FDA (CxBladder™). We excluded studies of diagnostic accuracy of other biomarkers or studies of included biomarkers that did not evaluate diagnostic accuracy of biomarkers against standard diagnostic methods (cystoscopy and histopathology). For cystoscopic methods, we included studies of fluorescent cystoscopy following intravesical instillation of a photosensitizing agent or other methods of augmented cystoscopy (e.g., narrow band imaging) for the initial diagnosis or surveillance of bladder cancer compared with standard (white light) cystoscopy.

For treatments, we include studies of intravesical therapies (mitomycin C [MMC], apaziquone, paclitaxel, gemcitabine, thiotepa, valrubicin, doxorubicin, epirubicin, bacillus Calmette-Guérin [BCG] and interferon) and external beam radiation therapy with or without systemic chemotherapy or immunotherapy versus transurethral resection of the bladder tumor (TURBT), other intravesical therapies, or cystectomy. We also included studies that compared different dosing regimens, different surveillance intervals, and risk adapted versus other approaches. We also included studies on the effects of patient and tumor characteristics on estimates of effectiveness.

For all Key Questions, we included randomized trials and cohort studies with concurrent controls, when randomized trials were not available. For diagnostic accuracy, we also included cross-sectional studies. We excluded uncontrolled observational studies, case-control studies, case series, and case reports, as these studies are less informative than studies with a control group. For studies on diagnostic accuracy of urinary biomarkers, case-control studies were defined as studies that selected patients known to have bladder cancer [cases] and patients known to not have bladder cancer [controls]).16 We did not include systematic reviews, though we reviewed reference lists for relevant studies.

### Outcomes of Interest

For diagnostic accuracy of urinary biomarkers, we evaluated sensitivity, specificity, predictive values, and likelihood ratios, using cystoscopy with biopsy as the reference standard. Clinical outcomes for trials of diagnostic methods and treatments were mortality, need for cystectomy, progression to muscle invasive bladder cancer, bladder cancer recurrence, and quality of life. We also evaluated adverse effects of diagnostic testing (e.g., false-positives, labeling, anxiety, and complications of cystoscopy) and adverse effects of treatment (e.g., cystitis, urinary urgency, urinary frequency, incontinence, hematuria, pain, and urosepsis, myelosuppression).

### Timing and Setting of Interest

For all Key Questions, we included studies conducted in inpatient or outpatient settings, with any duration of followup.

## Data Extraction and Data Management

For treatment studies, we extracted the following information into evidence tables: study design, setting, inclusion and exclusion criteria, dose and duration of treatment for experimental and control groups, duration of followup, number of subjects screened, eligible and enrolled, population characteristics (including age, race/ethnicity, sex, tumor stage and grade, and functional status), results, adverse events, withdrawals due to adverse events, and sources of funding. We calculated relative risks and associated 95% confidence intervals (CI) based on the information provided (sample sizes and incidence of outcomes in each intervention group). We noted discrepancies between calculated and reported results when present.

For diagnostic accuracy studies, we abstracted the following information: setting, screening test or tests, method of data collection, reference standard, inclusion criteria, population characteristics (including age, sex, race/ethnicity, smoking status, signs or symptoms, and prior bladder cancer stage or grade), proportion of individuals with bladder cancer, bladder cancer stage and grade, definition of a positive screening exam, proportion of individuals unexaminable by the screening test, proportion who did not undergo reference standard test, results, and sources of funding. We attempted to create two-by-two tables from information provided (sample size, prevalence, sensitivity, and specificity) and compared calculated measures of diagnostic accuracy based on the two-by-two tables with reported results. We noted discrepancies between calculated and reported results when present. When reported, we also recorded the area under the receiver operating characteristic curve.17,18

Data extraction for each study was completed by one investigator and independently reviewed for accuracy and completeness by a second investigator. See Appendix E for evidence tables with extracted data.

## Assessment of the Risk of Bias of Individual Studies

We assessed the risk of bias for randomized trials and observational studies using criteria adapted from those developed by the U.S. Preventive Services Task Force.19 Studies of diagnostic accuracy were rated using criteria adapted from QUADAS-2.^16^ These criteria were applied in conjunction with the approaches recommended in the AHRQ Methods Guide for medical interventions and the AHRQ Methods Guide for Medical Test Reviews.15,20

Two investigators independently assessed the risk of bias of each study. Discrepancies were resolved through discussion and consensus.

Each study was rated as “low,” “medium,” or “high” risk of bias.15 We rated the quality of each randomized trial based on the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; whether attrition was adequately reported and acceptable; similarity in use of cointerventions; compliance to allocated treatments; the use of intent-to-treat analysis; and avoidance of selective outcomes reporting.19

We rated the quality of each cohort study based on whether it enrolled a consecutive or random sample of patients meeting inclusion criteria; whether it evaluated comparable groups; whether rates of loss to followup were reported and acceptable; whether it used accurate methods for ascertaining exposures, potential confounders, and outcomes; and whether it performed adjustment for important potential confounders.19

We rated the quality of each study on diagnostic accuracy based on whether it evaluated a consecutive or random sample of patients meeting predefined criteria, whether the index test was performed in all patients, whether the index test results were interpreted without knowledge of the reference standard, whether a prespecified threshold was used to define a positive index test, whether the reference standard was interpreted without knowledge of the reference standard, whether there was an appropriate interval between the index test and the reference standard, whether the same reference standard was applied in all patients, and whether all patients were included in the analysis.16,20

Studies rated “low risk of bias” were considered to have no more than very minor methodological shortcomings and their results are likely to be valid. Studies rated “medium risk of bias” have some methodological shortcomings, but no flaw or combination of flaws judged likely to cause major bias. In some cases, the article did not report important information, making it difficult to assess its methods or potential limitations. The “medium risk of bias” category is broad and studies with this rating vary in their strengths and weaknesses; the results of some studies assessed to have medium risk of bias are likely to be valid, while others may be only possibly valid. Studies rated “high risk of bias” have significant flaws that may invalidate the results. They have a serious or “fatal” flaw or combination of flaws in design, analysis, or reporting; large amounts of missing information (including publication of only preliminary results in a subgroup of patients randomized); or serious discrepancies in reporting. An example of a fatally flawed study would be one with very high loss to followup (e.g., >50%), failure to perform intention-to-treat analysis, lack of blinding and failure to adequately describe randomization procedures. The results of these studies are at least as likely to reflect flaws in the study design as the differences between the compared interventions. We did not exclude studies rated as having high risk of bias a priori, but they were considered the least reliable when synthesizing the evidence, particularly when discrepancies between studies were present.

For further details about the assessment of the risk of bias see Appendix F.

## Assessing Applicability

We recorded factors important for understanding the applicability of studies, such as whether the publication adequately described the study sample, the country in which the study was conducted, the characteristics of the patient sample (e.g., age, sex, race/ethnicity, risk factors for bladder cancer, presenting symptoms, and medical comorbidities), tumor characteristics (e.g., stage and grade, primary or recurrent, unifocal or multifocal lesions), the characteristics of the diagnostic tests (e.g., specific test evaluated and cutoffs used) and interventions (e.g., treatment dose, duration and interval) used, and the magnitude of effects on clinical outcomes.15 We also recorded the funding source and role of the sponsor.

Applicability depends on the particular question and the needs of the user of the review. There is no generally accepted universal rating system for applicability. In addition, applicability depends in part on context. Therefore, a rating of applicability (such as “high” or “low”) was not assigned because applicability may differ based on the user of this report.

## Data Synthesis

For studies on diagnostic accuracy of urinary biomarkers, we performed meta-analyses to help summarize data and obtain more precise estimates.21 All quantitative analyses were conducted using SAS^®^ 10.0 (SAS Institute Inc., Cary, NC). We used a bivariate logistic mixed effects model22 to analyze sensitivity and specificity, incorporating the correlation between sensitivity and specificity. We assumed random effects across studies with a bivariate normal distribution for sensitivity and specificity, and heterogeneity among the studies was measured based on the random effect variance (τ^2^). The advantage of using a logistic mixed effects model is that it handles sparse data better and does not need to assume an ad hoc continuity correction when a study has zero events.22 When few studies were available for an analysis, we used the moment estimates of correlation between sensitivity and specificity in the bivariate model. We calculated positive likelihood ratio (LR+) and negative likelihood ratio (LR-) using the summarized sensitivity and specificity.23,24 Because studies of a particular biomarker generally used the same definition for a positive test, we did not attempt to plot summary receiver operating characteristic (ROC), which are based on estimates of sensitivity and specificity at different thresholds.25 For head-to-head comparisons, we used the same bivariate logistic mixed effects model as described above, but added an indicator variable for imaging modalities (equivalent to a meta-regression approach).

We conducted analyses for each biomarker based on data from all patients who underwent testing, as well as stratified according to whether testing was performed for evaluation of signs or symptoms of bladder cancer or for surveillance for previously treated bladder cancer. We also performed analyses stratified according to aspects of study design (retrospective or prospective design, use of prespecified threshold to define a positive test), risk of bias (overall risk of bias rating and whether the study performed blinded to the results of the index test), and setting (based on the country in which the study was performed), and in subgroups defined by tumor grade and stage. We performed separate analyses on the subset of studies that directly compared two or more imaging modalities or techniques in the same population against a common reference standard. Research indicates that results based on such direct comparisons differ from results based on noncomparative studies, and may be better suited for evaluating comparative diagnostic test performance.26

We also conducted meta-analyses on trials of intravesical therapy that reported effects on clinical outcomes and were homogeneous enough to provide a meaningful combined estimate. We used the Dersimonian-Laird random effects method using SAS software, Version 10.0 (SAS Institute Inc., Cary, NC).27 We assessed the presence of statistical heterogeneity among the studies using the standard Cochran's chi-square test, and the magnitude of heterogeneity by using the I^2^ statistic.28 When statistical heterogeneity was present, we performed sensitivity analyses by conducting meta-analysis using the profile likelihood method.29 We also performed sensitivity and subgroup analyses based on ratings for risk of bias, dose of intravesical therapy, inclusion of high-risk patients, and duration of followup. We also stratified trials according to the type of instillation regimen, classified as single instillation, induction therapy (treatment for 4 to 8 weeks), maintenance therapy (treatment for longer than 8 weeks), or other. We calculated pooled relative risks for the dichotomous outcomes bladder cancer recurrence, bladder cancer progression, all-cause mortality, bladder cancer mortality, and local and systemic adverse events. Similar analyses were performed for trials of augmented cystoscopy (fluorescent light or narrow band imaging) versus white light cystoscopy.

## Grading the Strength of Evidence for Each Key Question

We assessed the strength of evidence for each Key Question and outcome using the approach described in the AHRQ Methods Guide,15 based on the overall quality of each body of evidence, the risk of bias (graded low, medium, or high); the consistency of results across studies (graded consistent, inconsistent, or unable to determine when only one study was available); the directness of the evidence linking the intervention and health outcomes (graded direct or indirect); the precision of the estimate of effect, based on the number and size of studies and confidence intervals for the estimates (graded precise or imprecise); and reporting bias (suspected of undetected)

Assessments of reporting bias were based on whether studies defined and reported primary outcomes, identification of relevant unpublished studies, and when available, by comparing published results to results reported in trial registries.

We graded the strength of evidence for each Key Question using the four key categories recommended in the AHRQ Methods Guide.15 A “high” grade indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect. A “moderate” grade indicates moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate. A “low” grade indicates low confidence that the evidence reflects the true effect and further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. An “insufficient” grade indicates evidence either is unavailable or is too limited to permit any conclusion, due to the availability of only poor-quality studies, extreme inconsistency, or extreme imprecision.

See Appendix G for the strength of evidence tables.

## Peer Review and Public Commentary

Experts in urology (including experts in urologic oncology and urinary biomarkers), medical oncology, and radiation oncology, were invited to provide peer review of the draft report. The AHRQ Task Order Officer and an Evidence-based Practice Center Associate Editor also provided comments and editorial review. The draft report was posted on the AHRQ Web site for 4 weeks for public comment. A disposition of comments report with authors' responses to the peer and public review comments will be posted after publication of the final CER on the public Web site.