# Introduction

## Background

### Nature and Burden of Non–Muscle-Invasive Bladder Cancer

Bladder cancer is the fourth most commonly diagnosed cancer in men and tenth most commonly diagnosed cancer in women in the United States.1 The American Cancer Society estimates there will be 74,690 new cases of bladder cancer in the United States in 2014 (about 56,390 men and 18,300 women), and about 15,580 deaths due to bladder cancer (about 11,170 men and 4,410 women).1 The lifetime probability of developing bladder cancer in the United States is approximately 3.8 percent in men and 1.2 percent in women; the incidence of bladder cancer is increasing in women. Bladder cancer occurs primarily in men older than 60 and roughly twice as frequently in white compared to black men,2 though the number of deaths due to bladder cancer is similar, presumably due to delayed diagnosis in black men.

Bladder cancer is an important health problem, with no improvement in associated mortality since 1975.^3^ Economic analyses have shown bladder cancer to be the costliest cancer to treat in the United States on a per capita basis, taking into account diagnostic testing, management, and long-term followup.4 The most common risk factor for bladder cancer is cigarette smoking, though other risk factors include occupational exposures and family history. The most common symptom of bladder cancer is painless hematuria (blood in the urine).

Bladder cancer is staged based on the extent of penetration or invasion into the bladder wall and adjacent structures (Table 1).5 Bladder cancers that have not invaded the bladder smooth muscle layer (stage classifications Tis [carcinoma in situ], Ta [noninvasive papillary carcinoma], and T1 [cancer that invades the subepithelial connective tissue]) are broadly grouped as non–muscle-invasive bladder cancers (NMIBC). Stage T2 cancers are muscle-invasive, and higher stage cancers invade beyond the muscle layer into surrounding fat (stage classification T3 bladder cancer) or beyond the fat into nearby organs or structures (stage classification T4 bladder cancer). Approximately 75 percent of newly diagnosed bladder cancers are NMIBC.6 Individuals with NMIBC generally have a good prognosis, with 5-year survival rates higher than 88 percent.7 However, as many as 70 percent of NMIBC tumors will recur after initial treatment, with a 10-20 percent risk of progression to invasive bladder cancer.6 The likelihood of progression from NMIBC to muscle invasive cancer depends on the tumor grade (based on the degree of cell differentiation), the tumor stage, the size of the cancer, and whether the cancer is recurrent or multifocal.8 Prognosis is poorer for patients with muscle-invasive bladder cancers (5-year survival rates from 63% to 15%).7

Table 1 Bladder cancer tumor staging

| Cancer Stage | Description
T stages (tumor) | CIS (also called Tis) | Flat, high grade, cancer cells are only present in the innermost layer of the bladder lining.
T stages (tumor) | Ta | The cancer is just in the innermost layer of the bladder lining
T stages (tumor) | T1 | The cancer has started to grow into the connective tissue beneath the bladder lining
T stages (tumor) | T2 | The cancer has grown through the connective tissue into the muscle
T stages (tumor) | T2a | The cancer has grown into the superficial muscle
T stages (tumor) | T2b | The cancer has grown into the deeper muscle
T stages (tumor) | T3 | The cancer has grown through the muscle into the fat layer
T stages (tumor) | T3a | The cancer in the fat layer can only be seen under a microscope
T stages (tumor) | T3b | The cancer in the fat layer can be seen on tests, or felt by a doctor during an examination under anesthetic
T stages (tumor) | T4 | The cancer has spread outside the bladder
T stages (tumor) | T4a | The cancer has spread to the prostate, womb (uterus), or vagina
T stages (tumor) | T4b | The cancer has spread to the wall of the pelvis or abdomen
N stages (lymph nodes) | N0 | No cancer in any lymph nodes
N stages (lymph nodes) | N1 | There is cancer in one lymph node in the pelvis
N stages (lymph nodes) | N2 | There is cancer in more than one lymph node in the pelvis
N stages (lymph nodes) | N3 | There is cancer in one or more lymph nodes in the groin
M stages (metastasized) | M0 | There are no signs of distant spread
M stages (metastasized) | M1 | The cancer has spread to distant parts of the body
1973 WHO grading urothelial papilloma | Grade 1 (G1) | Well differentiated
1973 WHO grading urothelial papilloma | Grade 2 (G2) | Moderately differentiated
1973 WHO grading urothelial papilloma | Grade 3 (G3) | Poorly differentiated
2004 WHO grading | | Flat lesions
2004 WHO grading | | Hyperplasia (flat lesion without atypia or papillary)
2004 WHO grading | | Reactive atypia (flat lesion with atypia)
2004 WHO grading | | Atypia of unknown significance
2004 WHO grading | | Urothelial dysplasia
2004 WHO grading | | Urothelial carcinoma in situ
2004 WHO grading | | Papillary lesions
2004 WHO grading | | Urothelial papilloma (which is a completely benign lesion)
2004 WHO grading | | Papillary urothelial neoplasm of low malignant potential
2004 WHO grading | | Low-grade papillary urothelial carcinoma
2004 WHO grading | | High-grade papillary urothelial carcinoma

CIS = carcinoma in situ; WHO = World Health Organization

Sources: Cancer Research UK, 2013.^9^ American Cancer Society, 2014.^10^ EUA Guidelines (Babjuk 2013)8

### Diagnosis and Surveillance of Bladder Cancer

A number of tests are available for screening, diagnosis, and staging of bladder cancer. Standard methods for identification of bladder cancer include urine dipstick and microscopic urinalysis (to detect hematuria) and urine cytology (to detect abnormal or cancerous cells in the urine), followed by imaging tests and cystoscopy.11 Urine-based biomarkers have been developed as potential diagnostic alternatives or supplements to cytology, imaging, and cystoscopy.12 A number of biomarkers have been evaluated in conjunction with cytology for diagnosis of bladder cancer, potentially reducing the need for cystoscopy. In addition to initial diagnosis and staging, diagnostic surveillance with cystoscopy and cytology is also performed following treatment, to identify patients with recurrence or progression of cancer. Urine-based biomarker tests may also be used to help identify recurrence and need for cystoscopy during surveillance.

There are five diagnostic biomarker tests approved by the US Food and Drug Administration (FDA) for diagnosis or surveillance of bladder cancer: quantitative NMP22 (Alere NMP22^®^), qualitative NMP22 (BladderChek^®^), qualitative BTA (BTAstat^®^), quantitative BTA (BTA TRAK^®^), fluorescence in situ hybridization (FISH, UroVysion^®^), and fluorescence immunohistochemistry (ImmunoCyt^™^, which uses monoclonal antibodies to test for carcinoembryonic antigens and mucin glycoproteins). The qualitative NMP22 and BTA tests can be used as point-of-care tests and the others are performed in a laboratory. The CxBladder™ test, which tests for five specific mRNA biomarkers, is a “Laboratory Developed Test” that does not require FDA approval. A number of other biomarkers, including those based on detection of fibroblast growth factor receptor 3 (FGFR3); cytokeratin fragments (e.g., CYFRA 21-1, TPA, TPS); survivin; telomerase; vascular endothelial growth factor (VEGF); aurora kinase, or metalloproteinases (MMP-2 and MMP-9) have also been developed, but are not FDA-approved. The large number of available tests and testing strategies and potential trade-offs in diagnostic accuracy, risks, and patient preferences pose significant challenges in determining optimal testing and monitoring strategies. Tests with high false positive rates could lead to unnecessary invasive procedures for further evaluation and tests with high false negative rates could lead to missed diagnoses.

### Interventions and Outcomes For Non–Muscle-Invasive Bladder Cancer

Once bladder cancer has been diagnosed, a number of factors affect prognosis and treatment options. These include the stage of the cancer, tumor grade, whether the tumor is an initial tumor or a recurrence, the number and size of tumors, the patient's age and general health, and other factors. The main treatment for NMIBC is local resection with transurethral resection of the bladder tumor (TURBT), often with adjuvant intravesical therapy to destroy residual tumor cells using chemotherapeutic agents (e.g., mitomycin C [MMC], apaziquone, paclitaxel, gemcitabine, thiotepa, valrubicin, doxorubicin, epirubicin), bacillus Calmette-Guérin (BCG), or interferon immunotherapy.13 All of these treatments are FDA-approved and available in the United States. Electromotive drug administration is a method for enhancing the effectiveness of intravesical chemotherapy that is increasingly used, especially in Europe. Clinical trials of electromotive drug administration of intravesical therapy are ongoing in the United States, but the method is not widely available or used in the United States, and is not FDA-approved for this purpose.

Post-TURBT adjuvant intravesical therapy is associated with potential local (e.g., dysuria frequency, and hematuria) and systemic side effects. However, not using adjuvant intravesical therapy may increase the risk of bladder cancer recurrence or progression, particularly in patients with higher risk lesions. The European Association of Urology advocates an assessed risk-adapted approach to treatment decisionmaking, based on prognostic factors such as tumor grade, tumor stage, and the number and size of tumors.14 This approach, which stratifies patients into three risk groups based on the presence of risk factors, helps identify patients in the intermediate and high risk groups who are more likely to benefit from intravesical therapy.

### Rationale for Evidence Review

The purpose of this report is to review the currently available evidence on the comparative effectiveness of diagnostic tests and treatments for NMIBC. Although updated guidelines for the treatment and followup of NMIBC from the European Association of Urology were published in 2013,^8^ the literature continues to evolve, with much of the new evidence focusing on diagnostic techniques such as fluorescence cystoscopy or urine-based biomarkers, and treatments with intravesical therapy alternatives to MMC and BCG. A systematic evidence review that includes recently published research may provide a better understanding of the comparative effectiveness of currently available approaches to diagnosis, treatment, and post-treatment surveillance for NMIBC. The systematic review may be used to update existing clinical recommendations that are several years old or may be out-of-date due to the development of new technologies and therapies.

## Scope of Review and Key Questions

This topic was nominated for review by the American Urological Association and focuses on diagnosis of bladder cancer and treatment of NMIBC. The Key Questions and analytic framework used to guide this report are shown below. The analytic framework (Figure 1) shows the scope of this review, including the target population, interventions, comparisons, and health outcomes we examined.

Figure 1 Analytic framework

KQ = Key Question. Cancer stages shown are the TNM (tumor, node, metastasis) classification.

^a^ Urinary biomarkers of interest are restricted to tests that are approved for diagnosis of bladder cancer by the U.S. Food and Drug Administration (BTAstat^®^ [bladder tumor antigen], Alere NMP22^®^, BladderChek^®^ [nuclear matrix protein 22], UroVysion^®^ [fluorescence in situ hybridization], and ImmunoCyt^™^ [immunocytology]) or available in the United States and classified as a Laboratory Developed Test by the Food and Drug Administration (CxBladder™).

^b^ Chemotherapeutic and immunotherapeutic agents of interest include mitomycin C, apaziquone, paclitaxel, gemcitabine, thiotepa, epirubicin, valrubicin, doxorubicin, bacillus Calmette-Guérin, and interferon.

^c^ Muscle-Invasive Bladder Cancer Comparative Effectiveness Review: Chou R, Selph S, Buckley D, et al. (2015). Treatment of Nonmetastatic Muscle-Invasive Bladder Cancer. .

Figure 1 is an analytic framework that depicts the populations, interventions, outcomes, and adverse effects of interest for emerging approaches to diagnosis and treatment of non-muscle-invasive bladder cancer. The far left of the framework describes the target population for utilizing diagnostic tests for bladder cancer, patients with signs or symptoms of bladder cancer. To the right is diagnostic testing, utilizing one or more of the following urinary biomarkers: BTAstat® for bladder tumor-associated antigen (BTA); Alere NMP22® and BladderChek® for nuclear matrix protein 22 (NMP22); UroVysion® fluorescence in situ hybridization (FISH) assay; Cxbladder™, and ImmunoCyt™. Below the diagnostic testing is an oval for adverse effects of diagnostic testing. To the right of the diagnostic testing are four possible results of testing. Diagnostic workup negative, Muscle-invasive bladder cancer (Stage T2, T3, or T4a; N0, M0), and Metastatic bladder cancer (Stage T4b; N0; M0, or Any T; N1-3; M0, or Any T; Any N; M1) are not included in this systematic review. The third outcome is diagnosis of non-muscle invasive bladder cancer with stage Ta, Tis, or T1; N0; M0. Continuing to the right from the box with non-muscle invasive bladder cancer, are treatment of bladder cancer with chemotherapeutic and immunotherapeutic agents of interest, including mitomycin; apaziquone; paclitaxel; gemcitabine; thiotepa; valrubicin; doxorubicin; epirubicin; bacillus Calmette-Guérin (BCG); and interferon. To the right of treatment is surveillance for recurrence or progression of bladder cancer. Below the treatment and surveillance boxes is an oval for the adverse effects of treatment and/or surveillance. To the right of surveillance is a box for the health outcomes of treating and using surveillance for bladder cancer, mortality, need for cystectomy, recurrence of cancer, progression of cancer, and quality of life.

The list of Key Questions follows.

Key Question 1. What is the diagnostic accuracy of various urinary biomarkers compared with other urinary biomarkers or standard diagnostic methods (cystoscopy, cytology, and imaging) in (1) people with signs or symptoms warranting evaluation for possible bladder cancer or (2) people undergoing surveillance for previously treated bladder cancer?

a. Does the diagnostic accuracy differ according to patient characteristics (e.g., age, sex, race/ethnicity) or according to the nature of the presenting signs or symptoms?

Key Question 2. For patients with non–muscle-invasive bladder cancer, does the use of a formal risk-adapted assessment approach to treatment decisions (e.g., based on Guidelines of the European Association of Urology or on urinary biomarker tests) decrease mortality or improve other outcomes (e.g., recurrence, progression, need for cystectomy, quality of life) compared with treatment not guided by a formal assessed risk-adapted approach?

Key Question 3. For patients with non–muscle-invasive bladder cancer treated with transurethral resection of bladder tumor, what is the effectiveness of various intravesical chemotherapeutic or immunotherapeutic agents for decreasing mortality or improving other outcomes (e.g., recurrence, progression, need for cystectomy, quality of life) compared with TURBT alone?

a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination?
b. Does the comparative effectiveness differ according to tumor characteristics, such as stage, grade, size, multiplicity, whether the tumor is primary or recurrent, or molecular/genetic markers?
c. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities?
d. Does the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents differ according to dosing frequency, duration of treatment, and/or the timing of administration relative to TURBT?

Key Question 4. For patients with high-risk non–muscle-invasive bladder cancer treated with TURBT, what is the effectiveness of external beam radiation therapy (either alone or with systemic chemotherapy/immunotherapy) for decreasing mortality or improving other outcomes compared with intravesical chemotherapy/immunotherapy alone or cystectomy?

Key Question 5. In surveillance of patients treated for non–muscle-invasive bladder cancer, what is the effectiveness of various urinary biomarkers to decrease mortality or improve other outcomes compared with other urinary biomarkers or standard diagnostic methods (cystoscopy, cytology, and imaging)?

a. Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers?
b. Does the comparative effectiveness differ according to the treatment used (i.e., specific chemotherapeutic or immunotherapeutic agents and/or TURBT)?
c. Does the comparative effectiveness differ according to the length of surveillance intervals?
d. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, or race/ethnicity?

Key Question 6. For initial diagnosis or surveillance of patients treated for non–muscle-invasive bladder cancer, what is the effectiveness of blue light or other methods of augmented cystoscopy compared with standard cystoscopy for recurrence rates, progression of bladder cancer, mortality, or other clinical outcomes?

Key Question 7. What are the comparative adverse effects of various tests for diagnosis and post-treatment surveillance of bladder cancer, including urinary biomarkers, cytology, and cystoscopy?

Key Question 8. What are the comparative adverse effects of various treatments for non–muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT?

a. How do adverse effects of treatment vary by patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease?