# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers who participated in reviewing this report follows:

- M. Craig Hall, M.D., FACS
  High Point Regional Hospital
  High Point, NC
- Michael Koch, M.D.
  Indiana University School of Medicine
  Indianapolis, IN
- Seth P. Lerner, M.D., FACS
  Baylor College of Medicine
  Houston, Texas
- John Seigne, M.D.
  Dartmouth Hitchcock Medical Center
  Lebanon, NH
- Angela Smith, M.D., M.S.
  University of North Carolina
  Chapel Hill, NC