# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Karim Chamie, M.D., M.S.H.S.
  University of California, Los Angeles
  Los Angeles, CA
- Sam S. Chang, M.D., FACS
  Vanderbilt University Medical Center
  Vanderbilt-Ingram Cancer Center
  Nashville, TN
- Yair Lotan, M.D.
  University of Texas Southwestern Medical Center
  Dallas, TX
- Raj Pruthi, M.D., FACS
  University of North Carolina School of Medicine
  Chapel Hill, NC
- Howard Sandler, M.D., M.S., FASTRO
  Cedars-Sinai Medical Center
  Los Angeles, CA
- Seth Strope, M.D., M.P.H.
  Washington University School of Medicine
  St. Louis, MO
- Yu-Ning Wong, M.D., M.S.C.E.
  Fox Chase Cancer Center
  Philadelphia, PA