# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Sam S. Chang, M.D., FACS
  Vanderbilt University Medical Center
  Vanderbilt-Ingram Cancer Center
  Nashville, TN
- Yair Lotan, M.D.
  University of Texas Southwestern Medical Center
  Dallas, TX
- Michael O'Donnell, M.D., FACS
  University of Iowa
  Iowa City, IA
- Yuval Raizen, M.D.
  Oncology Consultants
  Houston, TX
- Howard Sandler M.D., M.S., FASTRO
  Cedars-Sinai Medical Center
  Los Angeles, CA
- Monica Smith, B.A.
  Bladder Cancer Advocacy Network
  Bethesda, MD
- Yu-Ning Wong, M.D., M.S.C.E.
  Fox Chase Cancer Center
  Philadelphia, PA
- John Yao, M.D., M.B.A., M.P.H., M.P.P., FACP
  Blue Shield
  San Francisco, CA