# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Andrew Hamilton, M.L.S., for assistance with literature search strategy development; Leah Williams, B.S., for editorial support; William Lawrence, M.D., M.S., for his support and guidance in developing this report; and our Associate Editor, Issa Dahabreh, for his review of this report.