# Discussion

## Key Findings and Strength of Evidence

The key findings of this review are summarized in the summary of evidence table (Table 21) and the factors used to determine the overall strength of evidence grades are summarized in Appendix G.

Table 21 Summary of the strength of evidence

Key Question | Outcome | Strength-of-Evidence Grade | Conclusion
Key Question 1. What is the diagnostic accuracy of various urinary biomarkers compared with other urinary biomarkers or standard diagnostic methods (cystoscopy, cytology, and imaging) in 1) people with signs or symptoms warranting evaluation for possible bladder cancer or 2) people undergoing surveillance for previously treated bladder cancer? | Quantitative NMP22: sensitivity and specificity | Moderate | Sensitivity was 0.69 (95% CI, 0.62 to 0.75) and specificity 0.77 (95% CI, 0.70 to 0.83), based on 19 studies, for a positive likelihood ratio of 3.05 (95% CI, 2.28 to 4.10) and negative likelihood ratio of 0.40 (95% CI, 0.32 to 0.50).
| Qualitative NMP22: sensitivity and specificity | Low | Sensitivity was 0.58 (95% CI, 0.39 to 0.75) and specificity 0.88 (95% CI, 0.78 to 0.94), based on 4 studies, for a positive likelihood ratio of 4.89 (95% CI, 3.23 to 7.40) and negative likelihood ratio of 0.48 (95% CI, 0.33 to 0.71).
| Qualitative BTA: sensitivity and specificity | Moderate | Sensitivity was 0.64 (95% CI, 0.58 to 0.69; 22 studies) and specificity 0.77 (95% CI, 0.73 to 0.81; 21 studies), for a positive likelihood ratio of 2.80 (95% CI, 2.31 to 3.39) and negative likelihood ratio of 0.47 (95% CI, 0.30 to 0.55).
| Quantitative BTA: sensitivity and specificity | Low | Sensitivity was 0.65 (95% CI, 0.54 to 0.75) and specificity 0.74 (95% CI, 0.64 to 0.82), based on 4 studies, for a positive likelihood ratio of 2.52 (95% CI, 1.86 to 3.41) and negative likelihood ratio of 0.47 (95% CI, 0.37 to 0.61).
| FISH: sensitivity and specificity | Moderate | Sensitivity was 0.63 (95% CI, 0.50 to 0.75) and specificity 0.87 (95% CI, 0.79 to 0.93), based on 11 studies, for a positive likelihood ratio of 5.02 (95% CI, 2.93 to 8.60) and negative likelihood ratio of 0.42 (95% CI, 0.30 to 0.59).
| ImmunoCyt^™^: sensitivity and specificity | Moderate | Sensitivity was 0.78 (95% CI, 0.68 to 0.85) and specificity 0.78 (95% CI, 0.72 to 0.82), based on 14 studies, for a positive likelihood ratio of 3.49 (95% CI, 2.82 to 4.32) and negative likelihood ratio of 0.29 (95% CI, 0.20 to 0.41).
| CxBladder^™^: sensitivity and specificity | Low | Sensitivity was 0.82 (95% CI, 0.70 to 0.90) and specificity 0.85 (95% CI, 0.81 to 0.88) for evaluation of symptoms, based on 1 study, for a positive likelihood ratio of 5.53 (95% CI, 4.28 to 7.15) and negative likelihood ratio of 0.21 (95% CI, 0.13 to 0.36).
| Quantitative NMP22 versus qualitative BTA: sensitivity and specificity | Moderate | Based on 7 studies, there was no difference between quantitative NMP22 (cutoff >10 U/mL) and qualitative BTA in sensitivity (0.69; 95% CI, 0.62 to 0.76 vs. 0.66; 95% CI, 0.59 to 0.73, for a difference of 0.03; 95% CI, -0.04 to 0.10) or specificity (0.73; 95% CI, 0.62 to 0.82 vs. 0.76; 95% CI, 0.66 to 0.84, for a difference of 0.03; 95% CI, -0.08 to 0.01).
| ImmunoCyt versus FISH: sensitivity vs. specificity | Low | ImmunoCyt was associated with higher sensitivity than FISH (0.71; 95% CI, 0.54 to 0.84 vs. 0.61; 95% CI, 0.43 to 0.76, for a difference of 0.11; 95% CI, 0.001 to 0.21) but lower specificity (0.71; 95% CI, 0.62 to 0.79 vs. 0.79; 95% CI, 0.71 to 0.85, for a difference of -0.08; 95% CI, -0.15 to -0.001), based on 3 studies.
| Other head-to-head comparisons of urinary biomarkers | Insufficient | Evidence for other head-to-head comparisons of urinary biomarkers was based on small numbers of studies with imprecise estimates and methodological shortcomings, precluding reliable conclusions regarding comparative test performance.
| Various urinary biomarkers plus cytology vs. the urinary biomarker alone: sensitivity and specificity | Moderate | Sixteen studies found various urinary biomarkers plus cytology to be associated with higher sensitivity than the urinary biomarker alone (0.81; 95% CI, 0.75 to 0.86 vs. 0.69; 95% CI, 0.61 to 0.76, for a difference of 0.13; 95% CI, 0.08 to 0.17), with no difference in specificity.
Key Question 1a. Does the diagnostic accuracy differ according to patient characteristics (e.g., age, sex, race/ethnicity), or according to the nature of the presenting signs or symptoms? | Effects of tumor stage: sensitivity | High | Across urinary biomarkers, sensitivity increased with higher tumor stage. Evidence was most robust for quantitative NMP22 (11 studies), qualitative BTA (18 studies), and FISH (8 studies); the association between higher tumor stage and increased sensitivity was least pronounced for ImmunoCyt (10 studies). Sensitivity was generally similar to or slightly lower for CIS tumors than for T1 tumors.
Key Question 1a. Does the diagnostic accuracy differ according to patient characteristics (e.g., age, sex, race/ethnicity), or according to the nature of the presenting signs or symptoms? | Effects of tumor grade: sensitivity | High | Across urinary biomarkers, sensitivity increased with higher tumor grade. Evidence was most robust for quantitative NMP22 (12 studies), ImmunoCyt (10 studies), qualitative BTA (18 studies), and FISH (9 studies).
Key Question 1a. Does the diagnostic accuracy differ according to patient characteristics (e.g., age, sex, race/ethnicity), or according to the nature of the presenting signs or symptoms? | Effects of tumor size: sensitivity | Low | Two studies found that sensitivity was higher for larger (>1 cm or >2 cm) vs. smaller tumors.
Key Question 1a. Does the diagnostic accuracy differ according to patient characteristics (e.g., age, sex, race/ethnicity), or according to the nature of the presenting signs or symptoms? | Effects of patient characteristics (age, sex, smoking status, and presence of other clinical conditions): sensitivity and specificity | Low | Evidence on the effects of patient characteristics, such as age, sex, smoking status, and presence of other clinical conditions, on diagnostic accuracy of urinary biomarkers was limited but did not clearly or consistently indicate effects on sensitivity or specificity.
Key Question 2. For patients with non–muscle-invasive bladder cancer, does the use of a formal risk-adapted assessment approach to treatment decisions (e.g., Guidelines of the European Association of Urology or based on urinary biomarker tests) decrease mortality or improve other outcomes (e.g., recurrence, progression, need for cystectomy, quality of life) compared with treatment not guided by a formal assessed risk-adapted approach? | Mortality, recurrence, progression, need for cystectomy, quality of life | Insufficient | No studies.
Key Question 3. For patients with non–muscle-invasive bladder cancer treated with transurethral resection of bladder tumor (TURBT), what is the effectiveness of various intravesical chemotherapeutic or immunotherapeutic agents for decreasing mortality or improving other outcomes (e.g., recurrence, progression, need for cystectomy, quality of life) compared with TURBT alone? | BCG vs. no intravesical therapy: All-cause mortality | Insufficient | No trial evaluated effects of BCG vs. no intravesical therapy on risk of all-cause mortality..
| BCG vs. no intravesical therapy: Bladder cancer specific mortality | Insufficient | One trial found BCG to be associated with decreased risk of bladder cancer specific mortality vs. no intravesical therapy, but the difference was not statistically significant (RR, 0.62; 95% CI, 0.32 to 1.19).
| BCG vs. no intravesical therapy: Recurrence | Low | BCG was associated with decreased risk of bladder cancer recurrence vs. no intravesical therapy (3 trials; RR, 0.56; 95% CI, 0.43 to 0.71; I^2^ = 0%).
| BCG vs. no intravesical therapy: Progression | Low | BCG was associated with decreased risk of bladder cancer progression (4 trials; RR, 0.39; 95% CI, 0.24 to 0.64; I^2^ = 40%) vs. no intravesical therapy
| MMC vs. no intravesical therapy : All-cause mortality | Low | There was no difference in risk of all cause-mortality for MMC vs. no intravesical therapy (1 trial; HR, 1.17; 95% CI, 0.89 to 1.53).
| MMC vs. no intravesical therapy : Bladder cancer specific mortality | Low | The effects on bladder cancer specific mortality were not statistically significant for MMC vs. no intravesical therapy (1 trial; HR, 0.71; 95% CI, 0.34 to 1.46).
| MMC vs. no intravesical therapy : Recurrence | Moderate | MMC was associated with decreased risk of bladder cancer recurrence vs. no intravesical therapy (8 trials; RR, 0.71; 95% CI, 0.57 to 0.89; I^2^ = 72%).
| MMC vs. no intravesical therapy : Progression | Low | Effects of MMC on bladder cancer progression were not statistically significant (5 trials; RR, 0.68; 95% CI, 0.39 to 1.20; I^2^ = 0%) vs. no intravesical therapy.
| Doxorubicin vs. no intravesical therapy : All-cause mortality | Low | Doxorubicin was associated with no clear effects on all-cause mortality (2 trials) vs. no intravesical therapy.
| Doxorubicin vs. no intravesical therapy : Bladder cancer specific mortality | Low | Doxorubicin was associated with no clear effects on bladder cancer specific mortality (1 trial) vs. no intravesical therapy.
| Doxorubicin vs. no intravesical therapy : Recurrence | Moderate | Doxorubicin was associated with decreased risk of bladder cancer recurrence vs. no intravesical therapy (10 trials; RR, 0.80; 95% CI, 0.72 to 0.88; I^2^ = 46%).
| Doxorubicin vs. no intravesical therapy : Progression | Low | Doxorubicin was associated with no difference in risk of bladder cancer progression (5 trials; RR, 1.03; 95% CI, 0.72 to 1.46; I^2^ = 0.0%) vs. no intravesical therapy.
| Epirubicin vs. no intravesical therapy : Recurrence | Moderate | Epirubicin was associated with decreased risk of bladder cancer recurrence (9 trials; RR, 0.63; 95% CI, 0.53 to 0.75; I^2^ = 64%) vs. no intravesical therapy.
| Epirubicin vs. no intravesical therapy : Progression | Low | Epirubicin was associated with a non–statistically significant effect on bladder cancer progression (8 trials; RR, 0.79; 95% CI, 0.84 to 1.30; I^2^ = 27%).
| Gemcitabine vs. no intravesical therapy : All-cause mortality, bladder cancer specific mortality, progression | Insufficient | Estimates for progression (RR, 3.00; 95% CI, 0.32 to 28.4), all-cause mortality (RR, 0.50; 95% CI, 0.13 to 2.00), and bladder cancer specific mortality (RR, 1.00; 95% CI, 0.06 to 15.81) were very imprecise for gemcitabine vs. no intravesical therapy.
| Gemcitabine vs. no intravesical therapy : Recurrence | Low | One trial found no difference between single-instillation gemcitabine vs. no intravesical therapy in risk of bladder cancer recurrence (RR, 0.98; 95% CI, 0.70 to 1.36).
| Interferon alpha vs. no intravesical therapy : Bladder cancer specific mortality | Low | Interferon alpha was associated with no difference in risk of bladder cancer specific mortality (1 trial; RR, 1.00; 95% CI, 0.15 to 6.75).
| Interferon alpha vs. no intravesical therapy : Recurrence | Low | Interferon alpha was associated with a non–statistically significant reduction in risk for bladder cancer recurrence vs. no intravesical therapy (3 trials; RR, 0.75; 95% CI, 0.53 to 1.06; I^2^ = 50%).
| Interferon alpha vs. no intravesical therapy : Progression | Low | Interferon alpha was associated with decreased risk of bladder cancer progression vs. no intravesical therapy (2 trials; RR, 0.33; 95% CI, 0.14 to 0.76; I^2^ = 0%).
| Interferon gamma vs. no intravesical therapy : Recurrence | Low | Interferon gamma was associated with decreased risk of bladder cancer recurrence vs. no intravesical therapy (1 trial; RR, 0.72; 95% CI, 0.51 to 1.01).
| Interferon gamma vs. no intravesical therapy : Progression | Low | Interferon gamma was associated with no difference in risk of bladder cancer progression vs. no intravesical therapy (1 trial; RR, 1.08; 95% CI, 0.07 to 16.4).
| Thiotepa vs. no intravesical therapy : Recurrence | Low | Thiotepa was associated with decreased risk of bladder cancer recurrence vs. no intravesical therapy in 5 trials (RR, 0.78; 95% CI, 0.58 to 1.06; I^2^ = 69%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. MMC: All-cause mortality | Moderate | There was no difference in risk of all-cause mortality between BCG and MMC (7 trials; RR, 0.94; 95% CI, 0.83 to 1.06; I^2^ = 0%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. MMC: Bladder cancer specific mortality | Moderate | There was no difference between BCG and MMC in risk of bladder cancer specific mortality (5 trials; RR, 0.77; 95% CI, 0.54 to 1.10; I^2^ = 0%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. MMC: Recurrence | Low | There were no differences between BCG and MMC in risk of bladder cancer recurrence (10 trials; RR, 0.95; 95% CI, 0.81 to 1.11; I^2^ = 67%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. MMC: Progression | Moderate | There was no difference in risk of progression (7 trials; RR, 0.88; 95% CI, 0.66 to 1.17; I^2^ = 18%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG alone vs. BCG plus MMC given sequentially: All-cause mortality, bladder cancer specific mortality, recurrence, progression | Low | There were no differences sequentially in risk of all-cause (1 trial; RR, 1.57; 95% CI, 0.67 to 3.71) or bladder cancer specific mortality (2 trials; RR, 1.10; 95% CI, 0.50 to 2.38; I^2^ = 17%), bladder cancer recurrence (4 trials; RR, 1.03; 95% CI, 0.70 to 1.52; I^2^ = 75%), progression (3 trials; RR, 0.87; 95% CI, 0.40 to 1.91; I^2^ = 22%), or cystectomy (4 trials; RR, 0.87; 95% CI, 0.41 to 1.84; I^2^ = 0%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG plus MMC given sequentially vs. MMC alone: All-cause mortality, bladder cancer specific mortality, recurrence, progression | Low | There were no differences in risk of all-cause (2 trials; RR, 1.53; 95% CI, 0.72 to 1.74 and RR, 0.95; 95% CI, 0.71 to 1.30) or bladder cancer mortality (2 trials; RR, 0.64; 95% CI, 0.22 to 1.88 and RR, 0.95; 95% CI, 0.45 to 1.56), bladder cancer recurrence (2 trials; RR, 0.88; 95% CI, 0.75 to 1.03; I^2^ = 0%), or progression (2 trials; RR, 0.82; 95% CI, 0.40 to 1.68 and RR, 1.28; 95% CI, 0.35 to 4.61).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. doxorubicin: All-cause mortality, recurrence, progression | Low | BCG was associated with decreased risk of bladder cancer recurrence vs. doxorubicin (2 trials; RR, 0.31; 95% CI, 0.16 to 0.61 and RR, 0.75; 95% CI. 0.64 to 0.88), but there was no difference in risk of all-cause mortality (2 trials; RR, 0.40; 95% CI, 0.01 to 12 and RR, 1.00; 95% CI, 0.71 to 1.37) or bladder cancer progression (1 trial; RR, 0.20; 95% CI, 0.02 to 1.72).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. epirubicin: All-cause mortality | Low | Estimates favored BCG for all-cause mortality, but differences were not statistically significant (3 trials; RR, 0.72; 95% CI, 0.44 to 1.19; I^2^ = 87%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. epirubicin: Bladder cancer specific mortality | Low | Estimates favored BCG for bladder cancer specific mortality, but differences were not statistically significant (3 trials; RR, 0.72; 95% CI, 0.25 to 2.08; I^2^ = 80%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. epirubicin: Recurrence | Moderate | BCG was associated with reduced risk of bladder cancer recurrence, but statistical heterogeneity was high (5 trials; RR, 0.54; 95% CI, 0.40 to 0.74; I^2^ = 76%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. epirubicin: Progression | Low | Estimates favored BCG for bladder cancer progression, but differences were not statistically significant (5 trials; RR, 0.60; 95% CI, 0.36 to 1.01; I^2^ = 47%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG alone vs. BCG plus epirubicin given sequentially: Recurrence, progression | Low | There were no differences in risk of bladder cancer recurrence (3 trials; RR, 1.25; 95% CI, 0.92 to 1.69; I^2^ = 0%). BCG was associated with increased risk of bladder cancer progression, but the difference was not statistically significant (3 trials; RR, 1.92; 95% CI, 0.73 to 5.07; I^2^ = 0%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. epirubicin plus interferon: Bladder cancer specific mortality, progression | Low | One trial found no differences in risk of bladder cancer mortality (RR, 0.79;, 95% CI, 0.32 to 1.63) or progression-free survival, although BCG was associated with decreased risk of bladder cancer recurrence (RR, 0.66; 95% CI, 0.51 to 0.85).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. gemcitabine: All-cause mortality | Low | There were no differences in risk of all-cause mortality (1 trial; RR, 1.20; 95% CI, 0.04 to 34).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. gemcitabine: Recurrence | Insufficient | Evidence from 3 trials was insufficient to determine risk of bladder cancer recurrence because of clinical heterogeneity and inconsistent findings (RR, 1.67; 95% CI, 1.21 to 2.29; RR, 0.53; 95% CI, 0.28 to 1.01; and RR, 0.76; 95% CI, 0.44 to 1.90).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. gemcitabine: Progression | Low | There were no differences in risk of progression (2 trials; RR, 1.11; 95% CI, 0.53 to 2.34 and RR, 0.52; 95% CI, 0.13 to 2.06).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. gemcitabine: Quality of life | Low | There were no differences for BCG vs. gemcitabine in quality of life (1 trial).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG alone vs. BCG plus gemcitabine given sequentially: Recurrence, progression | Low | There were no differences in risk of bladder cancer recurrence (1 trial; RR, 0.86; 95% CI, 0.49 to 1.51) or progression (1 trial; RR, 1.18; 95% CI, 0.30 to 4.61).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. interferon alpha-2a: Recurrence, progression | Low | BCG was associated with reduced risk of bladder cancer recurrence (1 trial; RR, 0.57; 95% CI, 0.39 to 0.82), but the difference in risk of bladder cancer progression was not statistically significant (1 trial; RR, 0.69; 95% CI, 0.25 to 1.92).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG alone vs. alternating BCG and interferon alpha-2b: Recurrence | Low | BCG alone was associated with reduced risk of bladder cancer recurrence (1 trial; RR, 0.42; 95% CI, 0.30 to 0.59).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG alone vs. coadministration of BCG and interferon alpha-2b: Recurrence, progression | Low | Differences in risk of bladder cancer recurrence (1 trial; RR, 0.88; 95% CI, 0.71 to 1.08) or progression (1 trial; RR, 0.76; 95% CI, 0.17 to 3.30) did not reach statistical significance.
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. thiotepa: Recurrence | Low | Two trials found maintenance therapy with BCG to be associated with decreased risk of recurrence vs. thiotepa (RR, 0.38; 95% CI, 0.19 to 0.76 and RR, 0.04; 95% CI, 0.00 to 0.63).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | BCG vs. thiotepa: Progression, mortality, and cystectomy | Insufficient | Estimates were too imprecise to evaluate effects.
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | MMC vs. doxorubicin: Recurrence, progression | Low | There was no difference in risk of bladder cancer recurrence (6 trials; RR, 1.00; 95% CI, 0.82 to 1.22; I^2^ = 44%), but MMC was associated with a non–statistically significant trend toward decreased risk of bladder cancer progression (4 trials; RR, 0.63; 95% CI, 0.37 to 1.08; I^2^ = 21%).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | MMC vs. epirubicin: Recurrence | Low | There was no difference in risk of bladder cancer recurrence in 1 trial (RR, 1.16; 95% CI, 0.52 to 2.58).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | MMC vs. gemcitabine: Recurrence, progression | Low | In 1 trial, there was no difference in risk of bladder cancer progression (p = 0.29). MMC was associated with increased risk of recurrence, but the difference was not statistically significant (RR, 1.64; 95% CI, 0.64 to 4.19).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | MMC vs. interferon alpha: Recurrence, progression | Low | One trial found no difference between MMC and interferon alpha in risk of bladder cancer recurrence (RR, 0.77; 95% CI, 0.58 to 1.01) or bladder cancer progression (RR, 1.38; 95% CI, 0.49 to 3.88).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | MMC vs. interferon gamma: Recurrence | Low | MMC was associated with increased risk of bladder cancer recurrence in 1 trial (RR, 1.61; 95% CI, 0.97 to 2.67).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | MMC vs. thiotepa: Recurrence | Low | Two trials found no difference between MMC and thiotepa in risk of recurrence (RR, 1.76; 95% CI, 0.36 to 8.70 and RR, 1.14; 95% CI, 0.60 to 2.16).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | Doxorubicin vs. epirubicin: Recurrence, progression | Low | Doxorubicin was associated with increased risk of bladder cancer recurrence (3 trials; RR, 1.56; 95% CI, 1.08 to 2.22; I^2^ = 0%); the difference in risk of progression was not statistically significant (1 trial; RR, 1.32; 95% CI, 0.50 to 3.47).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | Doxorubicin vs. thiotepa: Recurrence | Low | There was no statistically significant difference in risk of bladder cancer recurrence (RR, 1.22; 95% CI, 0.76 to 1.94).
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | Doxorubicin vs. thiotepa: Progression, noncancer mortality, cancer specific mortality | Insufficient | Estimates from 1 trial for progression (RR, 2.11; 95% CI, 0.40 to 11.06), noncancer mortality (RR, 0.35; 95% CI, 0.01 to 8.45), and cancer specific mortality (RR, 3.17; 95% CI, 0.13 to 76.1) were very imprecise.
Key Question 3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination? | Epirubicin vs. interferon alpha: Recurrence | Low | Epirubicin was associated with decreased risk of bladder cancer recurrence in 1 trial (RR, 0.67; 95% CI, 0.49 to 0.91).
Key Question 3b. Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers? | Stage, grade, tumor multiplicity, primary vs. recurrent | Low | There were no clear differences in estimates of effectiveness of intravesical therapies in subgroups defined by tumor stage, grade, size, multiplicity, recurrence status, or DNA ploidy
Key Question 3c. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities? | Age, sex, race/ethnicity, performance status, comorbidities | Insufficient | No studies.
Key Question 3c. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities? | Recurrence, disease-free survival | Low | In patients with recurrence or progression following prior BCG therapy, 1 trial found maintenance therapy with gemcitabine to be associated with decreased risk of recurrence vs. repeat treatment with BCG, and 1 trial found MMC maintenance therapy to be associated with lower likelihood of disease-free survival than gemcitabine; estimates for progression were imprecise.
Key Question 3d. Does the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents differ according to dosing frequency, duration of treatment, and/or the timing of administration relative to TURBT? | Standard vs. lower dose BCG: recurrence, progression, mortality, adverse events | Low | Six trials found no clear differences in risk of recurrence, progression, or bladder cancer mortality, including in patients with higher risk NMIBC, although there was some inconsistency between trials. Standard therapy was associated with increased risk of local and systemic adverse events vs. lower dose BCG.
| Maintenance vs. induction BCG: recurrence, progression, adverse events | Low | Two trials found more prolonged courses of BCG to be associated with decreased risk of bladder cancer recurrence vs. induction therapy in patients with higher risk NMIBC (RR, 0.54; 95% CI, 0.31 to 0.95) but increased risk of adverse events.
| BCG maintenance for 1 vs. 3 years: recurrence, progression, mortality, adverse events | Low | One trial of patients with solitary T1Grade(G)3 or multiple Ta–T1/G1–G3 tumors found no difference between 1 vs. 3 years of BCG maintenance therapy in risk of recurrence, progression, mortality, or adverse events.
| MMC single vs. 5 instillations: recurrence, progression, mortality, adverse events | Low | One trial of patients with NMIBC (not selected for being at higher risk) found no clear differences in risk of recurrence, progression, or mortality. The single instillation was associated with lower risk of local adverse events.
| MMC induction vs. maintenance: recurrence, adverse events | Low | One trial of patients with higher risk NMIBC found MMC 20 mg induction therapy for 6 weeks to be associated with higher risk of recurrence than maintenance therapy. There were no clear differences in risk of adverse events.
| MMC maintenance therapy with increased frequency and number of instillations vs. fewer instillations: recurrence, progression, adverse events | Low | Two trials of MMC maintenance regimens in patients with NMIBC not selected for being at higher risk found some evidence that a higher total number of instillations and increased frequency during initial therapy were associated with lower risk of recurrence and progression, and might be associated with lower risk of local adverse events.
| MMC optimized through alkalinization of urine vs. nonoptimized administration: recurrence, adverse events | Low | One trial found no difference between “optimized” versus nonoptimized administration of intravesical MMC in risk of recurrence in patients with low-risk NMIBC, but 1 other trial of patients with higher risk NMIBC found optimized administration to be associated with lower risk of recurrence and increased risk of local adverse events.
| Doxorubicin 8 weeks vs. 2 years: recurrence, progression, adverse events | Low | Two trials of patients with NMIBC not selected for being at higher risk found no differences between doxorubicin 30 mg and 20 mg given as short (8 weeks) or long (2 years) regimens in risk of recurrence or progression, with no differences in adverse events.
| Doxorubicin induction vs. maintenance: recurrence, progression, mortality, adverse events | Low | Two trials of patients with NMIBC not selected for being at higher risk found no clear differences between doxorubicin induction therapy and induction plus maintenance in risk of recurrence, progression, or mortality, with no differences in adverse events.
| Doxorubicin prior to vs. after TURBT: recurrence, adverse events | Low | Two trials of doxorubicin found no clear benefits associated with administration prior to TURBT or multiple instillations immediately after TURBT, with some evidence of increased adverse events with multiple immediate post-TURBT instillations.
| Epirubicin higher vs. lower doses: recurrence, progression, adverse events | Moderate | Three trials of epirubicin found no clear evidence that higher doses are associated with reduced risk of recurrence or progression vs. lower doses, with no differences in adverse events.
| Epirubicin single vs. multiple instillations: recurrence, progression, bladder cancer mortality, adverse events | Moderate | Three trials found no clear difference between single-instillation epirubicin and multiple instillations in patients with low- or high-risk NMIBC in risk of recurrence, progression, or bladder cancer mortality, with some evidence of lower risk of local adverse events with single instillation.
| Epirubicin maintenance vs. induction without maintenance: recurrence, progression, adverse events | Moderate | Two trials found no clear differences between epirubicin maintenance therapy and induction without maintenance in risk of recurrence or progression, including 1 trial of patients with higher risk NMIBC. There were no differences in risk of local adverse events.
| Epirubicin, more vs. less intensive therapy: recurrence, adverse events | Low | Five trials that evaluated different epirubicin regimens that included maintenance therapy found some evidence that more intensive therapy is associated with decreased risk of recurrence, but results were inconsistent. There was no difference in risk of adverse events.
| Thiotepa 30 vs. 60 mg: recurrence, adverse events | Low | Two trials found no clear differences between thiotepa 30 mg and 60 mg for maintenance or for treatment of incompletely resected NMIBC or CIS.
| Interferon alpha-2b, high vs. lower doses: recurrence, progression, resolution of bladder cancer marker lesions | Low | Three trials found higher doses of interferon alpha-2b to be associated with improved outcomes related to recurrence, progression, or resolution of bladder cancer marker lesions vs. lower doses, but most estimates were imprecise and did not reach statistical significance. There were no clear differences in risk of local or systemic adverse events.
| MMC or doxorubicin on day of TURBT vs. 1 to 2 weeks after TURBT: recurrence, progression, mortality, adverse events | Low | One trial found no difference between initiation of intravesical therapy (9 instillations over 6 months) with MMC or doxorubicin 50 mg on the day of TURBT versus 1 to 2 weeks after TURBT in risk of recurrence, progression, or mortality.
| MMC or doxorubicin maintenance vs. no maintenance: recurrence, progression, mortality, adverse events | Low | One trial found no difference between maintenance beyond 6 months vs. no additional maintenance therapy. There were no clear differences in local or systemic adverse events.
Key Question 4. For patients with high risk non–-muscle-invasive bladder cancer treated with TURBT, what is the effectiveness of external beam radiation therapy (either alone or with systemic chemotherapy/immunotherapy) for decreasing mortality or improving other outcomes compared with intravesical chemotherapy/immunotherapy alone or cystectomy? | Mortality, recurrence, progression | Low | One randomized trial of patients with T1G3 bladder cancer found no effects of radiation therapy vs. no radiotherapy (for unifocal disease and no CIS) or radiation therapy vs. intravesical therapy (for multifocal disease or CIS) in recurrence-free survival (HR, 0.94; 95% CI, 0.67 to 1.30), progression-free interval (HR, 1.07; 95% CI, 0.65 to 1.74), progression-free survival (HR, 1.35; 95% CI, 0.92 to 1.98), or overall survival (HR, 1.32; 95% CI, 0.86 to 2.04) after 5 years.
Key Question 5. In surveillance of patients treated for non–muscle-invasive bladder cancer, what is the effectiveness of various urinary biomarkers to decrease mortality or improve other outcomes compared with other urinary biomarkers or standard diagnostic methods (cystoscopy, cytology, and imaging)? | Mortality | Insufficient | No studies.
Key Question 5a. Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers? | | Insufficient | No studies.
Key Question 5b. Does the comparative effectiveness differ according to the treatment used (i.e., specific chemotherapeutic or immunotherapeutic agents and/or TURBT)? | | Insufficient | No studies.
Key Question 5c. Does the comparative effectiveness differ according to the length of surveillance intervals? | | Insufficient | No studies.
Key Question 5d. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, or race/ethnicity? | | Insufficient | No studies.
Key Question 6. For initial diagnosis or surveillance of patients treated for non–muscle-invasive bladder cancer, what is the effectiveness of blue light or other methods of augmented cystoscopy compared with standard cystoscopy for recurrence rates, progression of bladder cancer, mortality, or other clinical outcomes? | Fluorescent cystoscopy vs. white light cystoscopy: Mortality | Low | There was no difference between fluorescent and white light cystoscopy in risk of mortality (3 trials; RR, 1.28; 95% CI, 0.55 to 2.95; I^2^ = 41%).
| Fluorescent cystoscopy vs. white light cystoscopy: Recurrence | Low | Fluorescent cystoscopy with 5-ALA or HAL was associated with decreased risk of bladder cancer recurrence vs. white light cystoscopy at short-term (<3 months; 9 trials, RR 0.58, 95% CI 0.36 to 0.94, I^2^=75%), intermediate-term (3 months to <1 year, 5 trials, RR 0.67, 95% CI 0.51 to 0.88, I^2^=35%), and long-term followup (≥1 year, 11 trials, RR 0.81, 95% CI 0.68 to 0.98, I^2^=64%), but findings were inconsistent and potentially susceptible to performance bias (because of failure to blind the initial cystoscopy) and publication bias.
| Fluorescent cystoscopy vs. white light cystoscopy: Progression | Moderate | There was no difference between fluorescent and white light cystoscopy in risk of progression to muscle-invasive bladder cancer (9 trials; RR, 0.78; 95% CI, 0.55 to 1.12; I^2^ = 0%).
| Narrow band imaging vs. white light cystoscopy: Recurrence | Low | Narrow band imaging was associated with lower risk of bladder cancer recurrence at 3 months (3.9% vs. 17%; OR, 0.62; 95% CI, 0.41 to 0.92) and at 12 months (OR, 0.24; 95% CI, 0.07 to 0.81) in 1 trial.
Key Question 7. What are the comparative adverse effects of various tests for diagnosis and post-treatment surveillance of bladder cancer, including urinary biomarkers, cytology, and cystoscopy? | Urinary biomarkers: adverse clinical outcomes | Insufficient | Urinary biomarkers miss 23% to 42% of patients with bladder cancer and are incorrectly positive in 11% to 28% of patients without bladder cancer, but no study directly measured effects of inaccurate diagnosis on clinical outcomes.
Key Question 7. What are the comparative adverse effects of various tests for diagnosis and post-treatment surveillance of bladder cancer, including urinary biomarkers, cytology, and cystoscopy? | Fluorescent vs. white light cystoscopy: false-positives | Low | There were no clear differences between fluorescent cystoscopy and white light cystoscopy in risk of false-positives in 2 trials.
Key Question 7. What are the comparative adverse effects of various tests for diagnosis and post-treatment surveillance of bladder cancer, including urinary biomarkers, cytology, and cystoscopy? | Fluorescent vs. white light cystoscopy: renal and genitourinary adverse events | Low | There were no clear differences between fluorescent cystoscopy and white light cystoscopy in risk of renal and genitourinary adverse events in 2 trials.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. no intravesical therapy: local and systemic adverse events | Low | Four trials reported granulomatous cystitis or irritative symptoms in 27% to 84% of patients, macroscopic hematuria in 21% to 72%, and fever in 27% to 44%. Harms were not reported in patients who did not receive intravesical therapy.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | Non-BCG intravesical therapies vs. no intravesical therapy: local and systemic adverse events | Low (local adverse events); insufficient (systemic adverse events) | Evidence on harms was very limited, although some trials reported an increased risk of local adverse events. Evidence was insufficient to determine effects of non-BCG intravesical therapies vs. no intravesical therapy on risk of systemic adverse events.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. MMC: Local adverse events | Low (moderate for cystitis and hematuria) | BCG was associated with increased risk of any local adverse event (2 trials; RR, 2.01; 95% CI, 1.59 to 2.54; I^2^ = 0%), granulomatous cystitis (5 trials; RR, 1.71; 95% CI, 1.22 to 2.41; I^2^ = 58%), dysuria (3 trials; 48% vs. 32%; RR, 1.23; 95% CI, 1.03 to 1.46; I^2^ = 34%), and hematuria (6 trials; RR, 1.78; 95% CI, 1.24 to 2.56; I^2^ = 62%) vs. MMC.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. MMC: Systemic adverse events | Low | BCG was associated with increased risk of any systemic adverse event (2 trials; RR, 2.01; 95% CI, 1.59 to 2.54; I^2^ = 0%) and fever (4 trials; RR, 4.51; 95% CI, 2.31 to 8.82; I^2^ = 25%) vs. MMC.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG alone vs. BCG plus MMC given sequentially: Discontinuation of therapy | Low | BCG alone was associated with increased risk of discontinuation of instillations vs. BCG plus MMC given sequentially (1 trial; RR, 4.06; 95% CI, 2.09 to 7.86).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG plus MMC given sequentially vs. MMC alone: Local adverse events | Low | There was no difference between sequentially administered BCG plus MMC and MMC alone in local adverse events (1 trial; RR, 1.36; 95% CI, 0.60 to 3.08) or risk of granulomatous cystitis (1 trial; RR, 1.30; 95% CI, 0.88 to 1.93).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG plus MMC given sequentially vs. MMC alone: Systemic adverse events | Low | There was no difference between BCG and MMC given sequentially and MMC used alone in systemic adverse events (1 trial; RR, 1.07; 95% CI, 0.63 to 1.84), but BCG plus MMC was associated with increased risk of fever (1 trial; 12% vs. 3%; RR, 3.75; 95% CI, 1.08 to 13).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG plus MMC given sequentially vs. MMC alone: Discontinuation of therapy | Low | There was no difference between alternating BCG plus MMC and MMC alone in risk of discontinuation of instillations in patients with CIS (1 trial; RR, 0.54; 95% CI, 0.16 to 1.84) or in patients with Ta or T1 tumors (1 trial; RR, 0.93; 95% CI, 0.52 to 1.65).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. doxorubicin: Local adverse events | Low (cystitis); insufficient (dysuria and hematuria) | BCG was associated with increased risk of cystitis vs. doxorubicin (1 trial; RR, 17; 95% CI, 1 to 289), but there was insufficient evidence to determine effects on dysuria (3 trials; data not pooled) and hematuria (2 trials; data not pooled) because of small numbers of trials with inconsistent results.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. epirubicin: Local adverse events | Low | BCG was associated with increased risk of local side effects (1 trial; RR, 3.28; 95% CI, 1.26 to 8.53).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. epirubicin: Discontinuation of therapy | Insufficient | Results were mixed for discontinuation of intravesical therapy (2 trials; data not pooled).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. epirubicin: Systemic adverse events | Low | BCG was associated with increased risk of granulomatous cystitis (4 trials; RR, 1.86; 95% CI, 1.35 to 2.56; I^2^ = 65%), dysuria (1 trial; RR, 2.43; 95% CI, 1.13 to 5.24), hematuria (4 trials; RR, 1.77; 95% CI, 1.41 to 2.22; I^2^ = 0%), and fever (2 trials; RR, 9.73; 95% CI, 2.72 to 35; I^2^ = 0%).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG alone vs. BCG plus epirubicin given sequentially: Local adverse events | Low | There was no difference in risk of dysuria (1 trial; RR, 1.22; 95% CI, 0.56 to 2.66) or hematuria (2 trials; RR, 2.27; 95% CI, 0.86 to 6.00; I^2^ = 0%).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG alone vs. BCG plus epirubicin given sequentially: Systemic adverse events | Low | BCG was associated with increased risk of systemic adverse events (1 trial; RR, 5.97; 95% CI, 2.18 to 16) and granulomatous cystitis (1 trial; RR, 2.28; 95% CI, 1.46 to 3.54) but no difference in risk of fever (2 trials; RR, 2.09; 95% CI, 0.48 to 9.02; I^2^ = 0%).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG alone vs. BCG plus epirubicin given sequentially: Discontinuation of therapy | Low | BCG was associated with increased risk of discontinuation of instillations (1 trial; RR, 4.56; 95% CI, 1.35 to 15).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. gemcitabine: Local adverse events | Low | There were no differences between BCG and gemcitabine in risk of local adverse events requiring postponement or discontinuation of intravesical therapy (1 trial; RR, 1.33; 95% CI, 0.32 to 5.49).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. gemcitabine: Systemic adverse events | Low | There were no differences in systemic adverse events (1 trial; RR, 0.50; 95% CI, 0.10 to 2.5), dysuria (2 trials; RR, 1.51; 95% CI, 0.92 to 2.50; I^2^ = 0%), or hematuria (2 trials; RR, 4.62; 95% CI, 0.78 to 27; I^2^ = 29%), but BCG was associated with increased risk of fever (2 trials; RR, 6.24; 95% CI, 1.03 to 38; I^2^ = 5%).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG alone vs. BCG plus gemcitabine given sequentially: Local adverse events | Low | One trial found no difference in risk of dysuria (RR, 0.92; 95% CI, 0.52 to 1.65) or hematuria (RR, 0.30; 95% CI, 0.08 to 1.09).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. interferon alpha-2a: Local adverse events | Low | BCG was associated with increased risk of dysuria (1 trial; RR, 84; 95% CI, 5.29 to 1,319).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. interferon alpha-2a: Systemic adverse events | Low | There was no difference in risk of fever (1 trial; RR, 4.82; 95% CI, 0.25 to 94).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG alone vs. coadministration of BCG and interferon alpha-2b: Systemic adverse events | Low | BCG was associated with increased risk of constitutional symptoms (1 trial; RR, 1.63; 95% CI, 1.12 to 2.38) and fever (1 trial; RR, 2.26; 95% CI, 1.30 to 3.95).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. thiotepa: Local adverse events | Low | BCG was associated with increased risk of bladder irritability (1 trial; RR, 2.93; 95% CI, 1.45 to 5.90) and cystitis (1 trial; RR, 18; 95% CI, 1.11 to 306).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | BCG vs. thiotepa: Systemic adverse events | Low | BCG was associated with increased risk of fever (1 trial; RR, 8.36; 95% CI, 0.47 to 150).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | MMC vs. doxorubicin: Local adverse events | Insufficient | Evidence was insufficient to determine effects of MMC vs. doxorubicin on risk of local adverse events, based on inconsistent results from 6 trials.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | MMC vs. epirubicin: Local adverse events | Low | One small trial found no difference between MMC and epirubicin 80 mg in risk of urinary symptoms.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | MMC vs. interferon alpha: Local adverse events | Low | One trial found MMC to be associated with greater risk of hematuria vs. interferon alpha (RR, 2.00; 95% CI, 1.09 to 3.65) and no difference in risk of dysuria or urinary frequency.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | MMC vs. interferon alpha: Systemic adverse events | Low | One trial found MMC to be associated with decreased risk of fever (RR, 0.13; 95% CI, 0.03 to 0.55).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | MMC vs. gemcitabine: Local adverse events | Low | One trial found MMC to be associated with increased risk of chemical cystitis (RR, 3.93; 95% CI, 1.17 to 13.14), with no difference in risk of dysuria or hematuria.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | Doxorubicin vs. epirubicin: Local adverse events | Low | Doxorubicin was associated with increased risk of chemical cystitis (1 trial; RR, 1.85; 95% CI, 1.13 to 3.03), with no clear difference in risk of dysuria or urinary frequency (2 trials) or hematuria (3 trials; RR, 1.53; 95% CI, 0.50 to 4.66; I^2^ = 0%).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | Doxorubicin vs. thiotepa: Local adverse events | Low | One trial found no difference in risk of bladder irritability (RR, 0.92; 95% CI, 0.36 to 2.37).
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | Epirubicin vs. interferon alpha: Local adverse events | Low | One trial found no difference in risk of dysuria.
Key Question 8. What are the comparative adverse effects of various treatments for non–-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT? | Epirubicin vs. interferon alpha: Systemic adverse events | Low | One trial found no difference in risk of fever.
Key Question 8a. How do adverse effects of treatment vary by patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease? | Adverse effects | Insufficient | No studies

5-ALA = 5-aminolevulinic acid; BCG = bacillus Calmette–Guérin; BTA = bladder tumor antigen; CI = confidence interval; CIS = carcinoma in situ; FISH = fluorescence in situ hybridization; G1 = Grade 1; G3 = Grade 3; HAL = hexaminolevulinate; HR = hazard ratio; MMC = Mitomycin C; mg = milligram; NMP22 = nuclear matrix protein-22; NMIBC = non-muscle-invasive bladder cancer; OR = odds ratio; RR = risk ratio; T1 = Tumor stage 1; Ta = Tumor stage a; TURBT = transurethral resection of bladder tumor

Urinary biomarkers were associated with sensitivity for bladder cancer that ranged from 0.57 to 0.82 and specificity that ranged from 0.74 to 0.88, for positive likelihood ratios that ranged from 2.52 to 5.53 and negative likelihood ratios that ranged from 0.21 to 0.48. Findings were robust in sensitivity and stratified analyses., Evidence was strongest for quantitative NMP22, qualitative bladder tumor antigen (BTA), fluorescence in situ hybridization (FISH), and ImmunoCyt (strength of evidence [SOE]: moderate), and relatively sparse for other biomarkers (SOE: low). Across urinary biomarkers, sensitivity was greater for higher stage and higher grade tumors (SOE: high). For qualitative BTA, FISH, and ImmunoCyt sensitivity was somewhat higher for evaluation of patients with signs or symptoms of bladder cancer than for surveillance of patients previously treated for bladder cancer, but for quantitative nuclear matrix protein 22 (NMP22) there was no clear difference in diagnostic accuracy based on reason for obtaining the biomarker. Studies that directly compared the accuracy of quantitative NMP22 and qualitative BTA found no differences in diagnostic accuracy (SOE: moderate). ImmunoCyt was associated with higher sensitivity than FISH (0.71, 95% CI 0.54 to 0.84 vs. 0.61, 95% CI 0.43 to 0.76, for a difference of 0.11, 95% CI 0.001 to 0.21) but lower specificity (0.71, 95% CI 0.62 to 0.79 vs. 0.79, 95% CI 0.71 to 0.85, for a difference of -0.08, 95% CI -0.15 to -0.001), based on three studies (SOE: low). There were too few head-to-head comparisons of other urinary biomarkers to reach firm conclusions regarding comparative accuracy. Sensitivity was increased when urinary biomarkers were used in conjunction with urine cytology than when the biomarker was used alone (SOE: moderate). No study evaluated clinical outcomes associated with use of urinary biomarkers for diagnosis or surveillance of bladder cancer (SOE: insufficient). Urinary biomarkers miss 18 to 43 percent of patients with bladder cancer and are incorrectly positive in 12 to 26 percent of patients without bladder cancer, which could result in delayed diagnosis or unnecessary cystoscopies and other diagnostic procedures, but no study directly measured effects of inaccurate diagnosis on clinical outcomes (SOE: insufficient). Most trials found fluorescent cystoscopy associated with decreased risk of subsequent bladder recurrence versus white light cystoscopy, but there was no difference in risk of progression or mortality, though data for these outcomes was relatively sparse (SOE: low). In addition, evidence on effects on risk of recurrence were inconsistent, and the only trial259 designed to minimize performance bias (by blinding the cystoscopist to instillation of photosensitizer versus placebo) found no different in risk of bladder cancer recurrence.

Intravesical therapy was effective for reducing risk of bladder cancer recurrence versus no intravesical therapy (Tables 19, 20). Versus no intravesical therapy, bacillus Calmette Guérin (BCG) was associated with decreased risk of bladder cancer recurrence (RR 0.63, 95% CI 0.50 to 0.79) as well as progression (RR 0.50, 95% CI 0.32 to 0.77) (SOE: moderate). mitomycin C (MMC), doxorubicin, and epirubicin were also associated with decreased risk of bladder cancer recurrence versus no intravesical therapy (RR 0.66 to 0.80) but effects on bladder cancer progression were not statistically significant (MMC and epirubicin) or showed no effect (doxorubicin). Although trials varied with respect to doses, instillation regimens, and patient populations evaluated, findings were generally robust in sensitivity and subgroup analyses, including exclusion of single dose instillation trials. No intravesical agent, including BCG, was associated with decreased risk of all-cause or bladder cancer specific mortality versus no intravesical therapy. However, evidence on the effectiveness of “optimized” MMC regimens on mortality was limited. Evidence on gemcitabine, interferon alpha, and thiotepa was sparse, and we found no randomized trials of valrubicin, paclitaxel, or apaziquone.

Head-to-head trials of intravesical therapy using different drugs showed few clear differences. For BCG versus MMC, the most well-studied comparison, there was no difference on any outcome, including bladder cancer recurrence, progression, or mortality (SOE: moderate). However, BCG was associated with decreased risk of bladder cancer recurrence in the subgroup of trials that evaluated maintenance regimens (SOE: low). Other head-to-head comparisons were evaluated in fewer trials, and showed few differences, though limited evidence suggested that BCG might be associated with decreased risk of bladder cancer recurrence and progression versus epirubicin (SOE: low). Although doxorubicin was associated with increased risk of bladder cancer recurrence versus epirubicin (RR 1.56, 95% CI 1.08 to 2.22), this finding was based on only three trials (SOE: low).119,195,196

Evidence to determine the effects of tumor characteristics on estimates of effectiveness of intravesical therapies was limited, but indicated no differences in risk estimates based on factors such as tumor stage, grade, multiplicity, recurrence status, and size (SOE: low). However, even if relative estimates of effectiveness are similar, absolute effects will vary depending on the underlying incidence of recurrence, progression, mortality, or other outcomes. Therefore, patients with higher stage, higher grade, multiple, recurrent, or larger tumors would be expected to experience greater absolute benefits. Evidence to determine the effects of patient characteristics such as age, sex, race/ethnicity, performance status, or comorbidities on estimates of effectiveness of intravesical therapies was not available, and evidence on comparative effectiveness of therapies for patients with recurrence or progression following treatment with BCG was limited to two small trials comparing different intravesical therapies.184,194

Trials that compared effects of intravesical therapy using different doses or instillation regimens for the same agent were difficult to interpret due to variability in the patient populations, doses, instillation regimens, and other factors. For BCG, there were no clear difference between standard and lower doses of BCG in risk of bladder cancer recurrence, progression, or mortality, including in patients with higher-risk non–muscle-invasive bladder cancer (NMIBC), but there was some inconsistency between trials (SOE: low). Limited evidence suggested that BCG maintenance regimens (>6 weeks) are more effective than induction regimens (≤6 weeks) at reducing risk of bladder cancer recurrence in responders to induction therapy or in patients with higher risk tumors (SOE: low). Head-to-head trials suggest that BCG TICE may be less effective than other BCG strains at reducing risk of recurrence, with no clear difference between non-TICE strains (SOE: low). Trials on the effects of dose and duration of other intravesical agents on outcomes reported inconsistent results and were clinically heterogeneous, making it difficult to draw strong conclusions (SOE: insufficient to low). However, there was no evidence that prolonging therapy for more than one year is more effective than shorter regimens.

Evidence on harms associated with intravesical therapies was more limited than evidence on benefits. Trials of BCG versus no intravesical therapy found that local and systemic adverse events were relatively common (granulomatous cystitis or irritative symptoms in 27% to 84% of patients, macroscopic hematuria in 21% to 72%, and fever in 27% to 44%) (SOE: low). BCG was also associated with an increased risk of local adverse events and fever versus MMC (SOE: low). Standard dose BCG was associated with increased risk of local and systemic adverse events versus lower dose BCG. Few trials reported harms of intravesical agents other than BCG versus no intravesical therapy, or against another intravesical agent.

The only randomized trial of radiation therapy found no effects on recurrence, progression, or survival in patients with T1G3 cancers when compared against no radiotherapy (for unifocal cancers and no CIS) or against intravesical therapy (for multifocal disease or CIS) (SOE: low).239

## Findings in Relationship to What Is Already Known

Our findings on diagnostic accuracy were generally consistent with prior systematic reviews that found urinary biomarkers insufficiently accurate to replace cystoscopy.263-265 Estimates for sensitivity and specificity were generally similar in our review and prior reviews, even though we excluded case-control studies and included more recently published studies. In addition, prior reviews did not evaluate potential differences in diagnostic accuracy for testing performed for evaluation of signs and symptoms of bladder cancer versus for surveillance.

Prior systematic reviews266,267 found fluorescent cystoscopy associated with decreased risk of recurrent bladder cancer versus white light cystoscopy, but were published prior to a recent trial that was the only one to blind the cystoscopist to instillation of the photosensitizer and found no effect.259 Like our report, prior reviews found no effect of fluorescent cystoscopy on risk of progression or mortality. Although prior reviews also found that fluorescent cystoscopy detected more bladder cancers on initial cystoscopy, this was not an assessed outcome for our review.

Our findings regarding the comparative effectiveness and harms of intravesical therapies are generally consistent with prior reviews that found intravesical therapy associated decreased risk of bladder cancer recurrence versus no intravesical therapy,268,269 and BCG associated with decreased risk of bladder cancer progression. Prior systematic reviews that focused on immediate single instillation therapy also found intravesical therapy to be more effective than no intravesical therapy in reducing risk of bladder cancer recurrence, a conclusion consistent with our finding of no clear difference in risk estimates based on the type of instillation regimen.270-272 Like our review, prior systematic reviews found maintenance therapy with BCG associated with decreased risk of bladder cancer versus MMC, despite some differences in the trials that were included, definitions of maintenance therapy, and use of individual patient data in the prior review.273 Our findings are also consistent with prior systematic reviews that found BCG associated with decreased risk of bladder cancer versus epirubicin,274 that the evidence on intravesical gemcitabine is limited,275 and that the optimal dose and duration of intravesical therapy cannot be determined based on the available evidence.276

## Applicability

Some issues could impact the applicability of our findings. Some studies of diagnostic accuracy did not report results separately for patients undergoing evaluation of signs and symptoms of bladder cancer and those undergoing surveillance, though there is some evidence that diagnostic accuracy may vary based on the indication for testing. Studies of intravesical therapy varied in the doses used, the timing, number, frequency, and duration or instillations, and other factors (e.g., the BCG strain), making it difficult to reach conclusions that are widely generalizable. In addition, trials varied with regard to tumor characteristics in the patient populations evaluated. Another factor that potentially impacts applicability is that most studies focused on effects of intravesical therapy on recurrence of bladder cancer. Fewer trials evaluated more potentially serious, distal outcomes such as progression or mortality. A number of studies were conducted in Japan, where management of bladder cancer may differ from the U.S. Treatment studies tended to exclude patients with significant comorbidities or poor general performance status, which could limit applicability to these populations. Very little information was available to determine whether diagnostic accuracy or treatment effects vary according to patient factors such as age, sex, race/ethnicity, performance status, or comorbidities.

## Implications for Clinical and Policy Decisionmaking

Our review has implications for clinical and policy decisionmaking. As there are no studies evaluating effects of using urinary biomarkers for diagnosis or surveillance of bladder cancer on clinical outcomes, decisions regarding their use must necessarily be made on the basis of diagnostic test performance. Table 22 shows estimated probabilities for bladder cancer following use of urinary biomarkers, based on likelihood ratios calculated from pooled sensitivities and specificities. In populations with a pretest probability of 5 percent, the post-test probability increased to 16 to 24 percent following a positive result, and decreased to 1.8 to 2.5 percent following a negative result. In settings with a pretest probability of 20 percent, the post-test probability increased to 37 to 60 percent following a positive results, and decreased to 8.0 to 11 percent following a negative result. Whether urinary biomarkers are sufficiently accurate to rule out bladder cancer and thereby reduce the need for cystoscopy depends on the ability of clinicians to estimate the pretest probability of disease and the acceptable threshold for a missed or delayed diagnosis. Use of urinary biomarkers in combination with urinary cytology increases the sensitivity for bladder cancer, but still misses about 10 percent of cases.

Table 22 Post-test probability of bladder cancer using different biomarkers

Urinary Biomarker | Pretest Probability of Bladder Cancer | Positive Likelihood Ratio (95% CI) | Post-Test Probability of HCC Following a Positive Test | Negative Likelihood Ratio (95% CI) | Post-Test Probability of HCC Following a Negative Test
Quantitative NMP22 | 5% | 3.05 (2.28 to 4.10) | 14% | 0.40 (0.32 to 0.50) | 2.1%
Quantitative NMP22 | 20% | 3.05 (2.28 to 4.10) | 43% | 0.40 (0.32 to 0.50) | 9.1%
Qualitative NMP22 | 5% | 4.89 (3.23 to 7.40) | 20% | 0.48 (0.33 to 0.71) | 2.5%
Qualitative NMP22 | 20% | 4.89 (3.23 to 7.40) | 55% | 0.48 (0.33 to 0.71) | 11%
Qualitative BTA | 5% | 2.80 (2.31 to 3.39) | 13% | 0.47 (0.30 to 0.55) | 2.4%
Qualitative BTA | 20% | 2.80 (2.31 to 3.39) | 41% | 0.47 (0.30 to 0.55) | 11%
Quantitative BTA | 5% | 2.52 (1.86 to 3.41) | 12% | 0.47 (0.37 to 0.61) | 2.4%
Quantitative BTA | 20% | 2.52 (1.86 to 3.41) | 39% | 0.47 (0.37 to 0.61) | 11%
FISH | 5% | 5.02 (2.93 to 8.60) | 21% | 0.42 (0.30 to 0.59) | 2.2%
FISH | 20% | 5.02 (2.93 to 8.60) | 56% | 0.42 (0.30 to 0.59) | 9.5%
ImmunoCyt^™^ | 5% | 3.49 (2.82 to 4.32) | 16% | 0.29 (0.20 to 0.41) | 1.5%
ImmunoCyt^™^ | 20% | 3.49 (2.82 to 4.32) | 47% | 0.29 (0.20 to 0.41) | 6.8%

BTA = bladder tumor antigen; FISH = fluorescence in situ hybridization; HCC = hepatocellular carcinoma; NMP22 = nuclear matrix protein-22

Regarding fluorescent cystoscopy, studies have not shown an effect on progression or mortality and trials that found reduced risk of recurrence may have been affected by performance bias. These findings might inform decisions regarding widespread adoption of fluorescent cystoscopy. Cost may also impact decisions to use fluorescent cystoscopy and urinary biomarkers, but was outside the scope of this report.

Our findings also have implications for use of intravesical therapy. Although intravesical therapy was associated with decreased risk of bladder cancer recurrence, there were no clear effects on bladder cancer-specific or all-cause mortality, and intravesical therapies are associated with local and systemic adverse events. Our findings are consistent with guidelines that recommend BCG as first-line therapy,13,277 as no intravesical agent was more effective than BCG at reducing risk of bladder cancer recurrence, BCG is the only intravesical agent associated with decreased risk of bladder cancer progression versus no intravesical therapy, and some evidence indicates that BCG is associated with decreased risk of bladder cancer recurrence versus other intravesical agents. However, BCG is also associated with a high risk of adverse events. Some evidence indicates that using lower than standard doses of BCG maintains effectiveness while reducing harms. Other evidence suggests that longer courses of therapy may be necessary for optimal effects, particularly in higher risk patients. Therefore, decisions to use intravesical therapy and regarding the intravesical agent, doses, and regimen selected should take into account the trade-offs between potential benefits, which are likely to be higher in patients at higher risk for disease progression, and harms.

## Limitations of the Review Process

Substantial statistical heterogeneity was present in most pooled analyses of diagnostic accuracy; this situation is common in meta-analyses of diagnostic accuracy.278-280 As noted in the Cochrane Handbook for Systematic Reviews of Diagnostic Test Accuracy, “heterogeneity is to be expected in meta-analyses of diagnostic test accuracy.”280 To address the anticipated heterogeneity, we utilized random effects models to pool studies and stratified studies according to the reason that imaging was performed and the unit of analysis used. We also performed additional stratified and sensitivity analyses based on the reference standard used, study characteristics (such as country in which the study was conducted, factors related to risk of bias), patient characteristics, and technical factors related to the imaging tests under investigation. As noted previously, results were generally robust in sensitivity analyses, despite the heterogeneity. We also focused on evaluations of comparative test performance based on within-study comparisons of imaging modalities, which tended to be associated with less heterogeneity than pooled across-study estimates. A limitation of our analysis of within-group comparisons is that we had to treat the two compared groups as independent, because we had only aggregated data. Individual patient level data would be required to take into account the paired nature of the comparisons. Such correlations are generally positive and would be expected to result in more narrow confidence intervals. Although it is possible that this could have caused us to not detect statistically significant differences, the point estimates indicated very little difference between tests.

We did not construct summary receiver operating characteristic curves. Almost all studies of a specific urinary biomarker used the same definition for a positive test, including tests based on a quantitative threshold. Estimates of sensitivity and specificity at different thresholds are needed to construct informative ROC curves.25

Statistical heterogeneity was also present in some analyses of intravesical therapies and fluorescent cystoscopy. To address this, we used the Dersimonian-Laird random effects model to pool studies. The Dersimonian-Laird random effects model may result in confidence intervals that are too narrow when heterogeneity is present, particularly when the number of studies is small.29 Therefore, we repeated analyses using the profile likelihood method, which resulted in similar findings. Regardless of the method used, meta-analyses based on small numbers of trials can underestimate statistical heterogeneity and must be interpreted with caution.29 We also stratified trials according to factors such as risk of bias rating, dose, number of instillations, duration of followup, enrollment of patients with high-risk NMIBC, and other factors. Although statistical heterogeneity remained present in some analyses, with some unexplained outlier trials, results were generally robust.

We excluded non-English language articles and did not search for studies published only as abstracts. Because of small numbers of trials for meta-analyses involving intravesical therapies, we did not formally assess for publication bias using statistical or graphical methods for assessing sample size effects because of small numbers of studies, as research indicates that such methods can be seriously misleading in such situations.281,282 For fluorescent cystoscopy, we found one relatively large trial that showed no effect on risk of recurrence versus white light cystoscopy, suggesting that publication bias could have impacted results.260

## Limitations of the Evidence Base

Several limitations of the evidence base limited our ability to reach strong conclusions with regard to several aspects of diagnosis and treatment of NMIBC. Other than quantitative NMP22, qualitative BTA, FISH, and ImmunoCyt, urinary biomarkers were assessed in small numbers of studies , resulting in less precise estimates. In addition, almost all studies on diagnostic accuracy of biomarkers had methodological shortcomings. In some studies of urinary biomarkers, patients with positive markers and normal cystoscopy were considered to be positive without biopsy, which could result in verification bias and overestimation of diagnostic accuracy. In addition, most of the evidence on comparative accuracy was indirect, as relatively few studies directly compared the accuracy of two or more biomarkers against cystoscopy and histopathology.

For fluorescent cystoscopy, a limitation of the evidence base is that few trials reported effects on progression or mortality, and instead mostly focused on evaluating effects on recurrence. In addition, only one trial of fluorescent cystoscopy blinded the cystoscopist to whether the photosensitizer had been instilled, which may have a greater impact on assessments of recurrence due to performance bias related to knowledge of the type of initial cystoscopy performed.

A limitation of the evidence for all Key Questions addressed in our review is that very few trials were assessed as low risk of bias. Methodological shortcomings included failure to adequately describe randomization and allocation concealment methods and unblended design. Findings would be stronger if more high-quality trials were available.

Other limitations include the lack of evidence on how use of urinary biomarkers impacts clinical outcomes (including harms), a single randomized trial on effects of radiation therapy for NMIBC, no trials on effects of using a risk-adapted approach, and no studies on effects of how using different surveillance intervals impacts outcomes. Few studies evaluated effects of patient characteristics such as age, sex, race/ethnicity, performance status, or comorbidities on diagnostic test performance or effectiveness of intravesical therapy.

## Research Gaps

We identified a number of important research gaps. Given the increased sensitivity of urinary biomarkers with cytology, studies on how this combination impacts use of cystoscopy and subsequent clinical outcomes might be helpful for determining its role in diagnosis or surveillance and in followup of patients with abnormal cystoscopy or atypical cytology. Randomized trials that adequately safeguard against performance bias associated with use of photosensitizers for fluorescent cystoscopy are needed to determine effects on recurrence, progression, and mortality. Additional head-to-head trials of intravesical therapies that use more standardized instillation regimens and doses, “optimized” instillation of MMC, report outcomes in subgroups stratified by patient and tumor characteristics, include long-term outcomes related to progression and mortality, and assess and report harms using more standardized methods would help clarify optimal treatment strategies. Studies to determine optimal strategies for management of patients with recurrence or progression after standard intravesical therapy are needed. Research is also needed on determine the effectiveness of risk-adapted approaches to guide selection of therapy, including use of nontraditional prognostic markers, effects of different surveillance intervals and protocols, and newer techniques such as electromotive administration of intravesical therapy.