# Appendix H Abbreviations Used in the Appendixes

Abbreviation: Term
AE: Adverse event
5-ALA: 5-Aminolevulinic acid
ALT: Alanine transaminase
AOR: Adjusted odds ratio
AST: Aspartate transaminase
AUA: American Urological Association
AUC: Area under the curve
AUROC: Area under the receiver operating curve
BCG: Bacillus Calmette-Guérin
BCG-RIVM: RIVM strain of bacillus Calmette- Guérin
BPH: Benign prostatic hypertrophy
BTA: Bladder tumor antigen
BTA stat: Bladder tumor antigen Polymedco rapid test
BTA TRAK: Bladder tumor antigen quantitative immunoassay
BUN: Blood urea nitrogen
CBC: Complete blood count
CFU: Colony Forming Unit
CI: Confidence interval
CIS: Carcinoma in situ
Cr: Serum creatinine level
CRR: Cumulative recurrence rate
CT scan: Computerized axial tomography
DNA: Deoxyribonucleic acid
EAU: European Association of Urology
ECOG: Eastern Cooperative Oncology Group
EORTC: European Organisation for Research and Treatment of Cancer
FOCA: Fonds Cancer
FISH: Fluorescent in situ hybridization
G0: Grade 0
G1: Grade 1
G2: Grade 2
G3: Grade 3
G4: Grade 4
Gx: Grade unknown
GEM: Gemcitabine
HAL: Hexaminolevulinate
Hgb: Hemoglobin
HR: Hazard ratio
IA: Intra-arterial
IFN-a-2b: Interferon alpha 2b
INH: Isoniazid
IV: Intravenous
IQR: Interquartile range
ISUP: International Society of Urological Pathology
ITT: Intention-to-treat
KQ: Key question
LMP: Low malignant potential
MIBC: Muscle-invasive bladder cancer
MMC: Mitomycin C
MU: Million units
NA: Not applicable
NaCl: Sodium chloride
NMIBC: Non-muscle-invasive bladder cancer
NMP22: Nuclear matrix protein-22
NPV: Negative predictive value
NR: Not reported
NRCT: Nonrandomized controlled trial
NS: Not significant
OncoTICE BCG: OncoTICE strain of bacillus Calmette-Guérin
PBO: Placebo
PPD: Purified protein derivative
PPV: Positive predictive value
pT1: Tumor stage 1 determined by pathology
pT1b: Tumor stage 1b determined by pathology
pT2: Tumor stage 2 determined by pathology
pTis: Tumor in situ determined by pathology
RCT: Randomized controlled trial
RFS: Recurrence-free survival
RNA: Ribonucleic acid
RR: Risk ratio
SD: Standard deviation
SWOG: Southwest Oncology Group
T0: Tumor stage 0
T1: Tumor stage 1
T2: Tumor stage 2
T2a: Tumor stage 2a
T3: Tumor stage 3
T3a: Tumor stage 3a
T3b: Tumor stage 3b
T4: Tumor stage 4
TCC: Transitional cell carcinoma
Tis: Carcinoma in situ
TUC: Transurethral coagulation
TURBT: Transurethral resection of bladder tumor
Tx: Tumor stage unknown
UK: United Kingdom
UTI: Urinary tract infection
WBC: White blood cell
WHO: World Health Organization