# Appendix G Strength of Evidence

Table G1 Strength of evidence

Key Question Outcome | Study Design Number of Studies (N) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade
1. What is the diagnostic accuracy of various urinary biomarkers compared with other urinary biomarkers or standard diagnostic methods (cystoscopy, cytology, and imaging) in 1) persons with signs or symptoms warranting evaluation for possible bladder cancer or 2) persons undergoing surveillance for previously treated bladder cancer?
Quantitative NMP22: Sensitivity and specificity | 19 studies of diagnostic accuracy | Moderate | Inconsistent | Direct | Precise | Not detected | Moderate
Qualitative NMP22: Sensitivity and specificity | 4 studies of diagnostic accuracy | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
Qualitative BTA: Sensitivity and specificity | 22 studies of diagnostic accuracy | Moderate | Inconsistent | Direct | Precise | Not detected | Moderate
Quantitative BTA: Sensitivity and specificity | 4 studies of diagnostic accuracy | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
FISH: Sensitivity and specificity | 11 studies of diagnostic accuracy | Moderate | Inconsistent | Direct | Imprecise | Not detected | Moderate
ImmunoCyt: Sensitivity and specificity | 14 studies of diagnostic accuracy | Moderate | Inconsistent | Direct | Imprecise | Not detected | Moderate
CxBladder: Sensitivity and specificity | 1 study of diagnostic accuracy | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Quantitative NMP22 versus qualitative BTA: Sensitivity and specificity | 7 studies of diagnostic accuracy | Moderate | Consistent | Direct | Precise | Not detected | Moderate
ImmunoCyt versus FISH: Sensitivity and specificity | 3 studies | Moderate | Consistent | Direct | Precise | Not detected | Low
Other head-to-head urinary biomarkers | | | | | | | Insufficient
Various urinary biomarkers plus cytology versus the urinary biomarker alone: Sensitivity and specificity | 16 studies of diagnostic accuracy | Moderate | Consistent | Direct | Precise | Not detected | Moderate
KQ1a. Does the diagnostic accuracy differ according to patient characteristics (e.g., age, sex, ethnicity), or according to the nature of the presenting signs or symptoms?
Effects of tumor stage: Sensitivity | Quantitative NMP22: 11 studies Qualitative BTA: 18 studies FISH: 8 studies ImmunoCyt: 10 studies | Moderate | Consistent | Direct | Precise | Not detected | High
Effects of tumor grade: Sensitivity | Quantitative NMP22: 12 studies Qualitative BTA: 18 studies ImmunoCyt: 10 studies FISH: 9 studies | Moderate | Consistent | Direct | Precise | Not detected | High
Effects of tumor size: Sensitivity | 2 studies | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Effects of patient characteristics (age, sex, smoking status, and presence of other clinical conditions): sensitivity and specificity | | Moderate | Consistent | Direct | Imprecise | Not detected | Low
2. For patients with non-muscle-invasive bladder cancer, does the use of a formal risk- adapted assessment approach to treatment decisions (e.g., Guidelines of the European Association of Urology or based on urinary biomarker tests) decrease mortality or improve other outcomes (e.g., recurrence, progression, need for cystectomy, quality of life) compared with treatment not guided by an assessed risk- adapted approach?
Mortality, recurrence, progression, need for cystectomy, quality of life | No studies | - | - | - | - | - | Insufficient
3. For patients with non-muscle-invasive bladder cancer treated with transurethral resection of bladder tumor (TURBT), what is the effectiveness of various intravesical chemotherapeutic or immunotherapeutic agents for decreasing mortality or improving other outcomes (e.g., recurrence, progression, need for cystectomy, quality of life) compared with other agents, TURBT alone, or cystectomy?
BCG vs. no intravesical therapy
All-cause mortality | No studies | - | - | - | - | - | Insufficient
Bladder cancer-specific mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Insufficient
Recurrence | 3 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Low
Progression | 4 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Low
MMC vs. no intravesical therapy
All-cause mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Bladder cancer-specific mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Recurrence | 8 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
Progression | 5 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Doxorubicin vs. no intravesical therapy
All cause mortality | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
Bladder cancer-specific mortality | 1 RCTs | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Recurrence | 10 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
Progression | 5 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Epirubicin vs. no intravesical therapy
Recurrence | 9 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
Progression | 8 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Low
Gemcitabine vs. no intravesical therapy
All-cause mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Insufficient
Bladder cancer-specific mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Insufficient
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Insufficient
Interferon-alpha vs. no intravesical therapy
Bladder cancer-specific mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Recurrence | 3 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Progression | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Interferon-gamma vs. no intravesical therapy
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Thiotepa vs. no intravesical therapy
Recurrence | 4 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
3a. What is the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents, as monotherapy or in combination?
BCG versus MMC
All-cause mortality | 7 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
Bladder cancer- specific mortality | 5 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
Recurrence | 9 RCTs | Moderate | Inconsistent | Direct | Precise | Not detected | Low
Progression | 7 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
BCG vs. BCG plus MMC given sequentially
All-cause mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Bladder cancer- specific mortality | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Recurrence | 4 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
Progression | 3 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
BCG plus MMC given sequentially vs. MMC
All-cause mortality | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
Bladder cancer- specific mortality | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
Recurrence | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Progression | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
BCG vs. doxorubicin
All-cause mortality | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
Recurrence | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. epirubicin
All-cause mortality | 3 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
Bladder cancer-specific mortality | 3 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
Recurrence | 5 RCTs | Moderate | Inconsistent | Direct | Precise | Not detected | Moderate
Progression | 5 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
BCG vs. BCG plus epirubicin given sequentially
Recurrence | 3 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Progression | 3 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
BCG vs. Epirubicin plus interferon
Bladder cancer-specific mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. gemcitabine
All-cause mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Recurrence | 3 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Insufficient
Progression | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Quality of life | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. BCG plus gemcitabine given sequentially
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. interferon alpha-2a
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. alternating BCG and interferon alpha-2b
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. coadministration of BCG and interferon alpha-2b
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. thiotepa
Recurrence | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
MMC vs. doxorubicin
Recurrence | 6 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Progression | 4 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
MMC vs. epirubicin
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC vs. gemcitabine
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC vs. interferon-alpha
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC vs. interferon-gamma
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC vs. thiotepa
Recurrence | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Doxorubin vs. epirubicin
Recurrence | 3 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Doxorubicin vs. thiotepa
Bladder cancer-specific mortality | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Insufficient
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Insufficient
Epirubicin vs. interferon-alpha
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
3b. Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers? | Varied depending on tumor characteristic | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
3c. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, ethnicity, performance status, or medical comorbidities?
Age, sex, ethnicity, performance status, comorbidities | No studies | - | - | - | - | - | Insufficient
Recurrence, gemcitabine vs. BCG after progression or recurrence on BCG | 1RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Disease-free survival, MMC vs. gemcitabine maintenance | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
3d. Does the comparative effectiveness of various chemotherapeutic or immunotherapeutic agents differ according to dosing frequency, duration of treatment, and/or the timing of administration relative to TURBT?
Standard vs. lower dose BCG: Recurrence, progression, mortality, adverse events | 6 RCTs | Moderate | Inconsistent | Direct | Precise | Not detected | Low
Maintenance vs. induction BCG: Recurrence, progression, adverse events | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
BCG maintenance for 1 vs. 3 years: Recurrence, progression, mortality, adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC single vs. 5 instillations: Recurrence, progression, mortality, adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC induction vs. maintenance: Recurrence, adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC maintenance therapy with increased frequency and number of instillations vs. fewer instillations: Recurrence, progression, adverse events | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
MMC optimized vs. nonoptimized administration: Recurrence, adverse events | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Low
Doxorubicin eight weeks vs. two years: Recurrence, progression, adverse events | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Doxorubicin induction vs. maintenance: Recurrence, progression, mortality, adverse events | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Doxorubicin prior to vs. after TURBT: Recurrence, adverse events | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Epirubicin higher vs. lower doses: recurrence, progression, adverse events | 3 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
Epirubicin single vs. multiple instillations: Recurrence, progression, bladder cancer mortality, adverse events | 3 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
Epirubicin maintenance vs. induction without maintenance: Recurrence, progression, adverse events | 2 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
Epirubicin more versus less intensive therapy: Recurrence, adverse events | 5 RCTs | Moderate | Inconsistent | Direct | Precise | Not detected | Low
Thiotepa 30 vs. 60 mg: Recurrence, adverse events | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Interferon alpha-2b, high vs. lower doses: recurrence, progression, resolution of bladder cancer marker lesions | 3 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
MMC or doxorubicin on day of TURBT vs. 1 to 2 weeks after TURBT: Recurrence, progression, mortality, adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC or doxorubicin maintenance vs. no maintenance: Recurrence, progression, mortality, adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
4. For patients with high risk non-muscle- invasive bladder cancer treated with TURBT, what is the effectiveness of external beam radiation therapy (either alone or with systemic chemotherapy/immunotherapy) for decreasing mortality or improving other outcomes compared with intravesical chemotherapy/immunotherapy alone or cystectomy?
Mortality, recurrence, progression | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
5. In surveillance of patients treated for non- muscle-invasive bladder cancer, what is the effectiveness of various urinary biomarkers to decrease mortality or improve other outcomes compared with other urinary biomarkers or standard diagnostic methods (cystoscopy, cytology, and imaging)? | No Studies | - | - | - | - | - | Insufficient
a. Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers? | No Studies | - | - | - | - | - | Insufficient
b. Does the comparative effectiveness differ according to the treatment used (i.e., specific chemotherapeutic or immunotherapeutic agents and/or TURBT)? | No Studies | - | - | - | - | - | Insufficient
c. Does the comparative effectiveness differ according to the length of surveillance intervals? | No Studies | - | - | - | - | - | Insufficient
d. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, or ethnicity? | No Studies | - | - | - | - | - | Insufficient
6. For initial diagnosis or surveillance of patients treated for non-muscle-invasive bladder cancer, what is the effectiveness of blue light or other methods of augmented cystoscopy compared with standard cystoscopy for recurrence rates, progression of bladder cancer, mortality, or other clinical outcomes?
Fluorescent cystoscopy vs. white light cystoscopy
Mortality | 3 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Recurrence | 13 RCTs | Moderate | Inconsistent | Direct | Precise | Suspected | Low
Progression | 6 RCTs | Moderate | Consistent | Direct | Precise | Not detected | Moderate
Narrow band imaging vs. white light cystoscopy
Recurrence | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
7. What are the comparative adverse effects of various tests for diagnosis and post-treatment surveillance of bladder cancer, including urinary biomarkers, cytology, and cystoscopy?
Urinary biomarkers: Adverse clinical outcomes | No Studies | - | - | - | - | - | Insufficient
Fluorescent vs. white light cystoscopy: False positives | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
Fluorescent vs. white light cystoscopy: Renal and genitourinary adverse events | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
8. What are the comparative adverse effects of various treatments for non-muscle-invasive bladder cancer, including intravesical chemotherapeutic or immunotherapeutic agents and TURBT?
BCG vs. no intravesical therapy: Local and systemic adverse events | 4 RCTs (harms only reported for BCG arm) | High | Inconsistent | Direct | Imprecise | Not detected | Low
Non-BCG intravesical therapies vs. no intravesical therapy: Local and systemic adverse events | Varied depending on intravesical agent | High | Inconsistent | Direct | Imprecise | Not detected | Low for local adverse events, insufficient for systemic adverse events
BCG vs. MMC
Local adverse events | 2 to 6 RCTs | Moderate | Consistent | Direct | Imprecise (precise for cystitis and hematuria) | Not detected | Low (moderate for cystitis and hematuria)
Systemic adverse events | 2 to 4 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
BCG vs. BCG plus MMC given sequentially
Discontinuation of therapy | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG plus MMC given sequentially vs. MMC
Local adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Systemic adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Discontinuation of therapy | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. doxorubicin
Local adverse events | 1 to 3 RCTs | Moderate | Inconsistent or cannot determine | Direct | Imprecise | Not detected | Low (cystitis); insufficient (dysuria and hematuria)
BCG vs. epirubicin
Local adverse events | 1 to 4 RCTs | Moderate | Consistent or cannot determine | Direct | Imprecise | Not detected | Low
Discontinuation of therapy | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Insufficient
Systemic adverse events | 4 RCTs | Moderate | Consistent | Direct | Imprecise | Not detected | Low
BCG vs. BCG plus epirubicin given sequentially
Local adverse events | 1 to 2 RCTs | Moderate | Consistent or cannot determine | Direct | Imprecise | Not detected | Low
Systemic adverse events | 1 to 2 RCTs | Moderate | Consistent or cannot determine | Direct | Imprecise | Not detected | Low
Discontinuation of therapy
BCG vs. gemcitabine
Local adverse events | 1 to 2 RCTs | Moderate | Consistent or cannot determine | Direct | Imprecise | Not detected | Low
Systemic adverse events | 1 to 2 RCTs | Moderate | Consistent or cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. BCG plus gemcitabine given sequentially
Local adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. interferon alpha-2a
Local adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Systemic adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. coadministration of BCG and interferon alpha-2b
Systemic adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
BCG vs. thiotepa
Local adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Systemic adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC vs. doxorubicin
Local adverse events | 6 RCTs | Moderate | Inconsistent | Direct | Imprecise | Not detected | Insufficient
MMC vs. epirubicin
Local adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC vs. interferon-alpha
Local adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Systemic adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
MMC vs. gemcitabine
Local adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Doxorubicin vs. epirubicin
Local adverse events | 1 to 3 RCTs | Moderate | Consistent or cannot determine | Direct | Imprecise | Not detected | Low
Doxorubicin vs. thiotepa
Local adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Epirubicin vs. interferon-alpha
Local adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
Systemic adverse events | 1 RCT | Moderate | Cannot determine | Direct | Imprecise | Not detected | Low
8a. How do adverse effects of treatment vary by patient characteristics, such as age, sex, ethnicity, performance status, or medical comorbidities such as chronic kidney disease? | No studies | - | - | - | - | - | Insufficient