# Appendix F Risk of Bias

Table F1 Assessment of risk of bias of biomarker studies

Author, Year | Random or Consecutive Sample | Avoidance of Case- control Design | Avoidance of Inappropriate Exclusions | Index Test Performed In All Patients | Index Test Results Interpreted Without Knowledge of Reference Standard | Use of Prespecified Threshold or Definition for a Positive Test | Reference Standard Interpreted Independently from the Test Under Evaluation | Appropriate Interval Between Index Test and Reference Standard | Same Reference Standard Applied to All Patients | Were all patients included in the analysis? | Overall Risk of Bias (Low, Medium, High)
Cha, 2012 Germany | Yes | Yes | Yes | No | Yes | Yes | Unclear | Yes | Yes | No | Medium
Chahal, 2001 UK | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Medium
Feil, 2003 Germany | Yes | Yes | Yes | No | Unclear | Yes | Unclear | Yes | Yes | No | Medium
Friedrich, 2002 Germany | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Giannopoulos, 2001 Greece | Unclear | Yes | Yes | Yes | Unclear | No | Unclear | Yes | Yes | Yes | Medium
Gibanel, 2002 Spain | Unclear | Yes | Yes | Yes | Unclear | No | Unclear | Yes | Yes | Yes | Medium
Grossman, 2005 United States Lotan, 2009 | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Low
Grossman, 2006 United States | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Low
Gudjonsson, 2008 Sweden | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Medium
Gupta, 2009 India | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Medium
Gutierrez Banos, 2001 Spain | Unclear | Yes | No | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Medium
Halling, 2002 USA | Unclear | Yes | Yes | Unclear | Unclear | Yes | Unclear | Yes | Yes | No | High
Horstmann, 2009 Germany | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Unclear | Yes | Yes | Medium
Ianari, 1997 Italy | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Irani, 1999 France | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Medium
Junker, 2006 Germany | Unclear | Yes | Yes | No | Unclear | Yes | Unclear | Unclear | Yes | No | Medium
Karnwal, 2010 USA | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Medium
Leyh, 1997 Germany, UK, and France | Unclear | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Medium
Leyh, 1997 Germany and France | Unclear | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Medium
Leyh, 1999 Europe | Unclear | Yes | Unclear | No | Unclear | Yes | Yes | Yes | Yes | No | High
Lodde, 2003 Italy | Yes | Yes | Yes | No | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Messing, 2005 USA | Unclear | Yes | Yes | No | Yes | Yes | Unclear | Yes | Yes | Yes | Medium
Mian, 1999 Italy | Yes | Yes | Yes | No | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Mian, 2000 Italy and Austria | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Nasuti, 1999 USA | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Olsson, 2001 Sweden | Unclear | Yes | Yes | No | Unclear | Yes | Unclear | Yes | Yes | No | Medium
O'Sullivan, 2012 New Zealand | Yes | Yes | No | Yes | Unclear | Unclear | Unclear | Yes | Yes | Yes | Medium
Paoluzzi, 1999 Italy | Unclear | Yes | Yes | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Piaton, 2003 and Pfister, 2003 France | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Medium
Placer, 2002 Spain | Yes | Yes | Yes | No | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Pode, 1999 Israel | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Ponsky, 2001 USA | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Quek, 2002 Singapore | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Raitanen, 2001a and 2001b Finland | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | No | Medium
Saad, 2002 UK | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Sanchez-Carbayo, 2001 Spain | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Sarosdy, 2002 USA | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Medium
Sawczuk, 2000 USA | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Schamhart, 1998 the Netherlands | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | No | Medium
Schmitz-Drager, 2007a Germany | Yes | Yes | Yes | No | Unclear | Yes | Unclear | Unclear | Yes | Yes | Medium
Schmitz-Drager, 2007b Germany | Yes | Yes | Yes | No | Unclear | Yes | Unclear | Unclear | Yes | Yes | Medium
Serretta, 1998 Italy | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Serretta, 2000 Italy | Unclear | Yes | No | No | Unclear | Yes | Unclear | Unclear | Yes | No | High
Shariat, 2006 USA, Europe, Japan, Canada | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Sharma, 1999 USA | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Song, 2010 South Korea | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Medium
Sullivan, 2009 USA | Unclear | Yes | Yes | No | Unclear | Yes | Unclear | Unclear | No | No | Medium
Tetu, 2005 Canada | Yes | Yes | Yes | No | Unclear | Yes | Unclear | Unclear | Yes | No | Medium
Thomas, 1999 Europe | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Toma, 2004 Germany | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Unclear | Medium
United Kingdom and Eire Bladder Tumour Antigen Study Group, 1997 UK | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
van Der Poel, 1998 the Netherlands | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Varella-Garcia, 2004 | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Medium
Vriesema, 2001 the Netherlands | Unclear | Yes | Yes | No | Unclear | Yes | Unclear | Unclear | Yes | No | Medium
Wiener, 1998 Austria | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Unclear | Yes | Yes | Medium
Witjes, 1998 the Netherlands | Unclear | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Medium
Zippe, 1999 USA | Unclear | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Medium

Please see Appendix C. Included Studies for full study references.

Table F2 Assessment of risk of bias of randomized controlled trials

Author, Year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? (age, sex, race, smoking status-if available, bladder cancer stage) | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked? | Patient Masked? | Attrition Reported? | Overall loss to followup <20%? Differential attrition <10%? | Intention-to-Treat Analysis (analyzed by groups they were assigned to) | Postrandomization Exclusions | Outcomes Prespecified | Risk of Bias
Abrams, 1981 | No | No | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | High
Addeo, 2010 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | Unclear | Yes | Medium
Akaza, 1987 Study One (followup of Niijima, 1983) | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: No | Yes | Unclear | Yes | Medium
Akaza, 1987 Study Two | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Unclear | Yes | Medium
Akaza, 1992 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: No Differential: No | Yes | Unclear | Yes | High
Ali-El-Dein, 1997 (Brit J Urol) | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Yes Differential: Unclear | Yes | No | Yes | Medium
Ali-El-Dein, 1997 (J Urol) | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | No | Yes | Medium
Ali-El-Dein, 1999 | Unclear | Unclear | No: differences in single vs multiple tumors | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes: 11% not available for evaluation for reasons not reported | Yes | Medium
Au, 2001 | Unclear | Yes | Yes | Yes | No | No | No | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Babjuk, 2005 | Unclear | Unclear | Yes | Yes | No | No | No | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | High
Badalament,1987 | Yes | Unclear | Yes | Yes | Unclear | No | No | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Berrum-Svennung, 2008 | Yes | Unclear | Yes | Yes | Yes | No | Yes | Yes | Overall: Yes Differential: Unclear | Yes | Yes, but mainly due to incorrect inclusion | Yes | Medium
Bilen, 2000 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | All analyzed | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Boccardo, 1994 | Yes | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Böhle, 2009 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Bouffioux, 1995 | Unclear | Yes | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Overall: No Differential: Unclear | Yes | Yes | Yes | Medium
Brosman, 1982 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Burnand, 1976 | Yes | Unclear | Unclear | Yes | Unclear | No | Unclear | No | Unclear | Yes | No | Unclear | Medium
Cai, 2008 | Unclear | Yes | Yes | Yes | Unclear: double blind; statistician masked | Unclear: double blind | Unclear: double blind | Yes | Overall: Yes Differential: Yes | Yes | No | Unclear | Medium
Cheng, 2005 (Clin Urol) | Unclear | Unclear | No, control group with more solitary tumors | Yes | Unclear | Unclear | Unclear | No | Overall: Yes Differential: Unclear | Yes | No | Yes | Medium
Cheng, 2005 (Int. Journal of Urol.) | Unclear | Unclear | Some differences in distribution of tumor grade | Yes | Unclear | Unclear | Unclear | All analyzed | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Cho, 2009 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | all analyzed | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Colombo, 2012 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | No | No | Overall: Unclear Differential: Unclear | Yes | Unclear | Yes | Medium
De Nunzio, 2011 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | No | Yes | Medium
De Reijke, 2005 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | All analyzed | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
DeBruyne, 1988 Witjes, 1998a DeBruyne, 1992 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Di Lorenzo, 2010 | Yes | Yes | Yes | Yes | No | Unclear | No | All analyzed | Overall: Yes Differential: Yes | Yes | No | Yes | Low
Di Stasi, 2003 | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Low
Dragoescu, 2011 | Unclear | Unclear | Yes | Yes | No | No | No | Yes | Yes | Yes | Unclear | Unclear | Medium
Ducheck, 2010 Hemdan, 2014 | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Low
Ersoy, 2013 | No | Unclear | No | Yes | Unclear | Unclear | Unclear | No | Overall: Yes Differential: Unclear | Yes | Unclear | Yes | High
Eto, 1994 | Unclear | Yes | Yes (except age) | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | Unclear | Yes | Medium
Fellows, 1994 | Yes | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Medium
Flamm, 1990 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Yes Differential: Unclear | Yes | Yes, 9% not evaluable | Yes | Medium
Flanigan, 1986 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | No | No | Yes | Medium
Filbeck, 2002 Burger, 2008 Denginger, 2007a Denzinger, 2007b | Unclear | Unclear | No | Yes | No | No | No | Yes | Yes | Yes | No | Yes | Medium
Friedrich, 2007 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | No | Yes | Medium
Fukui, 1992 | Unclear | Unclear | Yes | Yes | Unclear | No | No | No | Unclear | Yes | Unclear | Unclear | High
Gardmark, 2005 | Unclear | Yes | Unclear | Yes | Unclear | Unclear | No | No | Unclear | Yes | Unclear | Yes | High
Geavlete, 2010 | Unclear | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | No | Yes | Medium
Geavlete, 2011 | Unclear | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | No | Yes | Medium
Giannakopoulos, 1998 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Giannopoulos, 2003 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Glashan, 1990 | Yes | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | No | Yes | Medium
Gontero, 2013 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | No; analyzed all individual who completed maintenance course for QOL | Yes | Yes | Medium
Gruenwald, 1997 | Yes | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Gudjónsson, 2009 | Unclear | No | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Gulpinar, 2012 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | No | Yes | Medium
Gustafson, 1991 | Unclear | Unclear | Yes | No | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Harland, 2007 | Unclear | No | Yes | Yes | Unclear | No | No | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Hendricksen, 2008 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | Yes | Yes | Medium
Hermann, 2011 | Unclear | Unclear | Yes | Yes | No | No | No | Yes | Yes | Yes | Yes | Yes | Medium
Herr, 1995 Herr, 1988 Herr, 1997 Cookson, 1997 Pinsky, 1985 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Hinotsu, 2006 | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Low
Hinotsu, 2011 | Yes (minimization method) | Yes (minimization method) | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Hirao, 1992 | Unclear | Unclear | No (grade) | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Unclear | Yes | Medium
Hoeltl, 1991 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: No Differential: Unclear | Yes | Yes | Yes | Medium
Huland, 1990 | Unclear | Unclear | No (age, grade) | Yes | Unclear | Unclear | No | Yes | Overall: Yes Differential: Unclear | Yes | Yes | Yes | Medium
Igawa, 1996 | Unclear | Unclear | No % solitary tumors | No | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | Unclear | Yes | Medium
Inamoto, 2013 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | Yes | No | Yes | Medium
Irie, 2003 | No (sequential) | No | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | Unclear | Yes | Low
Jarvinen, 2012 Rintala, 1996 Rintala, 1995 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Jauhiainen, 1987 | No | No | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | High
Jimenez-Cruz, 1997 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes, could not get interferon for 12 patients | Yes | Medium
Kaasinen, 2000 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | No 13% not eligible for randomization violations | Yes | Yes | Medium
Kaasinen, 2003 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | Yes | Yes | Medium
Karaolides, 2012 | Unclear | Unclear | Yes | Yes | No | No | No | Yes | Yes | Yes | No | Yes | Medium
Kim, 1989 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Koga, 2004 | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Koga, 2010 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Koontz, 1981 (prophylaxis) | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | Yes | Yes | Medium
Koontz, 1981 (treatment) | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | No | Yes | Medium
Krege, 1996 | Yes(randomization by random permuted block design?) | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Kriegmair, 2002 | Unclear | Unclear | Yes | Yes | No | No | No | Yes | Overall: No Differential: Yes | Yes | No | Yes | High
Kuroda, 2004 | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | Unclear | Yes | Medium
Kurth, 1997 Kurth, 1984 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Lamm, 1991 | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | All analyzed | Overall: Yes Differential: Yes | Unclear | Yes; 9% randomized not eligible and not analyzed | Yes | Medium
Lamm, 1995 | Yes (dynamic balancing algorithm) | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear as 16% not evaluable but | Yes | No | Yes | Medium
Lamm, 2000 Lerner, 2007 | Yes | Unclear | Yes, although specific grade and stage of tumor not reported by group | Yes | Unclear | Unclear | Unclear | All analyzed | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Liu, 2006 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Lundholm, 1996 Malmstrom, 1999 Gardmark, 2007 | Unclear | Yes | Unclear as only tumor information provided which showed no differences | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Malmström, 2002 | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Mangiarotti, 2008 | Unclear | Unclear | No, Tumor Stage differed | Yes | Unclear | Unclear | Unclear | All analyzed | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Martinez-Pineiro, 1990 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | No, excluded patients lost to followup | No | Unclear | Medium
Martinez-Pineiro, 2002 | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | No | Yes | Medium
Martinez-Pineiro, 2005 | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Masters, 1999 | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Matsumura, 1992 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | Yes | Unclear | Medium
Melekos, 1990 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | all analyzed | Overall: Yes Differential: Yes | Yes | No | Unclear | Medium
Melekos, 1992 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | No-19% not evaluated | Unclear | Yes | Medium
Melekos, 1993 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes: 15% excluded due to protocol violation, loss to followup, or | Yes | Medium
Melekos, 1996 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | All analyzed | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Mitsumori, 2004 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Mohsen, 2010 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Unclear | Unclear | Yes | Medium
Morales, 1992 | No (sequential) | No | Unclear | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | No | Yes | High
MRC Research Council, 1994 and 1985 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes | Unclear | Medium
Mukherjee, 1992 Kaisary, 1987 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | No | Unclear | Yes | Yes | Yes | High
Naselli, 2012 | Yes | Unclear | Yes | Yes | No (pathologist blinded but followup cystoscopies not) | No | No | Yes | Overall: Yes | Yes | No | Yes | Medium
Nepple, 2010 | Yes | Yes | Baseline characteristics by group not reported | Yes | Unclear | Unclear | Unclear | all analyzed | Differential: Yes | Yes | No | Yes | Medium
Niijima, 1983 Akaza,1987 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: No Differential: Unclear | Yes | Unclear | Yes | Medium
Nomata, 2002 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: No Differential: Yes | Yes | Yes | Yes | Medium
Obata, 1994 | Unclear | Unclear | No | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | No | Yes | Yes | Medium
O'Brien, 2013 | Unclear | Yes | Yes | Yes | No | No | No | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Oddens, 2013 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | Yes | Yes | Medium
Ojea, 2007 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | No | Yes | Medium
Okamura, 1998 | Unclear | Unclear | Yes | Yes | Unclear | No | No | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Okamura, 2002 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes- 10 patients not included | Yes | Medium
Oosterlinck, 1993 | Unclear | Unclear | No (grade) Unclear (age, sex) | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | Yes | Yes | Medium
Oosterlinck, 2011 | Unclear | Unclear | No: gender and performance status differences | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Pagano, 1991 Pagano, 1990 | Unclear | Unclear | Unclear, baseline characteristics not given | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Unclear | Unclear | Yes | High
Pagano, 1995 Bassi, 1992 | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | Unclear | Yes | High
Palou, 2001 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Porena, 2010 | Yes | Unclear | Yes | Yes | No | No | No | No | Overall: Unclear Differential: Unclear | Unclear | Unclear | Yes | Medium
Portillo, 1997 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | No-13% not evaluated | Unclear | Yes | Medium
Rajala, 1999 | Unclear | Unclear | No (grade) | Yes | Yes | Unclear | Unclear | No | Overall: Yes Differential: Yes | Yes | Yes | Unclear | Medium
Rajala, 2002 | Unclear | Unclear | Yes | Yes | No | No | No | Yes | Overall: Yes Differential: Unclear | Yes | Yes | Yes | Medium
Rentsch, 2014 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes Yes | Yes | No | Yes | Medium
Riedl, 2001 Daniltchenko, 2005 | Unclear | Unclear | Yes | Yes | No | No | No | Yes | Yes | Yes | No | Yes | Medium
Rintala, 1991 Jarvinen, 2009 | No, based on date of birth | Unclear | No, difference in recurrence rate before therapy | Yes | Unclear | Unclear | Unclear | All analyzed | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Rubben, 1988 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Yes | Unclear | Yes | Medium
Saika, 2010 | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Schulman, 1978 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear | Unclear | Yes | Overall: No Differential: Unclear | Yes | Unclear | Yes | Medium
Schumacher, 2010 | Unclear | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes | No | Yes | Medium
Schwaibold, 1997 | Unclear | Unclear | No | Yes | Unclear | Unclear | Unclear | Yes | Overall: No Differential: No | Yes | Yes | Yes | Medium
Sekine, 2001 | Unclear | Unclear | Unclear | Yes | Unclear | No | No | No | Unclear | Yes | Unclear | Yes | Medium
Sengiku, 2013 | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Serretta, 2010 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Unclear | Yes | Medium
Shuin, 1994 | Unclear | Unclear | No (single vs. multiple tumors) | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Unclear | High
Solsona, 1999 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Stavropoulos, 2002 | Unclear | Unclear | No (Ta vs. T1) | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | No, did not evaluate 10% | No | Yes | Medium
Stenzl, 2010 Grossman, 2012 Mostafid, 2009 | Unclear | Yes | Yes | Yes | No (pathologist blinded but followup cystoscopies not) | No | No | Yes | No | Yes | No | Yes | High
Stenzl, 2011 Penkoff, 2007 | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Tolley, 1996 Tolley, 1988 | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Tsushima, 1987 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | No | Yes | Medium
Turkeri, 2010 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Unclear Differential: Unclear | Unclear | Unclear | Yes | Medium
Ueda, 1992 | Unclear | Unclear | No | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Yes | Yes | Yes | Yes | Medium
Van Der Meljden, 2001 Sylvester, 2010 | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | No | Overall: Yes Differential: Yes | Yes | No | Yes | Medium
Van Gils-Gielen, 1995 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes/Yes | Yes | No | Yes | Medium
Witjes, 1993 Witjes, 1996 Vegt, 1995 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Unclear | Overall: Yes Differential: Unclear | Yes | No | Yes | Medium
Witjes, 1998b | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | All analyzed | Overall: Yes Differential: Yes | Yes | No | Unclear | Medium
Zincke, 1985 | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | No | Yes | Yes | Yes | Medium

Please see Appendix C. Included Studies for full study references.

Table F3 Assessment of risk of bias of cohort studies

Author, Year | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria, or a random sample (inception cohort)? | Were the groups comparable at baseline on key prognostic factors (age, sex, race, smoking status-if available, bladder cancer stage; e.g., by restriction or matching)? | Did the study maintain comparable groups through the study period? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the article report attrition? | Did the study perform appropriate statistical analyses on potential confounders? | Overall loss to followup <20%? Differential attrition <10%? | Were outcomes prespecified and defined, and ascertained using accurate methods? | Risk of Bias
Mulders, 1994 | Yes, all patients in registry | Yes | Yes | No | Not reported | Yes | No | No | Yes | High

Please see Appendix C. Included Studies for full study references.