# Appendix E Data Abstraction of Included Studies

Table E1 Key Question 1: Diagnostic accuracy

Table E2 Key Question 3: Trials of intravesical compared with no intravesical therapy

Table E3 Key Question 3: Trials of intravesical therapy versus intravesical therapy

Table E4 Key Question 3c: Trials of treatment dose and duration

Table E5 Key Question 4: Included randomized controlled trials

Table E6 Key Question 6: Included randomized controlled trials