# Appendix D Excluded Studies

Abbate I, D'Introno A, Cardo G, et al. (1998). Comparison of nuclear matrix protein 22 and bladder tumor antigen in urine of patients with bladder cancer. Anticancer Res.
Abern MR, Owusu RA, Anderson MR, et al. (2013). Perioperative intravesical chemotherapy in non-muscle-invasive bladder cancer: a systematic review and meta-analysis. J.
Aguilera Tubet C, Gutierrez Banos JL, Antolin Juarez F, et al. (2005). Actas Urol Esp.
Ajili F, Darouiche A, Chebil M, et al. (2013). The impact of age and clinical factors in non-muscle-invasive bladder cancer treated with Bacillus Calmette Guerin therapy. Ultrastruct Pathol.
Ajili F, Manai M, Darouiche A, et al. (2012). Tumor multiplicity is an independent prognostic factor of non-muscle-invasive bladder cancer treated with Bacillus Calmette-Guerin immunotherapy. Ultrastruct Pathol.
Ajit D, Dighe S, Desai S. (2010). Has urine cytology a role to play in the era of fluorescence in situ hybridization?. Acta Cytol.
Albers P, Park S-I, Niegisch G, et al. (2011). Randomized phase III trial of 2nd line gemcitabine and paclitaxel chemotherapy in patients with advanced bladder cancer: short-term versus prolonged treatment [German Association of Urological Oncology (AUO) trial AB 20/99. Ann Oncol.
Ali-El-Dein B. (2007). Maintenance Intravesical BCG Therapy for Superficial bladder tumors: 3-week multiple courses versus monthly doses. The Journal of urology.
Alken P, Siegsmund M, G-B K, et al. (2007). A randomised controlled multicenter trial to compare the effects of transurethral detection and resection of bladder carcinomas under 5-ALA induced fluorescence light to conventional white light [abstract 593]. Eur Urol Suppl.
Alkhateeb SS, Van Rhijn BWG, Finelli A, et al. (2010). Nonprimary pT1 nonmuscle invasive bladder cancer treated with bacillus Calmette-Guerin is associated with higher risk of progression compared to primary T1 tumors. J Urol.
Al'-Shukri SK, Danil'chenko DI, Kenig F, et al. (2000). Urologiia.
Altay B, Girgin C, Kefi A, et al. (2000). The best management of superficial bladder tumours: comparing TUR alone versus TUR combined with intravesical chemotherapy modalities?. Int Urol Nephrol.
Altieri VM, Castellucci R, Palumbo P, et al. (2012). Recurrence and progression in non-muscle-invasive bladder cancer using EORTC risk tables. Urol Int.
Amira N, Mourah S, Rozet F, et al. (2002). Non-invasive molecular detection of bladder cancer recurrence. Int J Cancer.
Anastasiadis A, Cordeiro E, Bus MT, et al. (2012). Follow-up procedures for non-muscle-invasive bladder cancer: an update. Expert Rev Anticancer Ther.
Ather MH, Aziz S, Sulaiman MN. (2007). Single instillation of mitomycin C reduces 1st year recurrence following transurethral resection of non-muscle invasive bladder cancer. J Ayub Med Coll Abbottabad.
Ayati M, Tousi VN, Sabokba T, et al. (2008). Molecular cytogenetic analysis of urothelial carcinomas using urine samples. Asian Pac J Cancer Prev.
Babjuk M, Bohle A, Burger E, et al. (2014). Guidelines on Non-muscle-invasive Bladder Cancer (Ta, T1 and CIS).
Babjuk M, Kostirova M, Mudra K, et al. (2002). Qualitative and quantitative detection of urinary human complement factor H-related protein (BTA stat and BTA TRAK) and fragments of cytokeratins 8, 18 (UBC rapid and UBC IRMA) as markers for transitional cell carcinoma of the bladder. Eur Urol.
Babjuk M, Oosterlinck W, Sylvester R, et al. (2008). EAU guidelines on non-muscle-invasive urothelial carcinoma of the bladder. Eur Urol.
Babjuk M, Soukup V, Pesl M, et al. (2008). Urinary cytology and quantitative BTA and UBC tests in surveillance of patients with pTapT1 bladder urothelial carcinoma. Urology.
Badalato GM, Hruby G, Razmjoo M, et al. (2011). Maximizing intravesical therapy options: is there an advantage to the administration of perioperative mitomycin C prior to an induction course of BCG?. Can J Urol.
Bartoletti R, Cai T, Gacci M, et al. (2005). Intravesical gemcitabine therapy for superficial transitional cell carcinoma: results of a Phase II prospective multicenter study. Urology.
Bendary, Salem K, Ashraf S, et al. (2011). Intravesical Gemcitabine Versus Bacillus Calmette-Guerin (BCG) in treatment of non-muscle invasive bladder cancer: short term comparative study. The Journal of urology.
Bergman J, Reznichek RC, Rajfer J. (2008). Surveillance of patients with bladder carcinoma using fluorescent in-situ hybridization on bladder washings. BJU Int.
Bertrand J, Soustelle L, Gres P, et al. (2012). Prog Urol.
Birkenhake S, Martus P, Kuhn R, et al. (1998). Radiotherapy alone or radiochemotherapy with platin derivatives following transurethral resection of the bladder. Organ preservation and survival after treatment of bladder cancer. Strahlenther Onkol.
Blanco S, Raber M, Leone BE, et al. (2010). Early detection of urothelial premalignant lesions using hexaminolevulinate fluorescence cystoscopy in high risk patients. J.
Blank LECM, Koedooder K, van Os R, et al. (2007). Results of bladder-conserving treatment, consisting of brachytherapy combined with limited surgery and external beam radiotherapy, for patients with solitary T1-T3 bladder tumors less than 5 cm in diameter. Int J Radiat Oncol Biol Phys.
Blumenstein BA, Ellis WJ, Ishak LM. (1999). The relationship between serial measurements of the level of a bladder tumor associated antigen and the potential for recurrence. J Urol.
Bohle A, Bock PR. (2004). Intravesical bacille Calmette-Guerin versus mitomycin C in superficial bladder cancer: formal meta-analysis of comparative studies on tumor progression. Urology.
Bohle A, Jocham D, Bock PR. (2003). Intravesical bacillus Calmette-Guerin versus mitomycin C for superficial bladder cancer: a formal meta-analysis of comparative studies on recurrence and toxicity. J Urol.
Böhm M, Vom Dorp F, Schostak M, et al. (2013). Urinzytologie - Update 2013: Eine systematische Übersicht der neueren Literatur.
Boman H, Hedelin H, Holmang S. (2002). Four bladder tumor markers have a disappointingly low sensitivity for small size and low grade recurrence. J Urol.
Boman H, Hedelin H, Jacobsson S, et al. (2002). Newly diagnosed bladder cancer: the relationship of initial symptoms, degree of microhematuria and tumor marker status. J Urol.
Bongiovanni L, Pirozzi F, Guidi F, et al. (2012). Bradeion (SEPT4) as a urinary marker of transitional cell bladder cancer: a real-time polymerase chain reaction study of gene expression. J Urol.
Bonner RB, Hemstreet GP, Fradet Y, et al. (1993). Bladder cancer risk assessment with quantitative fluorescence image analysis of tumor markers in exfoliated bladder cells. Cancer.
Boorjian SA, Zhu F, Herr HW. (2010). The effect of gender on response to bacillus Calmette-Guerin therapy for patients with non-muscle-invasive urothelial carcinoma of the bladder. BJU Int.
Brassell SA, Kamat AM. (2006). Contemporary intravesical treatment options for urothelial carcinoma of the bladder. J.
Brausi M, Campo B, Pizzocaro G, et al. (1998). Intravesical electromotive administration of drugs for treatment of superficial bladder cancer: a comparative Phase II study. Urology.
Bravaccini S, Casadio V, Gunelli R, et al. (2011). Combining cytology, TRAP assay, and FISH analysis for the detection of bladder cancer in symptomatic patients. Ann Oncol.
Bubendorf L, Grilli B, Sauter G, et al. (2001). Multiprobe FISH for enhanced detection of bladder cancer in voided urine specimens and bladder washings. Am J Clin Pathol.
Buchumensky V, Klein A, Zemer R, et al. (1998). Cytokeratin 20: a new marker for early detection of bladder cell carcinoma?. J Urol.
Burger M, Oosterlinck W, Konety B, et al. (2013). ICUD-EAU International Consultation on Bladder Cancer 2012: Non-muscle-invasive urothelial carcinoma of the bladder. Eur Urol.
Burger M, Stief CG, Zaak D, et al. (2009). Hexaminolevulinate is equal to 5-aminolevulinic acid concerning residual tumor and recurrence rate following photodynamic diagnostic assisted transurethral resection of bladder tumors. Urology.
Burger M, Thiounn N, Denzinger S, et al. (2010). The application of adjuvant autologous antravesical macrophage cell therapy vs. BCG in non-muscle invasive bladder cancer: a multicenter, randomized trial. J.
Cao M, Ma C-k, Ma J, et al. (2011). Chung Hua Chung Liu Tsa Chih.
Caraway NP, Khanna A, Fernandez RL, et al. (2010). Fluorescence in situ hybridization for detecting urothelial carcinoma: a clinicopathologic study. Cancer Cytopathol.
Carpinito GA, Stadler WM, Briggman JV, et al. (1996). Urinary nuclear matrix protein as a marker for transitional cell carcinoma of the urinary tract. J Urol.
Casadio V, Bravaccini S, Gunelli R, et al. (2009). Accuracy of urine telomerase activity to detect bladder cancer in symptomatic patients. Int J Biol Markers.
Casella R, Shariat SF, Monoski MA, et al. (2002). Urinary levels of urokinase-type plasminogen activator and its receptor in the detection of bladder carcinoma. Cancer.
Cassel A, Rahat MA, Lahat N, et al. (2001). Telomerase activity and cytokeratin 20 as markers for the detection and followup of transitional cell carcinoma: an unfulfilled promise. J Urol.
Catanzaro F, Torelli F, Catanzaro M, et al. (1996). Arch Ital Urol Androl.
Cauberg EC, Mamoulakis C, de la Rosette JJ, et al. (2011). Narrow band imaging-assisted transurethral resection for non-muscle invasive bladder cancer significantly reduces residual tumour rate. World J Urol.
Chang HW, Tsui KH, Shen LC, et al. (2007). Urinary cell-free DNA as a potential tumor marker for bladder cancer. Int J Biol Markers.
Chang Y-H, Wu C-H, Lee Y-L, et al. (2004). Evaluation of nuclear matrix protein-22 as a clinical diagnostic marker for bladder cancer. Urology.
Chautard D, Daver A, Bocquillon V, et al. (2000). Comparison of the Bard Trak test with voided urine cytology in the diagnosis and follow-up of bladder tumors. Eur Urol.
Chen C-H, Yang H-J, Shun C-T, et al. (2012). A cocktail regimen of intravesical mitomycin-C, doxorubicin, and cisplatin (MDP) for non-muscle-invasive bladder cancer. Urol.
Chen C-L, Lai Y-F, Tang P, et al. (2012). Comparative and targeted proteomic analyses of urinary microparticles from bladder cancer and hernia patients. J Proteome Res.
Chen H, Liou S, Loh C, et al. (2005). Bladder Cancer Screening and Monitoring of 4,4′-Methylenebis (2-Chloroaniline) exposure among workers in Taiwan. Urology.
Chen N, Gong J, Zeng H, et al. (2011). Sichuan Da Xue Xue Bao Yi Xue Ban.
Chen Y-T, Chen H-W, Domanski D, et al. (2012). Multiplexed quantification of 63 proteins in human urine by multiple reaction monitoring-based mass spectrometry for discovery of potential bladder cancer biomarkers. J Proteomics.
Cheng CW, Chan SFP, Chan LW, et al. (2004). 15-year experience on intravesical therapy of T1G3 urinary bladder cancer: a conservative approach. Jpn J Clin Oncol.
Cho I-C, Kim EK, Joung JY, et al. (2012). Adjuvant intravesical instillation for primary T1G3 bladder cancer: BCG versus MMC in Korea. Anticancer Res.
Chodak GW. (1989). Intravesical interferon treatment of superficial bladder cancer. Urology.
Chong TW, Cheng C. (1999). The role of the bladder tumour antigen test in the management of gross haematuria. Singapore Med J.
Chopin D, Hoznek A, Colombel M, et al. (1990). Ann Urol (Paris).
Chou R, Dana T. (2010). Screening adults for bladder cancer: a review of the evidence for the U.S. preventive services task force. Ann Intern Med.
Chung W, Bondaruk J, Jelinek J, et al. (2011). Detection of bladder cancer using novel DNA methylation biomarkers in urine sediments. Cancer Epidemiol Biomarkers Prev.
Colombo R, Da Pozzo LF, Lev A, et al. (1996). Neoadjuvant combined microwave induced local hyperthermia and topical chemotherapy versus chemotherapy alone for superficial bladder cancer. J Urol.
Colombo R, Da Pozzo LF, Salonia A, et al. (2003). Multicentric study comparing intravesical chemotherapy alone and with local microwave hyperthermia for prophylaxis of recurrence of superficial transitional cell carcinoma. J Clin Oncol.
Colombo R, Salonia A, Leib Z, et al. (2011). Long-term outcomes of a randomized controlled trial comparing thermochemotherapy with mitomycin-C alone as adjuvant treatment for non-muscle-invasive bladder cancer (NMIBC). BJU Int.
Crew JP, O'Brien T, Bicknell R, et al. (1999). Urinary vascular endothelial growth factor and its correlation with bladder cancer recurrence rates. J Urol.
Croswell J, Fall B. (2012). Screening for bladder cancer. Am Fam Physician.
da Silva FC, Ferrito F, Brandao T, et al. (1992). 4′-epidoxorubicin versus mitomycin C intravesical chemoprophylaxis of superficial bladder cancer. Eur Urol.
Dalbagni G, Han W, Zhang ZF, et al. (1997). Evaluation of the telomeric repeat amplification protocol (TRAP) assay for telomerase as a diagnostic modality in recurrent bladder cancer. Clin Cancer Res.
Dalbagni G, Kaag M, Cronin A, et al. (2010). Variability of treatment selection among surgeons for patients with cT1 urothelial carcinoma. BJU Int.
Dalbagni G, Russo P, Bochner B, et al. (2006). Phase II trial of intravesical gemcitabine in bacille Calmette-Guerin-refractory transitional cell carcinoma of the bladder. J Clin Oncol.
Danil'chenko DI, Koenig F, Riedl K, et al. (2003). Vopr Onkol.
Darenkov SP, Perlin DV, Chernyshev IV, et al. (2006). Urologiia.
Datta A, Adelson ME, Mogilevkin Y, et al. (2011). Oncoprotein DEK as a tissue and urinary biomarker for bladder cancer. BMC Cancer.
Davis R, Jones JS, Barocas DA, et al. (2012). Diagnosis, evaluation and follow-up of asymptomatic microhematuria (AMH) in adults: AUA guideline. J Urol.
De Berardinis E, Busetto GM, Antonini G, et al. (2011). T1G3 high-risk NMIBC (non-muscle invasive bladder cancer): conservative treatment versus immediate cystectomy. Int Urol Nephrol.
De Bruijn EA, Sleeboom HP, van Helsdingen PJ, et al. (1992). Pharmacodynamics and pharmacokinetics of intravesical mitomycin C upon different dwelling times. Int J Cancer.
Decobert M, LaRue H, Harel F, et al. (2008). Maintenance bacillus Calmette-Guerin in high-risk nonmuscle-invasive bladder cancer: how much is enough?. Cancer.
Degtyar P, Neulander E, Zirkin H, et al. (2004). Fluorescence in situ hybridization performed on exfoliated urothelial cells in patients with transitional cell carcinoma of the bladder. Urology.
Del Nero A, Esposito N, Curro A, et al. (1999). Evaluation of urinary level of NMP22 as a diagnostic marker for stage pTa-pT1 bladder cancer: comparison with urinary cytology and BTA test. Eur Urol.
Denzinger S, Burger M, Fritsche HM, et al. (2008). Aktuel Urol.
Denzinger S, Rossler W, Otto W. (2007). Dtsch Med Wochenschr.
Dettlaff-Pokora A, Matuszewski M, Schlichtholz B. (2005). Telomerase activity in urine sediments as a tool for noninvasive detection of bladder cancer. Cancer Lett.
D'Hallewin MA, Baert L. (1996). Initial evaluation of the bladder tumor antigen test in superficial bladder cancer. J Urol.
Di Stasi SM, Giannantoni A, Giurioli A, et al. (2006). Sequential BCG and electromotive mitomycin versus BCG alone for high-risk superficial bladder cancer: a randomised controlled trial. Lancet Oncol.
Di Stasi SM, Valenti M, Verri C, et al. (2011). Electromotive instillation of mitomycin immediately before transurethral resection for patients with primary urothelial non-muscle invasive bladder cancer: a randomised controlled trial. Lancet Oncol.
Dinney CP, Greenberg RE, Steinberg GD. (2013). Intravesical valrubicin in patients with bladder carcinoma in situ and contraindication to or failure after bacillus Calmette-Guerin. Urol Oncol.
Divrik RT, Sahin AF, Yildirim U, et al. (2010). Impact of routine second transurethral resection on the long-term outcome of patients with newly diagnosed pT1 urothelial carcinoma with respect to recurrence, progression rate, and disease-specific survival: a prospective randomised clinical trial. Eur Urol.
Divrik RT, Yildirim U, Zorlu F, et al. (2006). The effect of repeat transurethral resection on recurrence and progression rates in patients with T1 tumors of the bladder who received intravesical mitomycin: a prospective, randomized clinical trial. J Urol.
Durkan GC, Nutt JE, Marsh C, et al. (2003). Alteration in urinary matrix metalloproteinase-9 to tissue inhibitor of metalloproteinase-1 ratio predicts recurrence in nonmuscle-invasive bladder cancer. Clin Cancer Res.
Durkan GC, Nutt JE, Rajjayabun PH, et al. (2001). Prognostic significance of matrix metalloproteinase-1 and tissue inhibitor of metalloproteinase-1 in voided urine samples from patients with transitional cell carcinoma of the bladder. Clin Cancer Res.
Edgecombe A, Nguyen BN, Djordjevic B, et al. (2012). Utility of cytokeratin 5/6, cytokeratin 20, and p16 in the diagnosis of reactive urothelial atypia and noninvasive component of urothelial neoplasia. Appl Immunohistochem Molecul Morphol.
Eggener S, Herr H. (2006). NMP22 and surveillance for recurrent bladder cancer. Jama.
Eijan AM, Sandes E, Puricelli L, et al. (2000). Cathepsin B levels in urine from bladder cancer patients. Oncol Rep.
Eijsten A, Knonagel H, Hotz E, et al. (1990). Reduced bladder capacity in patients receiving intravesical chemoprophylaxis with mitomycin C. Br J Urol.
Eissa S, Badr S, Barakat M, et al. (2013). The diagnostic efficacy of urinary survivin and hyaluronidase mRNA as urine markers in patients with bladder cancer. Clin Lab.
Ellis WJ, Blumenstein BA, Ishak LM, et al. (1997). Clinical evaluation of the BTA TRAK assay and comparison to voided urine cytology and the Bard BTA test in patients with recurrent bladder tumors. The Multi Center Study Group. Urology.
Faba OR, Palou J, Breda A, et al. (2012). High-risk non-muscle-invasive bladder cancer: update for a better identification and treatment. World J Urol.
Feifer AH, Steinberg J, Tanguay S, et al. (2010). Utility of urine cytology in the workup of asymptomatic microscopic hematuria in low-risk patients. Urology.
Feil G, Bichler KH, Paulgen-Nelde HJ, et al. (2003). Urologe A.
Feil G, Stenzl A. (2006). Actas Urol Esp.
Fernandez Gomez JM, Garcia Rodriguez J, Escaf Barmadah S, et al. (2002). Arch Esp Urol.
Fernandez-Gomez J, Rodriguez-Martinez JJ, Barmadah SE, et al. (2007). Urinary CYFRA 21.1 is not a useful marker for the detection of recurrences in the follow-up of superficial bladder cancer. Eur Urol.
Ferra S, Denley R, Herr H, et al. (2009). Reflex UroVysion testing in suspicious urine cytology cases. Cancer.
Filson CP, Montgomery JS, Dailey SM, et al. (2014). Complications associated with single-dose, perioperative mitomycin-C for patients undergoing bladder tumor resection. Urol.
Fiorito C, Gontero P. (2013). Urologia.
Fradet Y, Campbell L. (1997). Performance characteristics of a new monoclonal antibody test for bladder cancer: ImmunoCyt. The Canadian Journal of Urology.
Fradet Y, Grossman HB, Gomella L, et al. (2007). A comparison of hexaminolevulinate fluorescence cystoscopy and white light cystoscopy for the detection of carcinoma in situ in patients with bladder cancer: a phase III, multicenter study. J Urol.
Francesco Bassi P, Milani C, Meneghini A, et al. (1990). Arch Esp Urol.
Friedrich MG, Hellstern A, Hautmann SH, et al. (2003). Urologe A.
Friedrich MG, Hellstern A, Toma MI, et al. (2003). Are false-positive urine markers for the detection of bladder carcinoma really wrong or do they predict tumor recurrence?. Eur Urol.
Friedrich MG, Toma MI, Hellstern A, et al. (2003). Comparison of multitarget fluorescence in situ hybridization in urine with other noninvasive tests for detecting bladder cancer. BJU Int.
Frigerio S, Padberg BC, Strebel RT, et al. (2007). Improved detection of bladder carcinoma cells in voided urine by standardized microsatellite analysis. Int J Cancer.
Froehner M, Brausi MA, Herr HW, et al. (2009). Complications following radical cystectomy for bladder cancer in the elderly. Eur Urol.
Fujimoto K, Chihara Y, Kondo H, et al. (2006). Hinyokika Kiyo.
Gacci M, Bartoletti R, Cai T, et al. (2006). Intravesical gemcitabine in BCG-refractory T1G3 transitional cell carcinoma of the bladder: a pilot study. Urol Int.
Gallagher BL, Joudi FN, Maymi JL, et al. (2008). Impact of previous bacille Calmette-Guerin failure pattern on subsequent response to bacille Calmette-Guerin plus interferon intravesical therapy. Urology.
Garcia Penalver C, Perez Barrios A, Leiva Galvis O. (2005). Actas Urol Esp.
Garcia-Baquero R, Puerta P, Beltran M, et al. (2013). Methylation of a novel panel of tumor suppressor genes in urine moves forward noninvasive diagnosis and prognosis of bladder cancer: a 2-center prospective study. J Urol.
Gardmark T, Carringer M, Beckman E, et al. (2005). Randomized phase II marker lesion study evaluating effect of scheduling on response to intravesical gemcitabine in recurrent Stage Ta urothelial cell carcinoma of the bladder. Urology.
Garfield SS, Gavaghan MB, Armstrong SO, et al. (2013). The cost-effectiveness of blue light cystoscopy in bladder cancer detection: United States projections based on clinical data showing 4.5 years of follow up after a single hexaminolevulinate hydrochloride instillation. Can J Urol.
Gayed BA, Seideman C, Lotan Y. (2013). Cost-effectiveness of fluorescence in situ hybridization in patients with atypical cytology for the detection of urothelial carcinoma. J Urol.
Geavlete B, Multescu R, Georgescu D, et al. (2008). Hexvix blue light fluorescence cystoscopy--a promising approach in diagnosis of superficial bladder tumors. Journal of Medicine & Life.
Geavlete B, Multescu R, Georgescu D, et al. (2008). Chirurgia (Bucur).
Geavlete B, Multescu R, Georgescu D, et al. (2009). Hexaminolevulinate fluorescence cystoscopy and transurethral resection of the bladder in noninvasive bladder tumors. J Endourol.
Geavlete B, Multescu R, Georgescu D, et al. (2009). HAL fluorescence cystoscopy and TURB one year of Romanian experience. Journal of Medicine & Life.
Gerhards S, Jung K, Koenig F, et al. (2001). Excretion of matrix metalloproteinases 2 and 9 in urine is associated with a high stage and grade of bladder carcinoma. Urology.
Giannopoulos A, Manousakas T, Mitropoulos D, et al. (2000). Comparative evaluation of the BTAstat test, NMP22, and voided urine cytology in the detection of primary and recurrent bladder tumors. Urology.
Giberti C, Gallo F, Schenone M, et al. (2010). Early results of urothelial carcinoma screening in a risk population of coke workers: urothelial carcinoma among coke workers. Biomed Environ Sci.
Gkialas I, Papadopoulos G, Iordanidou L, et al. (2008). Evaluation of urine tumor-associated trypsin inhibitor, CYFRA 21-1, and urinary bladder cancer antigen for detection of high-grade bladder carcinoma. Urology.
Gontero P, Bohle A, Malmstrom P-U, et al. (2010). The role of bacillus Calmette-Guerin in the treatment of non-muscle-invasive bladder cancer. Eur Urol.
Gontero P, Fiorito C, Oderda M, et al. (2013). Phase II study of biweekly gemcitabine as first line therapy in CIS of the bladder: what does an aborted trial tell us?. Urol.
Gregersen B, Mommsen S, Svanholm H. (1999). Ugeskr Laeger.
Grossman HB, Gomella L, Fradet Y, et al. (2007). A phase III, multicenter comparison of hexaminolevulinate fluorescence cystoscopy and white light cystoscopy for the detection of superficial papillary lesions in patients with bladder cancer. J Urol.
Gruschwitz T, Grimm MO. (2012). Studieearly recognition in urology. Früherkennung in der urologie.
Gutierrez Banos JL, Martin Garcia B, de Diego Rodriguez E, et al. (1999). Arch Esp Urol.
Gutierrez Banos JL, Martin Garcia B, Hernandez Rodriguez R, et al. (1998). Arch Esp Urol.
Gutierrez Banos JL, Rebollo Rodrigo MH, Antolin Juarez F, et al. (2000). Arch Esp Urol.
Gutierrez Banos JL, Rebollo Rodrigo MH, Antolin Juarez F, et al. (2000). Actas Urol Esp.
Hajdinjak T. (2008). UroVysion FISH test for detecting urothelial cancers: meta-analysis of diagnostic accuracy and comparison with urinary cytology testing. Urol Oncol.
Han J, Lin T, Xu K, et al. (2010). Improved detection of nonmuscle invasive urothelial carcinoma of the bladder using pirarubicin endoscopy: a prospective, single-center preliminary study. J Endourol.
Harland SJ. (2006). Electromotive drug delivery and bladder cancer. Lancet Oncol.
Hautmann RE, Volkmer BG, Gust K. (2009). Quantification of the survival benefit of early versus deferred cystectomy in high-risk non-muscle invasive bladder cancer (T1 G3). World J Urol.
Hautmann S, Toma M, Lorenzo Gomez MF, et al. (2004). Immunocyt and the HA-HAase urine tests for the detection of bladder cancer: a side-by-side comparison. Eur Urol.
Heicappell R, Wettig IC, Schostak M, et al. (1999). Quantitative detection of human complement factor H-related protein in transitional cell carcinoma of the urinary bladder. Eur Urol.
Heney NM. (1985). First-line chemotherapy of superficial bladder cancer: mitomycin vs thiotepa. Urology.
Heney NM, Koontz WW, Barton B, et al. (1988). Intravesical thiotepa versus mitomycin C in patients with Ta, T1 and TIS transitional cell carcinoma of the bladder: a phase III prospective randomized study. J Urol.
Henningsohn L, Wijkstrom H, Steven K, et al. (2003). Relative importance of sources of symptom-induced distress in urinary bladder cancer survivors. Eur Urol.
Henriksson R, Franzen L, Littbrand B. (1991). Prevention of irradiation-induced bowel discomfort by sucralfate: a double-blind, placebo-controlled study when treating localized pelvic cancer. Am J Med.
Henriksson R, Franzen L, Littbrand B. (1992). Effects of sucralfate on acute and late bowel discomfort following radiotherapy of pelvic cancer. J Clin Oncol.
Henriquez-Hernandez LA, Navarro P, Luzardo OP, et al. (2012). Polymorphisms of glutathione S-transferase mu and , MDR1 and VEGF genes as risk factors of bladder cancer: a case-control study. Urol.
Herr HW. (2010). Narrow-band imaging cystoscopy to evaluate the response to bacille Calmette-Guerin therapy: preliminary results. BJU Int.
Herr HW, Dalbagni G, Donat SM. (2011). Bacillus Calmette-Guerin without maintenance therapy for high-risk non-muscle-invasive bladder cancer. Eur Urol.
Herr HW, Donat SM. (2008). A comparison of white-light cystoscopy and narrow-band imaging cystoscopy to detect bladder tumour recurrences. BJU Int.
Herr HW, Donat SM. (2011). Reduced bladder tumour recurrence rate associated with narrow-band imaging surveillance cystoscopy. BJU Int.
Hinotsu S, Akaza H, Isaka S, et al. (2002). Gan To Kagaku Ryoho.
Ho CCK. (2011). Electromotive administration of mitomycin. Lancet Oncol.
Horstmann M. (2011). Blasenkrebs: Screening in Risikogruppen oder symptombasierte urologische Diagnostik?.
Horstmann M, Bontrup H, Hennenlotter J, et al. (2010). Clinical experience with survivin as a biomarker for urothelial bladder cancer. World J Urol.
Hotakainen K, Haglund C, Paju A, et al. (2002). Chorionic gonadotropin beta-subunit and core fragment in bladder cancer: mRNA and protein expression in urine, serum and tissue. Eur Urol.
Houghton BB, Chalasani V, Hayne D, et al. (2013). Intravesical chemotherapy plus bacille Calmette-Guerin in non-muscle invasive bladder cancer: a systematic review with meta-analysis. BJU Int.
Hsieh C-H, Chung S-D, Chan P-H, et al. (2011). Intensity modulated radiotherapy for elderly bladder cancer patients. Radiat.
Huncharek M, Kupelnick B. (2004). The influence of intravesical therapy on progression of superficial transitional cell carcinoma of the bladder: a metaanalytic comparison of chemotherapy versus bacilli Calmette-Guerin immunotherapy. Am J Clin Oncol.
Iborra JI, Ricos Torrent JV, Monros Lliso JL, et al. (1992). Arch Esp Urol.
Ihm CH, Kim JM, Sohn YH. (2007). Korean J Lab Med.
Iida S, Kondo T, Kobayashi H, et al. (2009). Clinical outcome of high-grade non-muscle-invasive bladder cancer: a long-term single center experience. Int J Urol.
Imamura M, Inoue K, Megumi Y, et al. (2000). Hinyokika Kiyo.
Institute of Applied Health Sciences. (2013). Systematic review of the clinical and cost-effectiveness, and economic evaluation, of photodynamic diagnosis and novel urine biomarker tests in the detection and follow-up of bladder cancer (Project record). Health Technology Assessment Database.
Isaka S, Okano T, Shimazaki J, et al. (1987). Prophylaxis of superficial bladder cancer with instillation of adriamycin or mitomycin C. Cancer chemotherapy and pharmacology.
Isaka S, Okano T, Shimazaki J, et al. (1987). Prophylaxis of superficial bladder cancer with instillation of adriamycin or mitomycin C. Cancer Chemother Pharmacol.
Isbarn H, Budaus L, Pichlmeier U, et al. (2008). Urologe A.
Iwaki H, Kageyama S, Isono T, et al. (2004). Diagnostic potential in bladder cancer of a panel of tumor markers (calreticulin, gamma -synuclein, and catechol-o-methyltransferase) identified by proteomic analysis. Cancer Sci.
Jager W, Thomas C, Haag S, et al. (2011). Early vs delayed radical cystectomy for ‘high-risk’ carcinoma not invading bladder muscle: delay of cystectomy reduces cancer-specific survival. BJU Int.
Jalon Monzon A, Fernandez Gomez JM, Escaf Barmadah S, et al. (2008). Actas Urol Esp.
Jalon Monzon A, Fernandez Gomez JM, Escaf Bramada S, et al. (2008). Actas Urol Esp.
Jamshidian H, Kor K, Djalali M. (2008). Urine concentration of nuclear matrix protein 22 for diagnosis of transitional cell carcinoma of bladder. Urol.
Jancke G, Damm O, Rosell J, et al. (2008). Risk factors for local recurrence in patients with pTa/pT1 urinary bladder cancer. Scand J Urol Nephrol.
Jauhiainen K, Rintala E. (1993). Superficial urinary bladder cancer. Results from the Finnbladder studies and a review on instillation treatments. Ann Chir Gynaecol Suppl.
Jeon SH, Lee SJ, Chang SG. (2001). Clinical significance of urinary vascular endothelial growth factor in patients with superficial bladder tumors. Oncol Rep.
Jeon SS, Kang I, Hong JH, et al. (2001). Diagnostic efficacy of fluorescence cystoscopy for detection of urothelial neoplasms. J Endourol.
Jiang F, Caraway NP, Sabichi AL, et al. (2003). Centrosomal abnormality is common in and a potential biomarker for bladder cancer. Int J Cancer.
Jichlinski P, Guillou L, Karlsen SJ, et al. (2003). Hexyl aminolevulinate fluorescence cystoscopy: new diagnostic tool for photodiagnosis of superficial bladder cancer--a multicenter study. J Urol.
Jimenez Cruz JF, Llopis Minguez B, Vera Donoso CD. (1990). Arch Esp Urol.
Jocham D, von Wietersheim J, Pfluger H, et al. (2009). Aktuel Urol.
Jocham D, Witjes F, Wagner S, et al. (2005). Improved detection and treatment of bladder cancer using hexaminolevulinate imaging: a prospective, phase III multicenter study. J Urol.
Johnston B, Morales A, Emerson L, et al. (1997). Rapid detection of bladder cancer: a comparative study of point of care tests. J Urol.
Jones G, Cleves A, Wilt TJ, et al. (2012). Intravesical gemcitabine for non-muscle invasive bladder cancer. Cochrane Database Syst Rev.
Jones JS. (2006). DNA-based molecular cytology for bladder cancer surveillance. Urology.
Joudi FN, Smith BJ, O'Donnell MA, et al. (2006). Final results from a national multicenter phase II trial of combination bacillus Calmette-Guerin plus interferon alpha-2B for reducing recurrence of superficial bladder cancer. Urol.
Jurincic-Winkler C, Metz KA, Beuth J, et al. (1995). Effect of keyhole limpet hemocyanin (KLH) and bacillus Calmette-Guerin (BCG) instillation on carcinoma in situ of the urinary bladder. Anticancer Res.
Kageyama S, Isono T, Matsuda S, et al. (2009). Urinary calreticulin in the diagnosis of bladder urothelial carcinoma. Int J Urol.
Kamat AM, Dickstein RJ, Messetti F, et al. (2012). Use of fluorescence in situ hybridization to predict response to bacillus Calmette-Guerin therapy for bladder cancer: results of a prospective trial. J Urol.
Kamat AM, Karam JA, Grossman HB, et al. (2011). Prospective trial to identify optimal bladder cancer surveillance protocol: reducing costs while maximizing sensitivity. BJU Int.
Kamat AM, Witjes JA, Brausi M, et al. (2014). Defining and treating the spectrum of intermediate risk nonmuscle invasive bladder cancer. J Urol.
Kamat MR, Kulkarni JN, Tongaonkar HB, et al. (1994). Intravesical bacillus Calmette-Guerin for superficial bladder cancer: experience with Danish 1331 strain. J Urol.
Karnes RJ, Fernandez CA, Shuber AP. (2012). A noninvasive multianalyte urine-based diagnostic assay for urothelial cancer of the bladder in the evaluation of hematuria. Mayo Clin Proc.
Kausch I, Sommerauer M, Montorsi F, et al. (2010). Photodynamic diagnosis in non-muscle-invasive bladder cancer: a systematic review and cumulative analysis of prospective studies. Eur Urol.
Kawamura J, Tochigi H, Obata K, et al. (1992). Hinyokika Kiyo.
Kehinde EO, Al-Mulla F, Kapila K, et al. (2011). Comparison of the sensitivity and specificity of urine cytology, urinary nuclear matrix protein-22 and multitarget fluorescence in situ hybridization assay in the detection of bladder cancer. Scand J Urol Nephrol.
Khanna OP, Son DL, Mazer H, et al. (1987). Superficial bladder cancer treated by intravesical bacillus Calmette-Guerin or adriamycin: multicenter study interim report. Urology.
Khanna OP, Son DL, Son K, et al. (1991). Multicenter study of superficial bladder cancer treated with intravesical bacillus Calmette-Guerin or adriamycin. Results of long-term follow-up. Urology.
Khochikar MV. (2011). Rationale for an early detection program for bladder cancer. Indian J Urol.
Kinjo M, Okegawa T, Horie S, et al. (2004). Detection of circulating MUC7-positive cells by reverse transcription-polymerase chain reaction in bladder cancer patients. Int J Urol.
Kinoshita H, Ogawa O, Kakehi Y, et al. (1997). Detection of telomerase activity in exfoliated cells in urine from patients with bladder cancer. J Natl Cancer Inst.
Kipp BR, Halling KC, Campion MB, et al. (2008). Assessing the value of reflex fluorescence in situ hybridization testing in the diagnosis of bladder cancer when routine urine cytological examination is equivocal. J Urol.
Kipp BR, Karnes RJ, Brankley SM, et al. (2005). Monitoring intravesical therapy for superficial bladder cancer using fluorescence in situ hybridization. J Urol.
Koenig F, McGovern FJ, Larne R, et al. (1999). Diagnosis of bladder carcinoma using protoporphyrin IX fluorescence induced by 5-aminolaevulinic acid. BJU Int.
Kohjimoto Y, Iba A, Shintani Y, et al. (2010). Impact of patient age on outcome following bladder-preserving treatment for non-muscle-invasive bladder cancer. World J Urol.
Kompier LC, Lurkin I, van der Aa MNM, et al. (2010). FGFR3, HRAS, KRAS, NRAS and PIK3CA mutations in bladder cancer and their potential as biomarkers for surveillance and therapy. PLoS ONE.
Kondas J, Kiss L, Hatar A, et al. (1999). The effect of intravesical mitomycin C on the recurrence of superficial (Ta-T1) bladder cancer. A Hungarian Multicenter Study. Int Urol Nephrol.
Kondas J, Szentgyorgyi E, Szecso L, et al. (1991). Local BCG therapy of superficial bladder tumours. Int Urol Nephrol.
Konety BR. (2006). Molecular markers in bladder cancer: a critical appraisal. Urol Oncol.
Krause FS, Rauch A, Schrott KM, et al. (2006). Clinical decisions for treatment of different staged bladder cancer based on multitarget fluorescence in situ hybridization assays?. World J Urol.
Krogsbøll LT. (2014). Guidelines for screening with urinary dipsticks differ substantially - A systematic review. Danish Medical Journal.
Kulkarni GS, Alibhai SMH, Finelli A, et al. (2009). Cost-effectiveness analysis of immediate radical cystectomy versus intravesical Bacillus Calmette-Guerin therapy for high-risk, high-grade (T1G3) bladder cancer. Cancer.
Kulkarni GS, Finelli A, Fleshner NE, et al. (2007). Optimal management of high-risk T1G3 bladder cancer: a decision analysis. PLoS Med.
Kulkarni JN, Gupta R. (2002). Recurrence and progression in stage T1G3 bladder tumour with intravesical bacille Calmette-Guerin (Danish 1331 strain). BJU Int.
Kumar A, Dubey D, Bansal P, et al. (2002). Urinary interleukin-8 predicts the response of standard and low dose intravesical bacillus Calmette-Guerin (modified Danish 1331 strain) for superficial bladder cancer. J Urol.
Lahme S, Bichler KH, Feil G, et al. (2001). Comparison of cytology and nuclear matrix protein 22 for the detection and follow-up of bladder cancer. Urol Int.
Lahme S, Bichler KH, Feil G, et al. (2003). Comparison of cytology and nuclear matrix protein 22 (NMP 22) for the detection and follow-up of bladder-cancer. Adv Exp Med Biol.
Lam JS, Benson MC, O'Donnell MA, et al. (2003). Bacillus Calmete-Guerin plus interferon-alpha2B intravesical therapy maintains an extended treatment plan for superficial bladder cancer with minimal toxicity. Urol.
Lamm D, Bohle A, Palou J, et al. (2010). Re: Per-Uno Malmstrom, Richard J. Sylvester, David E. Crawford, et al. An individual patient data meta-analysis of the long-term outcome of randomised studies comparing intravesical mitomycin C versus bacillus Calmette-Guerin for non-muscle-invasive bladder cancer. Eur Urol 2009;56:247-56. Eur Urol.
Lammers RJ, Witjes WP, Janzing-Pastors MH, et al. (2012). Intracutaneous and intravesical immunotherapy with keyhole limpet hemocyanin compared with intravesical mitomycin in patients with non-muscle-invasive bladder cancer: results from a prospective randomized phase III trial. Journal of clinical oncology : official journal of the American Society of Clinical Oncology.
Lammers RJM, Palou J, Witjes WPJ, et al. (2014). Comparison of expected treatment outcomes, obtained using risk models and international guidelines, with observed treatment outcomes in a Dutch cohort of patients with non-muscle-invasive bladder cancer treated with intravesical chemotherapy. BJU Int.
Lammers RJM, Witjes JA, Inman BA, et al. (2011). The role of a combined regimen with intravesical chemotherapy and hyperthermia in the management of non-muscle-invasive bladder cancer: a systematic review. Eur Urol.
Lammers RJM, Witjes WPJ, Hendricksen K, et al. (2011). Smoking status is a risk factor for recurrence after transurethral resection of non-muscle-invasive bladder cancer. Eur Urol.
Lamy A, Gobet F, Laurent M, et al. (2006). Molecular profiling of bladder tumors based on the detection of FGFR3 and TP53 mutations. J Urol.
Landman J, Chang Y, Kavaler E, et al. (1998). Sensitivity and specificity of NMP-22, telomerase, and BTA in the detection of human bladder cancer. Urology.
Landry JL, Gelet A, Bouvier R, et al. (2003). Detection of bladder dysplasia using 5-aminolaevulinic acid-induced porphyrin fluorescence. BJU Int.
Lapini A, Minervini A, Masala A, et al. (2012). A comparison of hexaminolevulinate (Hexvix()) fluorescence cystoscopy and white-light cystoscopy for detection of bladder cancer: results of the HeRo observational study. Surg Endosc.
Larré S, Catto JWF, Cookson MS, et al. (2013). Screening for bladder cancer: Rationale, limitations, whom to target, and perspectives. Eur Urol.
Laudadio J, Keane TE, Reeves HM, et al. (2005). Fluorescence in situ hybridization for detecting transitional cell carcinoma: implications for clinical practice. BJU Int.
Lee DH, Yang SC, Hong SJ, et al. (1998). Telomerase: a potential marker of bladder transitional cell carcinoma in bladder washes. Clin Cancer Res.
Lei T, Zhao X, Jin S, et al. (2013). Discovery of potential bladder cancer biomarkers by comparative urine proteomics and analysis. Clin Genitourin Cancer.
Lerner SP, Liu H, Wu M-F, et al. (2012). Fluorescence and white light cystoscopy for detection of carcinoma in situ of the urinary bladder. Urol.
Lerner SP, Skinner DG, Lieskovsky G, et al. (1993). The rationale for en bloc pelvic lymph node dissection for bladder cancer patients with nodal metastases: long-term results. J Urol.
Lerner SP, Tangen CM, Sucharew H, et al. (2009). Failure to achieve a complete response to induction BCG therapy is associated with increased risk of disease worsening and death in patients with high risk non-muscle invasive bladder cancer. Urol.
Li HX, Li M, Li CL, et al. (2010). ImmunoCyt and cytokeratin 20 immunocytochemistry as adjunct markers for urine cytologic detection of bladder cancer: a prospective study. Anal Quant Cytol Histol.
Li L-Y, Yang M, Zhang H-B, et al. (2008). Urinary fibronectin as a predictor of a residual tumour load after transurethral resection of bladder transitional cell carcinoma. BJU Int.
Li N-c, Ye Z-q, Na Y-q, et al. (2013). Efficacy of immediate instillation combined with regular instillations of pirarubicin for Ta and T1 transitional cell bladder cancer after transurethral resection: a prospective, randomized, multicenter study. Chin Med J.
Li Y-J, Zheng B-Z, Zhou Z-L. (2004). Ai Zheng.
Li Z, Qi F, Qi L, et al. (2011). VEGF-C as a decision-making biomarker for selected patients with invasive bladder cancer who underwent bladder-preserving radical surgery. Arch Med Res.
Librenjak D, Situm M, Eterovic D, et al. (2003). Immunoprophylactic intravesical application of bacillus Calmette-Guerin after transurethral resection of superficial bladder cancer. Croat Med J.
Librenjak D, Situm M, Vrdoljak E, et al. (2012). Results of long-term follow-up of patients with superficial bladder carcinoma treated with intravesically applied bacillus Calmette-Guerin vaccine according to the schedule of 6 weekly + 6 monthly instillations. Urol.
Liew MS, Azad A, Tafreshi A, et al. (2013). USANZ: Time-trends in use and impact on outcomes of perioperative chemotherapy in patients treated with radical cystectomy for urothelial bladder cancer. BJU Int.
Lin YL, Sun G, Liu XQ, et al. (2011). Clinical significance of CDH13 promoter methylation in serum samples from patients with bladder transitional cell carcinoma. J Int Med Res.
Lin Y-L, Liu X-Q, Li W-P, et al. (2012). Promoter methylation of H-cadherin is a potential biomarker in patients with bladder transitional cell carcinoma. Int Urol Nephrol.
Lipinski M, Jeromin L. (2002). Comparison of the bladder tumour antigen test with photodynamic diagnosis in patients with pathologically confirmed recurrent superficial urinary bladder tumours. BJU Int.
Liu B, Zhang Y, Wang Z, et al. (2002). Chung Hua Wai Ko Tsa Chih.
Loo RK, Lieberman SF, Slezak JM, et al. (2013). Stratifying risk of urinary tract malignant tumors in patients with asymptomatic microscopic hematuria. Mayo Clin Proc.
Lotan Y, Bensalah K, Ruddell T, et al. (2008). Prospective evaluation of the clinical usefulness of reflex fluorescence in situ hybridization assay in patients with atypical cytology for the detection of urothelial carcinoma of the bladder. J Urol.
Lotan Y, Elias K, Svatek RS, et al. (2009). Bladder cancer screening in a high risk asymptomatic population using a point of care urine based protein tumor marker. J Urol.
Lotan Y, Roehrborn CG. (2003). Sensitivity and specificity of commonly available bladder tumor markers versus cytology: results of a comprehensive literature review and meta-analyses. Urology.
Luciani LG, Neulander E, Murphy WM, et al. (2001). Risk of continued intravesical therapy and delayed cystectomy in BCG-refractory superficial bladder cancer: an investigational approach. Urology.
Lundbeck F, Mogensen P, Jeppesen N. (1983). Intravesical therapy of noninvasive bladder tumors (stage Ta) with doxorubicin and urokinase. J Urol.
Maekawa S, Suzuki H, Ohkubo K, et al. (2000). Hinyokika Kiyo.
Magrini S, Melone F, Chiavacci A, et al. (1992). Minerva Urol Nefrol.
Mahnert B, Tauber S, Kriegmair M, et al. (1999). BTA-TRAK--a useful diagnostic tool in urinary bladder cancer?. Anticancer Res.
Malmstrom P-U, Hedelin H, Thomas YK, et al. (2009). Fluorescence-guided transurethral resection of bladder cancer using hexaminolevulinate: analysis of health economic impact in Sweden. Scand J Urol Nephrol.
Malmstrom P-U, Sylvester RJ, Crawford DE, et al. (2009). An individual patient data meta-analysis of the long-term outcome of randomised studies comparing intravesical mitomycin C versus bacillus Calmette-Guerin for non-muscle-invasive bladder cancer. Eur Urol.
Mao Y, Zhao X, Wang S, et al. (2007). Urinary nucleosides based potential biomarker selection by support vector machine for bladder cancer recognition. Anal Chim Acta.
Marin-Aguilera M, Mengual L, Ribal MJ, et al. (2007). Utility of a multiprobe fluorescence in situ hybridization assay in the detection of superficial urothelial bladder cancer. Cancer Genet Cytogenet.
Martinez-Pineiro JA, Solsona E, Flores N, et al. (1995). Improving the safety of BCG immunotherapy by dose reduction. Cooperative Group CUETO. Eur Urol.
Matsuyama H, Baba Y, Shimabukuro T, et al. (2004). Novel prophylactic effect of doxifluridine in superficial bladder cancer. Scand J Urol Nephrol.
Melekos MD, Zarakovitis IE, Fokaefs ED, et al. (1996). Intravesical bacillus Calmette-Guerin versus epirubicin in the prophylaxis of recurrent and/or multiple superficial bladder tumours. Oncology (Williston).
Menendez V, Filella X, Alcover J, et al. (1995). Actas Urol Esp.
Mengual L, Marin-Aguilera M, Ribal MJ, et al. (2007). Clinical utility of fluorescent in situ hybridization for the surveillance of bladder cancer patients treated with bacillus Calmette-Guerin therapy. Eur Urol.
Messing E, Kim KM, Sharkey F, et al. (2006). Randomized prospective phase III trial of difluoromethylornithine vs placebo in preventing recurrence of completely resected low risk superficial bladder cancer. The Journal of urology.
Messing EM, Murphy-Brooks N. (1994). Recovery of epidermal growth factor in voided urine of patients with bladder cancer. Urology.
Mezzasoma L, Antognelli C, Del Buono C, et al. (2010). Expression and biological-clinical significance of hTR, hTERT and CKS2 in washing fluids of patients with bladder cancer. BMC Urol.
Mian C, Lodde M, Comploj E, et al. (2003). Liquid-based cytology as a tool for the performance of uCyt+ and Urovysion Multicolour-FISH in the detection of urothelial carcinoma. Cytopathology.
Mian C, Lodde M, Comploj E, et al. (2005). The value of the ImmunoCyt/uCyt+ test in the detection and follow-up of carcinoma in situ of the urinary bladder. Anticancer Res.
Mian C, Maier K, Comploj E, et al. (2006). uCyt+/ImmunoCyt in the detection of recurrent urothelial carcinoma: an update on 1991 analyses. Cancer.
Mian C, Mazzoleni G, Vikoler S, et al. (2010). Fluorescence in situ hybridisation in the diagnosis of upper urinary tract tumours. Eur Urol.
Migliari R, el Demiry M, Muscas G, et al. (1992). Intravesical instillation of beta-interferon in the treatment of bladder cancer. Br J Urol.
Migliari R, el-Demiry MI, Muscas G, et al. (1991). Arch Ital Urol Nefrol Androl.
Millikan R, Dinney C, Swanson D, et al. (2001). Integrated therapy for locally advanced bladder cancer: final report of a randomized trial of cystectomy plus adjuvant M-VAC versus cystectomy with both preoperative and postoperative M-VAC. J Clin Oncol.
Milowsky MI, Nanus DM, Maluf FC, et al. (2009). Final results of sequential doxorubicin plus gemcitabine and ifosfamide, paclitaxel, and cisplatin chemotherapy in patients with metastatic or locally advanced transitional cell carcinoma of the urothelium. J Clin Oncol.
Mitin T, Hunt D, Shipley WU, et al. (2013). Transurethral surgery and twice-daily radiation plus paclitaxel-cisplatin or fluorouracil-cisplatin with selective bladder preservation and adjuvant chemotherapy for patients with muscle invasive bladder cancer (RTOG 0233): a randomised multicentre phase 2 trial. Lancet Oncol.
Miyanaga N, Akaza H, Ishikawa S, et al. (1997). Clinical evaluation of nuclear matrix protein 22 (NMP22) in urine as a novel marker for urothelial cancer. Eur Urol.
Montanari E, de la Rosette J, Longo F, et al. (2012). Narrow-band imaging (NBI) and white light (WLI) transurethral resection of the bladder in the treatment of non-muscle-invasive bladder cancer. Arch Ital Urol Androl.
Monzo Gardiner JI, Herranz Amo F, Cabello Benavente R, et al. (2009). Arch Esp Urol.
Moonen PMJ, Kiemeney LALM, Witjes JA. (2005). Urinary NMP22 BladderChek test in the diagnosis of superficial bladder cancer. Eur Urol.
Moonen PMJ, Merkx GFM, Peelen P, et al. (2007). UroVysion compared with cytology and quantitative cytology in the surveillance of non-muscle-invasive bladder cancer. Eur Urol.
Mori Y, Arima M, Shimada K, et al. (1991). Hinyokika Kiyo.
Mowatt G, Zhu S, Kilonzo M, et al. (2013). Systematic review of the clinical effectiveness and cost-effectiveness of photodynamic diagnosis and urine biomarkers (FISH, ImmunoCyt, NMP22) and cytology for the detection and follow-up of bladder cancer (Structured abstract). Health Technology Assessment Database.
Moyer VA. (2011). Screening for bladder cancer: U.S. preventive services task force recommendation statement. Annals of Internal Medicine.
Mundy L, Hiller JE. (2013). NMP22 BladderChek Diagnostic test for bladder cancer: update (Structured abstract). Health Technology Assessment Database.
Muramaki M, Miyake H, Kurahashi T, et al. (2008). Prognostic significance of adjuvant cisplatin-based combination chemotherapy following radical cystectomy in patients with invasive bladder cancer. Int J Urol.
Murphy WM, Rivera-Ramirez I, Medina CA, et al. (1997). The bladder tumor antigen (BTA) test compared to voided urine cytology in the detection of bladder neoplasms. J Urol.
Muto S, Nakajima A, Horiuchi A, et al. (2013). Maintenance therapy with intravesical bacillus Calmette-Guerin in patients with intermediate- or high-risk non-muscle-invasive bladder cancer. Jpn J Clin Oncol.
Naselli A, Introini C, Bertolotto F, et al. (2010). Narrow band imaging for detecting residual/recurrent cancerous tissue during second transurethral resection of newly diagnosed non-muscle-invasive high-grade bladder cancer. BJU Int.
Nazeri N. (2014). Incidental sonographic detection of non-muscle-invasive papillary urothelial carcinoma in a low-risk patient. Journal of Diagnostic Medical Sonography.
Nechiporenko NA, Bushma TV. (1993). Vopr Onkol.
Nechiporenko NA, Zaborovskii GI, Bushma TV. (1992). Vopr Onkol.
Nisman B, Barak V, Shapiro A, et al. (2002). Evaluation of urine CYFRA 21-1 for the detection of primary and recurrent bladder carcinoma. Cancer.
Noguchi S, Takase K, Yoshida M, et al. (2005). Nippon Hinyokika Gakkai Zasshi.
Nogueira March JL. (2001). A Multicenter and randomised prospective study comparing three intravesical therapies, two with bacillus calmette-guerin immunotherapy and one with mitomycin-c chemotherapy in medium an dlow risk superficial bladder tumours. Eur Urol Suppl.
Novotny V, Hakenberg OW, Froehner M, et al. (2013). Systematic assessment of complications and outcome of radical cystectomy undertaken with curative intent in patients with comorbidity and over 75 years of age. Urol Int.
Novotny V, Hakenberg OW, Wiessner D, et al. (2007). Perioperative complications of radical cystectomy in a contemporary series. Eur Urol.
O'Donnell MA, Lilli K, Leopold C, et al. (2004). Interim results from a national multicenter phase II trial of combination bacillus Calmette-Guerin plus interferon alfa-2b for superficial bladder cancer. J Urol.
Ogawa H, Nishimura T, Hori N, et al. (1997). 10-year survival rate in 92 patients with invasive bladder carcinoma treated by bladder sparing methods. Nippon Ika Daigaku Zasshi.
Ojea Calvo A, Dominguez Freire F, Verez Vivero M, et al. (1996). Arch Esp Urol.
Okamura T, Akita H, Ando R, et al. (2012). Single monthly bacillus Calmette-Guerin intravesical instillation is effective maintenance therapy to prevent recurrence in Japanese patients with non-muscle-invasive bladder cancer. Int J Clin Oncol.
Ozono S, Sasaki K, Watanabe S, et al. (1991). Hinyokika Kiyo.
Paoluzzi M, Cuttano MG, Mugnaini P, et al. (1999). Urinary dosage of nuclear matrix protein 22 (NMP22) like biologic marker of transitional cell carcinoma (TCC): a study on patients with hematuria. Arch Ital Urol Androl.
Papatsoris AG, Deliveliotis C, Giannopoulos A, et al. (2004). Adjuvant intravesical mitoxantrone versus recombinant interferon-alpha after transurethral resection of superficial bladder cancer: a randomized prospective study. Urol Int.
Parrella A, Mundy L, Merlin T, et al. (2013). NMP22 BladderChek(TM) point-of-care diagnostic test for bladder cancer. Health Technology Assessment Database.
Patard J, Moudouni S, Saint F, et al. (2001). Tumor progression and survival in patients with T1G3 bladder tumors: multicentric retrospective study comparing 94 patients treated during 17 years. Urology.
Patard J-J, Rodriguez A, Leray E, et al. (2002). Intravesical Bacillus Calmette-Guerin treatment improves patient survival in T1G3 bladder tumours. Eur Urol.
Pawinski A, Sylvester R, Kurth KH, et al. (1996). A combined analysis of European Organization for Research and Treatment of Cancer, and Medical Research Council randomized clinical trials for the prophylactic treatment of stage TaT1 bladder cancer. European Organization for Research and Treatment of Cancer Genitourinary Tract Cancer Cooperative Group and the Medical Research Council Working Party on Superficial Bladder Cancer. J Urol.
Pegoraro C, Bondovalli C, Dall'Oglio B, et al. (1996). Arch Ital Urol Androl.
Perez Garcia FJ, Escaf Barmadah S, Fernandez Gomez JM, et al. (2000). Esp Urol.
Perez Garcia FJ, Eyo A, Escaf Barmadah S, et al. (2002). Arch Esp Urol.
Pesch B, Nasterlack M, Eberle F, et al. (2011). The role of haematuria in bladder cancer screening among men with former occupational exposure to aromatic amines. BJU Int.
Petrov SV, Malkhasyan KA, Ulyanin MY, et al. (2012). The value of the preoperative FISH test in unscreened bladder cancer patients with TUR indications. Pathol Oncol Res.
Peyromaure M, Zerbib M. (2004). T1G3 transitional cell carcinoma of the bladder: recurrence, progression and survival. BJU Int.
Pieras Ayala E, Palou J, Rodriguez-Villamil L, et al. (2001). Arch Esp Urol.
Pode D, Golijanin D, Sherman Y, et al. (1998). Immunostaining of Lewis X in cells from voided urine, cytopathology and ultrasound for noninvasive detection of bladder tumors. J Urol.
Portillo Martin JA, Martin Garcia B, Hernandez Rodriguez R, et al. (1995). Arch Esp Urol.
Pos FJ, Horenblas S, Lebesque J, et al. (2004). Low-dose-rate brachytherapy is superior to high-dose-rate brachytherapy for bladder cancer. Int J Radiat Oncol Biol Phys.
Poulakis V, Witzsch U, De Vries R, et al. (2001). A comparison of urinary nuclear matrix protein-22 and bladder tumour antigen tests with voided urinary cytology in detecting and following bladder cancer: the prognostic value of false-positive results. BJU Int.
Purins A, Hiller JE. (2013). Bladderchek: diagnostic test for bladder cancer (Structured abstract). Health Technology Assessment Database.
Pycha A, Lodde M, Comploj E, et al. (2004). Intermediate-risk urothelial carcinoma: an unresolved problem?. Urology.
Raitanen MP, Lukkarinen O. (1995). A controlled study of intravesical epirubicin with or without alpha 2b-interferon as prophylaxis for recurrent superficial transitional cell carcinoma of the bladder. Finnish Multicentre Study Group. Br J Urol.
Raitanen MP, Marttila T, Kaasinen E, et al. (2000). Sensitivity of human complement factor H related protein (BTA stat) test and voided urine cytology in the diagnosis of bladder cancer. J Urol.
Raj GV, Herr H, Serio AM, et al. (2007). Treatment paradigm shift may improve survival of patients with high risk superficial bladder cancer. J Urol.
Raj GV, Karavadia S, Schlomer B, et al. (2011). Contemporary use of perioperative cisplatin-based chemotherapy in patients with muscle-invasive bladder cancer. Cancer.
Ramakumar S, Bhuiyan J, Besse JA, et al. (1999). Comparison of screening methods in the detection of bladder cancer. J Urol.
Ray ER, Chatterton K, Khan MS, et al. (2009). Hexylaminolaevulinate ‘blue light’ fluorescence cystoscopy in the investigation of clinically unconfirmed positive urine cytology. BJU Int.
Ray ER, Chatterton K, Thomas K, et al. (2009). Hexylaminolevulinate photodynamic diagnosis for multifocal recurrent nonmuscle invasive bladder cancer. J Endourol.
Regueiro Lopez JC, Alvarez-Cienfuegos FR, Leva Vallejo M, et al. (1993). Actas Urol Esp.
Reid-Nicholson MD, Ramalingam P, Adeagbo B, et al. (2009). The use of Urovysion fluorescence in situ hybridization in the diagnosis and surveillance of non-urothelial carcinoma of the bladder. Mod Pathol.
Ricos Torrent JV, Monros Lliso JL, Iborra Juan I, et al. (1992). Arch Esp Urol.
Rieger-Christ KM, Mourtzinos A, Lee PJ, et al. (2003). Identification of fibroblast growth factor receptor 3 mutations in urine sediment DNA samples complements cytology in bladder tumor detection. Cancer.
Riesz P, Lotz G, Paska C, et al. (2007). Detection of bladder cancer from the urine using fluorescence in situ hybridization technique. Pathol Oncol Res.
Rink M, Babjuk M, Catto JWF, et al. (2013). Hexyl aminolevulinate-guided fluorescence cystoscopy in the diagnosis and follow-up of patients with non-muscle-invasive bladder cancer: a critical review of the current literature. Eur Urol.
Rink M, Zabor EC, Furberg H, et al. (2013). Impact of smoking and smoking cessation on outcomes in bladder cancer patients treated with radical cystectomy. Eur Urol.
Rodel C, Dunst J, Grabenbauer GG, et al. (2001). Radiotherapy is an effective treatment for high-risk T1-bladder cancer. Strahlenther Onkol.
Roobol MJ, Bangma CH, el Bouazzaoui S, et al. (2010). Feasibility study of screening for bladder cancer with urinary molecular markers (the BLU-P project). Urol Oncol.
Roosen JU, Geertsen U, Jahn H, et al. (1997). Invasive, high grade transitional cell carcinoma of the bladder treated with transurethral resection. A survival analysis focusing on TUR as monotherapy. Scand J Urol Nephrol.
Ru Y, Dancik GM, Theodorescu D. (2011). Biomarkers for prognosis and treatment selection in advanced bladder cancer patients. Curr Opin Urol.
Rubben H, Weissbach L, Knebel L, et al. (1990). Adjuvant systemic chemotherapy after complete transurethral resection of superficially invasive bladder carcinoma (T1 G3-4 and T2 G2-4). Urol Int.
Sabichi AL, Lerner SP, Atkinson EN, et al. (2008). Phase III prevention trial of fenretinide in patients with resected non-muscle-invasive bladder cancer. Clin Cancer Res.
Said MT, Abomelha MS, Orkubi SA. (2002). Intravesical immunotherapy for superficial bladder cancer. Saudi Med J.
Salman T, el-Ahmady O, el-Shafee M, et al. (1997). The clinical value of cathepsin-D and TNF-alpha in bladder cancer patients. Anticancer Res.
Samodai L, Kiss L, Kolozsy Z, et al. (1991). The efficacy of intravesical BCG in the treatment of patients with high risk superficial bladder cancer. Int Urol Nephrol.
Sanchez-Carbayo M, Espasa A, Chinchilla V, et al. (1999). New electrochemiluminescent immunoassay for the determination of CYFRA 21-1: analytical evaluation and clinical diagnostic performance in urine samples of patients with bladder cancer. Clin Chem.
Santos L, Costa C, Pereira S, et al. (2003). Neovascularisation is a prognostic factor of early recurrence in T1/G2 urothelial bladder tumours. Ann Oncol.
Sarosdy MF. (1997). A review of clinical studies of bropirimine immunotherapy of carcinoma in situ of the bladder and upper urinary tract. Eur Urol.
Sarosdy MF, deVere White RW, Soloway MS, et al. (1995). Results of a multicenter trial using the BTA test to monitor for and diagnose recurrent bladder cancer. J Urol.
Sarosdy MF, Hudson MA, Ellis WJ, et al. (1997). Improved detection of recurrent bladder cancer using the Bard BTA stat Test. Urology.
Sarosdy MF, Lowe BA, Schellhammer PF, et al. (1996). Oral bropirimine immunotherapy of carcinoma in situ of the bladder: results of a phase II trial. Urology.
Sarosdy MF, Manyak MJ, Sagalowsky AI, et al. (1998). Oral bropirimine immunotherapy of bladder carcinoma in situ after prior intravesical bacille Calmette-Guerin. Urology.
Schiffer E, Vlahou A, Petrolekas A, et al. (2009). Prediction of muscle-invasive bladder cancer using urinary proteomics. Clin Cancer Res.
Schlomer BJ, Ho R, Sagalowsky A, et al. (2010). Prospective validation of the clinical usefulness of reflex fluorescence in situ hybridization assay in patients with atypical cytology for the detection of urothelial carcinoma of the bladder. J Urol.
Schmitz-Drager BJ, Droller M, Lotan Y, et al. (2012). Molecular markes for bladder cancer screening, early diagnosis and surveillance. Soloway M, K S, editors. Bladder Cancer: 2nd International Consulation on Bladder Cancer.
Schulman CC, Rozencweig M, Staquet M, et al. (1976). EORTC randomized trial for the adjuvant therapy of T1 bladder carcinoma. Eur Urol.
Schulze M, Stotz N, Rassweiler J. (2007). Retrospective analysis of transurethral resection, second-look resection, and long-term chemo-metaphylaxis for superficial bladder cancer: indications and efficacy of a differentiated approach. J Endourol.
Schwaibold H, Klingenberger HJ, Huland H. (1994). Urologe A.
Seideman C, Canter D, Kim P, et al. (2014). Multicenter evaluation of the role of UroVysion FISH assay in surveillance of patients with bladder cancer: does FISH positivity anticipate recurrence?. World J Urol.
Selmy MA, Ibrahim GH, El Serafi TI, et al. (2010). Evaluation of urinary proepithelin as a potential biomarker for bladder cancer detection and prognosis in Egyptian patients. Cancer Biomark.
Selvaggi F. (1990). Acta Urol Ital.
Sengor F, Beysel M, Erdogan K, et al. (1996). Intravesical epirubicin in the prophylaxis of superficial bladder cancer. Int Urol Nephrol.
Senovilla Perez JL, Resel Estevez L, Moreno Sierra J, et al. (2000). Actas Urol Esp.
Serretta V, Altieri V, Morgia G, et al. (2013). Cigarette smoking status at diagnosis and recurrence in intermediate-risk non-muscle-invasive bladder carcinoma. Urology.
Serretta V, Vasile P, Falletta V, et al. (1998). Arch Ital Urol Androl.
Sexton WJ, Wiegand LR, Correa JJ, et al. (2010). Bladder cancer: a review of non-muscle invasive disease. Cancer Control.
Shahin O, Thalmann GN, Rentsch C, et al. (2003). A retrospective analysis of 153 patients treated with or without intravesical bacillus Calmette-Guerin for primary stage T1 grade 3 bladder cancer: recurrence, progression and survival. J Urol.
Shang PF, Kwong J, Wang ZP, et al. (2011). Intravesical Bacillus Calmette-Guerin versus epirubicin for Ta and T1 bladder cancer. Cochrane Database Syst Rev.
Shariat SF, Zippe C, Ludecke G, et al. (2005). Nomograms including nuclear matrix protein 22 for prediction of disease recurrence and progression in patients with Ta, T1 or CIS transitional cell carcinoma of the bladder. J Urol.
Sharp VJ, Barnes KT, Erickson BA. (2013). Assessment of asymptomatic microscopic hematuria in adults. Am Fam Physician.
Shelley M, Court JB, Kynaston H, et al. (2009). Intravesical Bacillus Calmette-Guerin versus mitomycin C for Ta and T1 bladder cancer. Cochrane Database Syst Rev.
Shelley M, Court JB, Kynaston H, et al. (2010). Intravesical Bacillus Calmette-Guerin in Ta and T1 bladder cancer. Cochrane Database Syst Rev.
Shelley MD, Kynaston H, Court J, et al. (2001). A systematic review of intravesical bacillus Calmette-Guerin plus transurethral resection vs transurethral resection alone in Ta and T1 bladder cancer. BJU Int.
Shelley MD, Mason MD, Kynaston H. (2010). Intravesical therapy for superficial bladder cancer: a systematic review of randomised trials and meta-analyses. Cancer Treat Rev.
Shelley MD, Wilt TJ, Court J, et al. (2004). Intravesical bacillus Calmette-Guerin is superior to mitomycin C in reducing tumour recurrence in high-risk superficial bladder cancer: a meta-analysis of randomized trials. BJU Int.
Sherif A, Holmberg L, Rintala E, et al. (2004). Neoadjuvant cisplatinum based combination chemotherapy in patients with invasive bladder cancer: a combined analysis of two Nordic studies. Eur Urol.
Shinka T, Hirano A, Uekado Y, et al. (1990). Nippon Hinyokika Gakkai Zasshi.
Siracusano S, Niccolini B, Knez R, et al. (2005). The simultaneous use of telomerase, cytokeratin 20 and CD4 for bladder cancer detection in urine. Eur Urol.
Skacel M, Fahmy M, Brainard JA, et al. (2003). Multitarget fluorescence in situ hybridization assay detects transitional cell carcinoma in the majority of patients with bladder cancer and atypical or negative urine cytology. J Urol.
Smaldone MC, Casella DP, Welchons DR, et al. (2010). Investigational therapies for non-muscle invasive bladder cancer. Expert Opin Investig Drugs.
Soloway MS, Briggman V, Carpinito GA, et al. (1996). Use of a new tumor marker, urinary NMP22, in the detection of occult or rapidly recurring transitional cell carcinoma of the urinary tract following surgical treatment. J Urol.
Solsona E, Iborra I, Ricos JV, et al. (1991). Carcinoma in situ associated with superficial bladder tumor. Eur Urol.
Solsona E, Iborra I, Ricos JV, et al. (1991). Recurrence of superficial bladder tumors in prostatic urethra. Eur Urol.
Somogyi L, Szanto A, Polyak L, et al. (1993). Orv Hetil.
Song J-w, Du L-l, Zhao X-w, et al. (2009). Chung Hua Chung Liu Tsa Chih.
Sonpavde G, Goldman BH, Speights VO, et al. (2009). Quality of pathologic response and surgery correlate with survival for patients with completely resected bladder cancer after neoadjuvant chemotherapy. Cancer.
Soukup V, Babjuk M, Bellmunt J, et al. (2012). Follow-up after surgical treatment of bladder cancer: a critical analysis of the literature. Eur Urol.
Soyuer I, Sofikerim M, Tokat F, et al. (2009). Which urine marker test provides more diagnostic value in conjunction with standard cytology- ImmunoCyt/uCyt+ or Cytokeratin 20 expression. Diagn Pathol.
Sozen S, Biri H, Sinik Z, et al. (1999). Comparison of the nuclear matrix protein 22 with voided urine cytology and BTA stat test in the diagnosis of transitional cell carcinoma of the bladder. Eur Urol.
Stadler WM, Lerner SP, Groshen S, et al. (2011). Phase III study of molecularly targeted adjuvant therapy in locally advanced urothelial cancer of the bladder based on p53 status. J Clin Oncol.
Stampfer DS, Carpinito GA, Rodriguez-Villanueva J, et al. (1998). Evaluation of NMP22 in the detection of transitional cell carcinoma of the bladder. J Urol.
Stankovic J, Dinic L, Pavlovic S. (2007). Vojnosanit Pregl.
Startsev V, Pouline I. (2005). Adjuvant therapy in different risk-groups of patients with superficial bladder cancer. Arch Ital Urol Androl.
Steiner G, Schoenberg MP, Linn JF, et al. (1997). Detection of bladder cancer recurrence by microsatellite analysis of urine. Nat Med.
Steiner H, Bergmeister M, Verdorfer I, et al. (2008). Early results of bladder-cancer screening in a high-risk population of heavy smokers. BJU Int.
Stejskal D, Fiala RR. (2006). Evaluation of serum and urine clusterin as a potential tumor marker for urinary bladder cancer. Neoplasma.
Stejskal D, Humenanska V, Hanulova Z, et al. (2006). Evaluation of urine N1,N12-Diacetylspermine as potential tumor marker for urinary bladder cancer. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub.
Sternberg IA, Keren Paz GE, Chen LY, et al. (2013). Role of immediate radical cystectomy in the treatment of patients with residual T1 bladder cancer on restaging transurethral resection. BJU Int.
Storm FK, Mahvi DM, Gilchrist KW. (1993). Hsp-27 has no diagnostic or prognostic significance in prostate or bladder cancers. Urology.
Su CK, Yang CR, Horng YY, et al. (2003). NMP22 in transitional cell carcinoma of the urinary bladder. J Chin Med Assoc.
Sumiyoshi Y, Yano M, Yokota K, et al. (1990). Gan To Kagaku Ryoho.
Svatek RS, Herman MP, Lotan Y, et al. (2006). Soluble Fas--a promising novel urinary marker for the detection of recurrent superficial bladder cancer. Cancer.
Svatek RS, Karam J, Karakiewicz PI, et al. (2008). Role of urinary cathepsin B and L in the detection of bladder urothelial cell carcinoma. J Urol.
Sylvester RJ. (2011). Bacillus Calmette-Guerin treatment of non-muscle invasive bladder cancer. Int J Urol.
Sylvester RJ, Brausi MA, Kirkels WJ, et al. (2011). Long-term efficacy results of EORTC genito-urinary group randomized phase 3 study 30911 comparing intravesical instillations of epirubicin, bacillus Calmette-Guerin, and bacillus Calmette-Guerin plus isoniazid in patients with intermediate- and high-risk stage Ta T1 urothelial carcinoma of the bladder. J Urol.
Sylvester RJ, Oosterlinck W, van der Meijden APM. (2004). A single immediate postoperative instillation of chemotherapy decreases the risk of recurrence in patients with stage Ta T1 bladder cancer: a meta-analysis of published results of randomized clinical trials. J Urol.
Sylvester RJ, van der Meijden APM, Lamm DL. (2002). Intravesical bacillus Calmette-Guerin reduces the risk of progression in patients with superficial bladder cancer: a meta-analysis of the published results of randomized clinical trials. J Urol.
Sylvester RJ, van der Meijden APM, Witjes JA, et al. (2005). Bacillus calmette-guerin versus chemotherapy for the intravesical treatment of patients with carcinoma in situ of the bladder: a meta-analysis of the published results of randomized clinical trials. J Urol.
Szarvas T. (2009). Magy Onkol.
Tadin T, Krpina K, Stifter S, et al. (2012). Lower cyclooxygenase-2 expression is associated with recurrence of solitary non-muscle invasive bladder carcinoma. Diagn Pathol.
Takashi M, Schenck U, Kissel K, et al. (1999). Use of diagnostic categories in urinary cytology in comparison with the bladder tumour antigen (BTA) test in bladder cancer patients. Int Urol Nephrol.
Takashi M, Wakai K, Ohno Y, et al. (1995). Evaluation of a low-dose intravesical bacillus Calmette-Guerin (Tokyo strain) therapy for superficial bladder cancer. Int Urol Nephrol.
Tan L-B, Chen K-T, Yuan Y-C, et al. (2010). Identification of urine PLK2 as a marker of bladder tumors by proteomic analysis. World J Urol.
Tanaka T, Miyazawa K, Tsukamoto T, et al. (2011). Pathobiology and chemoprevention of bladder cancer. Journal of Oncology.
Tauber S, Brunken C, Vierbuchen M. (2011). Urologe A.
Telu KH, Abbaoui B, Thomas-Ahner JM, et al. (2013). Alterations of histone H1 phosphorylation during bladder carcinogenesis. J Proteome Res.
Terrell JD, Elias KJ, Sagalowsky AI, et al. (2011). Patients with a negative cystoscopy and negative Nmp22 Bladderchek test are at low risk of missed transitional cell carcinoma of the bladder: a prospective evaluation. Int Braz J Urol.
Theodoropoulos VE, Lazaris AC, Sofras F, et al. (2004). Hypoxia-inducible factor 1 alpha expression correlates with angiogenesis and unfavorable prognosis in bladder cancer. Eur Urol.
Tizzani A, Casetta G, Cavallini A, et al. (1990). Minerva Urol Nefrol.
Todenhofer T, Hennenlotter J, Aufderklamm S, et al. (2013). Individual risk assessment in bladder cancer patients based on a multi-marker panel. J Cancer Res Clin Oncol.
Togashi M, Shinohara N, Toyota K, et al. (1992). Prophylactic chemotherapy for primary and recurrent superficial bladder cancer: preliminary results. The Hokkaido University Bladder Cancer Collaborating Group. Cancer Chemother Pharmacol.
Tomlinson DC, Hurst CD, Knowles MA. (2007). Knockdown by shRNA identifies S249C mutant FGFR3 as a potential therapeutic target in bladder cancer. Oncogene.
Tong M, Yu L-z, Ding Y, et al. (2003). Chung Hua I Hsueh Tsa Chih.
Tozawa K, Okamura T, Sasaki S, et al. (2001). Intravesical combined chemoimmunotherapy with epirubicin and bacillus Calmette-Guerin is not indicated for superficial bladder cancer. Urol Int.
Tsui KH, Chen SM, Wang TM, et al. (2007). Comparisons of voided urine cytology, nuclear matrix protein-22 and bladder tumor associated antigen tests for bladder cancer of geriatric male patients in Taiwan, China. Asian J Androl.
Tsui K-H, Tang P, Lin C-Y, et al. (2010). Bikunin loss in urine as useful marker for bladder carcinoma. J Urol.
Tsukamoto M, Matsuyama H, Oba K, et al. (2002). Numerical aberrations of chromosome 9 in bladder cancer. A possible prognostic marker for early tumor recurrence. Cancer Genet Cytogenet.
Tsushima T, Ohmori H, Ohi Y, et al. (1994). Intravesical instillation chemotherapy of adriamycin with or without verapamil for the treatment of superficial bladder cancer: the final results of a collaborative randomized trial. Cancer Chemother Pharmacol.
Ueda Y, Kawaguchi R, Takiuchi H, et al. (2009). Hinyokika Kiyo.
Urquidi V, Goodison S, Cai Y, et al. (2012). A candidate molecular biomarker panel for the detection of bladder cancer. Cancer Epidemiol Biomarkers Prev.
Urquidi V, Goodison S, Ross S, et al. (2012). Diagnostic potential of urinary alpha1-antitrypsin and apolipoprotein E in the detection of bladder cancer. J Urol.
Urquidi V, Kim J, Chang M, et al. (2012). CCL18 in a multiplex urine-based assay for the detection of bladder cancer. PLoS ONE.
van der Steen-Banasik E, Ploeg M, Witjes JA, et al. (2009). Brachytherapy versus cystectomy in solitary bladder cancer: a case control, multicentre, East-Netherlands study. Radiother Oncol.
van Helsdingen PJ, Rikken CH, Sleeboom HP, et al. (1988). Mitomycin C resorption following repeated intravesical instillations using different instillation times. Urol Int.
van Rhijn BW, van der Poel HG, Boon ME, et al. (2000). Presence of carcinoma in situ and high 2C-deviation index are the best predictors of invasive transitional cell carcinoma of the bladder in patients with high-risk Quanticyt. Urology.
van Rhijn BW, van der Poel HG, van der Kwast TH. (2005). Urine markers for bladder cancer surveillance: a systematic review. Eur Urol.
van Rhijn BWG, Burger M, Lotan Y, et al. (2009). Recurrence and progression of disease in non-muscle-invasive bladder cancer: from epidemiology to treatment strategy. Eur Urol.
Veeramachaneni R, Nordberg ML, Shi R, et al. (2003). Evaluation of fluorescence in situ hybridization as an ancillary tool to urine cytology in diagnosing urothelial carcinoma. Diagn Cytopathol.
Vinci S, Giannarini G, Selli C, et al. (2011). Quantitative methylation analysis of BCL2, hTERT, and DAPK promoters in urine sediment for the detection of non-muscle-invasive urothelial carcinoma of the bladder: a prospective, two-center validation study. Urol.
Volpe A, Racioppi M, D'Agostino D, et al. (2010). Mitomycin C for the treatment of bladder cancer. Minerva Urol Nefrol.
von der Maase H, Hansen SW, Roberts JT, et al. (2000). Gemcitabine and cisplatin versus methotrexate, vinblastine, doxorubicin, and cisplatin in advanced or metastatic bladder cancer: results of a large, randomized, multinational, multicenter, phase III study. J Clin Oncol.
von der Maase H, Sengelov L, Roberts JT, et al. (2005). Long-term survival results of a randomized trial comparing gemcitabine plus cisplatin, with methotrexate, vinblastine, doxorubicin, plus cisplatin in patients with bladder cancer. J Clin Oncol.
Wang H, Albadine R, Magheli A, et al. (2012). Increased EZH2 protein expression is associated with invasive urothelial carcinoma of the bladder. Urol.
Ward E, Halperin W, Thun M, et al. (1990). Screening workers exposed to 4,4′-methylenebis(2-chloroaniline) for bladder cancer by cystoscopy. J Occup Med.
Weikert S, Christoph F, Schrader M, et al. (2005). Quantitative analysis of survivin mRNA expression in urine and tumor tissue of bladder cancer patients and its potential relevance for disease detection and prognosis. Int J Cancer.
Weikert S, Krause H, Wolff I, et al. (2005). Quantitative evaluation of telomerase subunits in urine as biomarkers for noninvasive detection of bladder cancer. Int J Cancer.
Weiss C, Ott OJ, Wittlinger M, et al. (2008). Treatment options for high-risk T1 bladder cancer: status quo and future perspectives of radiochemotherapy. Strahlenther Onkol.
Weiss C, von Romer F, Capalbo G, et al. (2009). Survivin expression as a predictive marker for local control in patients with high-risk T1 bladder cancer treated with transurethral resection and radiochemotherapy. Int J Radiat Oncol Biol Phys.
Weiss C, Wolze C, Engehausen DG, et al. (2006). Radiochemotherapy after transurethral resection for high-risk T1 bladder cancer: an alternative to intravesical therapy or early cystectomy?. J Clin Oncol.
Weizer AZ, Tallman C, Montgomery JS. (2011). Long-term outcomes of intravesical therapy for non-muscle invasive bladder cancer. World J Urol.
Whitson J, Berry A, Carroll P, et al. (2009). A multicolour fluorescence in situ hybridization test predicts recurrence in patients with high-risk superficial bladder tumours undergoing intravesical therapy. BJU Int.
Wiklund ED, Bramsen JB, Hulf T, et al. (2011). Coordinated epigenetic repression of the miR-200 family and miR-205 in invasive bladder cancer. Int J Cancer.
Williams SK, Hoenig DM, Ghavamian R, et al. (2010). Intravesical therapy for bladder cancer. Expert Opin Pharmacother.
Witjes JA, Gomella LG, Stenzl A, et al. (2014). Safety of hexaminolevulinate for blue light cystoscopy in bladder cancer. A combined analysis of the trials used for registration and postmarketing data. Urology.
Witjes JA, Hendricksen K. (2008). Intravesical pharmacotherapy for non-muscle-invasive bladder cancer: a critical analysis of currently available drugs, treatment schedules, and long-term results. Eur Urol.
Witjes JA, Kolli PS. (2008). Apaziquone for non-muscle invasive bladder cancer: a critical review. Expert Opin Investig Drugs.
Witjes JA, Moonen PMJ, van der Heijden AG. (2006). Review pathology in a diagnostic bladder cancer trial: effect of patient risk category. Urology.
Witjes WP, Konig M, Boeminghaus FP, et al. (1999). Results of a European comparative randomized study comparing oral bropirimine versus intravesical BCG treatment in BCG-naive patients with carcinoma in situ of the urinary bladder. European Bropirimine Study Group. Eur Urol.
Woodman AC, Goodison S, Drake M, et al. (2000). Noninvasive diagnosis of bladder carcinoma by enzyme-linked immunosorbent assay detection of CD44 isoforms in exfoliated urothelia. Clin Cancer Res.
Woolcott CG, Kolonel LN. (2012). Regarding measures of impact: Diabetes and urothelial cancer. Cancer Epidemiology.
Wright JL, Lin DW, Porter MP. (2008). The association between extent of lymphadenectomy and survival among patients with lymph node metastases undergoing radical cystectomy. Cancer.
Wu WJ, Liu LT, Huang CH, et al. (2001). Telomerase activity in human bladder tumors and bladder washing specimens. Kaohsiung J Med Sci.
Xi RC, Sheng YR, Chen WH, et al. (2013). Expression of survivin and livin predicts early recurrence in non-muscle invasive bladder cancer. J Surg Oncol.
Xia G, Kumar SR, Hawes D, et al. (2006). Expression and significance of vascular endothelial growth factor receptor 2 in bladder cancer. J Urol.
Yalcinkaya F, Kamis L, Ozteke O, et al. (1998). Prospective randomized comparison of intravesical BCG therapy with standard dose versus low doses in superficial bladder cancer. Int Urol Nephrol.
Yamamoto T, Hagiwara M, Nakazono M, et al. (1990). Nihon Hinyokika Gakkai zasshi.
Yamashita T, Okada N, Ogawa A. (1993). Nippon Hinyokika Gakkai Zasshi.
Yang SC, Lee DH, Hong SJ, et al. (1997). Telomerase activity: a potential marker of bladder transitional cell carcinoma in bladder washes. Yonsei Med J.
Yates DR, Brausi MA, Catto JWF, et al. (2012). Treatment options available for bacillus Calmette-Guerin failure in non-muscle-invasive bladder cancer. Eur Urol.
Yin W, Chen N, Zhang Y, et al. (2006). Survivin nuclear labeling index: a superior biomarker in superficial urothelial carcinoma of human urinary bladder. Mod Pathol.
Yoder BJ, Skacel M, Hedgepeth R, et al. (2007). Reflex UroVysion testing of bladder cancer surveillance patients with equivocal or negative urine cytology: a prospective study with focus on the natural history of anticipatory positive findings. Am J Clin Pathol.
Yogi S, Ikeuchi T, Yoshikawa H, et al. (1991). Hinyokika Kiyo.
Yoneyama T, Ohyama C, Imai A, et al. (2008). Low-dose instillation therapy with bacille Calmette-Guerin Tokyo 172 strain after transurethral resection: historical cohort study. Urology.
Youssef RF, Schlomer BJ, Ho R, et al. (2012). Role of fluorescence in situ hybridization in bladder cancer surveillance of patients with negative cytology. Urol Oncol.
Zaak D, Hungerhuber E, Schneede P, et al. (2002). Role of 5-aminolevulinic acid in the detection of urothelial premalignant lesions. Cancer.
Zachos I, Konstantinopoulos PA, Vandoros GP, et al. (2009). Predictive value of telomerase reverse transcriptase expression in patients with high risk superficial bladder cancer treated with adjuvant BCG immunotherapy. J Cancer Res Clin Oncol.
Zancan M, Franceschini R, Mimmo C, et al. (2005). Free DNA in urine: a new marker for bladder cancer? Preliminary data. Int J Biol Markers.
Zhang J, Zeng L, Li G-z, et al. (2003). Chung Hua Chung Liu Tsa Chih.
Zhao J, He D, He H, et al. (2007). Primary application study in early diagnosis of bladder cancer by survivin molecular beacons. Urology.
Zhao J, Wang Z-Q, Wang X-Y, et al. (2010). Preliminary study of diagnostic utility of molecular beacons in bladder cancer. Urology.
Zhao L, Wang Y, Qu N, et al. (2012). Significance of plasma osteopontin levels in patients with bladder urothelial carcinomas. Mol Diagn Ther.
Zhau HY, Babaian RJ, Hong SJ. (1990). A new 180 kDa. urine protein marker associated with bladder cancer. J Urol.
Zhu S, Tang Y, Li K, et al. (2013). Optimal schedule of bacillus calmette-guerin for non-muscle-invasive bladder cancer: a meta-analysis of comparative studies. BMC Cancer.
Zieger K, Jensen KM-E. (2011). Long-term risk of progression of carcinoma in situ of the bladder and impact of bacille Calmette-Guerin immunotherapy on the outcome. Scand J Urol Nephrol.
Zlotta AR, Roumeguere T, Kuk C, et al. (2011). Select screening in a specific high-risk population of patients suggests a stage migration toward detection of non-muscle-invasive bladder cancer. Eur Urol.