# Appendix C Included Studies

Please refer to this section as a reference list for Appendixes E and F.

Abrams PH, Choa RG, Gaches CG, et al. (1981). A controlled trial of single dose intravesical adriamycin in superficial bladder tumours. Br J Urol.
Addeo R, Caraglia M, Bellini S, et al. (2010). Randomized phase III trial on gemcitabine versus mytomicin in recurrent superficial bladder cancer: evaluation of efficacy and tolerance. J Clin Oncol.
Akaza H, Isaka S, Koiso K, et al. (1987). Comparative analysis of short-term and long-term prophylactic intravesical chemotherapy of superficial bladder cancer. Prospective, randomized, controlled studies of the Japanese Urological Cancer Research Group. Cancer Chemother Pharmacol.
Akaza H, Koiso K, Kotake T, et al. (1992). Long-term results of intravesical chemoprophylaxis of superficial bladder cancer: experience of the Japanese Urological Cancer Research Group for Adriamycin. Cancer Chemother Pharmacol.
Ali-el-Dein B, el-Baz M, Aly AN, et al. (1997). Intravesical epirubicin versus doxorubicin for superficial bladder tumors (stages pTa and pT1): a randomized prospective study. J Urol.
Ali-el-Dein B, Nabeeh A, el-Baz M, et al. (1997). Single-dose versus multiple instillations of epirubicin as prophylaxis for recurrence after transurethral resection of pTa and pT1 transitional-cell bladder tumours: a prospective, randomized controlled study. Br J Urol.
Ali-El-Dein B, Nabeeh A, Ismail EH, et al. (1999). Sequential bacillus Calmette-Guerin and epirubicin versus bacillus Calmette-Guerin alone for superficial bladder tumors: a randomized prospective study. J Urol.
Au JL, Badalament RA, Wientjes MG, et al. (2001). Methods to improve efficacy of intravesical mitomycin C: results of a randomized phase III trial. J Natl Cancer Inst.
Babjuk M, Soukup V, Petrik R, et al. (2005). 5-aminolaevulinic acid-induced fluorescence cystoscopy during transurethral resection reduces the risk of recurrence in stage Ta/T1 bladder cancer. BJU Int.
Badalament RA, Herr HW, Wong GY, et al. (1987). A prospective randomized trial of maintenance versus nonmaintenance intravesical bacillus Calmette-Guerin therapy of superficial bladder cancer. J Clin Oncol.
Bassi P. (1992). Dose Response of Bacillus Calmette-Guerin (BCG) in superficial bladder cancer: a phase III randomized tial low-dose vs standard-dose BCG regimen. J Urol.
Berrum-Svennung I, Granfors T, Jahnson S, et al. (2008). A single instillation of epirubicin after transurethral resection of bladder tumors prevents only small recurrences. J Urol.
Bilen CY, Ozen H, Aki FT, et al. (2000). Clinical experience with BCG alone versus BCG plus epirubicin. Int J Urol.
Boccardo F, Cannata D, Rubagotti A, et al. (1994). Prophylaxis of superficial bladder cancer with mitomycin or interferon alfa-2b: results of a multicentric Italian study. J Clin Oncol.
Bohle A, Leyh H, Frei C, et al. (2009). Single postoperative instillation of gemcitabine in patients with non-muscle-invasive transitional cell carcinoma of the bladder: a randomised, double-blind, placebo-controlled phase III multicentre study. Eur Urol.
Bouffioux C, Kurth KH, Bono A, et al. (1995). Intravesical adjuvant chemotherapy for superficial transitional cell bladder carcinoma: results of 2 European Organization for Research and Treatment of Cancer randomized trials with mitomycin C and doxorubicin comparing early versus delayed instillations and short-term versus long-term treatment. European Organization for Research and Treatment of Cancer Genitourinary Group. J Urol.
Brausi M, Oddens J, Sylvester R, et al. (2014). Side effects of Bacillus Calmette-Guerin (BCG) in the treatment of intermediate- and high-risk Ta, T1 papillary carcinoma of the bladder: results of the EORTC genito-urinary cancers group randomised phase 3 study comparing one-third dose with full dose and 1 year with 3 years of maintenance BCG. Eur Urol.
Brosman SA. (1982). Experience with bacillus Calmette-Guerin in patients with superficial bladder carcinoma. J Urol.
Burger M, Stief C, Zaak D, et al. (2008). Does photodynamic TURB improve outcome of intitial T1 high grader bladder cancer? Long-term follow-up of a randomised study. European Urology Supplements.
Burnand KG, Boyd PJ, Mayo ME, et al. (1976). Single dose intravesical thiotepa as an adjuvant to cystodiathermy in the treatment of transitional cell bladder carcinoma. Br J Urol.
Cai T, Nesi G, Tinacci G, et al. (2008). Can early single dose instillation of epirubicin improve bacillus Calmette-Guerin efficacy in patients with nonmuscle invasive high risk bladder cancer? Results from a prospective, randomized, double-blind controlled study. J Urol.
Cha EK, Tirsar LA, Schwentner C, et al. (2012). Immunocytology is a strong predictor of bladder cancer presence in patients with painless hematuria: a multicentre study. Eur Urol.
Chahal R, Darshane A, Browning AJ, et al. (2001). Evaluation of the clinical value of urinary NMP22 as a marker in the screening and surveillance of transitional cell carcinoma of the urinary bladder. Eur Urol.
Cheng CW, Chan PS, Chan LW, et al. (2005). 17-year follow-up of a randomized prospective controlled trial of adjuvant intravesical doxorubicin in the treatment of superficial bladder cancer. Int Braz J Urol.
Cheng CW, Chan SFP, Chan LW, et al. (2005). Twelve-year follow up of a randomized prospective trial comparing bacillus Calmette-Guerin and epirubicin as adjuvant therapy in superficial bladder cancer. Int J Urol.
Cho DY, Bae JH, Moon DG, et al. (2009). The effects of intravesical chemoimmunotherapy with gemcitabine and Bacillus Calmette-Guerin in superficial bladder cancer: a preliminary study. J Int Med Res.
Colombo R, Rocchini L, Suardi N, et al. (2012). Neoadjuvant short-term intensive intravesical mitomycin C regimen compared with weekly schedule for low-grade recurrent non-muscle-invasive bladder cancer: preliminary results of a randomised phase 2 study. Eur Urol.
Cookson MS, Herr HW, Zhang ZF, et al. (1997). The treated natural history of high risk superficial bladder cancer: 15-year outcome. J Urol.
Daniltchenko DI, Riedl CR, Sachs MD, et al. (2005). Long-term benefit of 5-aminolevulinic acid fluorescence assisted transurethral resection of superficial bladder cancer: 5-year results of a prospective randomized study. J Urol.
De Nunzio C, Carbone A, Albisinni S, et al. (2011). Long-term experience with early single mitomycin C instillations in patients with low-risk non-muscle-invasive bladder cancer: prospective, single-centre randomised trial. World J Urol.
de Reijke TM, Kurth KH, Sylvester RJ, et al. (2005). Bacillus Calmette-Guerin versus epirubicin for primary, secondary or concurrent carcinoma in situ of the bladder: results of a European Organization for the Research and Treatment of Cancer--Genito-Urinary Group Phase III Trial (30906). J Urol.
DeBruyne FM, van der Meijden AP, Geboers AD, et al. (1988). BCG (RIVM) versus mitomycin intravesical therapy in superficial bladder cancer. First results of randomized prospective trial. Urology.
DeBruyne FMJ, van der Meijden PM, Witjes JA, et al. (1992). Bacillus Calmette-Guérin versus mitomycin intravesical therapy in superficial bladder cancer: Results of randomized trial after 21 months of follow-up. Urology.
Denzinger S, Burger M, Walter B, et al. (2007). Clinically relevant reduction in risk of recurrence of superficial bladder cancer using 5-aminolevulinic acid-induced fluorescence diagnosis: 8-year results of prospective randomized study. Urology.
Denzinger S, Wieland WF, Otto W, et al. (2007). Does photodynamic transurethral resection of bladder tumour improve the outcome of initial T1 high-grade bladder cancer? A long-term follow-up of a randomized study. BJU Int.
Di Lorenzo G, Perdona S, Damiano R, et al. (2010). Gemcitabine versus bacille Calmette-Guerin after initial bacille Calmette-Guerin failure in non-muscle-invasive bladder cancer: a multicenter prospective randomized trial. Cancer.
Di Stasi SM, Giannantoni A, Stephen RL, et al. (2003). Intravesical electromotive mitomycin C versus passive transport mitomycin C for high risk superficial bladder cancer: a prospective randomized study. J Urol.
Dragoescu O, Tomescu P, Panus A, et al. (2011). Photodynamic diagnosis of non-muscle invasive bladder cancer using hexaminolevulinic acid. Rom J Morphol Embryol.
Duchek M, Johansson R, Jahnson S, et al. (2010). Bacillus Calmette-Guerin is superior to a combination of epirubicin and interferon-alpha2b in the intravesical treatment of patients with stage T1 urinary bladder cancer. A prospective, randomized, Nordic study. Eur Urol.
Ersoy H, Yaytokgil M, Karakoyunlu AN, et al. (2013). Single early instillation of mitomycin C and urinary alkalinization in low-risk non-muscle-invasive bladder cancer: a preliminary study. Drug Des Devel Ther.
Eto H, Oka Y, Ueno K, et al. (1994). Comparison of the prophylactic usefulness of epirubicin and doxorubicin in the treatment of superficial bladder cancer by intravesical instillation: a multicenter randomized trial. Kobe University Urological Oncology Group. Cancer Chemother Pharmacol.
Feil G, Zumbragel A, Paulgen-Nelde HJ, et al. (2003). Accuracy of the ImmunoCyt assay in the diagnosis of transitional cell carcinoma of the urinary bladder. Anticancer Res.
Fellows GJ, Parmar MK, Grigor KM, et al. (1994). Marker tumour response to Evans and Pasteur bacille Calmette-Guerin in multiple recurrent pTa/pT1 bladder tumours: report from the Medical Research Council Subgroup on Superficial Bladder Cancer (Urological Cancer Working Party). Br J Urol.
Filbeck T, Pichlmeier U, Knuechel R, et al. (2002). Clinically relevant improvement of recurrence-free survival with 5-aminolevulinic acid induced fluorescence diagnosis in patients with superficial bladder tumors. J Urol.
Flamm J. (1990). Long-term versus short-term doxorubicin hydrochloride instillation after transurethral resection of superficial bladder cancer. Eur Urol.
Flanigan RC, Ellison MF, Butler KM, et al. (1986). A trial of prophylactic thiotepa or mitomycin C intravesical therapy in patients with recurrent or multiple superficial bladder cancers. J Urol.
Friedrich MG, Hellstern A, Hautmann SH, et al. (2002). Clinical use of urinary markers for the detection and prognosis of bladder carcinoma: a comparison of immunocytology with monoclonal antibodies against Lewis X and 486p3/12 with the BTA STAT and NMP22 tests. J Urol.
Friedrich MG, Pichlmeier U, Schwaibold H, et al. (2007). Long-term intravesical adjuvant chemotherapy further reduces recurrence rate compared with short-term intravesical chemotherapy and short-term therapy with Bacillus Calmette-Guerin (BCG) in patients with non-muscle-invasive bladder carcinoma. Eur Urol.
Fukui I, Kihara K, Sekine H, et al. (1992). Intravesical combination chemotherapy with mitomycin C and doxorubicin for superficial bladder cancer: a randomized trial of maintenance versus no maintenance following a complete response. Cancer Chemother Pharmacol.
Gardmark T, Jahnson S, Wahlquist R, et al. (2007). Analysis of progression and survival after 10 years of a randomized prospective study comparing mitomycin-C and bacillus Calmette-Guerin in patients with high-risk bladder cancer. BJU Int.
Geavlete B, Jecu M, Multescu R, et al. (2010). HAL blue-light cystoscopy in high-risk nonmuscle-invasive bladder cancer--re-TURBT recurrence rates in a prospective, randomized study. Urology.
Geavlete B, Multescu R, Georgescu D, et al. (2011). Treatment changes and long-term recurrence rates after hexaminolevulinate (HAL) fluorescence cystoscopy: does it really make a difference in patients with non-muscle-invasive bladder cancer (NMIBC)?. BJU Int.
Giannakopoulos S, Gekas A, Alivizatos G, et al. (1998). Efficacy of escalating doses of intravesical interferon alpha-2b in reducing recurrence rate and progression in superficial transitional cell carcinoma. Br J Urol.
Giannopoulos A, Constantinides C, Fokaeas E, et al. (2003). The immunomodulating effect of interferon-gamma intravesical instillations in preventing bladder cancer recurrence. Clin Cancer Res.
Giannopoulos A, Manousakas T, Gounari A, et al. (2001). Comparative evaluation of the diagnostic performance of the BTA stat test, NMP22 and urinary bladder cancer antigen for primary and recurrent bladder tumors. J Urol.
Gibanel R, Ribal MJ, Filella X, et al. (2002). BTA TRAK urine test increases the efficacy of cytology in the diagnosis of low-grade transitional cell carcinoma of the bladder. Anticancer Res.
Glashan RW. (1990). A randomized controlled study of intravesical alpha-2b-interferon in carcinoma in situ of the bladder. J Urol.
Gontero P, Oderda M, Mehnert A, et al. (2013). The impact of intravesical gemcitabine and 1/3 dose Bacillus Calmette-Guerin instillation therapy on the quality of life in patients with nonmuscle invasive bladder cancer: results of a prospective, randomized, phase II trial. J Urol.
Grossman HB, Messing E, Soloway M, et al. (2005). Detection of bladder cancer using a point-of-care proteomic assay. Jama.
Grossman HB, Soloway M, Messing E, et al. (2006). Surveillance for recurrent bladder cancer using a point-of-care proteomic assay. Jama.
Grossman HB, Stenzl A, Fradet Y, et al. (2012). Long-term decrease in bladder cancer recurrence with hexaminolevulinate enabled fluorescence cystoscopy. J Urol.
Gruenwald IE, Stein A, Rashcovitsky R, et al. (1997). A 12 versus 6-week course of bacillus Calmette-Guerin prophylaxis for the treatment of high risk superficial bladder cancer. J Urol.
Gudjonsson S, Adell L, Merdasa F, et al. (2009). Should all patients with non-muscle-invasive bladder cancer receive early intravesical chemotherapy after transurethral resection? The results of a prospective randomised multicentre study. Eur Urol.
Gudjonsson S, Isfoss BL, Hansson K, et al. (2008). The value of the UroVysion assay for surveillance of non-muscle-invasive bladder cancer. Eur Urol.
Gulpinar O, Halilioglu AH, Gokce MI, et al. (2012). The value of perioperative mitomycin C instillation in improving subsequent bacillus calmette-guerin instillation efficacy in intermediate and high-risk patients with non-muscle invasive bladder cancer: a prospective randomized study. Int Braz J Urol.
Gupta NP, Sharma N, Kumar R. (2009). Nuclear matrix protein 22 as adjunct to urine cytology and cystoscopy in follow-up of superficial TCC of urinary bladder. Urology.
Gustafson H, Wijkstrom H, Nyman C, et al. (1991). Prophylactic instillation therapy of superficial bladder cancer. A randomized study comparing mitomycin C and adriamycin with special reference to DNA ploidy. Scand J Urol Nephrol Suppl.
Gutierrez Banos JL, Rebollo Rodrigo MH, Antolin Juarez FM, et al. (2001). NMP 22, BTA stat test and cytology in the diagnosis of bladder cancer: a comparative study. Urol Int.
Halling KC, King W, Sokolova IA, et al. (2002). A comparison of BTA stat, hemoglobin dipstick, telomerase and Vysis UroVysion assays for the detection of urothelial carcinoma in urine. J Urol.
Halling KC, King W, Sokolova IA, et al. (2000). A comparison of cytology and fluorescence in situ hybridization for the detection of urothelial carcinoma. J Urol.
Harland SJ, Kynaston H, Grigor K, et al. (2007). A randomized trial of radical radiotherapy for the management of pT1G3 NXM0 transitional cell carcinoma of the bladder. J Urol.
Hemdan T, Johansson R, Jahnson S, et al. (2014). 5-Year outcome of a randomized prospective study comparing bacillus Calmette-Guerin with epirubicin and interferon-alpha2b in patients with T1 bladder cancer. J Urol.
Hendricksen K, Witjes WPJ, Idema JG, et al. (2008). Comparison of three schedules of intravesical epirubicin in patients with non-muscle-invasive bladder cancer. Eur Urol.
Hermann GG, Mogensen K, Carlsson S, et al. (2011). Fluorescence-guided transurethral resection of bladder tumours reduces bladder tumour recurrence due to less residual tumour tissue in Ta/T1 patients: a randomized two-centre study. BJU Int.
Herr HW. (1997). Tumour progression and survival in patients with T1G3 bladder tumours: 15-year outcome. Br J Urol.
Herr HW, Laudone VP, Badalament RA, et al. (1988). Bacillus Calmette-Guerin therapy alters the progression of superficial bladder cancer. J Clin Oncol.
Herr HW, Schwalb DM, Zhang ZF, et al. (1995). Intravesical bacillus Calmette-Guerin therapy prevents tumor progression and death from superficial bladder cancer: ten-year follow-up of a prospective randomized trial. J Clin Oncol.
Hinotsu S, Akaza H, Isaka S, et al. (2006). Sustained prophylactic effect of intravesical bacille Calmette-Guerin for superficial bladder cancer: a smoothed hazard analysis in a randomized prospective study. Urology.
Hinotsu S, Akaza H, Naito S, et al. (2011). Maintenance therapy with bacillus Calmette-Guerin Connaught strain clearly prolongs recurrence-free survival following transurethral resection of bladder tumour for non-muscle-invasive bladder cancer. BJU Int.
Hirao Y, Okajima E, Ozono S, et al. (1992). A prospective randomized study of prophylaxis of tumor recurrence following transurethral resection of superficial bladder cancer--intravesical thio-TEPA versus oral UFT. Cancer Chemother Pharmacol.
Hoeltl W, Hasun R, Albrecht W, et al. (1991). How effective is topical alpha-2b interferon in preventing recurrence of superficial bladder cancer?. Br J Urol.
Horstmann M, Patschan O, Hennenlotter J, et al. (2009). Combinations of urine-based tumour markers in bladder cancer surveillance. Scand J Urol Nephrol.
Huland H, Kloppel G, Feddersen I, et al. (1990). Comparison of different schedules of cytostatic intravesical instillations in patients with superficial bladder carcinoma: final evaluation of a prospective multicenter study with 419 patients. J Urol.
Huland H, Kloppel G, Otto U, et al. (1988). Cytostatic intravesical instillation in patients with superficial bladder carcinoma for the prevention of recurrent tumors. Eur Urol.
Ianari A, Sternberg CN, Rossetti A, et al. (1997). Results of Bard BTA test in monitoring patients with a history of transitional cell cancer of the bladder. Urology.
Igawa M, Urakami S, Shirakawa H, et al. (1996). Intravesical instillation of epirubicin: effect on tumour recurrence in patients with dysplastic epithelium after transurethral resection of superficial bladder tumour. Br J Urol.
Inamoto T, Ubai T, Nishida T, et al. (2013). Comparable effect with minimal morbidity of low-dose Tokyo 172 strain compared with regular dose Connaught strain as an intravesical bacillus Calmette-Guerin prophylaxis in nonmuscle invasive bladder cancer: Results of a randomized prospective comparison. Urol Ann.
Irani J, Desgrandchamps F, Millet C, et al. (1999). BTA stat and BTA TRAK: A comparative evaluation of urine testing for the diagnosis of transitional cell carcinoma of the bladder. Eur Urol.
Irie A, Uchida T, Yamashita H, et al. (2003). Sufficient prophylactic efficacy with minor adverse effects by intravesical instillation of low-dose bacillus Calmette-Guerin for superficial bladder cancer recurrence. Int J Urol.
Jarvinen R, Kaasinen E, Rintala E, et al. (2012). Long-term results of maintenance treatment of mitomycin C or alternating mitomycin C and bacillus Calmette-Guerin instillation therapy of patients with carcinoma in situ of the bladder: a subgroup analysis of the prospective FinnBladder 2 study with a 17-year follow-up. Scand J Urol Nephrol.
Jarvinen R, Kaasinen E, Sankila A, et al. (2009). Long-term efficacy of maintenance bacillus Calmette-Guerin versus maintenance mitomycin C instillation therapy in frequently recurrent TaT1 tumours without carcinoma in situ: a subgroup analysis of the prospective, randomised FinnBladder I study with a 20-year follow-up. Eur Urol.
Jauhiainen. (1987). Instillation of mitomycin C and doxorubicin in the prevention of recurrent superficial (Ta-T1) bladder cancer. Br J Urol.
Jimenez-Cruz JF, Vera-Donoso CD, Leiva O, et al. (1997). Intravesical immunoprophylaxis in recurrent superficial bladder cancer (Stage T1): multicenter trial comparing bacille Calmette-Guerin and interferon-alpha. Urology.
Junker K, Fritsch T, Hartmann A, et al. (2006). Multicolor fluorescence in situ hybridization (M-FISH) on cells from urine for the detection of bladder cancer. Cytogenet Genome Res.
Kaasinen E, Rintala E, Pere AK, et al. (2000). Weekly mitomycin C followed by monthly bacillus Calmette-Guerin or alternating monthly interferon-alpha2B and bacillus Calmette-Guerin for prophylaxis of recurrent papillary superficial bladder carcinoma. J Urol.
Kaasinen E, Wijkstrom H, Malmstrom PU, et al. (2003). Alternating mitomycin C and BCG instillations versus BCG alone in treatment of carcinoma in situ of the urinary bladder: a nordic study. Eur Urol.
Kaisary AV. (1987). Intravesical BCG Therapy in the Management of Multiple Superficial Bladder Carcinoma Comparison between Glaxo and Pasteur Strains. Br J Urol.
Karaolides T, Skolarikos A, Bourdoumis A, et al. (2012). Hexaminolevulinate-induced fluorescence versus white light during transurethral resection of noninvasive bladder tumor: does it reduce recurrences?. Urology.
Karnwal A, Venegas R, Shuch B, et al. (2010). The role of fluorescence in situ hybridization assay for surveillance of non-muscle invasive bladder cancer. Can J Urol.
Kim HH, Lee C. (1989). Intravesical mitomycin C instillation as a prophylactic treatment of superficial bladder tumor. J Urol.
Koga H, Kuroiwa K, Yamaguchi A, et al. (2004). A randomized controlled trial of short-term versus long-term prophylactic intravesical instillation chemotherapy for recurrence after transurethral resection of Ta/T1 transitional cell carcinoma of the bladder. J Urol.
Koga H, Ozono S, Tsushima T, et al. (2010). Maintenance intravesical bacillus Calmette-Guerin instillation for Ta, T1 cancer and carcinoma in situ of the bladder: randomized controlled trial by the BCG Tokyo Strain Study Group. Int J Urol.
Koontz WW, Prout GR, Smith W, et al. (1981). The use of intravesical thio-tepa in the management of non-invasive carcinoma of the bladder. J Urol.
Krege S, Giani G, Meyer R, et al. (1996). A randomized multicenter trial of adjuvant therapy in superficial bladder cancer: transurethral resection only versus transurethral resection plus mitomycin C versus transurethral resection plus bacillus Calmette-Guerin. Participating Clinics. J Urol.
Kriegmair M, Zaak D, Rothenberger KH, et al. (2002). Transurethral resection for bladder cancer using 5-aminolevulinic acid induced fluorescence endoscopy versus white light endoscopy. J Urol.
Kuroda M, Niijima T, Kotake T, et al. (2004). Effect of prophylactic treatment with intravesical epirubicin on recurrence of superficial bladder cancer--The 6th Trial of the Japanese Urological Cancer Research Group (JUCRG): a randomized trial of intravesical epirubicin at dose of 20mg/40ml, 30mg/40ml, 40mg/40ml. Eur Urol.
Kurth K, Tunn U, Ay R, et al. (1997). Adjuvant chemotherapy for superficial transitional cell bladder carcinoma: long-term results of a European Organization for Research and Treatment of Cancer randomized trial comparing doxorubicin, ethoglucid and transurethral resection alone. J Urol.
Kurth KH, Bouffioux C, Sylvester R, et al. (1988). Is there an optimal treatment scheme for adjuvant intravesical therapy? Preliminary analysis of an EORTC protocol comparing early and delayed instillation with and without maintenance of either adriamycin or mitomycin-C in patients with superficial transitional carcinoma of the bladder. Prog Clin Biol Res.
Kurth KH, Schroder FH, Tunn U, et al. (1984). Adjuvant chemotherapy of superficial transitional cell bladder carcinoma: preliminary results of a European organization for research on treatment of cancer. Randomized trial comparing doxorubicin hydrochloride, ethoglucid and transurethral resection alone. J Urol.
Lamm DL, Blumenstein BA, Crawford ED, et al. (1991). A randomized trial of intravesical doxorubicin and immunotherapy with bacille Calmette-Guerin for transitional-cell carcinoma of the bladder. N Engl J Med.
Lamm DL, Blumenstein BA, Crissman JD, et al. (2000). Maintenance bacillus Calmette-Guerin immunotherapy for recurrent TA, T1 and carcinoma in situ transitional cell carcinoma of the bladder: a randomized Southwest Oncology Group Study. J Urol.
Lamm DL, Blumenstein BA, David Crawford E, et al. (1995). Randomized intergroup comparison of bacillus calmette-guerin immunotherapy and mitomycin C chemotherapy prophylaxis in superficial transitional cell carcinoma of the bladder a southwest oncology group study. Urol Oncol.
Lerner SP, Tangen CM, Sucharew H, et al. (2007). Patterns of recurrence and outcomes following induction bacillus Calmette-Guerin for high risk Ta, T1 bladder cancer. J Urol.
Leyh H, Hall R, Mazeman E, et al. (1997). Comparison of the Bard BTA test with voided urine and bladder wash cytology in the diagnosis and management of cancer of the bladder. Urology.
Leyh H, Marberger M, Conort P, et al. (1999). Comparison of the BTA stat test with voided urine cytology and bladder wash cytology in the diagnosis and monitoring of bladder cancer. Eur Urol.
Leyh H, Mazeman E. (1997). Bard BTA test compared with voided urine cytology in the diagnosis of recurrent bladder cancer. Eur Urol.
Liu B, Wang Z, Chen B, et al. (2006). Randomized study of single instillation of epirubicin for superficial bladder carcinoma: long-term clinical outcomes. Cancer Invest.
Lodde M, Mian C, Negri G, et al. (2003). Role of uCyt+ in the detection and surveillance of urothelial carcinoma. Urology.
Lotan Y, Capitanio U, Shariat SF, et al. (2009). Impact of clinical factors, including a point-of-care nuclear matrix protein-22 assay and cytology, on bladder cancer detection. BJU Int.
Lundholm C, Norlen BJ, Ekman P, et al. (1996). A randomized prospective study comparing long-term intravesical instillations of mitomycin C and bacillus Calmette-Guerin in patients with superficial bladder carcinoma. J Urol.
Malmstrom P-U. (2002). A randomized comparative dose-ranging study of interferon-alpha and mitomycin-C as an internal control in primary or recurrent superficial transitional cell carcinoma of the bladder. BJU Int.
Malmstrom PU, Wijkstrom H, Lundholm C, et al. (1999). 5-year followup of a randomized prospective study comparing mitomycin C and bacillus Calmette-Guerin in patients with superficial bladder carcinoma. Swedish-Norwegian Bladder Cancer Study Group. J Urol.
Mangiarotti B, Trinchieri A, Del Nero A, et al. (2008). A randomized prospective study of intravesical prophylaxis in non-musle invasive bladder cancer at intermediate risk of recurrence: mitomycin chemotherapy vs BCG immunotherapy. Arch Ital Urol Androl.
Martinez-Pineiro JA, Flores N, Isorna S, et al. (2002). Long-term follow-up of a randomized prospective trial comparing a standard 81 mg dose of intravesical bacille Calmette-Guerin with a reduced dose of 27 mg in superficial bladder cancer. BJU Int.
Martinez-Pineiro JA, Jimenez Leon J, Martinez-Pineiro L, et al. (1989). Intravesical therapy comparing BCG, adriamycin, and thiotepa in 200 patients with superficial bladder cancer: a randomized prospective study. Progress in clinical and biological research.
Martinez-Pineiro JA, Jimenez Leon J, Martinez-Pineiro L, et al. (1990). Bacillus Calmette-Guerin versus doxorubicin versus thiotepa: a randomized prospective study in 202 patients with superficial bladder cancer. J Urol.
Martinez-Pineiro JA, Martinez-Pineiro L, Solsona E, et al. (2005). Has a 3-fold decreased dose of bacillus Calmette-Guerin the same efficacy against recurrences and progression of T1G3 and Tis bladder tumors than the standard dose? Results of a prospective randomized trial. J Urol.
Masters JR, Popert RJ, Thompson PM, et al. (1999). Intravesical chemotherapy with epirubicin: a dose response study. J Urol.
Matsumura Y, Akaza H, Isaka S, et al. (1992). The 4th study of prophylactic intravesical chemotherapy with adriamycin in the treatment of superficial bladder cancer: the experience of the Japanese Urological Cancer Research Group for Adriamycin. Cancer Chemother Pharmacol.
Melekos MD. (1990). Intravesical Bacillus Calmette-Guerin prophylactic treatment for superficial bladder tumors: results of a controlled prospective study. Urol Int.
Melekos MD, Chionis HS, Paranychianakis GS, et al. (1993). Intravesical 4'-epi-doxorubicin (epirubicin) versus bacillus Calmette-Guerin. A controlled prospective study on the prophylaxis of superficial bladder cancer. Cancer.
Melekos MD, Dauaher H, Fokaefs E, et al. (1992). Intravesical instillations of 4-epi-doxorubicin (epirubicin) in the prophylactic treatment of superficial bladder cancer: results of a controlled prospective study. J Urol.
Melekos MD, Zarakovitis I, Dandinis K, et al. (1996). BCG versus epirubicin in the prophylaxis of multiple superficial bladder tumours: results of a prospective randomized study using modified treatment schemes. Int Urol Nephrol.
Messing EM, Teot L, Korman H, et al. (2005). Performance of urine test in patients monitored for recurrence of bladder cancer: a multicenter study in the United States. J Urol.
Mian C, Lodde M, Haitel A, et al. (2000). Comparison of two qualitative assays, the UBC rapid test and the BTA stat test, in the diagnosis of urothelial cell carcinoma of the bladder. Urology.
Mian C, Pycha A, Wiener H, et al. (1999). Immunocyt: a new tool for detecting transitional cell cancer of the urinary tract. J Urol.
Mitsumori K, Tsuchiya N, Habuchi T, et al. (2004). Early and large-dose intravesical instillation of epirubicin to prevent superficial bladder carcinoma recurrence after transurethral resection. BJU Int.
Mohsen MAE, Shelbaia A, Ghobashy SE, et al. (2010). Sequential chemoimmunotherapy using mitomycin followed by bacillus Calmette-Guerin (MCC + BCG) versus single-agent immunotherapy (BCG) for recurrent superficial bladder tumors. UroToday International Journal.
Morales A, Nickel JC, Wilson JW. (1992). Dose-response of bacillus Calmette-Guerin in the treatment of superficial bladder cancer. J Urol.
Mostafid H, Bunce C. (2009). Improved detection and reduced early recurrence of non-muscle-invasive bladder cancer using hexaminolaevulinate fluorescence cystoscopy: results of a multicentre prospective randomized study (PC B305). BJU Int.
MRC. (1994). The effect of intravesical thiotepa on tumour recurrence after endoscopic treatment of newly diagnosed superficial bladder cancer. A further report with long-term follow-up of a Medical Research Council randomized trial. Medical Research Council Working Party on Urological Cancer, Subgroup on Superficial Bladder Cancer. Br J Urol.
MRC Working Party. (1985). The effect of intravesical thiotepa on the recurrence rate of newly diagnosed superficial bladder cancer. An MRC Study. MRC Working Party on Urological Cancer. Br J Urol.
Mukherjee A, Persad R, Smith PJ. (1992). Intravesical BCG treatment for superficial bladder cancer: long-term results using two different strains of BCG. Br J Urol.
Mulders PF, Hoekstra WJ, Heybroek RP, et al. (1994). Prognosis and treatment of T1G3 bladder tumours. A prognostic factor analysis of 121 patients. Dutch South Eastern Bladder Cancer Study Group. Eur J Cancer.
Naselli A, Introini C, Timossi L, et al. (2012). A randomized prospective trial to assess the impact of transurethral resection in narrow band imaging modality on non-muscle-invasive bladder cancer recurrence. Eur Urol.
Nasuti JF, Gomella LG, Ismial M, et al. (1999). Utility of the BTA stat test kit for bladder cancer screening. Diagn Cytopathol.
Nepple KG, Lightfoot AJ, Rosevear HM, et al. (2010). Bacillus Calmette-Guerin with or without interferon alpha-2b and megadose versus recommended daily allowance vitamins during induction and maintenance intravesical treatment of nonmuscle invasive bladder cancer. J Urol.
Niijima T, Koiso K, Akaza H. (1983). Randomized clinical trial on chemoprophylaxis of recurrence in cases of superficial bladder cancer. Cancer Chemother Pharmacol.
Nomata K, Noguchi M, Kanetake H, et al. (2002). Intravesical adjuvant chemotherapy for superficial transitional cell bladder carcinoma: results of a randomized trial with epirubicin comparing short-term versus long-term maintenance treatment. Cancer Chemother Pharmacol.
Noon AP, Kulkarni GS. (2014). All bacillus Calmette-Guerin (BCG) strains are equal, but some BCG strains are more equal than others. Eur Urol.
Obata K, Ohashi Y, Akaza H, et al. (1994). Prophylactic chemotherapy with intravesical instillation of adriamycin and oral administration of 5-fluorouracil after surgery for superficial bladder cancer. The Japanese Urological Cancer Research Group for Adriamycin. Cancer Chemother Pharmacol.
O'Brien T, Ray E, Chatterton K, et al. (2013). Prospective randomized trial of hexylaminolevulinate photodynamic-assisted transurethral resection of bladder tumour (TURBT) plus single-shot intravesical mitomycin C vs conventional white-light TURBT plus mitomycin C in newly presenting non-muscle-invasive bladder cancer. BJU Int.
Oddens J, Brausi M, Sylvester R, et al. (2013). Final results of an EORTC-GU cancers group randomized study of maintenance bacillus Calmette-Guerin in intermediate- and high-risk Ta, T1 papillary carcinoma of the urinary bladder: one-third dose versus full dose and 1 year versus 3 years of maintenance. Eur Urol.
Ojea A, Nogueira JL, Solsona E, et al. (2007). A multicentre, randomised prospective trial comparing three intravesical adjuvant therapies for intermediate-risk superficial bladder cancer: low-dose bacillus Calmette-Guerin (27 mg) versus very low-dose bacillus Calmette-Guerin (13.5 mg) versus mitomycin C. Eur Urol.
Okamura K. (1998). A randomized study of short- versus long-term intravesical epirubicin instillation for superficial bladder cancer. Eur Urol.
Okamura K, Ono Y, Kinukawa T, et al. (2002). Randomized study of single early instillation of (2″R)-4′-O-tetrahydropyranyl-doxorubicin for a single superficial bladder carcinoma. Cancer.
Olsson H, Zackrisson B. (2001). ImmunoCyt a useful method in the follow-up protocol for patients with urinary bladder carcinoma. Scand J Urol Nephrol.
Oosterlinck W, Kirkali Z, Sylvester R, et al. (2011). Sequential intravesical chemoimmunotherapy with mitomycin C and bacillus Calmette-Guerin and with bacillus Calmette-Guerin alone in patients with carcinoma in situ of the urinary bladder: results of an EORTC genito-urinary group randomized phase 2 trial (30993). Eur Urol.
Oosterlinck W, Kurth KH, Schroder F, et al. (1993). A prospective European Organization for Research and Treatment of Cancer Genitourinary Group randomized trial comparing transurethral resection followed by a single intravesical instillation of epirubicin or water in single stage Ta, T1 papillary carcinoma of the bladder. J Urol.
O'Sullivan P, Sharples K, Dalphin M, et al. (2012). A multigene urine test for the detection and stratification of bladder cancer in patients presenting with hematuria. J Urol.
Pagano F, Bassi P, Milani C, et al. (1990). Low Dose BGC therapy in superficial bladder cancer; a clinicopathological perspective. Edinburgh, editor. Immunotherapy of urological tumours.
Pagano F, Bassi P, Milani C, et al. (1991). A low dose bacillus Calmette-Guerin regimen in superficial bladder cancer therapy: is it effective?. J Urol.
Pagano F, Bassi P, Piazza N, et al. (1995). Improving the efficacy of BCG immunotherapy by dose reduction. Eur Urol.
Palou J, Laguna P, Millan-Rodriguez F, et al. (2001). Control group and maintenance treatment with bacillus Calmette-Guerin for carcinoma in situ and/or high grade bladder tumors. J Urol.
Penkoff H. (2007). Transurethral detection and resection of bladder carcinomas under white or 5-ALA induced fluorescence light: results of the first double-blind-placebo controlled clinical trial. The Journal of urology.
Pfister C, Chautard D, Devonec M, et al. (2003). Immunocyt test improves the diagnostic accuracy of urinary cytology: results of a French multicenter study. J Urol.
Piaton E, Daniel L, Verriele V, et al. (2003). Improved detection of urothelial carcinomas with fluorescence immunocytochemistry (uCyt+ assay) and urinary cytology: results of a French Prospective Multicenter Study. Lab Invest.
Pinsky CM, Camacho FJ, Kerr D, et al. (1985). Intravesical administration of bacillus Calmette-Guerin in patients with recurrent superficial carcinoma of the urinary bladder: report of a prospective, randomized trial. Cancer Treat Rep.
Placer J, Espinet B, Salido M, et al. (2002). Clinical utility of a multiprobe FISH assay in voided urine specimens for the detection of bladder cancer and its recurrences, compared with urinary cytology. Eur Urol.
Pode D, Shapiro A, Wald M, et al. (1999). Noninvasive detection of bladder cancer with the BTA stat test. J Urol.
Ponsky LE, Sharma S, Pandrangi L, et al. (2001). Screening and monitoring for bladder cancer: refining the use of NMP22. J Urol.
Porena M, Del Zingaro M, Lazzeri M, et al. (2010). Bacillus Calmette-Guerin versus gemcitabine for intravesical therapy in high-risk superficial bladder cancer: a randomised prospective study. Urol Int.
Portillo J, Martin B, Hernandez R, et al. (1997). Results at 43 months' follow-up of a double-blind, randomized, prospective clinical trial using intravesical interferon alpha-2b in the prophylaxis of stage pT1 transitional cell carcinoma of the bladder. Urology.
Quek P, Chin CM, Lim PHC. (2002). The role of BTA stat in clinical practice. Ann Acad Med Singapore.
Raitanen MP, Hellstrom P, Marttila T, et al. (2001). Effect of intravesical instillations on the human complement factor H related protein (BTA stat) test. Eur Urol.
Raitanen MP, Leppilahti M, Tuhkanen K, et al. (2001). Routine follow-up cystoscopy in detection of recurrence in patients being monitored for bladder cancer. Ann Chir Gynaecol.
Rajala P, Kaasinen E, Raitanen M, et al. (2002). Perioperative single dose instillation of epirubicin or interferon-alpha after transurethral resection for the prophylaxis of primary superficial bladder cancer recurrence: a prospective randomized multicenter study--FinnBladder III long-term results. J Urol.
Rajala P, Liukkonen T, Raitanen M, et al. (1999). Transurethral resection with perioperative instilation on interferon-alpha or epirubicin for the prophylaxis of recurrent primary superficial bladder cancer: a prospective randomized multicenter study--Finnbladder III. J Urol.
Rentsch CA, Birkhauser FD, Biot C, et al. (2014). Bacillus Calmette-Guerin strain differences have an impact on clinical outcome in bladder cancer immunotherapy. Eur Urol.
Riedl CR, Daniltchenko D, Koenig F, et al. (2001). Fluorescence endoscopy with 5-aminolevulinic acid reduces early recurrence rate in superficial bladder cancer. J Urol.
Rintala E, Jauhiainen K, Alfthan O, et al. (1991). Intravesical chemotherapy (mitomycin C) versus immunotherapy (bacillus Calmette-Guerin) in superficial bladder cancer. Eur Urol.
Rintala E, Jauhiainen K, Kaasinen E, et al. (1996). Alternating mitomycin C and bacillus Calmette-Guerin instillation prophylaxis for recurrent papillary (stages Ta to T1) superficial bladder cancer. Finnbladder Group. J Urol.
Rintala E, Jauhiainen K, Rajala P, et al. (1995). Alternating mitomycin C and bacillus Calmette-Guerin instillation therapy for carcinoma in situ of the bladder. The Finnbladder Group. J Urol.
Rubben H, Lutzeyer W, Fischer N, et al. (1988). Natural history and treatment of low and high risk superficial bladder tumors. J Urol.
Saad A, Hanbury DC, McNicholas TA, et al. (2002). A study comparing various noninvasive methods of detecting bladder cancer in urine. BJU Int.
Saika T, Tsushima T, Nasu Y, et al. (2010). Two instillations of epirubicin as prophylaxis for recurrence after transurethral resection of Ta and T1 transitional cell bladder cancer: a prospective, randomized controlled study. World J Urol.
Sanchez-Carbayo M, Urrutia M, Silva JM, et al. (2001). Comparative predictive values of urinary cytology, urinary bladder cancer antigen, CYFRA 21-1 and NMP22 for evaluating symptomatic patients at risk for bladder cancer. J Urol.
Sarosdy MF, Schellhammer P, Bokinsky G, et al. (2002). Clinical evaluation of a multi-target fluorescent in situ hybridization assay for detection of bladder cancer. J Urol.
Sawczuk IS, Bagiella E, Sawczuk AT, et al. (2000). Clinical application of NMP22 in the management of transitional cell carcinoma of the bladder. Cancer Detect Prev.
Schamhart DH, de Reijke TM, van der Poel HG, et al. (1998). The Bard BTA test: its mode of action, sensitivity and specificity, compared to cytology of voided urine, in the diagnosis of superficial bladder cancer. Eur Urol.
Schmitz-Drager B, Tirsar LA, Schmitz-Drager C, et al. (2007). Immunocytology in the assessment of patients with painless gross haematuria. BJU Int.
Schmitz-Drager BJ, Beiche B, Tirsar LA, et al. (2007). Immunocytology in the assessment of patients with asymptomatic microhaematuria. Eur Urol.
Schulman C, Sylvester R, Robinson M, et al. (1978). Adjuvant therapy of T1 bladder carcinoma: preliminary results of an EORTC randomized study. Recent results in cancer research Fortschritte der Krebsforschung Progres dans les recherches sur le cancer.
Schulman CC, Robinson M, Denis L, et al. (1982). Prophylactic chemotherapy of superficial transitional cell bladder carcinoma: an EORTC randomized trial comparing thiotepa, an epipodophyllotoxin (VM26) and TUR alone. Eur Urol.
Schumacher MC, Holmang S, Davidsson T, et al. (2010). Transurethral resection of non-muscle-invasive bladder transitional cell cancers with or without 5-aminolevulinic Acid under visible and fluorescent light: results of a prospective, randomised, multicentre study. Eur Urol.
Schwaibold H, Pichlmeier U, Klingenberger HJ, et al. (1997). Long-term follow-up of cytostatic intravesical instillation in patients with superficial bladder carcinoma. Is short-term, intensive instillation better than maintenance therapy?. Eur Urol.
Sekine H, Ohya K, Kojima SI, et al. (2001). Equivalent efficacy of mitomycin C plus doxorubicin instillation to bacillus Calmette-Guerin therapy for carcinoma in situ of the bladder. Int J Urol.
Sengiku A, Ito M, Miyazaki Y, et al. (2013). A prospective comparative study of intravesical bacillus Calmette-Guerin therapy with the Tokyo or Connaught strain for nonmuscle invasive bladder cancer. J Urol.
Serretta V, Lo Presti D, Vasile P, et al. (1998). Urinary NMP22 for the detection of recurrence after transurethral resection of transitional cell carcinoma of the bladder: experience on 137 patients. Urology.
Serretta V, Morgia G, Altieri V, et al. (2010). A 1-year maintenance after early adjuvant intravesical chemotherapy has a limited efficacy in preventing recurrence of intermediate risk non-muscle-invasive bladder cancer. BJU Int.
Serretta V, Pomara G, Rizzo I, et al. (2000). Urinary BTA-stat, BTA-trak and NMP22 in surveillance after TUR of recurrent superficial transitional cell carcinoma of the bladder. Eur Urol.
Shariat SF, Marberger MJ, Lotan Y, et al. (2006). Variability in the performance of nuclear matrix protein 22 for the detection of bladder cancer. J Urol.
Sharma S, Zippe CD, Pandrangi L, et al. (1999). Exclusion criteria enhance the specificity and positive predictive value of NMP22 and BTA stat. J Urol.
Shuin T, Kubota Y, Noguchi S, et al. (1994). A phase II study of prophylactic intravesical chemotherapy with 4'-epirubicin in recurrent superficial bladder cancer: comparison of 4'-epirubicin and adriamycin. Cancer Chemother Pharmacol.
Skinner EC, Goldman B, Sakr WA, et al. (2013). SWOG S0353: Phase II trial of intravesical gemcitabine in patients with nonmuscle invasive bladder cancer and recurrence after 2 prior courses of intravesical bacillus Calmette-Guerin. J Urol.
Solsona E, Iborra I, Ricos JV, et al. (1999). Effectiveness of a single immediate mitomycin C instillation in patients with low risk superficial bladder cancer: short and long-term followup. J Urol.
Song M-J, Lee H-M, Kim S-H. (2010). Clinical usefulness of fluorescence in situ hybridization for diagnosis and surveillance of bladder cancer. Cancer Genet Cytogenet.
Stavropoulos NE, Hastazeris K, Filiadis I, et al. (2002). Intravesical instillations of interferon gamma in the prophylaxis of high risk superficial bladder cancer--results of a controlled prospective study. Scand J Urol Nephrol.
Stenzl A, Burger M, Fradet Y, et al. (2010). Hexaminolevulinate guided fluorescence cystoscopy reduces recurrence in patients with nonmuscle invasive bladder cancer. J Urol.
Stenzl A, Penkoff H, Dajc-Sommerer E, et al. (2011). Detection and clinical outcome of urinary bladder cancer with 5-aminolevulinic acid-induced fluorescence cystoscopy : A multicenter randomized, double-blind, placebo-controlled trial. Cancer.
Sullivan PS, Nooraie F, Sanchez H, et al. (2009). Comparison of ImmunoCyt, UroVysion, and urine cytology in detection of recurrent urothelial carcinoma: a “split-sample” study. Cancer.
Sylvester RJ, Brausi MA, Kirkels WJ, et al. (2010). Long-term efficacy results of EORTC genito-urinary group randomized phase 3 study 30911 comparing intravesical instillations of epirubicin, bacillus Calmette-Guerin, and bacillus Calmette-Guerin plus isoniazid in patients with intermediate- and high-risk stage Ta T1 urothelial carcinoma of the bladder. Eur Urol.
Tetu B, Tiguert R, Harel F, et al. (2005). ImmunoCyt/uCyt+ improves the sensitivity of urine cytology in patients followed for urothelial carcinoma. Mod Pathol.
The United Kingdom and Eire Bladder Tumour Antigen Study Group. (1997). The use of the bladder-tumour associated analyte test to determine the type of cystoscopy in the follow-up of patients with bladder cancer. Br J Urol.
Thomas L, Leyh H, Marberger M, et al. (1999). Multicenter trial of the quantitative BTA TRAK assay in the detection of bladder cancer. Clin Chem.
Tolley DA, Hargreave TB, Smith PH, et al. (1988). Effect of intravesical mitomycin C on recurrence of newly diagnosed superficial bladder cancer: interim report from the Medical Research Council Subgroup on Superficial Bladder Cancer (Urological Cancer Working Party). Br Med J (Clin Res Ed).
Tolley DA, Parmar MK, Grigor KM, et al. (1996). The effect of intravesical mitomycin C on recurrence of newly diagnosed superficial bladder cancer: a further report with 7 years of follow up. J Urol.
Toma MI, Friedrich MG, Hautmann SH, et al. (2004). Comparison of the ImmunoCyt test and urinary cytology with other urine tests in the detection and surveillance of bladder cancer. World J Urol.
Tsushima T, Matsumura Y, Ozaki Y, et al. (1987). Prophylactic intravesical instillation therapy with adriamycin and mitomycin C in patients with superficial bladder cancer. Cancer chemotherapy and pharmacology.
Turkeri L, Tanidir Y, Cal C, et al. (2010). Comparison of the efficacy of single or double intravesical epirubicin instillation in the early postoperative period to prevent recurrences in non-muscle-invasive urothelial carcinoma of the bladder: prospective, randomized multicenter study. Urol Int.
Ueda T, Naito S, Iguchi A, et al. (1992). Adjuvant chemotherapy with early intravesical instillation of adriamycin and long-term oral administration of 5-fluorouracil in superficial bladder cancer. The Kyushu University Urological Oncology Group. Cancer Chemother Pharmacol.
van der Meijden AP, Brausi M, Zambon V, et al. (2001). Intravesical instillation of epirubicin, bacillus Calmette-Guerin and bacillus Calmette-Guerin plus isoniazid for intermediate and high risk Ta, T1 papillary carcinoma of the bladder: a European Organization for Research and Treatment of Cancer genito-urinary group randomized phase III trial. J Urol.
van der Poel HG, van Balken MR, Schamhart DH, et al. (1998). Bladder wash cytology, quantitative cytology, and the qualitative BTA test in patients with superficial bladder cancer. Urology.
van Gils-Gielen RJ, Witjes WP, Caris CT, et al. (1995). Risk factors in carcinoma in situ of the urinary bladder. Dutch South East Cooperative Urological Group. Urology.
Varella-Garcia M, Akduman B, Sunpaweravong P, et al. (2004). The UroVysion fluorescence in situ hybridization assay is an effective tool for monitoring recurrence of bladder cancer. Urol Oncol.
Vegt PD, Witjes JA, Witjes WP, et al. (1995). A randomized study of intravesical mitomycin C, bacillus Calmette-Guerin Tice and bacillus Calmette-Guerin RIVM treatment in pTa-pT1 papillary carcinoma and carcinoma in situ of the bladder. J Urol.
Vriesema JL, Atsma F, Kiemeney LA, et al. (2001). Diagnostic efficacy of the ImmunoCyt test to detect superficial bladder cancer recurrence. Urology.
Wiener HG, Mian C, Haitel A, et al. (1998). Can urine bound diagnostic tests replace cystoscopy in the management of bladder cancer?. J Urol.
Witjes JA, Caris CT, Mungan NA, et al. (1998). Results of a randomized phase III trial of sequential intravesical therapy with mitomycin C and bacillus Calmette-Guerin versus mitomycin C alone in patients with superficial bladder cancer. J Urol.
Witjes JA, v d Meijden AP, Collette L, et al. (1998). Long-term follow-up of an EORTC randomized prospective trial comparing intravesical bacille Calmette-Guerin-RIVM and mitomycin C in superficial bladder cancer. EORTC GU Group and the Dutch South East Cooperative Urological Group. European Organisation for Research and Treatment of Cancer Genito-Urinary Tract Cancer Collaborative Group. Urology.
Witjes JA, van der Poel HG, van Balken MR, et al. (1998). Urinary NMP22 and karyometry in the diagnosis and follow-up of patients with superficial bladder cancer. Eur Urol.
Witjes JA, vd Meijden AP, Witjes WP, et al. (1993). A randomised prospective study comparing intravesical instillations of mitomycin-C, BCG-Tice, and BCG-RIVM in pTa-pT1 tumours and primary carcinoma in situ of the urinary bladder. Dutch South-East Cooperative Urological Group. Eur J Cancer.
Witjes WP, Witjes JA, Oosterhof GO, et al. (1996). Update on the Dutch Cooperative Trial: mitomycin versus bacillus Calmette-Guerin-Tice versus bacillus Calmette-Guerin RIVM in the treatment of patients with pTA-pT1 papillary carcinoma and carcinoma in situ of the urinary bladder. Dutch South East Cooperative Urological Group. Semin Urol Oncol.
Zincke H, Benson RC, Hilton JF, et al. (1985). Intravesical thiotepa and mitomycin C treatment immediately after transurethral resection and later for superficial (stages Ta and Tis) bladder cancer: a prospective, randomized, stratified study with crossover design. J Urol.
Zippe C, Pandrangi L, Potts JM, et al. (1999). NMP22: a sensitive, cost-effective test in patients at risk for bladder cancer. Anticancer Res.