# Appendix B PICOTS

Table B1 PICOTS

PICOT | Inclusion and Exclusion Criteria
Populations | Include: Patients with signs or symptoms of possible bladder cancer [KQ 1; KQ 6; KQ7] Patients with non-muscle invasive bladder cancer (stages Ta, Tis, or T1) [KQ 2] Adults with non-muscle invasive bladder cancer treated with TURBT [KQ 3; KQ 8] Adults with high-risk non-muscle invasive bladder cancer treated with TURBT [KQ4; KQ8] Adults undergoing surveillance following treatment for non-muslce invasive bladder cancer [KQ 1; KQ 5; KQ 6; KQ 7]
Interventions | Include: Urinary biomarkers [KQ 1; KQ 5; KQ 7] Risk-adapted treatment approaches [KQ 2] Intravesical chemotherapeutic or immunotherapeutic agents [KQ 3; KQ 8] External beam radiation therapy, with or without systemic chemotherapy or immunotherapy [KQ 4] Blue light cystoscopy or other methods of augmented cystoscopy Biomarkers included are: BTAstat^®^ [BTA], Alere NMP22^®^, BladderChek^®^ [NMP22], UroVysion^®^ [FISH] and ImmunoCyt^™^ [immunocytology], CxBladder™ Chemotherapeutic and immunotherapeutic agents of interest include: mitomycin; apaziquone; paclitaxel; gemcitabine; thiotepa; valrubicin; doxorubicin; epirubicin; bacillus Calmette-Guérin (BCG); and interferon Exclude: Electromotive drug administration
Comparators | Include: Other urinary biomarkers or standard diagnostic methods (cystoscopy, cytology and imaging) [KQ 1; KQ 5; KQ 7] Treatment not guided by risk-adapted approach [KQ 2] Other Intravesical chemotherapeutic or immunotherapeutic agent, different dose or duration of intravesical chemotherapy or immunotherapy, or TURBT alone [KQ 3; KQ 8] Intravesical chemotherapeutic or immunotherapeutic agents or cystectomy. [KQ 4]
Outcomes | Include: Diagnostic accuracy, using cystoscopy with biopsy as the reference standard [KQ 1; KQ 5] Mortality, disease specific and all-cause [KQ 2; KQ 3; KQ 4; KQ 5] Need for cystectomy [KQ 2; KQ 3; KQ 4; KQ 5] Recurrence of cancer [KQ 2; KQ 3;’ KQ 4; KQ 5; KQ 6] Progression of cancer [KQ 2; KQ 3; KQ 4; KQ 5] Quality of life [KQ 2; KQ 3; KQ 4; KQ 5] Adverse effects of diagnostic testing [KQ 7] Adverse effects of treatment [KQ 8] Exclude: Prediction of treatment response
Timing | Include: Any duration of followup
Setting | Include: Inpatient or outpatient settings
Study Design | Include: RCTs, Cohort Studies Must be comparative Systematic reviews must evaluate quality of individual studies

KQ = key question; PICOTS = populations, interventions, comparators, outcomes, timing, setting; RCT = randomized controlled trial; T1 = Tumor stage 1; Ta = Tumor stage a; Tis = carcinoma in situ; TURBT = transurethral resection of bladder tumor