# Appendix A Search Strategies

## Primary Search Strategy (Ovid MEDLINE)

1. exp Urinary Bladder Neoplasms/
2. ((((non or “not”) adj (invas$ or invad$ or infiltrat$)) or noninvas$ or noninvad$ or noninfiltrat$) adj5 muscle$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
3. (cis or Tis or ta or t1$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
4. 2 or 3
5. ((sign or signs or symptom$ or possib$ or suspect$ or potential$) adj5 (bladder$ adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or malig$ or adenocarcin$))).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
6. 4 or 5
7. 1 and 6
8. exp Biological Markers/
9. 7 and 8
10. ((urin$ adj3 biomark$) or bladder tumor associated antigen$ or nuclear matrix protein or nmp22 or fluorescence in situ hybrid$ or (fish adj assay$) or fibroblast growth factor receptor 3 or fgfr3 or cxbladder or immunocyt or cytokeratin fragment$ or cyfra 21-1 or (cytokerat$ adj3 (tpa or tps)) or survivin or telomeras$ or vascular endothelial growth factor$ or vegf or metalloproteinas$ or mmp-2 or mmp-9 or twist homolog$ or twist1 or nidogen-2 or nid2).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
11. 7 and 10
12. ((assess$ or analyz$ or judg$ or consider$ or quantif$ or predict$ or identif$ or adapt$) adj7 risk$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
13. exp Surgical Procedures, Operative/
14. exp Drug Therapy/
15. exp Antineoplastic Agents/
16. exp Radiotherapy/
17. (th or su or rt or dh or dt).fs.
18. 13 or 14 or 15 or 16 or 17
19. 12 and 18
20. 7 and 19
21. (mitomycin$ or apaziquone or paclitaxel or gemcitabine or thiotepa or valrubicin or doxorubicin or bacillus calmette guerin or bcg or interferon$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
22. 7 and 21
23. (electromotiv$ or emda).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
24. 1 and 23
25. (blue adj5 cystoscop$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
26. 1 and 25
27. exp Radiotherapy/
28. rt.fs.
29. 27 or 28
30. 7 and 29
31. 9 or 11 or 20 or 22 or 24 or 26 or 30
32. exp Urinary Bladder Neoplasms/
33. ((invas$ or invad$ or infiltrat$) adj5 muscl$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
34. (t2$ or t3$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
35. 33 or 34
36. 32 and 35
37. cystectom$.mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
38. ((excis$ or remov$ or ((cut or cutting or cuts) adj3 (out or away))) adj5 bladder$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
39. 37 or 38
40. (bladder$ adj5 (spare or sparing or spares or spared or preserv$)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
41. (avoid$ adj7 cystectom$).mp.
42. 40 or 41
43. exp Lymph Node Excision/
44. ((excis$ or remov$ or ((cut or cutting or cuts) adj3 (out or away))) adj5 (lymph$ or node or nodes)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
45. 43 or 44
46. (adjuvant$ or neoadjuvant$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
47. (abraxane or carboplatin$ or cisplatin$ or docetaxel or doxorubicin or epirubicin or 5-fluorouracil or gemcitabine or methotrexate or mitomycin or paclitaxel or valrubicin or vinblastin).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
48. 46 or 47
49. 39 or 42 or 45 or 48
50. 36 and 49
51. 31 or 50
52. limit 51 to yr=”1990 -Current”
53. limit 52 to english language
54. limit 52 to abstracts
55. 53 or 54

## Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. ((Urinar$ or urothel$) adj5 (bladder$ adj3 (neoplas$ or cancer$ or tumor$ or tumour$ or carcino$ or adenocarcin$ or malig$))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. ((((non or “not”) adj (invas$ or invad$ or infiltrat$)) or noninvas$ or noninvad$ or noninfiltrat$) adj5 muscle$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. (cis or Tis or ta or t1$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. 2 or 3
5. ((sign or signs or symptom$ or possib$ or suspect$ or potential$) adj5 (bladder$ adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or malig$ or adenocarcin$))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6. 4 or 5
7. 1 and 6
8. ((urin$ adj3 biomark$) or bladder tumor associated antigen$ or nuclear matrix protein or nmp22 or fluorescence in situ hybrid$ or (fish adj assay$) or fibroblast growth factor receptor 3 or fgfr3 or cxbladder or immunocyt or cytokeratin fragment$ or cyfra 21-1 or (cytokerat$ adj3 (tpa or tps)) or survivin or telomeras$ or vascular endothelial growth factor$ or vegf or metalloproteinas$ or mmp-2 or mmp-9 or twist homolog$ or twist1 or nidogen-2 or nid2).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
9. 7 and 8
10. ((assess$ or analyz$ or judg$ or consider$ or quantif$ or predict$ or identif$ or adapt$) adj7 risk$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11. (surger$ or surgic$ or surgeon$ or cystectom$ or excis$ or (remov$ adj3 bladder$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
12. ((drug$ adj3 (therap$ or treat$ or regimen$ or protocol$)) or pharmacother$ or chemother$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13. Antineoplastic$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
14. (Radiother$ or ((radio$ or irradiat$ or radiat$ or x-ray or gamma) adj3 (treat$ or therap$ or protocol$))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
15. 11 or 12 or 13 or 14
16. 10 and 15
17. 7 and 16
18. (mitomycin$ or apaziquone or paclitaxel or gemcitabine or thiotepa or valrubicin or doxorubicin or bacillus calmette guerin or bcg or interferon$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
19. 7 and 18
20. (electromotiv$ or emda).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
21. 1 and 20
22. (blue adj5 cystoscop$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
23. 1 and 22
24. 9 or 17 or 19 or 21 or 23
25. ((Urinar$ or urothel$) adj5 (bladder$ adj3 (neoplas$ or cancer$ or tumor$ or tumour$ or carcino$ or adenocarcin$ or malig$))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
26. ((invas$ or invad$ or infiltrat$) adj5 muscl$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
27. (t2$ or t3$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
28. 26 or 27
29. 25 and 28
30. cystectom$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
31. ((excis$ or remov$ or ((cut or cutting or cuts) adj3 (out or away))) adj5 bladder$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
32. 30 or 31
33. (bladder$ adj5 (spare or sparing or spares or spared or preserv$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
34. (avoid$ adj7 cystectom$).mp.
35. 33 or 34
36. ((excis$ or remov$ or biops$ or ((cut or cutting or cuts) adj3 (out or away))) adj5 (lymph$ or node or nodes)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
37. (adjuvant$ or neoadjuvant$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
38. (abraxane or carboplatin$ or cisplatin$ or docetaxel or doxorubicin or epirubicin or 5-fluorouracil or gemcitabine or methotrexate or mitomycin or paclitaxel or valrubicin or vinblastin).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
39. 37 or 38
40. 32 or 35 or 36 or 39
41. 29 and 40
42. 24 or 41
43. limit 42 to yr=”1990 -Current”

## Database: EBM Reviews – Cochrane Database of Systematic Reviews

1. ((Urinar$ or urothel$) adj5 (bladder$ adj3 (neoplas$ or cancer$ or tumor$ or tumour$ or carcino$ or adenocarcin$ or malig$))).mp. [mp=title, abstract, full text, keywords, caption text]

## Database: EBM Reviews – Database of Abstracts of Reviews of Effects

1. ((Urinar$ or urothel$) adj5 (bladder$ adj3 (neoplas$ or cancer$ or tumor$ or tumour$ or carcino$ or adenocarcin$ or malig$))).mp. [mp=title, full text, keywords]
2. ((((non or “not”) adj (invas$ or invad$ or infiltrat$)) or noninvas$ or noninvad$ or noninfiltrat$) adj5 muscle$).mp. [mp=title, full text, keywords]
3. (cis or Tis or ta or t1$).mp. [mp=title, full text, keywords]
4. 2 or 3
5. ((sign or signs or symptom$ or possib$ or suspect$ or potential$) adj5 (bladder$ adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or malig$ or adenocarcin$))).mp. [mp=title, full text, keywords]
6. 4 or 5
7. 1 and 6
8. ((urin$ adj3 biomark$) or bladder tumor associated antigen$ or nuclear matrix protein or nmp22 or fluorescence in situ hybrid$ or (fish adj assay$) or fibroblast growth factor receptor 3 or fgfr3 or cxbladder or immunocyt or cytokeratin fragment$ or cyfra 21-1 or (cytokerat$ adj3 (tpa or tps)) or survivin or telomeras$ or vascular endothelial growth factor$ or vegf or metalloproteinas$ or mmp-2 or mmp-9 or twist homolog$ or twist1 or nidogen-2 or nid2).mp. [mp=title, full text, keywords]
9. 7 and 8
10. ((assess$ or analyz$ or judg$ or consider$ or quantif$ or predict$ or identif$ or adapt$) adj7 risk$).mp. [mp=title, full text, keywords]
11. (surger$ or surgic$ or surgeon$ or cystectom$ or excis$ or (remov$ adj3 bladder$)).mp. [mp=title, full text, keywords]
12. ((drug$ adj3 (therap$ or treat$ or regimen$ or protocol$)) or pharmacother$ or chemother$).mp. [mp=title, full text, keywords]
13. Antineoplastic$.mp. [mp=title, full text, keywords]
14. (Radiother$ or ((radio$ or irradiat$ or radiat$ or x-ray or gamma) adj3 (treat$ or therap$ or protocol$))).mp. [mp=title, full text, keywords]
15. 11 or 12 or 13 or 14
16. 10 and 15
17. 7 and 16
18. (mitomycin$ or apaziquone or paclitaxel or gemcitabine or thiotepa or valrubicin or doxorubicin or bacillus calmette guerin or bcg or interferon$).mp. [mp=title, full text, keywords]
19. 7 and 18
20. (electromotiv$ or emda).mp. [mp=title, full text, keywords]
21. 1 and 20
22. (blue adj5 cystoscop$).mp. [mp=title, full text, keywords]
23. 1 and 22
24. 9 or 17 or 19 or 21 or 23
25. ((Urinar$ or urothel$) adj5 (bladder$ adj3 (neoplas$ or cancer$ or tumor$ or tumour$ or carcino$ or adenocarcin$ or malig$))).mp. [mp=title, full text, keywords]
26. ((invas$ or invad$ or infiltrat$) adj5 muscl$).mp. [mp=title, full text, keywords]
27. (t2$ or t3$).mp. [mp=title, full text, keywords]
28. 26 or 27
29. 25 and 28
30. cystectom$.mp. [mp=title, full text, keywords]
31. ((excis$ or remov$ or ((cut or cutting or cuts) adj3 (out or away))) adj5 bladder$).mp. [mp=title, full text, keywords]
32. 30 or 31
33. (bladder$ adj5 (spare or sparing or spares or spared or preserv$)).mp. [mp=title, full text, keywords]
34. (avoid$ adj7 cystectom$).mp.
35. 33 or 34
36. ((excis$ or remov$ or biops$ or ((cut or cutting or cuts) adj3 (out or away))) adj5 (lymph$ or node or nodes)).mp. [mp=title, full text, keywords]
37. (adjuvant$ or neoadjuvant$).mp. [mp=title, full text, keywords]
38. (abraxane or carboplatin$ or cisplatin$ or docetaxel or doxorubicin or epirubicin or 5-fluorouracil or gemcitabine or methotrexate or mitomycin or paclitaxel or valrubicin or vinblastin).mp. [mp=title, full text, keywords]
39. 37 or 38
40. 32 or 35 or 36 or 39
41. 29 and 40
42. 24 or 41

## Database: EBM Reviews – Health Technology Assessment

1. ((Urinar$ or urothel$) adj5 (bladder$ adj3 (neoplas$ or cancer$ or tumor$ or tumour$ or carcino$ or adenocarcin$ or malig$))).mp. [mp=title, text, subject heading word]

## Database: EBM Reviews – NHS Economic Evaluation Database

1. ((Urinar$ or urothel$) adj5 (bladder$ adj3 (neoplas$ or cancer$ or tumor$ or tumour$ or carcino$ or adenocarcin$ or malig$))).mp. [mp=title, text, subject heading word]
2. ((((non or “not”) adj (invas$ or invad$ or infiltrat$)) or noninvas$ or noninvad$ or noninfiltrat$) adj5 muscle$).mp. [mp=title, text, subject heading word]
3. (cis or Tis or ta or t1$).mp. [mp=title, text, subject heading word]
4. 2 or 3
5. ((sign or signs or symptom$ or possib$ or suspect$ or potential$) adj5 (bladder$ adj3 (cancer$ or tumor$ or tumour$ or neoplas$ or carcino$ or malig$ or adenocarcin$))).mp. [mp=title, text, subject heading word]
6. 4 or 5
7. 1 and 6
8. ((urin$ adj3 biomark$) or bladder tumor associated antigen$ or nuclear matrix protein or nmp22 or fluorescence in situ hybrid$ or (fish adj assay$) or fibroblast growth factor receptor 3 or fgfr3 or cxbladder or immunocyt or cytokeratin fragment$ or cyfra 21-1 or (cytokerat$ adj3 (tpa or tps)) or survivin or telomeras$ or vascular endothelial growth factor$ or vegf or metalloproteinas$ or mmp-2 or mmp-9 or twist homolog$ or twist1 or nidogen-2 or nid2).mp. [mp=title, text, subject heading word]
9. 7 and 8
10. ((assess$ or analyz$ or judg$ or consider$ or quantif$ or predict$ or identif$ or adapt$) adj7 risk$).mp. [mp=title, text, subject heading word]
11. (surger$ or surgic$ or surgeon$ or cystectom$ or excis$ or (remov$ adj3 bladder$)).mp. [mp=title, text, subject heading word]
12. ((drug$ adj3 (therap$ or treat$ or regimen$ or protocol$)) or pharmacother$ or chemother$).mp. [mp=title, text, subject heading word]
13. Antineoplastic$.mp. [mp=title, text, subject heading word]
14. (Radiother$ or ((radio$ or irradiat$ or radiat$ or x-ray or gamma) adj3 (treat$ or therap$ or protocol$))).mp. [mp=title, text, subject heading word]
15. 11 or 12 or 13 or 14
16. 10 and 15
17. 7 and 16
18. (mitomycin$ or apaziquone or paclitaxel or gemcitabine or thiotepa or valrubicin or doxorubicin or bacillus calmette guerin or bcg or interferon$).mp. [mp=title, text, subject heading word]
19. 7 and 18
20. (electromotiv$ or emda).mp. [mp=title, text, subject heading word]
21. 1 and 20 (0)
22. (blue adj5 cystoscop$).mp. [mp=title, text, subject heading word]
23. 1 and 22
24. 9 or 17 or 19 or 21 or 23
25. ((Urinar$ or urothel$) adj5 (bladder$ adj3 (neoplas$ or cancer$ or tumor$ or tumour$ or carcino$ or adenocarcin$ or malig$))).mp. [mp=title, text, subject heading word]
26. ((invas$ or invad$ or infiltrat$) adj5 muscl$).mp. [mp=title, text, subject heading word]
27. (t2$ or t3$).mp. [mp=title, text, subject heading word]
28. 26 or 27
29. 25 and 28
30. cystectom$.mp. [mp=title, text, subject heading word]
31. ((excis$ or remov$ or ((cut or cutting or cuts) adj3 (out or away))) adj5 bladder$).mp. [mp=title, text, subject heading word]
32. 30 or 31
33. (bladder$ adj5 (spare or sparing or spares or spared or preserv$)).mp. [mp=title, text, subject heading word]
34. (avoid$ adj7 cystectom$).mp.
35. 33 or 34
36. ((excis$ or remov$ or biops$ or ((cut or cutting or cuts) adj3 (out or away))) adj5 (lymph$ or node or nodes)).mp. [mp=title, text, subject heading word]
37. (adjuvant$ or neoadjuvant$).mp. [mp=title, text, subject heading word]
38. (abraxane or carboplatin$ or cisplatin$ or docetaxel or doxorubicin or epirubicin or 5-fluorouracil or gemcitabine or methotrexate or mitomycin or paclitaxel or valrubicin or vinblastin).mp. [mp=title, text, subject heading word]
39. 37 or 38
40. 32 or 35 or 36 or 39
41. 29 and 40
42. 24 or 41