# Addendum

This addendum details updated results for Key Question 3 (comparative effectiveness of intravesical therapies) and Key Question 6 (comparative effectiveness of fluorescent versus white light cystoscopy). An updated search using the same search strategy from the original report was conducted in September 2015. The methods used for this update were the same as in the original report.

## Key Question 3

We identified two additional trials (n=43 and 63) of adjuvant intravesical therapy versus TURBT alone.^1, 2^ One trial was rated medium risk of bias^1^ and the other high risk of bias.^2^ Both trials evaluated single dose therapy with MMC in patients with lower-risk NMIBC.

We updated the meta-analyses of MMC versus TURBT alone with the new trials. For recurrence, we also added data from a previously included trial that was omitted in the original report.^3^ The only outcomes that were affected in the new analysis were bladder cancer recurrence and progression; updated estimates and conclusions were generally similar to those in the original report (Table 1).

Table 1 Updated results for MMC versus no intravesical therapy (TURBT alone)

Intravesical Therapy | All-Cause Mortality | Bladder Cancer-Specific Mortality | Bladder Cancer Recurrence | Bladder Cancer Progression
MMC | 1 trial, HR 1.17, 95% CI 0.89 to 1.53 | 1 trial, HR 0.71, 95% CI 0.34 to 1.46 | 11 trials, RR 0.68, 95% CI 0.55 to 0.83, I^2^=74% | 7 trials, RR 0.65, 95% CI 0.38 to 1.11, I^2^=0%

BCG = bacillus Calmette Guérin; CI = confidence interval; RR = relative risk; HR = hazard ratio

Regarding head-to-head comparisons of intravesical therapies, we identified one additional trial (n=407, medium risk of bias) of intravesical BCG versus BCG plus MMC given sequentially.^4^ We updated the meta-analyses with the new study; we also added data on progression from a previously included trial^5^ that was omitted from the original report. Updated estimates and conclusions were similar to those in the original report (Table 2)

Table 2 Updated results for BCG versus BCG plus MMC given sequentially

Comparison | All-Cause Mortality | Bladder Cancer-Specific Mortality | Bladder Cancer Recurrence | Bladder Cancer Progression
BCG vs. BCG plus MMC given sequentially | 2 trials, RR 1.15, 95% CI 0.84 to 1.57, I^2^=0% | 3 trials, RR 1.27, 95% CI 0.76 to 2.12, I^2^=0% | 5 trials, RR 1.17, 95% CI 0.77 to 1.77, I^2^=77% | 5 trials, RR 0.86, 95% CI 0.61 to 1.22, I^2^=0%

BCG = bacillus Calmette Guérin; CI = confidence interval; MMC = mitomycin C; RR = risk ratio

For comparisons involving dose or duration, we identified one additional trial (n=166, medium risk of bias) that compared BCG Tokyo strain 40 mg versus 80 mg (each administered once weekly for eight weeks).^6^ It was consistent with two trials in the original report that found no clear difference between higher and lower doses of BCG. In the new trial, there was no clear difference between the lower and higher dose in risk of complete response (78% vs. 85%, p=0.12), recurrence-free survival (p=0.94), or progression (6.2% vs. 5.8%).^6^

## Key Question 6

We identified one new trial (n=85, medium risk of bias) of fluorescent cystoscopy plus white light cystoscopy versus white light cystoscopy alone that reported effects on bladder cancer recurrence.^7^ It found no clear difference between fluorescent plus white light cystoscopy versus white light cystoscopy alone in risk of recurrence through up to 40 months of follow-up (38% vs. 46%, RR 0.82, 95% CI 0.49 to 1.35), though results slightly favored fluorescent cystoscopy. All patients received a single instillation of epirubicin immediately following TURBT. There were also no differences between fluorescent versus white light cystoscopy when patients were stratified according to tumor risk category. The trial did not evaluate effects on progression or mortality. Patients were randomized to intravesical HAL or placebo administered one hour prior to white light cystoscopy, which was performed in all patients. Surgeons were blinded to treatment allocation until after white light cystoscopy was completed; only patients randomized to HAL underwent fluorescent cystoscopy.

We updated the meta-analyses on recurrence with data from the new trial. We also found errors in the data used for long-term recurrence and progression for one trial^8^ included in the original report and used corrected data in the updated meta-analysis. The updated analyses resulted in similar estimates and conclusions and are shown in Table 3. Estimates and overall conclusions were similar to those in the original report.

Table 3 Updated results for fluorescent cystoscopy versus white light cystoscopy

Outcome | Number of trials | Relative risk, fluorescent cystoscopy versus white light cystoscopy (95% confidence interval)^*^ | I^2^
Short-term (<3 months) recurrence | 9 | 0.59 (0.40 to 0.88) | 69%
HAL | 6 | 0.62 (0.38 to 1.00) | 51%
5-ALA | 4 | 0.57 (0.28 to 1.16) | 84%
Intermediate-term (3 months to <1 year) recurrence | 6 | 0.70 (0.56 to 0.88) | 19%
Long-term (≥1 year) recurrence | 12 | 0.81 (0.70 to 0.93) | 49%
HAL | 7 | 0.75 (0.62 to 0.92) | 41%
5-ALA | 5 | 0.86 (0.68 to 1.08) | 65%
Progression | 9 | 0.74 (0.52 to 1.03) | 0%
HAL | 4 | 0.51 (0.28 to 0.96) | 0%
5-ALA | 5 | 0.86 (0.57 to 1.28) | 0%
Mortality | 3 | 1.28 (0.55 to 2.95) | 43%

HAL=hexaminolevulinate, 5-ALA=aminolevulinic acid

* p for interaction based on photosensitizer used 0.97 for short-term recurrence, 0.41 for long-term recurrence, and 0.18 for progression

Study characteristics and risk of bias ratings for the additional studies are shown in Tables 4, 5 and 6.

Table 4 Characteristics and results of additional trials of intravesical therapy

Author, Year Risk of Bias | Inclusion Criteria | Population Characteristics | Intervention | Followup Duration | Main Results
Barghi, 2006^1^ Medium | Primary or papillary tumors, single tumors of 3 cm or less in size, and low-grade superficial tumors (TaG1, TaG2, T1G1) | Age, mean (years): 56 vs. 54 Male: 77% vs. 81% Recurrent bladder cancer: NR Ta: 73% vs. 71% T1: 28% vs. 29% G1: 91% vs. 91% G2: 9% vs. 9% | A: Mitomycin C 30 mg (in 30mL distilled water). Single instillation 6 to 24 hours after TURBT. Catheter clamped for 2 hours (n=22). B: Placebo (distilled water). Single instillation 6 to 24 hours after TURBT. Catheter clamped for 2 hours (n=21). | 24 months | Recurrence within 1 year: 4.5% (1/22) vs. 38.1% (8/21), p=0.007 Progression within 1 year: 0% (1/22) vs. 14.3% (3/21), p=0.06
El-Ghobashy, 2007^2^ High | 2 cm or less, single, papillary, primary or recurrent transitional cell carcinoma of the urinary bladder, who were disease free for more than 1 year. | Age, mean (years): 62.2 vs. 59.9 Sex: NR Recurrent bladder cancer: 9.7% vs. 13% Ta: 18% vs. 50% T1: 52% vs. 50% G1: 48% vs. 53% G2: 52% vs. 47% | A: Mitomycin, 30mg (in 50mL saline), instilled when hematuria stopped, usually within 6 hours of TURBT. Catheter clamped for 1 hour (n=31). B: No adjuvant treatment. TURBT alone (n=32). | Mean (months): 44 vs. 43 | Recurrence within two years: 16.1% (5/31) vs. 34.3% (11/32), p<0.05 Recurrence after 2 years: 26.9% (7/31) vs. 28.6% (6/32), non significant Progression: 3.2% (1/31) vs. 3.1% (1/32), non significant
Solsona, 2015^4^ Medium | Papillary NMIBC, TaG3 or T1G1-3 tumors, and Tis alone or associated with papillary tumors Ta-1G1-3 | Age: 65 vs. 66 years Male: 91% vs. 89% Recurrent bladder cancer: 29% vs. 35% Stage Ta: 17% vs. 16% Stage T1: 77% vs. 74% Grade G1: 16% vs. 10% Grade G2: 64% vs. 59% Grade G3: 20% vs. 31% | A: MMC, 30 mg (in 50 mL water), later reduced to 10 mg due to adverse effects one day prior to BCG Connaught, 1.5–5 × 108 CFU (in 50 mL water). Total 9 instillations; 6 weekly instillations starting 14 to 28 days after TURBT, then 3 instillations every 2 weeks (n=211). B: BCG Connaught, 1.5–5 × 108 CFU (in 50 mL water). Total 9 instillations; 6 weekly instillations starting 14 to 28 days after TURBT, then 3 instillations every 2 weeks (n=196). | Median (years): 7.1 years | Bladder cancer mortality: 4.7% (10/211) vs. 7.6% (15/196), RR 0.62 (95% CI 0.28 to 1.35) All-cause mortality: 24% (51/211) vs. 26% (52/196), RR 0.91 (95% CI 0.65 to 1.27) Recurrence (Ta, T1, or Tis tumor): 18% (38/211) vs. 33% (64/196), RR 0.55 (95% CI 0.39 to 0.78) Relapse (Ta, T1, Tis, or upper urinary tract tumor, prostatic urethral involvement, T2 or higher tumor, nodal involvement or metastasis): 21% (44/211) vs. 35% (68/196), RR 0.60 (95% CI 0.43 to 0.83)
Yokomizo, 2015^6^ Medium | CIS or unresectable NMIBC with CIS, age 20–85 | Age: 68 vs. 68 (CIS, n=155), 67 vs. 72 (no CIS, n=21) Male: 80% vs. 85% (CIS), 91% vs. 70% (no CIS) Race/ethnicity: Not reported Recurrent bladder cancer: 13% vs. 13% (CIS), 14% vs. 20% (no CIS) Stage Tis, pure (CIS): 49% vs. 36%, Stage Ta + Tis (CIS): 26% vs. 33% Stage T1 + Tis (CIS): 26% vs. 19% Stage Ta (no CIS): 55% vs. 70% Stage T1 (no CIS): 45% vs. 30% | A: BCG Tokyo strain, 40 mg once weekly for 8 weeks (n=81) B: BCG Tokyo strain, 80 mg once weekly for 8 weeks (n=85) | Median 3.6 years | Complete response (no residual tumor): 78% vs. 85% (p=0.12) Recurrence-free survival: p=0.94 Progression: 5/81 vs. 5/86

Table 5 Characteristics and selected results of an additional trial of fluorescent cystoscopy

Author, Year | Setting and Study Years | Interventions (number analyzed for recurrence) | Duration of Followup and Cystoscopic Followup Method | Population Characteristics by Treatment Group | Main Results
Gkritsios, 2014^7^ Medium | Greece Single center Study years not reported | A: White light and HAL fluorescent cystoscopy with TURBT (n=48) B: White light cystoscopy (n=37) All patients received single instillation of epirubicin 50 mg immediately following TURBT | Duration: up to 40 months (mean not reported) Method: White light cystoscopy | Age (mean): 66 vs. 68 years Male: 80% vs. 73% Stage: 76% vs. 70% Ta, 24% vs. 30% T1 and CIS Grade: 85% vs. 73% low grade, 15% vs. 27% high grade and CIS | Recurrence: Intermediate-term: 8.3% (4/48) vs. 11% (4/37) Long-term: 38% (18/48) vs. 46% (17/37)

Table 6 Risk of bias of additional trials

Author, Year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? (age, sex, race, smoking status-if available, bladder cancer stage) | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked? | Patient Masked? | Attrition Reported? | Overall loss to followup <20%? Differential attrition <10%? | Intention-to-Treat Analysis (analyzed by groups they were assigned to) | Postrandomization Exclusions | Outcomes Prespecified | Risk of Bias
Barghi, 2006^1^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Overall: Yes Differential: Unclear | Yes | Yes | Yes | Medium
El-Ghobashy, 2007^2^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Unclear | Yes | Unclear | Yes | High
Gkritsios, 2014^7^ | Yes | Unclear | Yes | Yes | Unclear | Yes | Unclear | Yes | Overall: Yes Differential: No | Yes | Yes | Yes | Medium
Solsona, 2015^4^ | Unclear | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes (36/443) | Yes | Medium
Yokomizo, 2016^6^ | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | Yes | Yes (13/171) | Yes | Medium

### References

1 Barghi MR, Rahmani MR, Hosseini Moghaddam SM, et al. (2006). Immediate intravesical instillation of mitomycin C after transurethral resection of bladder tumor in patients with low-risk superficial transitional cell carcinoma of bladder. Urol J.
2 El-Ghobashy S, El-Leithy TR, Roshdy MM, et al. (2007). Effectiveness of a single immediate mitomycin C instillation in patients with low risk superficial bladder cancer: short and long-term follow-up. J Egypt Natl Canc Inst.
3 Tolley DA, Parmar MK, Grigor KM, et al. (1996). The effect of intravesical mitomycin C on recurrence of newly diagnosed superficial bladder cancer: a further report with 7 years of follow up. J Urol.
4 Solsona E, Madero R, Chantada V, et al. (2015). Sequential combination of mitomycin C plus bacillus Calmette-Guerin (BCG) is more effective but more toxic than BCG alone in patients with non-muscle-invasive bladder cancer in intermediate- and high-risk patients: final outcome of CUETO 93009, a randomized prospective trial. Eur Urol.
5 Mohsen MAE, Shelbaia A, Ghobashy SE, et al. (2010). Sequential chemoimmunotherapy using mitomycin followed by bacillus Calmette-Guerin (MCC + BCG) versus single-agent immunotherapy (BCG) for recurrent superficial bladder tumors. UIJ.
6 Yokomizo A, Kanimoto Y, Okamura T, et al. (2016). Randomized controlled study of the efficacy, safety and quality of life with low dose bacillus Calmette-Guerin instillation therapy for nonmuscle invasive bladder cancer. J Urol.
7 Gkritsios P, Hatzimouratidis K, Kazantzidis S, et al. (2014). Hexaminolevulinate-guided transurethral resection of non-muscle-invasive bladder cancer does not reduce the recurrence rates after a 2-year follow-up: a prospective randomized trial. International Urology & Nephrology.
8 Stenzl A, Burger M, Fradet Y, et al. (2010). Hexaminolevulinate guided fluorescence cystoscopy reduces recurrence in patients with nonmuscle invasive bladder cancer. J Urol.