# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BCG: Bacillus Calmette-Guèrin
CER: Comparative Effectiveness Review
CI: Confidence interval
ECOG: Eastern Cooperative Oncology Group
FDA: U.S. Food and Drug Administration
HAL: Hexaminolevulinate
LR-: Negative likelihood ratio
LR+: Positive likelihood ratio
MMC: Mitomycin C
NMIBC: Non-muscle-invasive bladder cancer
PICOTS: Populations, interventions, comparators, outcomes, timing, and study designs
ROC: Receiver operating characteristic
SRC: Scientific Research Center
TEP: Technical Expert Panel
TOO: Task Order Officer
TURBT: Transurethral resection of the bladder tumor
WHO: World Health Organization