# Results

## Results of Literature Searches

The search and selection of articles are summarized in the literature flow diagram (Figure 2). Database searches resulted in 3,921 potentially relevant articles. After dual review of abstracts and titles, 295 articles were selected for full-text dual review, and 39 studies (in 41 publications) were determined to meet inclusion criteria and were included in this review. Data extraction and quality assessment tables for all included studies per Key Question are available in Appendixes E and F.

Figure 2 Literature flow diagram

^a^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews. ^b^ Other sources include prior reports, reference lists of relevant articles, systematic reviews, etc. ^c^ Some studies have multiple publications and some are included for more than one Key Question.

Figure 2 is a literature flow diagram depicting the search and selection of articles for the present review. The diagram shows that 3,921 abstracts of potentially relevant articles were identified by a research librarian experienced in conducting literature searches for CERs. The librarian searched in Ovid MEDLINE (January 1990 - October 2014), Cochrane Central Register of Controlled Trials (through September 2014), Cochrane Database of Systematic Reviews (through September 2014), Health Technology Assessment (through 3rd Quarter, 2014), National Health Sciences Economic Evaluation Database (through 3rd Quarter, 2014), and Database of Abstracts of Reviews of Effects (through 3rd Quarter, 2014) to capture both published and grey literature, as well as other sources, while 295 articles were reviewed at the full-text level after excluding 3,621 non-relevant abstracts and background articles. From the 295 articles reviewed for inclusion, 37 were excluded due to wrong population, 33 due to wrong intervention, 10 due to wrong outcomes, 60 due to wrong comparator, 26 due to wrong study design for key question, 33 due to wrong publication type, 27 due to non-English language but possibly relevant, 2 due to sample size too small and 23 due to being a systematic review or meta-analysis used only as a source document. After excluding these studies, 41 publications were included that provide evidence for any of the four Key Questions. The following numbers of studies were included: 9 studies for Key Question 1, 4 studies for Key Question 2, 1 study for Key Question 2a, 12 studies for Key Question 2b, 10 studies in 12 publications for Key Question 3, 3 studies for Key Question 3a, 7 studies for Key Question 3b, 5 studies for Key Question 3c, 6 studies for Key Question 3d, and 12 studies in 13 publications for Key Question 4. No studies were included for Key Questions 1a-c or 4a.

## Key Question 1 For patients with nonmetastatic muscle-invasive bladder cancer, what is the effectiveness of bladder-preserving treatments (chemotherapy, external beam or interstitial radiation therapy, partial cystectomy, and/or maximal transurethral resection of bladder tumor) for decreasing mortality or improving other outcomes (e.g., recurrence, metastasis, quality of life, functional status) compared with cystectomy alone or cystectomy in combination with chemotherapy?

### Key Points

- One high risk of bias randomized controlled trial (RCT) found no difference between bladder preserving external beam radiation therapy (60 Gray) versus radical cystectomy plus external beam radiation therapy (40 Gray) in median survival duration (18 vs. 20 months, p=0.21), but increased risk of local or regional recurrence (35.8% vs. 6.8%) (Strength of evidence [SOE]: insufficient).
- There was insufficient evidence from cohort studies and a nonrandomized controlled clinical trial to evaluate effects of bladder-preserving therapies versus radical cystectomy on risk of overall or bladder-specific mortality (seven studies) or local or regional recurrence (three studies), due to methodological shortcomings in the studies, inconsistent results, and imprecise estimates (SOE: insufficient).
- No study evaluated effects of bladder-sparing therapy versus radical cystectomy on quality of life (SOE: insufficient).

### Detailed Synthesis

One RCT,19 seven retrospective cohort studies,20-26 and one nonrandomized controlled clinical trial27 compared bladder-sparing therapy versus radical cystectomy either alone or in combination with chemotherapy in patients with clinically nonmetastatic muscle-invasive bladder cancer (Tables 2, 3; Appendix E). Tumor stage was reported in seven studies.19, 21-26 In addition to muscle-invasive bladder cancer, three studies included some patients with T1 tumors (proportion 2.3% to 24%),24-26 including one study restricted to patients with T1 and T2 cancers.25 One study was restricted to T2 tumors.23 No study reported the proportion of patients undergoing radical cystectomy found to have lymph node metastasis based on pathological staging, or described whether such patients were excluded from analyses.

Table 2 Characteristics of studies on bladder-preserving treatments

Author, Year | Country, Number of Centers, Study Years, Type of Study | Interventions (Sample Size) | Duration of Followup and Followup Method | Population Characteristics by Treatment Group (Age, Race/Ethnicity, Sex, Stage of Disease, Functional Status)
Bekelman, 2013^20^ | US Population-based SEER-Medicare data 1995-2005 Retrospective cohort | A: Bladder-sparing chemoradiation defined by TURBT, EBRT, and concurrent cisplatin-based chemotherapy (n=417) B: Radical cystectomy with or without lymphadenectomy (n=1426) | Not reported | Age (mean): 79.3 ± 6.0 vs. 75.4 ± 6.2 years Male: 72% vs. 63% Stage: Not reported Functional Status: Not reported
Goossens-Laan, 2014^21^ | Netherlands Population-based cancer registry data 1995-2009 Retrospective cohort | A: Radical cystectomy (n=835) B: EBRT (n=859) C: Interstitial radiotherapy/brachytherapy (n=172) D: Maximal TURBT (n=417) | Not reported | Age: crossover between groups allows total for each group to equal >100%. A: 52% 60, 43% 61-74, 13% 75+ B: 15% 60, 31% 61-74, 48% 75+ C: 10% 60, 9% 61-74, 3% 75+ D: 10% 60, 12% 61-74, 28% 75+ Male: 75% vs. 25% Stage: A: 25% stage 2, 59% stage 3, 30% stage 4 B: 43% stage 2, 24% stage 3, 23% stage 4 C: 10% stage 2, 3% stage 3, 1% stage 4 D: 23% stage 2, 8% stage 3, 16% stage 4 Functional Status: Not reported
Holmang, 1997^22^ | Sweden Population-based Swedish cancer registry data 1987-1988 Retrospective cohort | A: EBRT with 3-field box, 60 Gray or more (n=42) B: Radical TURBT alone (n=70) C: Radical cystectomy, unspecified number received preoperative radiotherapy, 2 of whom received preoperative chemotherapy, no routine lymphadenectomy (n=36) | ≥ 5 years, minimum available records, censored for deaths | Age: Not reported Sex: Not reported Stage: 79% vs. 63% vs. 83% T2 or T3, 21% vs. 37% vs. 17% T4a Functional Status: Not reported
James, 2012^28^ | United Kingdom 45 centers 2001-2011 Randomized trial | A: EBRT 55 Gy in 20 fractions over 4 weeks or 64 Gy in 32 fractions over 6.5 weeks, fluorouracil 500 mg/m2 during fraction 1 to 5 and 16 to 20 and mitomycin c 12 mg/m2 on day 1; 18 patients underwent modified volume radiotherapy (n=178) B: EBRT alone (n=182) | Median 70 months in group A | Age (median): 72 vs. 71 years Male: 82% vs. 79% Stage: 85% vs. 80% T2, 5.5% vs. 8.4% T3a, 3.8% vs. 3.9% T3b, 3.8% vs. 3.9% T4 WHO performance status 0-1: 97% vs. 97%
Kalogeras, 2008^23^ | Greece Single institution 1995-2006 Retrospective cohort | A: EBRT with box configuration, 64 Gray (n=119) B: Radical cystectomy, no perioperative radiotherapy, no note of lymphadenectomy (n=26) | 38 months (range 5-125 months) vs. 37 months (range 8-89 months), mean | Age: 33% vs. 38% < 70 years, 67% vs. 62% > 70 years Sex: Not reported Stage: all patients T2 Functional Status: Not reported
Kotwal, 2008^24^ | UK Single institution 1996-2000 Retrospective cohort | A: Radical radiotherapy with 50-55 Gray (n=97) B: Radical cystectomy (n=72), including lymphadenectomy in 52 patients | Not reported | Age (median): 75 years (range 42-99) vs. 68 years (range 37-85 years) vs. Male: 75% vs. 65% Stage: 9% vs. 19% Tis or T1, 38% vs. 31% T2, 49% vs. 43% T3 or T4a, 3% vs. 7% unknown Functional Status: Not reported
Nieuwenhuijzen, 2005^25^ | Netherlands Single institution 1988-2003 Retrospective cohort | A: EBRT with 30 Gray followed by brachytherapy (n=108), combined with partial cystectomy in 24 patients B: Radical cystectomy with lymphadenectomy (n=77) | Not reported | Age (median): 63 years (range 31-88) vs. 63 years (range 36-84) Male: 82% vs. 81% Stage: 16% vs. 36% T1, 84% vs. 64% T2 Tumor size: 71% vs. 16% < 3 cm, 24% vs. 14% 3-5 cm, 5% vs. 70% unknown size Functional Status: Not reported
Rincon Mayans, 2010^26^ | Spain Single institution 1994-2007 Retrospective cohort | A: EBRT with two regimens: from 1997-2003 patients received Taxol®-methotrexate-5-fluorouracil-cisplatin, 45-65 Gray concurrent with 5-fluorouracil-cisplatin, and 2 subsequent cycles of chemotherapy; from 2003-2007, patients received Taxol®-gemcitabine-cisplatin, IMRT with 55-65 Gray (n=43) B: Radical cystectomy, no perioperative radiotherapy, no note of lymphadenectomy (n=145) | 51 months vs. 29 months, mean 39 months vs. 18 months, median | Age: Not reported Sex: Not reported Stage: 47% vs. Not reported T1 or T2, 53% vs. Not reported for T3/T4 Functional Status: Not reported
Sell, 1997^19^ | Denmark Multicenter 1983-1986 Randomized controlled trial | A: Radical EBRT with 60 Gray (n=95) B: Preoperative EBRT with 40 Gray followed by radical cystectomy (n=88), including lymphadenectomy in 40/61 patients | 50 months, median, followup not further stratified | Age (mean): 61.3 years vs. 61.3 years Male: 80 vs. 82% Stage: 37% vs. 42% T2, 63% vs. 58%T3 or T4a Functional Status: Not reported
Solsona, 2009^27^ | Spain Multicenter 1980-1990 Nonrandomized clinical trial | A: Bladder-sparing cisplatin-based chemotherapy (n=75) B: Radical cystectomy with lymphadenectomy (n=71) | 84 months among those with a complete response to chemotherapy, no other followup reported | Age (median): 62 years vs. 64 years Male: 91% vs. 87% Stage: Not reported Functional Status: Not reported

EBRT = external beam radiation therapy; IMRT = intensity-modulated radiation therapy; RCT = randomized controlled trial; SEER = Surveillance, Epidemiology, and End Results program; T1 = tumor stage 1; T2 = tumor stage 2; T3 = tumor stage 3; T4 = tumor stage 4; T4a = tumor stage 4a; TURBT = transurethral resection of bladder tumor; UK = United Kingdom; US = United States

Table 3 Summary of results for studies of bladder-preserving treatments

Author, Year | Interventions (Sample Size) | Recurrence | Progression | Mortality
Bekelman, 2013^20^ | A: Bladder-sparing chemoradiation defined by TURBT, EBRT, and concurrent cisplatin-based chemotherapy (n=417) B: Radical cystectomy with or without lymphadenectomy (n=1426) | Not reported | Not reported | Overall survival: 28% vs. 47%; HR 0.79 (95% CI 0.67 to 0.93) in Cox proportional hazards model, HR 0.79 (95% CI 0.65 to 0.95) in propensity score-adjusted model, HR 0.94 (95% CI 0.76 to 1.28) in instrumental variable analysis Disease-specific survival: 52% vs. 65% at 5 years; HR 0.78 (95% CI 0.60 to 1.02) in Cox proportional hazards model (similar for propensity score-adjusted model), HR 1.06 (0.85 to 1.82) in instrumental variable analysis
Goossens-Laan, 2014^21^ | A: Radical cystectomy (n=835) B: EBRT (n=859) C: Interstitial radiotherapy/brachytherapy (n=172) D: Maximal TURBT (n=417) | Not reported | Not reported | Unadjusted 5-year survival, A vs. B vs. C vs. D: "Relative": 48% vs. 29% vs. 70% vs. 19%, no significance test
Holmang, 1997^22^ | A: EBRT with 3-field box, 60 Gray or more (n=42) B: Radical TURBT alone (n=70) C: Radical cystectomy, unspecified number received preoperative radiotherapy, 2 of whom received preoperative chemotherapy, no routine lymphadenectomy (n=36) | Not reported | Not reported | T2 or T3 tumors All-cause mortality: 85% (28/33) vs. 86% (38/44) vs. 67% (20/30); RR 1.27 (95% CI 0.95 to 1.70) for A vs. C, RR 1.30 (95% CI 0.98 to 1.71) for B vs. C, and RR 0.98 (95% CI 0.82 to 1.18) for A vs. B Bladder-cancer mortality: 82% (27/33) vs. 75% (33/44) vs. 57% (17/30); RR 1.44 (95% CI 1.02 to 2.05) for A vs. C, RR 1.32 (95% CI 0.93 to 1.89) for B vs. C, RR 1.09 (95% CI 0.86 to 1.38) for A vs. B T4 tumors All-cause mortality: 100% (9/9) vs. 100% (26/26) vs. 100% (6/6)
James, 2012^28^ | A: EBRT 55 Gy in 20 fractions over 4 weeks or 64 Gy in 32 fractions over 6.5 weeks, fluorouracil 500 mg/m2 during fraction 1 to 5 and 16 to 20 and mitomycin c 12 mg/m2 on day 1; 18 patients underwent modified volume radiotherapy (n=178) B: EBRT alone (n=182) | 2-year locoregional recurrence: 33% vs. 46%, HR 0.68 (95% CI 0.48-0.95) 5-year disease-free survival: difference 8.9% (favors A), HR 0.78 (95% CI 0.60 to 1.03) | 2-year invasive locoregional disease: 18% vs. 32%, HR 0.57 (95% CI 0.37 to 0.89) 5-year metastasis rate: difference 11%, HR 0.72 (95% CI 0.53 to 0.99) | Overall mortality: 55% (98/178) vs. 60% (110/182), RR 0.91 (95% CI 0.76 to 1.09) 5-year mortality: 52% vs. 65%, HR 0.82 (95% CI 0.63 to 1.09) favoring A Bladder cancer mortality: 42% (74/178) vs. 51% (92/182), HR 0.77 (95% CI 0.57 to 1.05)
Kalogeras, 2008^23^ | A: EBRT with box configuration, 64 Gray (n=119) B: Radical cystectomy, no perioperative radiotherapy, no note of lymphadenectomy (n=26) | Local disease control: 42% (50/119) vs. 88% (23/26), RR 0.48 (95% CI 0.37 to 0.61) | Distant metastasis: 16% (19/119) vs. 7.7% (2/26), RR 2.08 (95% CI 0.52 to 8.37) | 3-year overall survival: 39% vs. 69% (p=0.03)
Kotwal, 2008^24^ | A: Radical radiotherapy with 50-55 Gray (n=97) B: Radical cystectomy (n=72), including lymphadenectomy in 52 patients | Local or distant recurrence: 34% (33/97) vs. 38% (27/72), RR 0.91 (95% CI 0.60 to 1.36) | Not reported | All-cause mortality: 71% (69/97) vs. 62% (45/72), RR 1.14 (95% CI 0.91 to 1.42) Overall survival: 35% vs. 41% vs. at 5 years, 18% vs. 36% at 8 years (p=0.39) Bladder cancer mortality: 38% (37/97) vs. 44% (32/72), RR 0.86 (0.60 to 1.23) 5-year disease-specific survival: 57% vs. 53% (p=0.38)
Nieuwenhuijzen, 2005^25^ | A: EBRT with 30 Gray followed by brachytherapy (n=108), combined with partial cystectomy in 24 patients B: Radical cystectomy with lymphadenectomy (n=77) | Local recurrence: 21% vs. Not reported | Not reported | Overall survival: 62% vs. 67% at 5 years, 50% vs. 58% at 10 years; adjusted HR 0.62 (95% CI 0.28 to 1.43) Disease-specific survival: 73% vs. 72% at 5 years, 67% vs. 72% at 10 years; adjusted HR 0.5 (95% CI 0.20 to 1.25)
Rincon Mayans, 2010^26^ | A: EBRT with two regimens: from 1997-2003 patients received Taxol®-methotrexate-5-fluorouracil-cisplatin, 45-65 Gray concurrent with 5-fluorouracil-cisplatin, and 2 subsequent cycles of chemotherapy; from 2003-2007, patients received Taxol®-gemcitabine-cisplatin, IMRT with 55-65 Gray (n=43) B: Radical cystectomy, no perioperative radiotherapy, no note of lymphadenectomy (n=145) | Not reported | Progression-free survival: 69% vs. 72% at 3 years, 61% vs. 63% at 5 years (p=0.83) | Not reported
Sell, 1997^19^ | A: Radical EBRT with 60 Gray (n=95) B: Preoperative EBRT with 40 Gray followed by radical cystectomy (n=88), including lymphadenectomy in 40/61 patients | Local recurrence: 35.8% (34/95) vs. 6.8% (6/88), RR 5.25 (95% CI 2.31 to 11.9) | Distant metastasis: 31.5% (30/95) vs. 34.0% (30/88), RR 1.08, 95% CI 0.71 to 1.63 | Overall survival (median): 18 vs. 20 months (p=0.21)
Solsona, 2009^27^ | A: Bladder-sparing cisplatin-based chemotherapy (n=75) B: Radical cystectomy with lymphadenectomy (n=71) | Need for cystectomy: 72% (54/75) vs. N/A | Not reported | 5-year disease-specific survival: 65% vs. Not reported

CI = confidence interval; EBRT = external beam radiation therapy; HR = hazard ratio; IMRT = intensity modulated radiation therapy; N/A = not applicable; RR=relative risk; TURBT = transurethral resection of bladder tumor

The interventions evaluated in the studies varied. The RCT evaluated bladder-sparing radical external beam radiation therapy with 60 Gray versus preoperative external beam radiation therapy with 40 Gray followed by radical cystectomy.19 In three cohort studies, the bladder-sparing therapy was radical external beam radiation therapy with at least 55 Gray, though the amount of conformal radiation delivered was less than in contemporary techniques.22-24 One of these studies also included patients who underwent bladder-preserving therapy primarily with maximal transurethral resection of bladder tumor (TURBT), though some patients also received lower dose (21 Gray) radiation therapy.22 Another cohort study evaluated bladder-sparing therapy with external beam radiation therapy with 30 Gray combined with brachytherapy delivered through a suprapubic cystotomy, with or without partial cystectomy depending on initial response.25 Two cohort studies evaluated bladder-sparing therapy that included both radiation therapy and chemotherapy.20, 26 One of these was a population-based study conducted in the United States, in which bladder-sparing therapy consisted of the combination of TURBT, external beam radiation therapy of variable dosing, and concurrent cisplatin-based chemotherapy.20 The other was a single institution Spanish study that evaluated two bladder-sparing regimens depending on the time period: from 1997-2003, chemotherapy with paclitaxel, methotrexate, 5-fluorouracil, and cisplatin for two cycles, followed by external beam radiation therapy with 45-65 Gray concurrent with 5-fluorouracil and cisplatin, then an additional two cycles of the first chemotherapy regimen; from 2003-2007, chemotherapy with paclitaxel, gemcitabine, and cisplatin for two cycles, followed by intensity-modulated radiation therapy with 55-65 Gray, then an additional two cycles of the first chemotherapy regimen.26 A cohort study based on population-based registry data from the Netherlands compared external beam radiation therapy, brachytherapy, TURBT, or radical cystectomy, but did not provide details about the interventions.21 The non-RCT evaluated bladder-sparing therapy with one of three cisplatin-based chemotherapy regimens.27 In two studies, comparison groups were not entirely concurrent (i.e., patients tended to receive one intervention during an earlier time period and a different intervention at a later time period).23, 25

Sample sizes ranged from 145 to 2,455 patients. Duration of followup was reported in six studies and ranged from a median of 18 months26 to at least 5 years.22 One study was conducted in the United States20 and the other eight were conducted in Europe. All studies had methodological limitations (Appendix F). The RCT was rated high risk of bias.19 Methodological shortcomings included baseline differences between treatment groups and poor reporting of attrition and loss to followup. In addition, its applicability to current practice is uncertain as it used radiation therapy regimens and surgical techniques that appeared outdated. Two nonrandomized studies were rated medium risk of bias20, 25 and six were rated high risk of bias. Methodological shortcomings in the nonrandomized studies included failure to report enrollment of a consecutive or random sample and poorly reported methods for ascertaining potential confounders. The high risk of bias nonrandomizedstudies did not attempt to adjust for potential confounders21-23, 26, 27 or did not clearly report the results of adjusted analyses or the factors adjusted for.24 Four cohort studies were conducted in single institutions.23-26 Three other cohort studies evaluated population-based data20-22 and the nonrandomized controlled clinical trial evaluated multi-institutional27 data.

#### Mortality

Seven studies evaluated overall survival with bladder-sparing therapies versus radical cystectomy.19-25 In one RCT (n=183), there was no difference between bladder-sparing therapy with external beam radiation therapy (60 Gray) versus radical cystectomy plus external beam radiation therapy (40 Gray) in median survival duration (18 versus 20 months, p=0.21).19 A population-based cohort study (n=1,843) found bladder-sparing therapy associated with decreased likelihood of 5-year survival versus radical cystectomy (27.9% vs. 46.5%).20 In multivariate analyses, the difference was statistically significant in a Cox proportional hazards analysis that adjusted for age, sex, comorbid conditions, race/ethnicity, marital status, and socioeconomic, physician, and hospital factors (HR for mortality 0.79, 95% CI 0.67 to 0.93) and in a propensity-adjusted analysis (HR 0.79, 95 CI 0.65 to 0.95). However, the difference was not statistically significant in an instrumental variable analysis (HR 0.94, 95% CI 0.76 to 1.28) that used local area cystectomy rate as the instrumental variable. A retrospective cohort study (n =108) also found radical cystectomy associated with higher likelihood of survival (50% vs. 58% at 10 years) after adjustment for age, tumor stage, nodal status, grade, and tumor multiplicity, though the difference was not statistically significant (HR 0.62, 95% CI 0.28 to 1.43).25 Four other cohort studies evaluated all-cause mortality but did not attempt to adjust for potential confounders.21-24 In one study (n=148), both radiation therapy and maximal TURBT were associated with increased risk of 5-year all-cause mortality in patients with T2 and T3 tumors, though the differences were not statistically significant (85% vs. 86% vs. 67%, RR 1.27, 95% CI 0.95 to 1.70 and RR 1.30, 95% CI 0.98 to 1.71 for radiation therapy versus radical cystectomy and maximal TURBT versus radical cystectomy, respectively).22 All patients with T4a bladder cancer in this study died, including 9 patients who underwent radiation therapy, 26 who underwent maximal TURBT, and 6 who underwent radical cystectomy. One study (n=169) found external beam radiation therapy with at least 55 Gray associated with decreased likelihood of 5-year survival (35% vs. 41%) and 8-year survival (18% vs. 36%), though the difference was not statistically significant (p=0.39).24 Another study (n=145) found radiotherapy associated with decreased likelihood of survival at 3 years versus radical cystectomy (39% vs. 69%, p=0.03).23 One study (n=2,455) found brachytherapy associated with higher unadjusted 5-year survival than radical cystectomy, external beam radiation therapy, or TURBT alone (70% vs. 48%, 29%, and 19%, respectively), but there were substantial differences between groups in age and bladder cancer stage.21

Four cohort studies evaluated effects of bladder sparing therapy versus radical cystectomy on risk of bladder cancer-specific mortality, but results were inconsistent.20, 22, 24, 25 The population-based U.S. study (n=1,843) found bladder-sparing chemotherapy and radiation associated with lower likelihood of 5-year disease specific survival versus radical cystectomy, though the difference was not statistically significant (52% vs. 65%, adjusted HR 0.78, 95% CI 0.60 to 1.02).20 Another study (n=185) found the combination of external beam radiation therapy followed by brachytherapy associated with lower likelihood of disease-specific survival versus radical cystectomy after adjustment for age, tumor stage, nodal status, and tumor multiplicity (67% vs. 72% at 10 years, HR 0.50, 95% CI 0.20 to 1.25), though the difference was not statistically significant.25 Two other cohort studies did not adjust for potential confounders.22, 24 One study (n=148) found bladder-preserving radiation therapy or maximal TURBT each associated with increased risk of 5-year bladder cancer-specific mortality versus radical cystectomy in patients with T2 or T3 tumors (82% vs. 75% vs. 57%), though the difference was only statistically significant for radiation therapy (RR 1.44, 95% CI 1.02 to 2.05).22 The other study (n=169) found no difference between external beam radiation therapy with at least 55 Gray versus radical cystectomy in 5-year disease-specific survival (57% vs. 53%, p=0.38).24

#### Local and Regional Recurrence and Progression

Two studies evaluated effects of bladder-sparing therapy on local or regional recurrence.19, 23 In one RCT (n=183), bladder-sparing external beam radiation therapy (60 Gray) was associated with increased risk of local or regional recurrence versus radical cystectomy plus external beam radiation therapy (40 Gray) over a median followup of 50 months (35.8% vs. 6.8%, RR 5.25, 95% CI 2.31 to 11.9).19 A cohort study (n=145) found bladder-sparing therapy associated with lower likelihood of achieving local disease control (42% vs. 88% RR 0.48, 95% CI 0.37 to 0.61) and higher likelihood of developing distant metastases (16% vs.7.7%, RR 2.08, 95% CI 0.52 to 8.37), but the estimate for metastases was imprecise and the study did not perform statistical adjustment for potential confounders.23

One cohort study found no difference between radical cystectomy versus radiation therapy in risk of local recurrence or distant progression (34% vs. 38%, RR 0.91, 95% CI 0.60 to 1.36).24 Another cohort study found no difference between bladder-sparing chemotherapy and radiation versus radical cystectomy in unadjusted progression free survival (local or distant) (61% vs. 63% at 5 years, p=0.83).26 One non-randomized controlled clinical trial found that 72% (54/75) of patients who underwent bladder-sparing cisplatin-based chemotherapy as monotherapy subsequently required salvage radical cystectomy.27 The proportion that underwent cystectomy was not explicitly reported in the other studies.

##### Quality of Life

No study evaluated effects of bladder-sparing therapy versus radical cystectomy on quality of life.

## Key Question 1a Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers?

### Key Points

- No study evaluated how estimates of effectiveness of bladder-sparing therapy versus radical cystectomy vary in subgroups defined by tumor characteristics such as stage, grade, size, or molecular or genetic markers (SOE: insufficient).

### Detailed Synthesis

No studies.

## Key Question 1b Does the comparative effectiveness differ according to patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease?

### Key Points

- No study evaluated how estimates of effectiveness of bladder-sparing therapy versus radical cystectomy vary in subgroups defined by patient characteristics such as age, sex, race/ethnicity, performance status, or comorbidities (including chronic kidney disease) (SOE: insufficient).

### Detailed Synthesis

No studies.

## Key Question 1c What is the comparative effectiveness of various combinations of agents and/or radiation therapy used for bladder-preserving chemotherapy?

### Key Points

- No study compared the effectiveness of different combinations of chemotherapeutic agents and/or radiation treatment (SOE: insufficient).

### Detailed Synthesis

No study compared the effectiveness of different combinations of chemotherapeutic agents and/or radiation treatment. Although three studies included different chemotherapy regimens in their bladder-sparing therapy treatment groups,20, 26, 27 they did not analyze the comparative effectiveness of different chemotherapy regimens on clinical outcomes.

## Key Question 1d What is the effectiveness of different bladder-preserving treatments (chemotherapy, external beam or interstitial radiation therapy, partial cystectomy, and/or maximal transurethral resection of bladder tumor) compared with one another?

### Key Points

- One RCT found external beam radiation therapy with synchronous chemotherapy associated with lower likelihood of 2-year locoregional recurrence (33% vs. 46%, HR 0.68, 95% CI 0.48 to 0.95) and 5-year metastasis (HR 0.72, 95% CI 0.53 to 0.99) and trends towards decreased risk of overall (52% vs. 65%, HR 0.82, 95% CI 0.63 to 1.09) and bladder cancer-specific mortality (42% vs. 51%, HR 0.77, 95% CI 0.57 to 1.05) versus radiation therapy alone (SOE: low).
- There was insufficient evidence from one cohort study with serious methodological limitations to determine the comparative effectiveness of bladder-preserving radiation therapy versus maximal TURBT (SOE: insufficient).

### Detailed Synthesis

One RCT found external beam radiation therapy with synchronous chemotherapy with fluorouracil and mitomycin C associated with lower likelihood of 2-year locoregional recurrence (33% vs. 46%, HR 0.68, 95% CI 0.48 to 0.95) or invasive locoregional disease (18% vs. 32%, HR 0.57, 95% CI 0.37 to 0.89), and 5-year metastasis (HR 0.72, 95% CI 0.53 to 0.99) versus radiation therapy without chemotherapy in patients with T2 to T4a tumors.28 Effects were similar in subgroups that received different radiotherapy or according to receipt of neoadjuvant chemotherapy (about one-third of patients in both groups). Although chemoradiotherapy also was associated with lower risk of overall (52% vs. 65% at 5 years, HR 0.82, 95% CI 0.63 to 1.09) and bladder cancer mortality (42% vs. 51%, HR 0.77, 95% CI 0.57 to 1.05), differences were not statistically significant. The trial was not blinded and was rated medium risk of bias.

One cohort study found no difference between bladder-preserving radiation therapy versus maximal TURBT in all-cause (85% vs. 86%, RR 0.98, 95% CI 0.82 to 1.18) or bladder cancer-specific mortality (82% vs. 75%, RR 1.09, 95% CI 0.86 to 1.38) at 5 years in patients with T2 or T3 tumors.22 It did not adjust for potential confounders and was rated high risk of bias.

## Key Question 2 For patients with clinically nonmetastatic muscle-invasive bladder cancer that is treated with cystectomy, does regional lymph node dissection improve outcomes compared with cystectomy alone?

### Key Points

- Three cohort studies found regional lymph node dissection associated with lower risk of mortality than no lymph dissection; two cohort studies examined the same population-based database and one did not perform statistical adjustment for potential confounders (SOE: low).

### Detailed Synthesis

Four retrospective cohort studies evaluated effects of radical cystectomy with regional lymph node dissection versus radical cystectomy without regional lymph node dissection. (Tables 4, 5; Appendix E).29-32 Two were U.S. population-based studies based on Surveillance, Epidemiology, and End Results (SEER) program data (n=11,183 and n=1,923),29, 31 one (n=268) was a secondary analysis of a multicenter RCT of neoadjuvant chemotherapy before cystectomy,33 and one (n=169) was a single institution series from Japan.32 All four studies included patients of all stage classifications. In one study duration of followup was at least 2 years but otherwise not specified31 and in the other three studies duration of followup was not reported. All four studies had methodological shortcomings, including baseline differences between treatment groups, poor reporting of attrition, and failure to adjust for potential confounders (Appendix F).

Table 4 Characteristics of studies on lymph node dissection with radical cystectomy

Author, Year | Country, Number of Centers, Study Years, Type of Study | Interventions (Sample Size) | Duration of Followup and Followup Method | Population Characteristics by Treatment Group (Age, Race/Ethnicity, Sex, Stage of Disease, Functional Status)
Abdollah, 2012^29^ | USA 1988-2006 Retrospective cohort | A: Cystectomy with extended lymph node dissection (≥10 lymph nodes removed and examined) (A +B n= 8394) B: Cystectomy with limited lymph node dissection (<10 lymph nodes removed and examined) C: Cystectomy without pelvic lymph node dissection (n=2789) | Not reported | A+B vs. C Age (mean): 67.1 vs. 68.8, p<0.001 Male: 75% vs. 73%, p<0.01 Caucasian:90% vs. 90% Stage: Ta/Tis:2% vs. 6% T1: 10% vs. 15% T2: 38% vs. 43% T3: 30% vs. 18% T4: 20% vs. 18%; p<0.001 Grade: G1/G2: 7% vs. 12% G3: 53% vs. 56% G4: 40% vs. 32%; p<0.001 Functional status: Not reported
Brossner, 2004^34^ | Austria and Italy Two centers 1998-2002 Retrospective cohort | A (Italian cohort): Cystoprostatectomy in men or pelvectomy in women, with "extended" lymphadenectomy, including the perivesical, hypogastric, obturator, external iliac, common iliac and aortal lymph nodes, into the region of the inferior mesenteric artery (n=46). B (Austrian cohort): Cystoprostatectomy in men or pelvectomy in women, with "minimal" lymphadenectomy, including perivesical lymph nodes and lymphatic tissue of the obturator fossa, confined laterally by the external iliac vein and medial by the obturator nerve (n=46). | 30 days Unclear method of followup | Age (mean): 66.3 vs. 68.2 years Race/Ethnicity: Not reported Male: Not reported Stage: pT1: 4 vs. 6; pT2-3a: 24 vs. 18; pT3b-4: 18 vs. 22; Node positive: 18 vs. 10 Functional Status: Not reported
Brunocilla, 2013^35^ | Italy 1995-2011 Retrospective cohort | A: Limited template: Cystectomy including external and obturator lymph nodes; or no lymphadenectomy (n=116) B: Standard template: Cystectomy including external, obturator, internal iliac, and 2 cm common iliac lymph nodes up to the cross with the ureters (n=94) C: Extended template: Cystectomy including external, obturator, internal iliac, presacral, and complete common iliac lymph nodes up to the aortic bifurcation (n=39) D: Super-extended template: Cystectomy including external, obturator, internal iliac, presacral, complete common iliac lymph nodes up to the aortic bifurcation, preaortic and precaval lymph nodes up to inferior mesenteric artery (n=23) Selection of template was based on preference and skills of the surgeons | Mean: 59.2±44.3 months | Reported for 0-14 lymph nodes removed (n=128) vs. ≥14 lymph nodes removed (n=154): Age (mean): 69.6±8.4 vs. 667.3±8.1; p=0.010 Male: 82.8% vs. 83.1% Race/Ethnicity: Not reported Stage: T0: 18% vs. 12% T1: 16% vs. 13% T2: 19% vs. 27% T3: 29% vs. 32% T4: 18% vs. 16% Tumor Grade: G1-G2: 25% vs. 22% G3: 75% vs. 78% Functional status: Not reported
Dhar, 2008^36^ | USA and Switzerland Two centers 1987-2000 Retrospective cohort | A (Switzerland cohort): Cystectomy with extended lymphadenectomy, with cephalad dissection extended to the crossing of the ureters with the common iliac arteries and removal of all tissue along the lateral and medial portion of internal iliac vessels. (n=322). B (USA cohort): Cystectomy with limited lymphadenectomy, with boundaries of the pelvic sidewall between the genitofemoral and obturator nerves, and bifurcation of the iliac vessels to the circumflex iliac vein. (n=336). | 5 years A: Every 6 months for 2 years and annually thereafter. B: 3 and 6 months after surgery, 6-month intervals until 5 years and annually thereafter. | Age (median): 66.9 vs. 61.6 years, p<0.001 Race/Ethnicity: Not reported Male: 78% vs. 79% Stage: Not reported Functional status: Not reported
Herr, 2002^30^ | USA Single center 1980-1990 Retrospective cohort | A: Radical cystectomy with standard lymphadenectomy, including the distal common iliac, external iliac, hypogastric, obturator, presacral and perivesical lymph nodes (n=not reported) B: Cystectomy with limited lymphadenectomy, with obturator and perivesical lymph nodes removed en bloc with the bladder. (n=not reported) | Minimum 10 years | Age: Not reported Male: Not reported Race/Ethnicity: Not reported Stage: 188 T2, 134 T2-T3 Functional status: Not reported
Herr, 2004^33^ | USA Multiple centers 1987-1998 Reanalysis of RCT | A: Cystectomy with standard lymphadenectomy (n=146), median 15 lymph nodes B: Cystectomy with limited lymphadenectomy (n=98), median 7 lymph nodes C: Cystectomy with no lymphadenectomy (n=24) | Until death | Overall characteristics, not reported by treatment group: Age: 148/268 <65 years, 120/268 ≥ 65 years Male 81% (216/268) Race/Ethnicity: Not reported Stage: 69% (184/268) T0-T2 31% (84/268) T3-T4 Functional status: 100% SWOG 0 or 1
Konety, 2003^31^ | USA Population based study (SEER data) 1988-1996 Retrospective cohort | Patients with bladder cancer who underwent cystectomy, number of lymph nodes examined: 0 (n=645), 1-3 (n=203), 4-6 (n=239), 7-9 (n=164), 10-14 (n=163), 15-19 (n=106), ≥20 (n=81), missing data (n=322) | Minimum 2 years; Median in surviving post-cystectomy patients: 63.5 months | Age: <35: 70 (3.6%); 35-44: 86 (4.5%); 45-54: 237 (12.3%); 55-64: 476 (24.8%); 65-74: 681 (35.4%); 75-84: 349 (18.2%); ≥85: 24 (1.3%) Race/Ethnicity: White: 1698/1923 (93.6%); Black: 117/1923 (6.5%) Male: 1265/1923 (65.8%) Stage: In situ or 1: 150 (12.9%); Stage 2: 249 (21.4%); Stage 3: 300 (25.8%); Stage 4: 465 (39.9%); missing: 759 Functional status: Not reported
Leissner, 2000^37^ | Germany Single center 1986-1997 Retrospective cohort | Patients with bladder cancer who underwent cystectomy, number of lymph nodes examined: 1-5, 6-10, 11-15, 16-20, and >20 (N=447) | Minimum 2 years; Mean: 38.7 months | Age: 62.8 years Male: male: female ratio 4.5:1 Race/Ethnicity: Not reported Smoking status: Not reported Stage of disease (for all patients with radical cystectomy): pTis: 15 (3.4%); pT1: 100 (22.4%); pT2a: 88 (19.7%); pT2b: 51(11.4%); pT3: 146 (32.7%); pT4: 47 (10.5%) Tumor grade: Not reported Functional status: Not reported
Poulsen, 1998^38^ | Denmark Single center 1990-1997 Retrospective cohort | A: Radical cystectomy with extended lymphadenectomy, bounded proximally by bifurcation of the aorta, laterally by the genitofemoral nerve, distally by the circumflex iliac vein and Cloquet's lymph node and posteriorly by the internal ileac vessel, including the presacral nodes and obturator fossa (n=126) B: Cystectomy with limited lymphadenectomy, bounded proximally by bifurcation of the common iliac vessels, while the lateral, distal and posterior boundaries were the same as for the extended dissection, including dissection of the obturator fossa. (n=68) | 4-month intervals for the first year, then annually. | Age, mean: 61.8 vs. 63.2 years Race/Ethnicity: Not reported Male: 102/126 vs. 55/68 Stage: T0-Ta: 7.1% vs. 5.9%; Tis: 13.5% vs. 5.9%; T1: 12.7% vs. 25%; T2: 10.3% vs. 13.2%; T3a: 13.5% vs. 16.2%; T3b: 35.7% vs. 29.4%; T4a: 4.0% vs. 1.5%; T4b: 1.6% vs. 1.5%; prostate: 0.8% vs. 1.5%; adenocarcinoma: 0.8% vs. 0% Functional status: Not reported
Shirotake, 2010^32^ | Japan Single center 1987-2008 Retrospective cohort | A: Cystectomy with lymphadenectomy (n=107) B: Cystectomy without lymphadenectomy (n=62, includes those without lymphadenectomy or unknown number of nodes removed) Neoadjuvant chemotherapy, n=16, mostly T3-4 Adjuvant chemotherapy, n=26, T3-4 or Node positive | 3-month intervals for 2 years and every 6 months thereafter | Age, mean: 67.65 vs. 69.4 years Race/Ethnicity: Not reported Male: overall 127/169 Stage: ≤T2: 52/107 vs. 34/62; T3-4: 55/107 vs. 28/62 Functional status: Not reported
Simone, 2013^40^ | Italy Two centers 2002-2010 Retrospective cohort | A: Cystectomy with extended lymphadenectomy, dissected nodes up to and, in some cases, above the aortic bifurcation including the presacral nodes (n=349) B: Cystectomy with standard lymphadenectomy, dissected nodes with an upper boundary at the iliac bifurcation (not including presacral and common nodes) (n=584) | Not reported | Age, mean: 65.4 years vs. 66.9 years Race/Ethnicity: Not reported Male: 309/349 vs. 502/584 Stage: T0, a, is, 1: 94/349 vs. 140/584; T2: 98/349 vs. 131/584; T3: 108/349 vs. 235/584; T4: 49/349 vs. 78/584 Functional status: Not reported
Zehnder, 2011^39^ | USA and Switzerland Two centers 1985-2005 Retrospective cohort | A (USA cohort): Cystectomy with lymphadenectomy, pure intrapelvic template plus removal of lymphatic tissue along the common iliac vessels, the distal vena cava/aorta to the IMA takeoff and complete dissection of the presacral space from the bifurcation of the aorta into the sacral fossa. (n=554) B (Switzerland cohort): Cystectomy with lymphadenectomy, pure intrapelvic template ended proximally at the mid-upper third of the common iliac vessels, included the presacral region medial to the internal iliac vessels but left tissue containing the hypogastric nerves located medial to the retracted ureters and inferior to the aortic bifurcation (n=405) Both groups used pure intrapelvic template for lymphadenectomy, with boundaries of the genitofemoral nerve and the pelvic side wall laterally, the circumflex iliac vein and Cloquet's node distally, the obturator fossa with full exposure of the intrapelvic course of the obturator nerve and the internal iliac vessels posteriorly, and the tissue medial to these vessels. | A: 4-month intervals in year 1, 6-month intervals in year 2, annually thereafter; Median followup: 10.9 years B: 3, 6, 12 months postoperatively, annually thereafter; Median followup: 9.9 years | Age, median: 67 vs. 67 years Race/Ethnicity: Not reported Male: 421/554 vs. 314/405 Stage: T2: 253/554 vs. 169/554; T3: 301/554 vs. 236/405 Functional status: Not reported

pT1 = tumor stage 1 determined by pathology; pT2 = tumor stage 2 determined by pathology; pT3a = tumor stage 3a determined by pathology; pT3b = tumor stage 3b determined by pathology; pT4 = tumor stage 4 determined by pathology; SEER = Surveillance, Epidemiology and End Results Program; T0 = tumor stage 0; T1 = tumor stage 1; T2 = tumor stage 2; T3 = tumor stage 3; T3a = tumor stage 3a; T3b = tumor stage 3b; T4 = tumor stage 4; T4a = tumor stage 4a; Ta = tumor stage a; Tis = tumor stage is; US = United States

Table 5 Summary of results for studies of lymph node dissection

Author, Year | Interventions | Recurrence | Progression | Mortality
Abdollah, 2012^29^ | A: Cystectomy with extended lymph node dissection (≥10 lymph nodes removed and examined) (A +B n= 8394) B: Cystectomy with limited lymph node dissection (<10 lymph nodes removed and examined) C: Cystectomy without pelvic lymph node dissection (n=2789) | Not Reported | Not Reported | A+B vs. C Adjusted HR (95%CI): 10-year cancer-specific mortality-free: 1.33 (1.24-1.44) Ta/Tis: 2.09 (1.16-3.79) T1: 1.60 (1.18-2.17) T2: 1.68 (1.47-1.91) T3: 1.15 (1.01-1.33) T4: 1.11 (0.9-1.28) 10-year overall mortality-free: 1.29 (1.22-1.37) Ta/Tis: 1.49 (1.02-2.17) T1: 1.29 (1.06-1.57) T2: 1.44 (1.31-1.58) T3: 1.13 (1.01-1.28) T4: 1.24 (1.11-1.39) A vs. B 10-year cancer-specific mortality-free rates: 62.2% vs. 54.0% (log rank p<0.001) Ta/Tis: 70.8% vs. 85.7%, p=0.1 T1:85.8% vs. 78.%,p=0.01 T2:76.1% vs67.7%,p<0.001 T3: 48.7% vs 39.7%,p<0.001 T4: 38.6% vs 32.5%,p=0.02 10-year overall mortality –free rates: 39.4% vs. 30.3% (log rank p<0.001) Ta/Tis:39.1% vs 63.3%,p=0.05 T1:66.7% vs 51.2%,p<0.001 T2:50.0% vs 40.4%,p<0.001 T3:28.2% vs 19.7%,p<0.001 T4:21.5% vs 14.8%,p<0.001
Brossner, 2004^34^ | A (Italian cohort): Cystoprostatectomy in men or pelvectomy in women, with "extended" lymphadenectomy, including the perivesical, hypogastric, obturator, external iliac, common iliac and aortal lymph nodes, into the region of the inferior mesenteric artery (n=46). B (Austrian cohort): Cystoprostatectomy in men or pelvectomy in women, with "minimal" lymphadenectomy, including perivesical lymph nodes and lymphatic tissue of the obturator fossa, confined laterally by the external iliac vein and medial by the obturator nerve (n=46). | Not reported | Not reported | Perioperative mortality: 2.2% (1/46) (pulmonary embolus) vs. 4.3% (2/46) (pneumonia) vs. 2.2% (1/46) (pulmonary embolus), RR 0.50 (95% CI 0.047 to 5.32)
Brunocilla, 2013^35^ | A: Limited template: Cystectomy including external and obturator lymph nodes; or no lymphadenectomy (n=116) B: Standard template: Cystectomy including external, obturator, internal iliac, and 2 cm common iliac lymph nodes up to the cross with the ureters (n=94) C: Extended template: Cystectomy including external, obturator, internal iliac, presacral, and complete common iliac lymph nodes up to the aortic bifurcation (n=39) D: Super-extended template: Cystectomy including external, obturator, internal iliac, presacral, complete common iliac lymph nodes up to the aortic bifurcation, preaortic and precaval lymph nodes up to inferior mesenteric artery (n=23) Selection of template was based on preference and skills of the surgeons | Not reported | Not reported | Cancer-specific survival, hazard ratio (95%CI) Univariable: B vs. A: 0.828 (0.547-1.255) C vs. A: 0.350 (0.221-0.740) ≥14 lymph nodes removed vs. 0-14 lymph nodes removed: 0.576 (0.382-0.847) Multivariable: B vs. A: 0.986 (0.547-1.354) C vs. A: 0.455 (0.365-0.894) ≥14 lymph nodes removed vs. 0-14 lymph nodes removed: 0.556 (0.282-0.995)
Dhar, 2008^36^ | A (Switzerland cohort): Cystectomy with extended lymphadenectomy, with cephalad dissection extended to the crossing of the ureters with the common iliac arteries and removal of all tissue along the lateral and medial portion of internal iliac vessels. (n=322). B (USA cohort): Cystectomy with limited lymphadenectomy, with boundaries of the pelvic sidewall between the genitofemoral and obturator nerves, and bifurcation of the iliac vessels to the circumflex iliac vein. (n=336). | A vs. B 5 year recurrence-free survival(median followup: 40 vs. 25, p<0.001) pT2: 63% vs. 71%, p=0.10 pT3: 49% vs. 19%, p<0.0001 | A vs. B Progression (local or systemic): 40% (130/322) vs. 55% (184/336), RR 0.74 (95% CI 0.63 to 0.87) Local progression (p for log-rank test): pT2: 4% vs. 24%, p<0.0001 pT3: 10% vs. 60%, p<0.0001 Systemic progression (includes those with both local and systemic progression): pT2: 27% vs. 14%, p=0.0048 pT3: 45% vs. 20%, p=0.0012 | A vs. B 5 year overall survival (median followup: 51 vs. 36 months, p<0.001) pT2: 61% vs. 64%, p=0.10 pT3: 42% vs. 22%, p=0.0002
Herr, 2002^30^ | A: Radical cystectomy with standard lymphadenectomy, including the distal common iliac, external iliac, hypogastric, obturator,presacral and perivesical lymph nodes (n=not reported) B: Cystectomy with limited lymphadenectomy, with obturator and perivesical lymph nodes removed en bloc with the bladder. (n=not reported) | Local recurrence (uncertain followup): No patients: 5% (7/131) when 8 or more nodes, 24% (31/127) when 1-8 nodes, p=0.001; N+ patients, 9% (3/34) when 11 or more nodes, 30% (10/30) when 1-11 nodes, p=0.002 5-year recurrence-free survival: Stage ≤T3a: 85% vs. 64%, p<0.02; Stage ≥T3b: 27% vs. 39%, p=0.87 | Not reported | 0-year survival Node negative patients (n=258): 82% when 8 or more nodes, 63% when 4-7 nodes, 23% when 0-3 nodes, p=0.004. 59% (75/127) ≥ 8 vs. 18% (23/131) <8 lymph nodes Node positive patients (n=64): 45% when > 14 nodes, 39% when 9-14 nodes, 16% when 1-8 nodes, p=0.02.56% (19/34) ≥ 11 vs. 80% (24/30) for < 11 lymph nodes, p=0.004
Herr, 2004^33^ | A: Cystectomy with standard lymphadenectomy (n=146), median 15 LN B: Cystectomy with limited lymphadenectomy (n=98), median 7 LN C: Cystectomy with no lymphadenectomy (n=24) | A vs. B vs. C Local Recurrence (no median followup reported): 7/146 (5%) vs. 22/98 (22%) vs.12/24 (50%), p<0.0001 RR 0.21, 95% CI 0.09 to 0.48 ≥10 nodes removed vs. <10 nodes removed: 6% vs. 25%, p<0.0001, multivariate Cox proportional hazards model <10 nodes (HR 0.20, 95% CI 0.07 to 0.56) | Not reported | A vs. B vs. C 5-year overall survival: 60% vs. 46% vs. 33%, p=0.01 ≥10 nodes removed vs. <10 nodes removed: 5-year overall survival: 61% vs. 44%, p=0.0007, multivariate Cox proportional hazards model <10 nodes HR 0.50, 95% CI 0.36 to 0.71 A vs. B Risk of mortality: 52% (59/146) vs. 64% (63/98), RR 0.94, 95% CI 0.68 to 1.04
Konety, 2003^31^ | Patients with bladder cancer who underwent cystectomy, number of lymph nodes examined: 0 (n=645), 1-3 (n=203), 4-6 (n=239), 7-9 (n=164), 10-14 (n=163), 15-19 (n=106), ≥20 (n=81) | Not reported | Not reported | Risk of death by number of lymph nodes examined; Adjusted hazard ratio (95% CI);: 0: 1 (reference) 1-3: 0.93 (0.69 to 1.27) 4-6: 0.52 (0.36 to 0.76) 7-9: 0.57 (0.39 to 0.81) 10-14: 0.38 (0.25 to 0.57) 15-19: 0.57 (0.39 to 0.85) ≥20: 0.48 (0.30 to 0.76) ≥4: 0.53 (0.36 to 0.76)
Leissner, 2000^37^ | Patients with bladder cancer who underwent cystectomy, number of lymph nodes examined: 1-5, 6-10, 11-15, 16-20, and >20 (N=447) | ≥16 nodes removed vs. ≤15 nodes removed: Local recurrence: 17% vs. 27%, p<0.01 | ≥16 nodes removed vs. ≤15 nodes removed: Distant metastasis: 10.5% vs. 17%, p<0.01 | ≥16 nodes removed vs. ≤15 nodes removed: 5-year bladder cancer- specific survival: 65% vs. 51%, p<0.013
Poulsen, 1998^38^ | A: Radical cystectomy with extended lymphadenectomy, bounded proximally by bifurcation of the aorta, laterally by the genitofemoral nerve, distally by the circumflex iliac vein and Cloquet's lymph node and posteriorly by the internal ileac vessel, including the presacral nodes and obturator fossa (n=126). B: Cystectomy with limited lymphadenectomy, bounded proximally by bifurcation of the common iliac vessels, while the lateral, distal and posterior boundaries were the same as for the extended dissection, including dissection of the obturator fossa. (n=68). | 5-year recurrence-free survival: 62% vs. 56%, p=0.33 5-year recurrence-free survival: Stage ≤T3a: 85% vs. 64%, p<0.02; Stage ≥T3b: 27% vs. 39%, p=0.87 | 5-year risk of distant metastasis: 29% vs. 30%, p not reported 5-year risk of pelvic metastasis: 10% vs. 10%, p not reported | 5-year survival: Stage ≤T3a,N0: 90% vs. 71%, p<0.02; Stage ≥T3b,N0: 38% vs. 67%, p=0.46
Shirotake, 2010^32^ | A: Cystectomy with lymphadenectomy (n=107). B: Cystectomy without lymphadenectomy (n=62, includes those without lymphadenectomy or unknown number of nodes removed). Neoadjuvant chemotherapy, n=16, mostly T3-4 Adjuvant chemotherapy, n=26, T3-4 or Node positive | Not reported | Not reported | Node positive (N+) vs. Node negative (N-) vs. Nodes not removed or unknown (Nx) 5-year Cancer-specific survival: 40.8% vs. 72.3% vs. 73.5%; N+ vs. N-, p=0.0471, Nx vs. N-, p=0.846 ≥9 nodes removed vs. <9 nodes removed, 5-year Cancer-specific survival, node-positive and node negative patients: 84.3% vs. 52.7%, adjusted HR 3.48 (95% CI 1.50 to 9.31) Node-negative patients: adjusted HR 6.94 (95% CI 1.88 to 38.21)
Simone, 2013^40^ | A: Cystectomy with extended lymphadenectomy, dissected nodes up to and, in some cases, above the aortic bifurcation including the presacral nodes (n=349). B: Cystectomy with standard lymphadenectomy, dissected nodes with an upper boundary at the iliac bifurcation (not including presacral and common nodes) (n=584). | Not reported | Not reported | Bladder-cancer specific survival: Adjusted HR 1.80 (95% CI 1.37 to 2.37)
Zehnder, 2011^39^ | A (California cohort): Cystectomy with lymphadenectomy, pure intrapelvic template plus removal of lymphatic tissue along the common iliac vessels, the distal vena cava/aorta to the IMA takeoff and complete dissection of the presacral space from the bifurcation of the aorta into the sacral fossa (n=554). B (Switzerland cohort): Cystectomy with lymphadenectomy, pure intrapelvic template ended proximally at the mid-upper third of the common iliac vessels, included the presacral region medial to the internal iliac vessels but left tissue containing the hypogastric nerves located medial to the retracted ureters and inferior to the aortic bifurcation (n=405). Both groups used pure intrapelvic template for lymphadenectomy, with boundaries of the genitofemoral nerve and the pelvic side wall laterally, the circumflex iliac vein and Cloquet's node distally, the obturator fossa with full exposure of the intrapelvic course of the obturator nerve and the internal iliac vessels posteriorly, and the tissue medial to these vessels. | Recurrence: 38% (210/554) vs. 38% (154/405), RR 1.0 (95% CI 0.85 to 1.17) Recurrence-free survival: ~58% in each group (p=0.75) | Not reported | Overall survival: ~17% in each group (p=0.45)

CI = confidence interval; HR = hazard ratio; IMA = inferior mesenteric artery; N+ = Node positive; N = Nodes; N- = Node negative; N0 = Node stage 0; N2 = Node stage 2; Nx = nodes not removed or unknown; pT2 = Tumor stage 2 determined by pathology; pT3 = Tumor stage 3 determined by pathology; pT3a = Tumor stage 3a determined by pathology; RR= relative risk; T2 = Tumor stage 2; T3 = Tumor stage 3; T3a = Tumor stage 3a; T3b = Tumor stage 3b; T4 = Tumor stage 4

One study based on SEER data found regional lymph node dissection with at least four lymph nodes removed was associated with decreased risk of overall mortality over time versus no lymph node dissection (HR 0.53, 95% CI 0.36 to 0.76), after adjustment for age, gender, tumor stage, race/ethnicity, and receipt of radiation or chemotherapy.31 Risk of mortality did not differ between patients with fewer than four lymph nodes removed versus no lymph node dissection (HR 0.93, 95% CI 0.69 to 1.27). Another study of SEER data found limited or extended lymph node dissection associated with decreased risk of 10-year bladder cancer specific and overall mortality versus no lymph node dissection (HR 0.75, 95% CI 0.69 to 0.81 and HR 0.78, 95% CI 0.73 to 0.82, respectively).29 A third study found greater unadjusted 5-year survival with standard or limited lymph node dissection than no dissection (60% vs. 46% vs. 33%, respectively, p=0.01) as well as decreased risk of recurrence (5% vs. 22% vs. 50%, p<0.0001).33 The Japanese study found that cancer-specific survival at 5 years was similar among patients with negative lymph node dissection versus those who did not undergo lymph node dissection (74% vs. 72%, p=0.85), but lower (41%) among patients with positive lymph nodes on dissection.32 However, data were not provided to compare survival between all patients who underwent lymph node dissection versus those who did not.

## Key Question 2a Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers?

### Key Points

- One study found that effects of lymph node dissection on reducing risk of all-cause and bladder cancer-specific mortality appeared to be stronger for lower stage tumors, but for all-cause mortality there was no clear pattern suggesting differential effectiveness according to tumor stage (SOE: low).

### Detailed Synthesis

One previously described retrospective cohort study (n=11,183) based on SEER program data evaluated effects of radical cystectomy with no lymph node dissection versus radical cystectomy with limited or extended lymph node dissection (Appendix E).29 It found that lymph node dissection was associated with decreased mortality in patients at all stages of bladder cancer, though the effects on bladder cancer-specific mortality appeared strongest for lower stage tumors. Adjusted hazard ratios (HR) for 10-year bladder cancer-specific mortality ranged from 2.09 (95% CI 1.16 to 3.79) for stage classification Ta/Tis to an HR of 1.11 (95% CI 0.96 to 1.28) for stage classification T4. For all-cause mortality, there was no clear pattern suggesting differential effectiveness of lymph node dissection based on tumor stage (HRs ranged from 1.13 to 1.49).

## Key Question 2b Does the comparative effectiveness differ according to the extent of the regional lymph node dissection (e.g., as measured by the number of lymph nodes removed or the anatomic extent of dissection)?

### Key Points

- Eleven cohort studies found more extensive lymph node dissection associated with improved all-cause or bladder cancer-specific mortality versus less extensive lymph node dissection, but studies had methodological limitations, there was variability in the lymph node dissection techniques evaluated, and there was some inconsistency in results (SOE: low).
- Six cohort studies found that more extensive lymph node dissection was associated with lower risk of bladder cancer recurrence or progression, but most studies had serious methodological limitations and there was some inconsistency in results (SOE: low).

### Detailed Synthesis

Twelve retrospective cohort studies evaluated effects of the extent of lymph node dissection on clinical outcomes (Tables 4 and 5; Appendix E).29-40 Six were multicenter studies.31, 33, 34, 36, 39, 40 One study was a reanalysis of data from patients enrolled in a RCT,33 five were single institution series,30, 32, 35, 37, 38 and one was a U.S. population-based study based on SEER program data.29 The SEER study included data for 11,183 patients and the sample sizes in the other studies ranged from 92 to 1923. Duration of followup was reported in seven studies: one reported minimum followup of 2 years,31 two reported minimum followup of 5 years,33, 36 one reported minimum followup of 10 years,30 and the other studies reported mean followup of 38.7 months,37 59.2 months,35 and median followup of 10.9 years.39 Five studies were conducted in Europe,34, 35, 37, 38, 40 two studies evaluated patients in the United States and Europe,36 four studies evaluated U.S. patients,29-31, 33 and one study evaluated patients in Japan.32 Six studies were rated medium risk of bias (Appendix F)29, 31-33, 35, 40 and six were rated high risk of bias.30, 33, 34, 36-39 Common methodological limitations included insufficient information to determine baseline comparability of groups, failure to report attrition, and unclear methods for ascertaining confounders. The high risk of bias studies did not perform statistical adjustment for potential confounders. Two of the high risk of bias studies also evaluated comparisons of a U.S. cohort undergoing one lymph node dissection technique versus a European cohort undergoing a different lymph node dissection technique.36, 39 One of these studies compared patients who underwent radical cystectomy with less extensive lymph node dissection in the United States versus patients who underwent more extended lymph node dissection in Europe.36 The other compared outcomes in a U.S. cohort that underwent more extensive lymph node dissection versus a European cohort that underwent more limited lymphadenectomy, based on the median number of lymph nodes removed (38 vs. 22).39 One other study compared patients who underwent less extensive lymph node dissection in an Austrian center versus patients who underwent more extensive lymph node dissection in an Italian center.34 In one study, comparison groups were not entirely concurrent.38

Two studies compared “extended” versus “standard” lymph node dissection methods,35, 40 four compared “extended” versus “limited” dissection,34-36, 38 and three compared “standard” versus “limited” dissection.30, 33, 35 One study compared “extended” versus “super extended” lymph node dissection.39 35Standard and limited lymph node dissection was mostly restricted to a pelvic dissection that was bordered proximally by the common iliac bifurcation, laterally by the genitofemoral nerve, medially by the internal iliac artery, posteriorly by the obturator nerve, and the node of Cloquet distally. Extended templates varied and usually involved more proximal lymphadenectomy with dissection of periaortic nodes up to the inferior mesenteric artery38-40 or described inclusion of more medial tissue such as presacral lymph nodes35, 39, 40 or lymph nodes along and medial to the internal iliac artery.35, 36 Seven studies, including two studies of “standard” versus “limited” dissection,30, 33 performed analyses based on the node yield (number of nodes in pathological specimen) rather than or in addition to the lymph node dissection template used.29-33, 35, 37

#### Mortality

Seven studies evaluated effects of more versus less extensive lymph node dissection on all-cause mortality.29-33, 36, 38, 39 Although studies found standard versus limited lymph node dissection and higher versus lower lymph node yield both associated with decreased risk of all-cause mortality, the effects of more extended versus standard dissection templates were less clear. One study (n=1601) based on SEER data found lymph node dissection involving four or more lymph nodes associated with decreased risk of mortality versus no lymph node dissection (HR 0.53, 95% CI 0.36 to 0.76) after adjustment for age, gender, tumor stage, race/ethnicity, and receipt of radiation or chemotherapy, but no difference between lymph node dissection of fewer than four nodes and no lymph node dissection (HR 0.93, 95% CI 0.69 to 1.27).31 However, there was no clear dose-response relationship with increasing number of nodes dissected beyond four. Another study based on US SEER data (n=11,183) found lymph node dissection involving ≥10 lymph nodes removed associated with lower 10-year mortality versus lymph node dissection with <10 lymph nodes (30.3% vs. 39.4%, p<0.001).29 One study (n=268) of patients undergoing standard or limited lymph node dissection found removal of ≥10 nodes associated with decreased risk of mortality versus <10 nodes, after adjustment for treatment, age, tumor stage, positive or negative node status, and positive or negative margin status (HR 0.50, 95% CI 0.36 to 0.71).33 This study also found standard dissection associated with lower risk of mortality than limited dissection in an unadjusted analysis, though the difference did not reach statistical significance (52% vs. 64%, RR 0.84, 95% CI 0.68 to 1.04). Another study (n=322) of standard or limited lymph node dissection also found an association between a greater number of lymph nodes examined and lower mortality risk among both node-positive (56% for ≥11 vs. 80% for <11 lymph nodes, p=0.004) and node-negative (18% for ≥8 vs. 59%, p<0.0005) patients.30 Findings were similar when patients were stratified according to tumor stage.29 One study (n=658) found no difference between extended lymph node dissection performed at a European institution versus limited dissection performed at a U.S. institution in unadjusted 5-year survival in patients with T2 tumors (61% vs. 64%, p=0.10), but extended lymph node dissection was associated with higher 5-year survival in patients with T3 tumors (42% vs. 22%, respectively, p=0.002).36 Another study (n=959) found no difference in unadjusted survival between “super extended” lymph node dissection performed in a U.S. institution versus “extended” lymph node dissection performed in a European institution (~17% in each group, p=0.45).39 A Danish within-institution study (n=194) found no difference between extended versus limited lymph node dissection in survival among patients with stage T3b and higher tumors, but extended lymph node dissection was associated with higher (unadjusted) survival in patients with stage T3a or lower cancers (90% vs. 71%, p<0.02).38

Five studies also found more extensive lymph node dissection associated with higher likelihood of bladder cancer-specific survival than less extensive lymph node dissection.29, 32, 35, 37, 40 In a US study (n=11,183), 10-year cancer-specific mortality-free rate was 62.2% with extended versus 54.0% with limited lymph node dissection.29 Hazards ratios after adjustment for age, sex, race/ethnicity, tumor grade, and year of surgery were nonoverlapping (HR 0.65, 95% CI 0.59 to 0.71 and HR 0.83, 95% CI 0.76 to 0.89, respectively). In one Italian study (n=933), extended lymph node dissection was associated with higher likelihood of cancer-specific survival than standard lymph node dissection after adjustment for tumor stage and nodal status (HR 1.80, 95% CI 1.37 to 2.37).40 In another Italian study (n=272), extended lymph node dissection was associated with decreased risk of bladder cancer-specific mortality versus limited or no lymph node dissection after adjustment for tumor stage and number of lymph nodes (HR 0.46, 95% CI 0.36 to 0.89), but there was no difference between standard versus limited or no dissection (HR 0.99, 95% CI 0.55 to 1.35).35 However, confidence intervals for the two estimates overlapped. The same study also found ≥14 lymph nodes removed associated with decreased risk of bladder cancer-specific mortality versus 0-14 lymph nodes removed (HR 0.56 95% CI 0.28 to 0.995). In a Japanese study, node yields of <9 lymph nodes was associated with poorer 5-year bladder cancer-specific survival versus yield of ≥9 nodes after adjustment for tumor stage (53% vs. 84%, HR 3.48, 95% CI 1.50 to 9.31).32 A German study (n=447) found removal of 16 or more nodes associated with greater unadjusted disease-specific survival at 5 years than removal of 15 or fewer nodes (65% vs. 15%, p<0.013).37

#### Recurrence and Progression

Six studies evaluated effects of more extensive versus less extensive lymph node dissection on risk of bladder cancer recurrence or progression.30, 33, 36-39 One study (n=268) of patients who underwent standard or limited lymph node dissection found removal of ≥10 nodes associated with decreased risk of mortality versus <10 nodes, after adjustment for treatment, age, tumor stage, positive or negative node status, and positive or negative margin status (HR 0.20, 95% CI 0.07 to 0.56).33 This study also found standard dissection associated with lower risk of recurrence than limited dissection in an unadjusted analysis (4.8% vs. 22%, RR 0.21, 95% CI 0.09 to 0.48). Another study (n=322) of standard or limited lymph node dissection also found an association between a larger number of lymph nodes examined and lower risk of local recurrence among both node-positive (9% for ≥11 vs. 30% for <11 lymph nodes, p=0.002) and node-negative (5% for ≥8 vs. 24% for <8 lymph nodes, p=0.001) patients.30 Findings were similar when patients were stratified according to tumor stage. Adjustment was not performed in the other four studies. One study (n=658) found extended lymph node dissection (performed in Europe) associated with lower risk of local or systemic progression than limited lymph node dissection (performed in the United States; 40% vs. 55%, RR 0.74, 95% CI 0.63 to 0.87).36 Similar effects were seen in patients with either T2 or T3 tumors. The difference between extended versus limited lymph node dissection in 5-year recurrence-free survival was not statistically significant for T2 tumors (71% vs. 63%, p=0.22), but for T3 tumors extended lymph node dissection was associated with superior recurrence-free survival (49% vs. 19%, p<0.001). Another study (n=447) found yields of ≥16 lymph nodes associated with decreased risk of local recurrence (17% vs. 27%) and distant metastasis (17% vs. 10%) versus yields of 15 or fewer nodes (p<0.01).37 Two other studies found no difference in recurrence-free survival based on the extent of regional lymph node dissection.38, 39 One study (n=194) reported 5-year bladder cancer recurrence free survival of 62 percent for extended lymphadenectomy versus 56 percent for standard lymph node dissection (p=0.33).38 Risks of distant metastasis and pelvic recurrence were similar. One study (n=959) found no difference between less extensive lymph node dissection (performed in Europe) versus more extensive dissection (performed in the United States) in risk of recurrence (38% vs. 38%, RR 1.00, 95% CI 0.85 to 1.17).39

## Key Question 3 For patients with nonmetastatic muscle-invasive bladder cancer that is treated with cystectomy, does neoadjuvant or adjuvant chemotherapy improve outcomes compared with cystectomy alone?

### Key Points

#### Neoadjuvant Chemotherapy

- Six trials found neoadjuvant chemotherapy (NAC) associated with decreased risk, or a trend towards decreased risk, of mortality versus no NAC. Three trials evaluated standard chemotherapy regimens (cisplatin, methotrexate, and vinblastine [CMV] and methotrexate, vinblastine, doxorubicin, and cisplatin [MVAC]) and three trials utilized cisplatin-based regimens not commonly used in clinical practice (cisplatin and doxorubicin or cisplatin and methotrexate) (SOE: moderate).
- Three trials found NAC (CMV, MVAC, or cisplatin and methotrexate) associated with lower risk of disease progression, the largest trial and the only one to show a statistically significant effect found neoadjuvant CMV associated with lower likelihood of metastasis or death versus no NAC after 4 years (45% vs. 53%, HR 0.79, 95% CI 0.66 to 0.93) (SOE: low).
- Three trials found that NAC was not superior to no NAC in risk of locoregional bladder cancer recurrence (SOE: moderate).

#### Adjuvant Chemotherapy

- Four trials found adjuvant chemotherapy (AC) associated with decreased risk of mortality versus no AC, but no trial reported a statistically significant effect and there was some inconsistency in findings (SOE: low).
- One trial found that AC was not superior to no AC in risk of bladder cancer progression (SOE: insufficient).
- There was insufficient evidence to determine effects of AC versus no AC on risk of locoregional recurrence, due to imprecise estimates and inconsistency between studies (SOE: insufficient).

### Detailed Synthesis

Six trials (reported in eight publications) evaluated NAC41-48 and four trials evaluated AC (Tables 6 and 7; Appendix E)49-52 for muscle-invasive bladder cancer. Four RCTs compared NAC plus radical cystectomy versus radical cystectomy alone,41, 44, 47, 48 one compared NAC, radiation therapy and radical cystectomy versus radiation therapy plus radical cystectomy,45, 46 and one compared NAC plus radical cystectomy, radiation therapy, or both versus radical cystectomy, radiation therapy, or both.42, 43 The chemotherapy regimens evaluated in the NAC trials were MVAC, CMV, cisplatin/methotrexate, and cisplatin/doxorubicin. All four trials of AC compared AC after radical cystectomy versus cystectomy alone.49-52 No study evaluated AC among patients that had received NAC. The chemotherapy regimens evaluated in the AC trials were CMV, cisplatin/gemcitabine, cisplatin/methotrexate, and cisplatin/doxorubicin/cyclophosphamide.

Table 6 Characteristics of studies on adjuvant and neoadjuvant chemotherapy

Type of Chemotherapy | Author, Year | Country, Number of Centers, Study Years, Type of Study | Interventions (Sample Size) | Duration of Followup and Cystoscopic Followup Method | Population Characteristics by Treatment Group (Age, Race/Ethnicity, Sex, Stage of Disease, Functional Status)
Neoadjuvant | Dash, 2008^59^ | United States Single Center 2000-2006 Retrospective cohort | A: NAC: Gemcitabine + Cisplatin, predominately given as: "Single dose" cisplatin administration consisted of 4 cycles, with 21 day intervals of cisplatin 70 mg/m2 and gemcitabine 1000 mg/m2 on day 1, and gemcitabine 1000 mg/m2 on day 8. "Split-dose" cisplatin administration consisted of 4 cycles, with 21 day intervals of cisplatin 35 mg/m2 and gemcitabine 1000 mg/m2 on days 1 and 8. (n=42) B: NAC: Methotrexate, vinblastine, doxorubicin and cisplatin given as 4 cycles at 28-day intervals. Doses were not reported. (n=54) | Overall duration of followup: Not reported Median followup for survivors: Gemcitabine/Cisplatin: 24.2 months; MVAC: 48.1 months Followup method not reported | A vs. B Age (median): 64 vs. 63 Male: 76% (32/42) vs. 8% (43/54) Race/Ethnicity: Not reported Stage of disease: T2: 45% (19/42) vs. 59% (32/54) T3: 45% (19/42) vs. 28% (15/54) T4: 10% (4/42) vs. 13% (7/54) Functional status: Not reported
Neoadjuvant | Fairey, 2013^53^ | United States Single Center 1985-2011 Retrospective cohort | A. NAC, 4 cycles of GC at 21-day intervals over 12 weeks + cystectomy with super-extended pelvic LN dissection (n= 58) B. NAC, 4 cycles of M-VAC at 28-day intervals over 16 weeks + cystectomy with super-extended pelvic LN dissection (n= 58) | Median followup 2.1 years for GC group and 7.4 years for M-VAC group. Method: Every 4 months in year 1, every 6 months in year 2 and annually thereafter. | Age (median): 67 vs. 63 Male: 76% vs. 79% Race/Ethnicity: Not reported Stage of disease: T2: 48% vs. 48% T3: 31% vs. 24% T4: 20% vs. 28% Functional status: Not reported
Neoadjuvant | Grossman, 2003^41^ | USA 126 centers 1987-1998 Randomized controlled trial | A: NAC, three 28-day cycles with methotrexate 30 mg/m^2^ on days 1, 15 and 22; vinblastine 3 mg/m^2^ on days 2, 15 and 22; doxorubicin 30 mg/m^2^ and cisplatin 70 mg/m^2^ on day 2 (MVAC) + cystectomy with LN dissection (n=153) B: Cystectomy with LN dissection (n=154) | Median: 8.7 years vs. 8.4 years | Age (mean): 63 vs. 63 Male: 83% vs. 81% Race/Ethnicity: Not reported Smoker: Not reported Stage: T2: 40% vs. 40% T3/T4a: 60% vs. 60% Functional status: Not reported
Neoadjuvant | International Collaboration of Trialists, 1999^42^ | 20 countries 106 centers 1989-1995 Randomized controlled trial | A: NAC every 21 days for 3 cycles with methotrexate 30 mg/m^2^, vinblastine 4 mg/m^2^ on day 1 and day 8; cisplatin 100 mg/m^2^ on day 2 (CMV) + cystectomy +/- LN dissection or RT or RT and cystectomy (n=491) B: cystectomy with LN dissection or radiotherapy or RT and cystectomy. (n=485) Cystectomy as salvage therapy for recurrence in RT group. Local radical treatment chosen before randomization for each patient | Median: 4 years. Method: Option for group A: cystoscopy, bimanual palpation, TURBT after 3 cycles of chemotherapy before radiotherapy or cystectomy to assess for response. | Age (median): 64 vs. 64 Male: 433/491 vs. 430/485 Race/Ethnicity: Not reported Stage: T2: 34% vs. 34% T3: 58% vs. 58% T4: 85 vs. 8% Tumor grade: G1: 1%vs. 0.2% G2: 11%vs. 13% G3: 885 vs. 87% Unknown grade: 0% vs. 0.2% Functional status: WHO 0: 69% vs. 69% WHO 1: 26% vs. 26% WHO 2: 4% vs. 4% WHO 3: 0.2% vs. 0.2% Nodal status: N0: 67% vs. 63% NX: 33% vs. 37% Radical treatment: Radiotherapy: 42% vs. 43% Cystectomy: 50% vs. 49% Radiotherapy + cystectomy: 8% vs. 8%
Neoadjuvant | International Collaboration of Trialists, 2011^43^ | 20 countries 106 centers 1989-1995 Randomized controlled trial | A: NAC every 21 days for 3 cycles methotrexate 30 mg/m^2^ and vinblastine 4 mg/m^2^ on day 1 and 8, cisplatin 100 mg/m^2^ day 2 (CMV) + RT, cystectomy or RT and cystectomy (n=491) B: RT cystectomy or RT+cystectomy (n=485) The choice of definitive treatment was based on patient and physician choice, not randomly assigned. | Median: 8 years | Per group numbers not reported Age (mean): 64 Male: 863 (88%) Race/Ethnicity: Not reported Stage: T2: 334 (34%) T3: 567 (58%) T4a: 75 (8%) Functional Status: WHO 0-3 (most 0-1) Local definitive treatment: RT: 43% (415/976, 193 vs. 210) Cystectomy: 50% (485/976, 216 vs. 212) RT + cystectomy: 8% (76/976)
Neoadjuvant | Kitamura, 2014^44^ | Japan 28 centers 2003-2009 Randomized controlled trial | A: NAC, 2 cycles 28 days apart with methotrexate 30 mg/m2 on days 1, 15, and 22, vinblastine 3 mg/m2 on days 2, 15, and 22, doxorubicin 30 mg/m2 on day 2, and cisplatin 70 mgm2 on day 2 + radical cystectomy (n=64) B: Cystectomy with LN dissection including the external iliac, internal iliac, and obturator nodes (n=66) | Median: 55 months | Age (median): 63 vs. 63 Male: 89% vs. 91% Race/Ethnicity: Not reported Stage: T2: 55% vs. 53% T3: 42% vs. 42% T4a: 3.1% vs. 4.5%
Neoadjuvant | Malmstrom, 1996^45^Rintala, 1993^46^ | Finland, Norway, Sweden 36 centers 1985-1989 Randomized controlled trial | A: NAC, 2 cycles separated by 3 weeks with cisplatin 70 mg/m^2^ and doxorubicin 30 mg/m^2^ + RT + cystectomy with LN dissection (n=151) B: RT and cystectomy with LN dissection (n=160) | Rintala, 1993: Mean: 18 months Malmstrom, 1996: Minimum of 5 years | Age (mean): 64 vs. 64 Male: 82% vs. 76% Race/Ethnicity: Not reported Stage: T1G3: 18% vs. 19% T2: 34% vs. 40% T3: 46% vs. 34% T4a: 2% vs. 6% Functional status: WHO 0: 74% vs. 76% WHO 1-2: 26% vs. 24%
Neoadjuvant | Pal, 2012^54^ | United States Single Center 1995-2012 Retrospective cohort | A: NAC with methotrexate, vinblastine, doxorubicin, cisplatin (n=22) B: NAC with gemcitabine, carboplatin (n=24) C: NAC with "other" chemotherapeutic regimens (n=15) Target doses were assumed to be a total of 3 months of NAC | Median followup: 28.7 months Method of followup: Not reported | A vs. B vs. C Age (median): 60.1 vs. 68.6 vs. 77.3 Male: 90.9% vs. 79.2% vs. 86.7% Race/Ethnicity: Not reported Tumor stage (clinical stage): ≤ T2: 81.8% vs 91.7% vs. 73.3% T3: 4.5% vs. 8.3% vs. 20.0% T4: 9.1% vs. 0 vs. 6.7% Tumor Grade: II (intermediate): 1/22 vs. 0/24 vs. 1/15 III (high): 95.4% vs. 100% vs. 93.3% Functional Status: Charlson Comorbidity Index: 4.0 vs. 5.0 vs. 6.0; p<0.05
Neoadjuvant | Sengelov, 2002^47^ | Denmark 1989-1993 Randomized controlled trial, based on two associated trials DAVECA 8901 and 8902 | A: NAC, 3 cycles at 3 week intervals with cisplatin 100 mg/m2, methotrexate 250 mg/m2 + cystectomy with LN dissection or XRT 3 weeks after chemotherapy (n=79; 17 underwent cystectomy) B: Cystectomy with LN dissection or XRT (n=74; 16 underwent cystectomy) | Minimum 42 months | Below comparisons are cystectomy (n=33) vs. XRT (n=120), no comparisons done within cystectomy only group in this paper Age: 66 vs. 63 Male: 79% (26/33) vs. 82% (98/120) Race/Ethnicity: Not reported Stage of disease: T1: 6% vs. 0 T2: 21% vs. 13% T3A: 39% vs. 28% T3B: 18% vs. 28% T4A: 12% vs. 16% T4B: 0 vs. 15% Functional/Performance status: 0: 55% vs. 37% 1: 42% vs. 58% 2: 3% vs. 5%
Neoadjuvant | Sherif, 2002^48^ | Sweden, Finland, Norway Multicenter, number not reported 1991-1997 Randomized controlled trial | A: NAC, 3 cycles at 3 week intervals with cisplatin 100 mg/m^2^, methotrexate 250 mg/m^2^ + cystectomy with LN dissection (n=155) B: Cystectomy with LN dissection (n=154) | Median: 5.3 years. Method: Every 4 months for 2 years, then every 6 months for 2 years, then yearly for 1 year (physical exam, creatinine, chest X-ray, Intravenous pyelography at 4, 16 and 36 months). | Age (mean): 64.6 vs. 65.1 Male: 75% vs. 86% Race/Ethnicity: Not reported Stage: T2: 41% vs. 42% T3: 52% vs. 49% T4a: 7% vs. 8% Tx: 1% vs. 0% Functional status: Not reported
Adjuvant | Bono, 1997^52^ | Italy Nine centers 1984-1987 Randomized controlled trial | A: Radical cystectomy with LN dissection + adjuvant chemotherapy with cisplatinum 70 mg/m^2^ day 1, and methotrexate 40 mg/m^2^ days 8 and 15 every 21 days for 4 cycles starting 21-28 days after surgery (n=35 for pN0 and n= 31 for pN+) B: Radical cystectomy with LN dissection (n=48) pN0 patients were randomized into the groups A or B; pN+ patients were assigned to group A | Mean: 69.12 months Method: Every 3 months for 2 years with blood work, chest X-ray, abdominal ultrasound, clinical exam. CT scan of abdomen and bone scan every 6 months for 2 years. | Age (mean): 62 vs. 62, 60 in pN+ group Male: 104/114, number in each group Not reported Race/Ethnicity: not reported Stage: pT2N0: 20% vs. 27%, pT2N+: 10% pT3aN0: 43% vs. 39%, pT3aN+: 32% pT3b-4aN0: 37% vs. 35%, pT3b-4aN+: 58% Nodal status: pN+ 22% Functional status: not reported
Adjuvant | Cognetti, 2012^50^ | Italy 45 centers 2001-2007 Randomized controlled trial | A: Cystectomy +/- LN dissection + adjuvant chemotherapy (AC) every 28 days for 4 cycles with gemcitabine 1000 mg/m^2^ days 1,8, and 15 plus cisplatin 70 mg/m^2^ on day 2 or day 15 (total n=97; cisplatin day 2 (A1), n=43, cisplatin day 15 (A2), n=46) B: Cystectomy +/- LN dissection + treatment on relapse (n=86) | Median: 35 months Method: Every 3 months for 2 years, then every 6 months for 3 years, yearly thereafter. CT scan every 6 months for 3 years then yearly thereafter. | Age (mean): 64 vs. 63 Male: 93% vs. 87% Race/Ethnicity: Not reported Stage: pT1: 3% vs. 1% pT2: 30%vs. 22% pT3: 47% vs. 57% pT4: 120% vs. 20% LN status: pN0: 48% vs. 57% pN1: 21% vs. 22% pN2: 31% vs. 21% Functional status: ECOG PS 0: 81% vs. 71% ECOG PS 1-2: 17% vs. 24% ECOG PS missing: 2% vs. 5%
Adjuvant | Freiha,1996^49^ | USA Single center 1986-1993 Randomized controlled trial | A: Radical cystectomy with LN dissection + adjuvant chemotherapy, 4 cycles every 21 day with methotrexate 30 mg/m^2^, and vinblastine 4 mg/m^2^ day 1 and 8, 100 mg/m^2^ cisplatin on day 2 (CMV) (n= 25) B: Radical cystectomy with LN dissection (n=25) | Mean, median: 57 and 62 months Method: Every 3 months for year 1, every 4 months for year 2 and every 6 months thereafter. Physical exam, blood studies, chest X-ray. Urine cytology every 6 months. CT at months 3,6,9,15,24 | Age (mean): 59 vs. 64 Male: 92% vs. 88% Race/Ethnicity: Not reported Stage: T3bN0: 16% vs. 28% T4N0: 12% vs. 4% pN+: 1 node: 16% vs. 40% pN+, 2 nodes: 20% vs. 12% pN+, 3 nodes: 16% vs. 8% pN+, 4+ nodes: 20% vs. 8% Functional status: Not reported
Adjuvant | Skinner, 1991^51^ | USA Single center 1980-1988 Randomized controlled trial | A: Cystectomy with LN dissection + AC, 4 cycles at 28-day intervals starting 6 weeks after surgery with cisplatin 100 mg/m^2^, doxorubicin 60 mg/m^2^ and cyclophosphamide 600 mg/m^2^ (n=44) B: Cystectomy with LN dissection (n=47) | Median: 32 months, with all but 6 patients followed beyond 1 year. Method: Every 4 month for 1 year, then every 6 months for 3 years, then yearly thereafter(Chest X-ray, urogram, laboratory tests, physical exam. CT, MRI or bone scans based on symptoms/abnormal lab values). | Age (median): 61 vs. 62 Male: 77% vs. 74% Race/Ethnicity: Not reported Stage: T1 or 2: 7% vs. 11% T3a: 23% vs. 15% T3b: 45% vs. 51% T4: 25% vs. 23% Tumor grade: G2 5% vs. 9% G3 50% vs. 50% G4 45% vs. 41% missing: 0% vs. 2% Lymph node status: 0 nodes 61% vs. 66% 1 +LN 16% vs. 21% ≥2 +LN 23% vs. 13% (6/47) Functional status: Not reported
Neoadjuvant Vs. Adjuvant | Matsubara, 2013^58^ | Japan Single center 2005-2010 Retrospective cohort | A: NAC, 4 cycles at 4 week intervals with gemcitabine 1000 mg/m2 and cisplatin 70 mg/m2 + cystectomy with LN dissection (n=25) B. Cystectomy with LN dissection + AC, 4 cycles at 4 week intervals with gemcitabine 1000 mg/m2 and cisplatin 70 mg/m2 (n=17) | Median: 28.6 months | Age (mean): 65 vs. 65 Male: 60% vs. 94% Race/Ethnicity: Not reported Stage of disease: ≤ cT2: 36% vs. 24% > cT2: 64% vs. 77% Functional status: Not reported
Neoadjuvant Vs. Adjuvant | Milikan, 2001^56^ | United States Single Center 1986-1998 Randomized controlled trial | A: Cystectomy + 5 cycles adjuvant chemotherapy with methotrexate 30 mg/m2, vinblastine 3 mg/m2, doxorubicin 30 mg/m2, cisplatin 70 mg/m2 (M-VAC) beginning 4 weeks postoperatively (n=70) B: 2 cycles NAC with methotrexate 30 mg/m2, vinblastine 3 mg/m2, doxorubicin 30 mg/m2, cisplatin 70 mg/m2 + cystectomy, followed by 3 additional cycles of chemotherapy beginning 6 weeks postoperatively (n=70) | Median followup: 6.8 years Followup method: Not reported | Age (median): 67 vs. 66 years Male: 64% vs. 79% Race/Ethnicity: Not reported Stage of disease: < T3b: 33% vs. 30% T3b: 56% vs. 60% T4a: 9% vs. 10% Upper tract: 3% vs. 0% Functional status: Not reported
Neoadjuvant Vs. Adjuvant | Wosnitzer, 2012^57^ | United States Single Center 1988-2009 Retrospective cohort | A: Neoadjuvant chemotherapy, cisplatin or carboplatin based (n=73) B: Adjuvant chemotherapy, cisplatin or carboplatin based (n=73) | Median followup: 12.8 vs. 14 months | Age (mean): 64 vs. 66 years Male: 71% vs. 73% Race/Ethnicity: Caucasian: 82% vs. 77%; African American: 4% vs. 3%; Latin: 11% vs. 1%; Other: 8% vs. 14% Stage of disease >T2: 25% vs. 55%; Node status >N0: 7% vs. 40% Functional status: Not reported
Neoadjuvant Vs. Adjuvant | Yeshchina, 2012^55^ | United States Single Center 1988-2010 Retrospective cohort | A: Methotrexate, vinblastine, doxorubicin, cisplatin (n=77; 45 neoadjuvant, 32 adjuvant) B: Gemcitabine, cisplatin (n=37; 16 neoadjuvant, 21 adjuvant) | Median followup: 30 vs. 25 months Followup method Not reported | Age (mean): 62.86 vs. 66.03 years Male: 66% vs. 70% Race/Ethnicity: White: 84% vs. 78% Stage: T2: 82% vs. 76%; >T2: 18% vs. 24% Functional status: Not reported

CMV = cisplatin, methotrexate, vinblastine; CT = computerized tomography; ECOG PS= eastern cooperative oncology group performance status; G1 = Grade 1; G2 = Grade 2; G3 = Grade 3; G4 = Grade 4; LN = lymph node; MRI, magnetic resonance imaging; MVAC = Methotrexate, Vinblastine, Doxorubicin, Cisplatin; N+ = without regional lymph node involvement; N+ = without regional lymph node involvement; N0 = without regional lymph node involvement; NAC = neoadjuvant chemotherapy; Nx = nodes not removed or unknown; pN+ = pathologically node-positive; pN0 = Node stage 0 determined by pathology; pT2 = Tumor stage 2 determined by pathology; pT3 = Tumor stage 3 determined by pathology; pT3a = Tumor stage 3a determined by pathology; pT3b = Tumor stage 3a determined by pathology; pT4a = Tumor stage 4a determined by pathology; RT = radiotherapy; T1 = Tumor stage 1; T2 = Tumor stage 2; T3 = Tumor stage 3; T3a = Tumor stage 3a; T3b = Tumor stage 3b; T4 = Tumor stage 4; TURBT = transurethral resection of bladder; Tx = Tumor stage unknown; WHO = World Health Organization; XRT=radiation therapy

Table 7 Summary of results for adjuvant and neoadjuvant chemotherapy studies

Type of Chemotherapy | Author, Year | Interventions (Number Analyzed for Recurrence) | Recurrence | Progression | Mortality
Neoadjuvant | Dash, 2008^59^ | A: NAC: Gemcitabine + Cisplatin, predominately given as: "Single dose" cisplatin administration consisted of 4 cycles, with 21 day intervals of cisplatin 70 mg/m2 and gemcitabine 1000 mg/m2 on day 1, and gemcitabine 1000 mg/m2 on day 8. "Split-dose" cisplatin administration consisted of 4 cycles, with 21 day intervals of cisplatin 35 mg/m2 and gemcitabine 1000 mg/m2 on days 1 and 8. (n=42) B: NAC: Methotrexate, vinblastine, doxorubicin and cisplatin given as 4 cycles at 28-day intervals. Doses were not reported. (n=54) | Not reported | Not reported | Not reported
Neoadjuvant | Fairey, 2013^53^ | A. NAC, 4 cycles of GC at 21-day intervals over 12 weeks + cystectomy with super-extended pelvic LN dissection (n= 58) B. NAC, 4 cycles of M-VAC at 28-day intervals over 16 weeks + cystectomy with super-extended pelvic LN dissection (n= 58) | A vs. B Cumulative incidence of recurrence, adjusted HR 0.60 (95%CI 0.34-1.03) Cumulative incidence of recurrence in pTanyN1-3M0 patients with median time to recurrence: 4 months vs. 7.4 months, p=0.019 Multivariable analysis showed no independent association between type of NAC and recurrence. Multivariable analysis showed no independent association between age and recurrence. | Not reported | A vs. B Overall mortality: adjusted HR 0.90 (95% CI 0.52-1.56) Multivariable analysis showed no independent association between type of NAC and overall mortality (HR 1.11, 95% CI 0.64-1.91, p=0.721). Multivariable analysis showed no independent association between age and overall mortality.
Neoadjuvant | Grossman, 2003^41^ | A: Neoadjuvant chemotherapy, three 28-day cycles with methotrexate 30 mg/m^2^ on days 1, 15 and 22; vinblastine 3 mg/m^2^ on days 2, 15 and 22; doxorubicin 30 mg/m^2^ and cisplatin 70 mg/m^2^ on day 2 (MVAC) + radical cystectomy with LN dissection (n=153) B: Radical cystectomy with LN dissection (n=154) | | | A vs. B All-cause mortality: 59% (90/153) vs. 65%, HR 0.75 (95% CI 0.57 to 1.00) Bladder cancer-specific mortality: 35% vs. 50%, HR 0.60 (95% CI 0.41 to 0.82) Median survival (months), unstratified: 77 vs. 46, p=0.05 log rank test Survival at 5 years: 57% vs. 43%, p=0.06 Median survival (months) stratified for age: age <65: 104 vs. 67, age ≥ 65: 61 vs. 30 p=0.05, log rank test Median survival (months) stratified for tumor stage: T2: 105 vs. 75; T3/T4a: 65 vs. 24, p=0.05, log rank test B vs. A Cystectomy only group had a 33% increased risk of death compared to the MVAC/cystectomy group (stratified analysis). Survival: HR 1.33 (95% CI 1.00 to 1.76) Disease-specific survival HR 1.66 (1.22-2.45), p=0.002
Neoadjuvant | International Collaboration of Trialists, 1999^42^ | A: NAC every 21 days for 3 cycles with methotrexate 30 mg/m^2^, vinblastine 4 mg/m^2^ on day 1 and day 8; cisplatin 100 mg/m^2^ on day 2 (CMV) + cystectomy +/- LN dissection or RT or RT and cystectomy (n=491) B: Cystectomy with LN dissection or radiotherapy or RT and cystectomy. (n=485) Cystectomy as salvage therapy for recurrence in RT group. Local radical treatment chosen before randomization for each patient. | Locoregional disease free survival: 47% vs. 42%, HR 0.87, 95% CI0.73 to 1.01 Median locoregional disease free survival (months): 23.5 vs. 20 No effect on locoregional control, HR 0.96, 95% CI 0.80 to 1.15) Disease free survival: 46% vs. 39%, HR 0.82, 95% CI 0.70 to 0.97 Median disease free survival (months): 20 vs. 16.5 | Metastasis free survival: 45% vs. 53%, HR 0.79 95% CI 0.66 to 0.93, Median metastasis free survival (months): 32 vs. 25 | Deaths: 229/491 vs. 256/485, RR 0.88, 95% CI 0.78 to 1.00 Survival: HR 0.85,95% CI 0.71 to 1.02
Neoadjuvant | International Collaboration of Trialists,2011^43^ | A: NAC every 21 days for 3 cycles methotrexate 30 mg/m^2^ and vinblastine 4 mg/m^2^ on day 1 and 8, cisplatin 100 mg/m^2^ day 2 (CMV) + RT, cystectomy or RT and cystectomy (n=491) B: RT, cystectomy or RT+cystectomy (n=485) | Cystectomy patients only: Locoregional recurrence: 40% (84/212) vs. 39% (84/216) RR 1.02, 95% CI 0.80 to 1.29 Locoregional disease-free survival 55% (119/216) vs. 65% (137/212), HR 0.74, 95% CI 0.58 to 0.95) | | Cystectomy patients only: Overall survival in patients: HR 0.74, 95% CI 0.57 to 0.96) Overall 3 year survival: 55.5% vs. 50% (95% CI for difference -0.5-11.0) Overall 10-year survival 36% vs. 30% Median survival (months): 44 vs. 37.5
Neoadjuvant | Kitamura, 2014^44^ | A: NAC, 2 cycles 28 days apart with methotrexate 30 mg/m2 on days 1, 15, and 22, vinblastine 3 mg/m2 on days 2, 15, and 22, doxorubicin 30 mg/m2 on day 2, and cisplatin 70 mgm2 on day 2 + radical cystectomy (n=64) B: Cystectomy with LN dissection including the external iliac, internal iliac, and obturator nodes (n=66) | | A vs. B Disease progression at 5 years: 36% (23/64) vs. 45% (29/64), HR 0.64 (95% CI 0.37-1.11) Progression-free survival at 5 years: 68% vs. 56% Progression-free survival interval (median, months): 99 vs. 78 | A vs. B Mortality: HR 0.65 (95% CI 0.19-2.18) Overall survival at 5 years: 72% vs. 62% Survival interval (median, months): 102 vs. 82 No differences in estimates based on age, tumor stage, papillary vs. nonpapillary, solitary vs. multiple, tumor size, tumor grade
Neoadjuvant | Malmstrom, 1996^45^ | A: NAC, 2 cycles separated by 3 weeks with cisplatin 70 mg/m^2^ and doxorubicin 30 mg/m^2^ + RT + cystectomy with LN dissection (n=151) B: RT + cystectomy with LN dissection (n=160) | Overall: 21% vs. 25%, RR 0.82, 95% CI 0.54 to 1.24 Median interval to relapse (months): 23 vs. 14, p=0.42) | | 5- year overall survival: 59% vs. 51%, p=0.10, log rank test 5- year cancer specific survival: 64% vs. 54%, p=0.07, log rank test Risk of death, adjusted for age, gender, histologic grade, hydronephrosis, and tumor stage: RR 0.69, 95% CI 0.49-0.98 5-year survival by age: < 60 years (N=75): 61% vs. 49%, p=0.21 ≥ 60 years (N=236): 58% vs. 51%, p=0.21 5- year cancer- specific survival by tumor grade: T1: 77% vs. 71%, not statistically significant T2 58% vs. 55%, not statistically significant T3-T4a: 52% (n=72) vs. 37% (n=65), p=0.03, log rank test
Neoadjuvant | Rintala, 1993^46^ | Same study as Malmstrom, 1996^45^ | | | Risk of death: RR 0.6, 95% CI 0.4-0.9 Survival, all patients (n=311), study states statistically significant difference in favor of A, p=0.034, log rank test, data not presented Survival, cystectomized patients (n=266), study states no statistically significant difference, p= 0.093, log rank test, data not presented Survival, T2-T4a (n=253), study states statistically significant difference in favor of A, p= 0.018, data not presented Survival, cystectomized patients T2-T4a (n=210), study states statistically significant difference in favor of A, p=0.057, data not presented Survival, patients with T2-T4a, according to downstaging, p0-1 vs. p2 (n=213), study states in favor of p0-1, p=0.0005, data not presented
Neoadjuvant | Pal, 2012^54^ | A: NAC with methotrexate, vinblastine, doxorubicin, cisplatin (n=22) B: NAC with gemcitabine, carboplatin (n=24) C: NAC with "other" chemotherapeutic regimens (n=15) Target doses were assumed to be a total of 3 months of NAC | Not reported | Not reported | Survival (months): A/B vs. C: 35.3 vs. 16.3; P=0.055 A vs. B: 104.3 vs. 21.8; P=0.73
Neoadjuvant | Sengelov, 2002^47^ | A: NAC, 3 cycles at 3 week intervals with cisplatin 100 mg/m2, methotrexate 250 mg/m2 + cystectomy with LN dissection or XRT 3 weeks after chemotherapy (n=79; 17 underwent cystectomy) B: Cystectomy with LN dissection or XRT (n=74; 16 underwent cystectomy) | Not reported | For cystectomy patients only (n=33, 17 vs. 16) Progression-free survival rate at 5 years: 41% vs. 36% | For cystectomy patients only (n=33, 17 vs. 16) Median survival: 82.5 months vs. 45.8 months, p = 0.76 5-year survival rates: 64% vs. 46%
Neoadjuvant | Sherif, 2002^48^ | A: NAC, 3 cycles at 3 week intervals with cisplatin 100 mg/m^2^, methotrexate 250 mg/m^2^ + cystectomy with LN dissection (n=155) B: Cystectomy with LN dissection (n=154) | Recurrence, locoregional and distant metastasis: 6% (9/155) vs.8% (12/154), RR 0.75, 95% CI 0.32 to 1.72 Locoregional only: 10% (15/155) vs. 9% (14/154), RR 1.06, 95% CI 0.53 to 2.13 Distant metastasis only: 13% (20/155) vs. 16% (24/154), RR 0.83, 95% CI 0.48 to 1.44 | | Overall 5-year survival: 53% vs. 46% (p=0.2375, log rank test) Overall survival, HR 0.8, 95% CI 0.6 to 1.1 5 year survival, T2 group, p=0.5356, log rank test Overall survival, T2 group, HR 0.8, 95% CI 0.5 to 1.5 5 year survival, T3-T4a group, p=0.2740, log rank test Overall survival, T3-T4a group, HR 0.8, 95% CI 0.6 to 1.2
Adjuvant | Bono, 1997^52^ | A: Radical cystectomy with LN dissection + adjuvant chemotherapy every 21 days for 4 cycles starting 21-28 days after surgery with cisplatinum 70 mg/m^2^ day 1, and methotrexate 40 mg/m^2^ days 8 and 15(n=35 for pN0 and n= 31 for pN+, total n=66) B: Radical cystectomy with LN dissection (n=48) | | Node negative patients: Progression: 49% vs. 44%, RR 0.91, 95% CI 0.61 to 1.37 | Node negative patients: Survival: 49% (17/35) vs. 38% (8/48) Bladder cancer- specific mortality: 46% (16/35) vs. 52% (25/48), RR 0.88, 95% CI 0.56 to 1.38 All- cause mortality: 51% (18/35) vs. 63% (30/48) pN+ from group A Survival: 32% (10/31) Died of disease: 58% (18/31) Death, any cause: 68% (21/31)
Adjuvant | Cognetti, 2012^50^ | A: Cystectomy +/- LN dissection + adjuvant chemotherapy (AC) every 28 days for 4 cycles with gemcitabine 1000 mg/m^2^ days 1,8, and 15 plus cisplatin 70 mg/m^2^ on day 2 or day 15 (GC) (n=97) A1: cisplatin on day 2 (n=43) A2: cisplatin on day 15 (n=46) B: Cystectomy +/- LN dissection + treatment on relapse (n=86) | Overall recurrence: 44% (43/97) vs. 47% (40/86), RR 0.95, 95% CI 0.69 to 1.31 5 year disease-free survival: Overall: 42% vs. 37%, p=0.70, HR 1.08, 95% CI 0.73-1.59 Node-negative patients: 58% vs. 60%, p=0.97 Node-positive patients: 19% vs. 19%, p=0.80 | | 5-year survival: Overall: 43% vs. 54%, p=0.24 Overall, A1 vs. A2: 47% vs. 40%, p=0.88 Lymph node negative disease: 65% vs. 73%, p=0.65 Lymph node positive disease: 26% vs. 28%, p=0.71 Mortality: HR = 1.29, 95% CI 0.84 to 1.99 Independent of treatment arm, mortality hazard was significantly associated with nodal status and T stage: pN1 vs. pN0: HR 2.42, 95% CI 1.38 to 4.26 pN2 vs. pN0: HR 4.33, 95% CI 2.6 to 7.2 pT3 vs. pT1-2: HR 2.01, 95% CI 1.14 to 3.56 pT4 vs. pT1-2: HR 2.57, 95% CI 1.34 to 4.92
Adjuvant | Freiha, 1996^49^ | A: Radical cystectomy with LN dissection + adjuvant chemotherapy, 4 cycles every 21 day with methotrexate 30 mg/m^2^, and vinblastine 4 mg/m^2^ day 1 and 8, 100 mg/m^2^ cisplatin on day 2 (CMV) (n=25) B: Radical cystectomy with LN dissection (n=25) | Recurrence: 52% (13/25) vs. 76% (19/25) RR 0.68, 95% CI 0.44 to 1.06 Mean / median interval to recurrence: 17.5 /16.2 months (range: 4-37 months) vs. 11.5 / 10.1 months (range: 2-34 months), p=0.01, log rank test 6/19 recurrences in group B, 6 received CMV therapy | | Survival: 52% (13/25) vs. 32% (8/25), RR 0.71, 95% CI 0.43 to 1.15 Survival according to nodal status N0: 71 % (5/7) vs. 25% (2/8), RR 0.68, 95% CI 0.11 to 1.31 N+: 44% (8/18) vs. 35% (6/17) ≤ N3: 46% (6/13) vs. 40% (6/15) > N3: 40% (2/5) vs. 0% (0/2)
Adjuvant | Skinner, 1991^51^ | A: Cystectomy with LN dissection + AC, 4 cycles at 28-day intervals starting 6 weeks after surgery with cisplatin 100 mg/m^2^, doxorubicin 60 mg/m^2^ and cyclophosphamide 600 mg/m^2^ (n=44) B: Cystectomy with LN dissection (n=47) | Probability of recurrence at 3 years: 0.30 (SE=0.08) vs. 0.54 (SE=0.08), p=0.011, unstratified Wilcoxon test Median time to recurrence 4.7 years. Benefit of chemotherapy was significant for time to recurrence, (p=0.0010, stratified Wilcoxon) after stratifying for the 3 nodal groups. | | All- cause mortality: 34% vs. 50%, p=0.10 Probability of bladder cancer- specific mortality within 3 years: 0.29 (SE=0.08) vs. 0.50 (SE=0.08) Node negative patients, no overall survival benefit from chemotherapy, p=0.14 Benefit of chemotherapy was significant for survival, (p=0.0062, stratified Wilcoxon) after stratifying for the 3 nodal groups (N0, N1, N2+)
Neoadjuvant vs. Adjuvant | Matsubara, 2012^58^ | A: NAC, 4 cycles at 4 week intervals with gemcitabine 1000 mg/m2 and cisplatin 70 mg/m2 + cystectomy with LN dissection (n=25) B. Cystectomy with LN dissection + AC, 4 cycles at 4 week intervals with gemcitabine 1000 mg/m2 and cisplatin 70 mg/m2 (n=17) | A vs. B Recurrence (metastatic): 9/25 (36%) vs. 3/17 (18%) Recurrence-free survival (at median followup): 66.7% vs. 76%, p=0.124, log-rank Overall HR 0.65 (95% CI 0.36-1.17) trending in favor of NAC | Not reported | Not reported
Neoadjuvant vs. Adjuvant | Milikan, 2001^56^ | A: Cystectomy + 5 cycles adjuvant chemotherapy with methotrexate 30 mg/m2, vinblastine 3 mg/m2, doxorubicin 30 mg/m2, cisplatin 70 mg/m2 (M-VAC) beginning 4 weeks postoperatively (n=70) B: 2 cycles NAC with methotrexate 30 mg/m2, vinblastine 3 mg/m2, doxorubicin 30 mg/m2, cisplatin 70 mg/m2 + cystectomy, followed by 3 additional cycles of chemotherapy beginning 6 weeks postoperatively (n=70) | A vs. B Disease- free survival: 42/70 (60%) vs. 39/70 (56%), NSD, RR 0.90 95% CI 0.61-1.33 | A vs. B Time to progression: NSD, numbers Not reported | A vs. B Overall survival: NSD, numbers Not reported
Neoadjuvant vs. Adjuvant | Wosnitzer, 2012^57^ | A: Neoadjuvant chemotherapy, cisplatin or carboplatin based (n=73) B: Adjuvant chemotherapy, cisplatin or carboplatin based (n=73) | Not reported | Not reported | A vs. B Disease specific survival: Univariate HR=1.28 (95%CI: 0.76-2.16), p=0.36; multivariate HR=1.24 (95%CI: 0.70-2.18), p=0.46 Overall survival: Univariate HR=1.12 (95% CI: 0.73-1.73), p=0.60; multivariate HR=1.08 (95% CI: 0.67-1.73), p=0.76 Cisplatin based treatment: median survival: 11 vs. 12.5 months Disease specific survival: NSD, data Not reported Overall survival: NSD, data Not reported MVAC treatment: median survival: 16 vs. 22 months Disease specific survival: NSD, p=0.555 Overall survival: NSD, p=0.573 Gemcitabine/cisplatin treatment: median survival: 11 vs. 10.5 months Disease specific survival: HR=10.06 (95%CI: 1.01-112.2), p=0.049 Overall survival: NSD, p=0.607 Carboplatin based treatments: median survival: 8.9 vs. 10 months Disease specific survival: NSD, p=0.764 Overall survival: NSD, p=0.388
Neoadjuvant vs. Adjuvant | Yeshchina, 2012^55^ | A: Methotrexate, vinblastine, doxorubicin, cisplatin (n=77; 45 neoadjuvant, 32 adjuvant) B: Gemcitabine, cisplatin (n=37; 16 neoadjuvant, 21 adjuvant) | Not reported | Not reported | Neoadjuvant vs. Adjuvant: Overall survival: HR=0.61 (95% CI: 0.37-1.00), p=0.51 Cancer specific survival: HR=0.69 (95%CI: 0.37-1.29), p=0.247 A vs. B: 5-year overall survival: 47% vs. 35%, p=0.346 5-year disease specific survival: 61% vs. 50%, p=0.482

AC = adjuvant chemotherapy; CI = confidence interval; CMV = cisplatin, methotrexate, vinblastine; NSD = no significant difference; GC = gemcitabine plus cisplatin; HR = hazard ratio; LN = lymph node; M-C = Mantel-Cox; MVAC, methotrexate, vinblastine, doxorubicin, cisplatin; N+ = without regional lymph node involvement; N0 = without regional lymph node involvement; N1 = Node stage 1; N2+ = Node stage 2 positive; N3 = Node stage 3; NAC = neoadjuvant chemotherapy; pN0 = Node stage 0 determined by pathology; pN1 = Node stage 1 determined by pathology; pN2 = Node stage 2 determined by pathology; pT1 = Tumor stage 1 determined by pathology; pT2 = Tumor stage 2 determined by pathology; pT3 = Tumor stage 3 determined by pathology; pT4 = Tumor stage 4 determined by pathology; RCT = randomized controlled trial; RR = relative risk; RT = radiotherapy; SE = standard error; T1 = Tumor stage 1; T2 = Tumor stage 2; T3 = Tumor stage 3; T4a = Tumor stage 4a; XRT = radiation therapy

Sample sizes in the NAC trials ranged from 33 to 976 and in the AC trials from 50 to 132. Mean age ranged from 59 to 71 years. The trials enrolled patients with T2-T4a, node-negative bladder cancer, however two NAC trials also included patients with high-grade T1 disease45, 46 and one AC trial only included patients with T3-T4a disease.49 The four AC trials49-52 included patients with clinically node negative disease found to be node positive following radical cystectomy. In these trials, results were reported separately for node positive and node negative patients. Lymph node dissection was included as part of surgical management in eight of the studies.42, 43, 45, 47-52 Average followup ranged from 32 to 104 months.

All RCTs were rated medium risk of bias. Methodological limitations included unclear randomization and allocation concealment methods, lack of blinding, and clinically important baseline differences between groups (Appendix F).

#### Neoadjuvant Chemotherapy

##### Mortality

Six trials evaluated effects of NAC versus no NAC on mortality.41, 42, 44-48 The largest trial (n=976) found neoadjuvant CMV prior to radical cystectomy, radiation therapy, or both associated with a decreased risk of mortality versus cystectomy, radiation therapy, or both without NAC after a median followup of 4 years, but the difference did not reach statistical significance (HR 0.85, 95% CI 0.71 to 1.02).42 In this trial, use of radical cystectomy and/or radiation therapy was left to the discretion of clinicians and patients, with 43 percent of patients undergoing radiation therapy rather than cystectomy. A subsequent report from this study found NAC associated with a statistically significant decreased risk of mortality (HR 0.74, 95% CI 0.57 to 0.96) in the subgroup of patients who underwent radical cystectomy (n=428) after a median of 8 years of followup.43 It also found a 16 percent reduction in mortality in those patients who received three cycles of CMV before radical cystectomy or radiation therapy, which corresponded to an increase in 3-year survival from 50 to 56 percent, an increase in 10-year survival from 30 to 36 percent, and a median survival advantage of 7 months (from 37 to 44 months). Another trial (n=307) found neoadjuvant MVAC plus radical cystectomy with regional lymph node dissection associated with decreased risk of all-cause mortality (59% vs. 65%, HR 0.75, 95% CI 0.57 to 1.00) and bladder cancer mortality (35% vs. 50%, HR 0.60, 95% CI 0.41 to 0.82) versus cystectomy plus lymph node dissection without NAC after a median of 8.7 years followup.41 Neoadjuvant MVAC was also associated with longer median duration of survival (77 vs. 46 months, p=0.05). One other trial (n=130) also found neoadjuvant MVAC associated with a non-statistically significant trend towards lower risk of 5-year mortality versus cystectomy without NAC (28% vs. 38%, HR 0.65, 95% CI 0.19 to 2.18); the study was underpowered due to poor accrual and early termination.44 Median survival also favored NAC (102 vs. 82 months).

Three other trials that evaluated cisplatin-based regimens not commonly used in current practice also found NAC associated with decreased risk of mortality, or a trend towards decreased risk.45, 47, 48 One trial (n=311) found neoadjuvant cisplatin and doxorubicin associated with lower risk of death after adjusting for age, gender, histologic grade, hydronephrosis, and tumor stage (RR 0.69, 95% CI 0.49 to 0.98).45 One trial (n=309) found neoadjuvant cisplatin and methotrexate associated with a trend towards higher 5-year survival that was not statistically significant (53% vs. 46% 5-year survival, p=0.24).48 Another very small (n=33) trial also found neoadjuvant cisplatin and methotrexate plus cystectomy associated with trends towards higher 5-year survival (64% vs. 46%) and median survival duration (82 vs. 46 months, p=0.76).47

##### Progression

The trial of neoadjuvant CMV found NAC associated with lower risk of metastasis or death versus no NAC after a median of 4 years (45% vs. 53%, HR 0.79, 95% CI 0.66 to 0.93).42A trial of neoadjuvant MVAC found NAC associated with a decreased risk of disease-progression at 5 years (36% vs. 45%, HR 0.64, 95% CI 0.37 to 1.11) and progression-free survival interval (99 vs. 78 months).44 A small trial (n=33) found neoadjuvant NAC associated with slightly higher likelihood of 5-year progression-free survival versus no NAC (41% vs. 36%), but the estimate was imprecise and the difference was not statistically significant.47

##### Recurrence

Three RCTs found no effects of NAC on risk of locoregional bladder cancer recurrence.42, 43, 45, 48 The largest trial (n=976) found a trend toward improvement in locoregional disease-free survival in those who received CMV prior to radical cystectomy, radiation therapy, or both with a 13 percent decrease in risk of locoregional recurrence or death, but the difference was not statistically significant (HR 0.87, 95% CI 0.75 to 1.01). This same study showed no effect of CMV NAC on locoregional control (HR 0.96, 95% CI 0.80 to 1.15) after 10 years.42, 43 When results were stratified according to receipt of radical cystectomy or radiation therapy, the effect was somewhat stronger in patients who underwent radical cystectomy (HR 0.74, 95% CI 0.58 to 0.95) than radiation therapy (HR 0.91, 95% CI 0.73 to 1.14), but confidence intervals overlapped.43 Another trial (n=311) found no differences between cisplatin plus doxorubicin prior to radical cystectomy versus radical cystectomy alone in risk of recurrence (21% vs. 25%, RR 0.82, 95% CI 0.54 to 1.24) or in time to relapse (median 23 vs. 14 months, p=0.42) after a minimum of 5 years of followup.45 The third trial (n=309) found no difference in locoregional or distant recurrence between NAC with cisplatin and methotrexate prior to radical cystectomy after 5 years (10% vs. 9%, RR 1.06, 95% CI 0.53 to 2.13).48

#### Adjuvant Chemotherapy

##### Mortality

Four trials reported effects of AC on mortality in patients following radical cystectomy.49-52 Though most trials reported results that favored AC, no trial reported a statistically significant effect, and there was some inconsistency. One trial (n=50) found no difference between adjuvant CMV versus no AC in 5-year survival (52% vs. 32%, RR 0.71 95% CI 0.43 to 1.15).49 There was also no difference in the subgroup of patients (n=15) found to be node-negative (71% vs. 25%, RR 0.38, 95% CI 0.11 to 1.31). Another trial (n=183) found no difference between adjuvant cisplatin and gemcitabine versus no AC in 5-year survival among all patients (43% vs. 54%, p=0.24) or in the subgroup of node-negative patients (65% vs. 73%, p=0.65).50 One trial (n=83) found no difference between adjuvant cisplatin and methotrexate versus no AC in survival among node-negative patients after a median followup of 69 months (49% vs. 38%).52 There was also no difference in bladder cancer-specific mortality (46% vs. 52%, RR 0.88, 95% CI 0.56 to 1.38). Another trial (n=91) found no difference between adjuvant cisplatin, doxorubicin, and cyclophosphamide versus no AC in all-cause mortality (34% vs. 50%, p=0.10), bladder cancer-specific mortality (probability 0.29 vs. 0.50) within 3 years in all patients, or among the subgroup of node-negative patients (p=0.14).51

##### Progression

One trial (n=83) found no difference between adjuvant cisplatin and methotrexate versus no AC in risk of progression among node-negative patients (49% vs. 44%, RR 0.91, 95% CI 0.61 to 1.37) after a mean followup of 69 months.52

##### Recurrence

Three trials of AC reported risk of recurrence.49-51 Results were inconsistent. One trial (n=50) found adjuvant CMV associated with decreased risk of recurrence after 5 years (52% vs. 76%, RR 0.68, 95% CI 0.44 to 1.06) versus no AC, as well as longer mean time to recurrence (17.5 vs. 11.5 months p=0.01).49 A trial (n=183) of adjuvant cisplatin and gemcitabine found no difference in risk of recurrence after a median followup of 35 months (44% vs. 47%, RR 0.95, 95% CI 0.69 to 1.31).50 In both trials, results weren’t reported separately for patients found to be node-negative following lymph node dissection. The third trial found adjuvant cisplatin, doxorubicin, and cyclophosphamide associated with decreased risk of recurrence at 3 years (probability 0.30 vs. 0.54, p=0.01), with an increase in median time to recurrence of 4.7 years.51 Effects on recurrence were also observed in the subgroup of patients who were node-negative (p=0.04).

## Key Question 3a What is the comparative effectiveness of various combinations of agents used for neoadjuvant or adjuvant chemotherapy?

### Key Points

- Evidence from three cohort studies of neoadjuvant or adjuvant MVAC versus cisplatin and gemcitabine was too unreliable to evaluate comparative effectiveness, due to serious methodological limitations (SOE: insufficient).

### Detailed Synthesis

No RCT directly compared different neoadjuvant or adjuvant chemotherapy regimens. Three retrospective cohort studies compared chemotherapy with MVAC versus cisplatin and gemcitabine.53-55 One study (n=116) found no difference between neoadjuvant MVAC versus cisplatin and gemcitabine in risk of mortality (HR 0.90, 95% CI 0.52 to 1.56) or bladder cancer recurrence (HR 0.60, 95% CI 0.34 to 1.03) after adjustment for age and tumor stage.53 The study was rated high risk of bias due to large differences in selection of neoadjuvant regimens based on year of treatment (7% of patients received gemcitabine and cisplatin from 1985-1999 vs. 93% from 2000-2011), which may explain differences in the number of lymph nodes evaluated (median 36 for MVAC vs. 53 for gemcitabine plus cisplatin). The other two studies did not attempt to adjust for potential confounders and were also rated high risk of bias. One study (n=66) found no difference in survival between neoadjuvant MVAC versus neoadjuvant cisplatin and gemcitabine, although median overall survival favored MVAC (104.3 vs. 21.8 months, p=0.73).54 Another retrospective cohort study (n=114) found no differences between MVAC versus cisplatin and gemcitabine administered either in the neoadjuvant or adjuvant setting in 5-year overall or cancer-specific survival.55 Both studies were rated high risk of bias and did not adjust for potential confounders (Appendix F).

## Key Question 3b Does the comparative effectiveness of various combinations of agents used for neoadjuvant or adjuvant chemotherapy differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers?

### Key Points

- Four trials found no clear differences in estimates of effectiveness of NAC versus no NAC in subgroups based on tumor stage or grade (SOE: low).
- Two trials found no clear differences in estimates of effectiveness of AC versus no AC in subgroups based on nodal status or tumor stage (SOE: low).

### Detailed Synthesis

Evidence on the effects of tumor characteristics on effectiveness of chemotherapy was largely limited to tumor stage and nodal status. One trial (n=311) found neoadjuvant cisplatin and doxorubicin associated with higher likelihood of bladder cancer-specific survival versus no NAC in patients with T3-T4a tumors (52% vs. 37%). Although NAC was also associated with higher likelihood of bladder cancer-specific survival in patients with T2 tumors (58% vs. 55%) and high grade T1 (77% vs. 71%) tumors, the effects were less pronounced.45 Another trial reported similar effects of neoadjuvant MVAC on median survival in patients with T2 (105 vs. 75 months) and T3/T4a (65 vs. 24 months) bladder cancer (p=0.45 for interaction between tumor stage and treatment effects).41 Three other RCTs43, 44, 48 that focused on patients with T2-T4a tumors found no interaction between stage of bladder cancer and effectiveness of NAC. In one of these trials, neoadjuvant CMV was associated with greater benefit in high grade tumors than for low grade cancers (p=0.003 for interaction) and there was a trend towards an interaction with tumor size (p=0.06); there was no interaction between nodal status and effects of NAC (p=0.96).43 Another trial found no differences in estimates of effectiveness of NAC in subgroups defined by presence of papillary versus nonpapillary tumors, solitary versus multiple tumors, tumor size, or tumor grade.44

Two trials of AC found no clear effects of nodal status on estimates of effectiveness;49, 50 one of these trials also found no clear effects of tumor stage on effectiveness.50

## Key Question 3c Does the comparative effectiveness differ according to patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease?

### Key Points

- Five trials found no clear interaction between age and estimates of effectiveness of NAC versus no NAC (SOE: low).
- One trial found no interaction between sex or performance status on effectiveness of NAC versus no NAC, but found NAC more effective in patients with better renal function (SOE: low).

### Detailed Synthesis

Few trials evaluated effect of patient characteristics on the comparative effectiveness of neoadjuvant or adjuvant chemotherapy. Five trials reported no clear interaction between age and estimates of effectiveness of NAC versus no NAC.41, 42, 44, 45, 47One trial of neoadjuvant CMV found no interaction between sex or World Health Organization (WHO) performance status of effects of chemotherapy, but found NAC more effective in patients with better renal function (p=0.024 for interaction).42

## Key Question 3d Does the comparative effectiveness of neoadjuvant or adjuvant chemotherapy differ according to dosing frequency and/or the timing of its administration relative to radical cystectomy?

### Key Points

- One trial and two cohort studies found that neither adjuvant nor neoadjuvant MVAC was superior for overall or bladder cancer-specific survival (SOE: low).
- There was insufficient evidence from one small cohort study with methodological shortcomings of adjuvant versus neoadjuvant gemcitabine plus cisplatin to determine effects on bladder cancer recurrence (SOE: insufficient).
- One trial found that neither administration of adjuvant cisplatin plus gemcitabine on day 2 versus day 15 was superior for 5-year survival (SOE: low).

### Detailed Synthesis

One trial of patients undergoing radical cystectomy found no differences between five cycles of adjuvant versus two cycles of neoadjuvant plus three cycles of adjuvant MVAC in overall or disease-free survival (60% vs. 56%, RR 0.90, 95% CI 0.61 to 1.33).56 The trial was rated medium risk of bias. One retrospective cohort study (rated medium risk of bias) also found no statistically significant difference in overall or disease-specific survival between neoadjuvant versus adjuvant cisplatin/carboplatin based therapies.57 Analyses controlling for age, race/ethnicity, sex, smoking history, tumor stage and grade, and chemotherapy type did not change the results. Another retrospective cohort study, rated high risk of bias,55 included two therapeutic arms: MVAC and cisplatin plus gemcitabine with regimens given as either NAC or AC. NAC was associated with decreased risk of mortality versus AC, regardless of regimen, though effects were not statistically significant; the HR for overall mortality was 0.61(95% CI 0.37 to 1.0) and HR for cancer-specific mortality was 0.69(95% CI 0.37 to 1.29). Another small (n=42) retrospective cohort study also found no difference in recurrence-free survival between adjuvant versus neoadjuvant gemcitabine and cisplatin, but did not adjust for potential confounders.58

One RCT (n=132) found no difference between administration of adjuvant cisplatin plus gemcitabine on day 2 versus day 15 in 5-year survival (47% vs. 40%, p=0.88).50 One retrospective cohort study found no difference between “standard” cisplatin and gemcitabine (cisplatin 70 mg/m^2^ day 1 and gemcitabine 1000 mg/m^2^ days 1 and 8 for four 21-day cycles) or “split dose” therapy (cisplatin 35 mg/m^2^ and gemcitabine 1000 mg/m^2^ on days 1 and 8 for four 21-day cycles) in overall survival (48% vs. 13%, RR 0.60, 95% CI 0.40 to 0.91), but the estimate was imprecise and the study did not attempt to adjust for potential confounding.59

## Key Question 4 What are the comparative adverse effects of treatments for nonmetastatic muscle-invasive bladder cancer?

### Key Points

#### Bladder-Preserving Therapies Versus Radical Cystectomy

- There was insufficient evidence from four studies of bladder-sparing therapies versus radical cystectomy to determine comparative risk of harms due to poor reporting of harms data and methodological limitations in the studies (SOE: insufficient).

#### More Versus Less Extensive Regional Lymph Node Dissection

- One cohort study found extended lymph node dissection associated with longer operative time than standard lymph node dissection (median 330 vs. 277 minutes) (SOE: insufficient).

#### Neoadjuvant Chemotherapy

- In three trials, NAC was not associated with increased risk of surgical complications or perioperative deaths versus no NAC (SOE: moderate).
- In two trials, NAC was associated with grade 3 or 4 hematological adverse events (SOE: low).

#### Adjuvant Chemotherapy

- Harms were poorly reported in three trials of AC versus no AC (SOE: insufficient).

#### Adjuvant Chemotherapy Versus Neoadjuvant Chemotherapy

- One trial found no difference between neoadjuvant versus adjuvant MVAC in risk of mortality related to chemotherapy toxicity (SOE: low).

### Detailed Synthesis

#### Bladder-Preserving Therapies Versus Radical Cystectomy

Four studies of bladder-sparing therapy versus radical cystectomy reported selected harms.19, 22, 23, 27 One RCT (n=183) found no difference between bladder-preserving therapy with external beam radiation therapy with 60 Gray versus radical cystectomy plus external beam radiation therapy with 40 Gray in risk of moderate gastrointestinal adverse events (20% vs. 25%).19 Three cohort studies also reported selected harms associated with bladder-preserving therapies, but did not perform statistical adjustment for potential confounders. One study (n=78) found no difference between bladder-sparing therapy with radiation therapy versus radical cystectomy in peri-treatment deaths (7.1% vs. 5.6%).22 Another study found that 6.7 percent of patients undergoing bladder-preserving radiation therapy (n=119) experienced grade 3 diarrhea and 6.7 percent experienced grade 3 leukopenia, while 46 percent of patients undergoing radical cystectomy experienced postoperative complications (primarily surgical site infections).23 The third cohort study found that among patients undergoing bladder-preserving cisplatin-based chemotherapy, 32 percent experienced at least grade 3 leukopenia, 66 percent neutropenia, 13 percent anemia, and 25 percent thrombocytopenia.27 Adverse events in patients undergoing radical cystectomy were not reported.

#### More Versus Less Extensive Lymph Node Dissection

One study (n=92) found extended lymph node dissection associated with longer operative time than standard lymph node dissection (median 330 vs. 277 minutes), though results were not adjusted for urinary diversion type.34 There were no differences in length of intensive care unit stay or length of hospitalization.

#### Neoadjuvant Chemotherapy

Harms were inconsistently reported in trials of NAC versus no NAC, though data were available from three trials.41, 42, 45 One trial (n=976) reported a mortality rate of 1 percent (5/491) among patients randomized to neoadjuvant CMV prior to radical cystectomy and/or radiation therapy; among 561 patients with planned cystectomy, four (0.7%) did not undergo surgery due to chemotherapy related adverse events.42 There was no difference in the number of treatment-related deaths among patients randomized to NAC versus no NAC (3.3% vs. 3.3%).43 Among patients who underwent radical cystectomy, NAC did not increase risk of deaths attributable to cystectomy (2.1% [6/284] vs. 4.3% [12/277] for post-operative wound infections, (7.0% [20/284] vs. 11% [31/277]) for wound dehiscence (2.1% [6/284] vs. 6.5% [18/277]) or development of urinary or fecal fistulae (1.8% [5/284] vs. 6.1% [17/277].42 The rate of serious (WHO grade 3-4) hematologic adverse events among patients who received NAC was 16 percent for leukopenia and 6.5 percent thrombocytopenia. No grade 3 or 4 renal toxic events were reported among patients who received NAC, though 26 percent required dose reductions or dose delays related to impaired renal function.

Another trial (n=307) of neoadjuvant MVAC prior to radical cystectomy reported that among those randomized to NAC, 57 percent (85/150) experienced grade 3 or 4 granulocytopenia, 4.7 percent (7/150) grade 3 thrombocytopenia, and 6.0 percent (9/150) grade 3 anemia.41 No chemotherapy-associated deaths were reported. The third trial (n=311) found no difference in risk of mortality within 30 days of cystectomy between patients randomized to neoadjuvant cisplatin and doxorubicin versus those randomized to no NAC (1.3% [2/151] vs. 2.5% [4/160]).45 There were also no differences in risk of any postoperative complications (48/151 vs. 48/160), though NAC was associated with a higher risk of ileus (13/151 vs. 4/160) and lower risk of wound dehiscence (10/151 vs. 4/160). Hematological and renal adverse events were not reported.

#### Adjuvant Chemotherapy

Three trials of AC versus no AC reported harms in patients randomized to AC.49, 51, 52 One small trial reported one death attributed to neutropenia among 25 patients (4%) randomized to AC after one cycle of CMV.49 Two patients (8%) were hospitalized for neutropenia and fever after AC (8%), eight (32%) had additional cycles of chemotherapy due to hematological adverse events, and three (12%) had decreases in renal function requiring dose reduction of chemotherapy; in one patient renal dysfunction (Cr 2.6) was permanent.

One trial (n=114) of adjuvant cisplatin and methotrexate reported renal adverse events in 17 percent (11/66), but the type and severity of events were not further described.52 One patient (1.5%) had a hematological adverse event and 11 percent (7/66) required cessation of chemotherapy for reasons that were not reported. A third trial (n=91) reported no deaths or long-term adverse events in patients randomized to adjuvant cisplatin, doxorubicin, and cyclophosphamide.51

#### Adjuvant Versus Neoadjuvant Therapy

One trial found no difference between neoadjuvant versus adjuvant MVAC in risk of death related to toxic effects of chemotherapy (9% [6/70] vs. 9% [6/70]).56 The estimate for perioperative death was imprecise (1.6% [1/63] vs. 4.5% [3/66]). Hematologic and renal adverse events were not reported.

## Key Question 4a How do adverse effects of treatment vary by patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease?

### Key Points

- No trial evaluated how estimates of harms associated with NAC or AC vary in subgroups defined by patient characteristics such as age, sex, race/ethnicity, performance status, or comorbidities.

### Detailed Synthesis

No studies.