# References

1 Siegel R, Ma J, Zou Z, et al. Cancer statistics, 2014. CA: a Cancer Journal for Clinicians. 2014;64(1):9-29. PMID: No PMID. [pmid: 24399786].
2 U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999–2009 Incidence and Mortality Web-based Report. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention and National Cancer Institute. Atlanta. 2013. www.cdc.gov/uscs. PMID: No PMID.
3 National Cancer Institute Surveillance Research Program. Surveillance Epidemiology and End Results. Browse the SEER Cancer Statistics Review 1975-2009 (Vintage 2009 Populations). http://seer.cancer.gov/csr/1975_2009_pops09/browse_csr.php?section=27&page=sect_27_table.01.html. on October 16^th^, 2013. [not found in PubMed].
4 James AC, Gore JL. The costs of non-muscle invasive bladder cancer. Urol Clin North Am. May. 2013;40(2):261-9. [pmid: 23540783].
5 American Cancer Society. Bladder Cancer; Early Detection, Diagnosis, and Staging Topics.
6 Konety BR, Joyce GF, W F. Bladder and upper tract urothelial cancer. Washington, DC. US Government Printing Office. 2007;07–5512. [pmid: 17437776].
7 Cancer Research UK. Bladder cancer stage and grade. London. Cancer Research UK. 2013.
8 American Cancer Society. How is bladder cancer staged?. Society AC, editor. 2014. PMID: No PMID.
9 Babjuk M, Burger M, Zigeuner R, et al. EAU guidelines on non-muscle-invasive urothelial carcinoma of the bladder: update 2013. Eur Urol. Oct. 2013;64(4):639-53. [pmid: 23827737].
10 Ru Y, Dancik GM, Theodorescu D. Biomarkers for prognosis and treatment selection in advanced bladder cancer patients. Curr Opin Urol. Sep. 2011;21(5):420-7. [pmid: 21814055].
11 Stenzl A, Witjes JA, Compérat E. Guidelines on Bladder Cancer Muscle-invasive and Metastatic. EAU. 2012. PMID: No PMID.
12 Bruins HM, Huang GJ, Cai J, et al. Clinical outcomes and recurrence predictors of lymph node positive urothelial cancer after cystectomy. J Urol. Nov. 2009;182(5):2182-7. [pmid: 19758623].
13 Stein JP, Cai J, Groshen S, et al. Risk factors for patients with pelvic lymph node metastases following radical cystectomy with en bloc pelvic lymphadenectomy: concept of lymph node density. J Urol. Jul. 2003;170(1):35-41. [pmid: 12796639].
14 Wright JL, Lin DW, Porter MP. The association between extent of lymphadenectomy and survival among patients with lymph node metastases undergoing radical cystectomy. Cancer. Jun. 2008;112(11):2401-8. [pmid: 18383515].
15 Gore JL, Litwin MS, Lai J, et al. Use of radical cystectomy for patients with invasive bladder cancer. JNCI. Jun 2. 2010;102(11):802-11. [pmid: 20400716].
16 Herr HW. Transurethral resection of muscle-invasive bladder cancer: 10-year outcome. J Clin Oncol. Jan. 1. 2001;19(1):89-93. [pmid: 11134199].
17 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. 2014. PMID: No PMID.
18 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. [Web Page]. 2008. www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. April 4th, 2014.
19 Sell A, Jakobsen A, Nerstrom B, et al. Treatment of advanced bladder cancer category T2 T3 and T4a. A randomized multicenter study of preoperative irradiation and cystectomy versus radical irradiation and early salvage cystectomy for residual tumor. DAVECA protocol 8201. Danish Vesical Cancer Group. Scand J Urol Nephrol Suppl. 1991;138:193-201. [pmid: 1785004].
20 Bekelman JE, Handorf EA, Guzzo T, et al. Radical cystectomy versus bladder-preserving therapy for muscle-invasive urothelial carcinoma: examining confounding and misclassification biasin cancer observational comparative effectiveness research. Value Health. Jun. 2013;16(4):610-8. [pmid: 23796296].
21 Goossens-Laan CA, Leliveld AM, Verhoeven RHA, et al. Effects of age and comorbidity on treatment and survival of patients with muscle-invasive bladder cancer. Int J Cancer. Aug. 15. 2014;135(4):905-12. [pmid: 24420527].
22 Holmang S, Hedelin H, Anderstrom C, et al. Long-term followup of all patients with muscle invasive (stages T2, T3 and T4) bladder carcinoma in a geographical region. J Urol. Aug. 1997;158(2):389-92. [pmid: 9224309].
23 Kalogeras D, Lampri E, Goussia A, et al. Radical therapy for muscle-infiltrating bladder cancer (cystectomy or radiotherapy): does age affect the final therapeutic benefit for the patient?. Journal of B.U.ON. Jul-Sep. 2008;13(3):353-8. [pmid: 18979549].
24 Kotwal S, Choudhury A, Johnston C, et al. Similar treatment outcomes for radical cystectomy and radical radiotherapy in invasive bladder cancer treated at a United Kingdom specialist treatment center. Int J Rad Oncol Biol, Phys. Feb. 1. 2008;70(2):456-63. [pmid: 17904301].
25 Nieuwenhuijzen JA, Pos F, Moonen LMF, et al. Survival after bladder-preservation with brachytherapy versus radical cystectomy; a single institution experience. Eur Urol. Aug. 2005;48(2):239-45. [pmid: 16005375].
26 Rincon Mayans A, Rosell Costa D, Zudaire Bergera JJ, et al. Response and progression-free survival in T2 to T4 bladder tumors treated with trimodality therapy with bladder preservation. Actas Urol Esp. Oct. 2010;34(9):775-80. [pmid: 20843454].
27 Solsona E, Climent MA, Iborra I, et al. Bladder preservation in selected patients with muscle-invasive bladder cancer by complete transurethral resection of the bladder plus systemic chemotherapy: long-term follow-up of a phase 2 nonrandomized comparative trial with radical cystectomy. Eur Urol. Apr. 2009;55(4):911-9. [pmid: 18722046].
28 James ND, Hussain SA, Hall E, et al. Radiotherapy with or without chemotherapy in muscle-invasive bladder cancer. N Engl J Med. Apr 19. 2012;366(16):1477-88. [pmid: 22512481].
29 Abdollah F, Sun M, Schmitges J, et al. Stage-specific impact of pelvic lymph node dissection on survival in patients with non-metastatic bladder cancer treated with radical cystectomy. BJU International. Apr. 2012;109(8):1147-54. [pmid: 21883849].
30 Herr HW, Bochner BH, Dalbagni G, et al. Impact of the number of lymph nodes retrieved on outcome in patients with muscle invasive bladder cancer. J Urol. Mar. 2002;167(3):1295-8. [pmid: 11832716].
31 Konety BR, Joslyn SA, O'Donnell MA. Extent of pelvic lymphadenectomy and its impact on outcome in patients diagnosed with bladder cancer: analysis of data from the Surveillance, Epidemiology and End Results Program data base. J Urol. Mar. 2003;169(3):946-50. [pmid: 12576819].
32 Shirotake S, Kikuchi E, Matsumoto K, et al. Role of pelvic lymph node dissection in lymph node-negative patients with invasive bladder cancer. Jpn J Clin Oncol. Mar. 2010;40(3):247-51. [pmid: 19887521].
33 Herr HW, Faulkner JR, Grossman HB, et al. Surgical factors influence bladder cancer outcomes: a cooperative group report. J Clin Oncol. Jul 15. 2004;22(14):2781-9. [pmid: 15199091].
34 Brossner C, Pycha A, Toth A, et al. Does extended lymphadenectomy increase the morbidity of radical cystectomy?. BJU International. Jan. 2004;93(1):64-6. [pmid: 14678370].
35 Brunocilla E, Pernetti R, Schiavina R, et al. The number of nodes removed as well as the template of the dissection is independently correlated to cancer-specific survival after radical cystectomy for muscle-invasive bladder cancer. Int Urol Nephrol. Jun. 2013;45(3):711-9. [pmid: 23666588].
36 Dhar NB, Klein EA, Reuther AM, et al. Outcome after radical cystectomy with limited or extended pelvic lymph node dissection. J Urol. Mar. 2008;179(3):873-8. discussion 8. [pmid: 18221953].
37 Leissner J, Hohenfellner R, Thuroff JW, et al. Lymphadenectomy in patients with transitional cell carcinoma of the urinary bladder; significance for staging and prognosis. BJU International. May. 2000;85(7):817-23. [pmid: 10792159].
38 Poulsen AL, Horn T, Steven K. Radical cystectomy: extending the limits of pelvic lymph node dissection improves survival for patients with bladder cancer confined to the bladder wall. J Urol. Dec. 1998;160(6 Pt 1):2015-9. discussion 20. [pmid: 9817313].
39 Zehnder P, Studer UE, Skinner EC, et al. Super extended versus extended pelvic lymph node dissection in patients undergoing radical cystectomy for bladder cancer: a comparative study. J Urol. Oct. 2011;186(4):1261-8. [pmid: 21849183].
40 Simone G, Papalia R, Ferriero M, et al. Stage-specific impact of extended versus standard pelvic lymph node dissection in radical cystectomy. Int J Urol. Apr. 2013;20(4):390-7. [pmid: 22970939].
41 Grossman HB, Natale RB, Tangen CM, et al. Neoadjuvant chemotherapy plus cystectomy compared with cystectomy alone for locally advanced bladder cancer. [Erratum appears in N Engl J Med. 2003 Nov 6;349(19):1880]. N Engl J Med. Aug. 28. 2003;349(9):859-66. [pmid: 12944571].
42 International Collaboration of Trialists. Neoadjuvant cisplatin, methotrexate, and vinblastine chemotherapy for muscle-invasive bladder cancer: a randomised controlled trial. International collaboration of trialists. [Erratum appears in Lancet 1999 Nov 6;354(9190):1650]. Lancet. Aug. 14. 1999;354(9178):533-40. [pmid: 10470696].
43 International Collaboration of Trialists, Medical Research Council Advanced Bladder Cancer Working P, European Organisation for R, et al. International phase III trial assessing neoadjuvant cisplatin, methotrexate, and vinblastine chemotherapy for muscle-invasive bladder cancer: long-term results of the BA06 30894 trial. J Clin Oncol. Jun. 1. 2011;29(16):2171-7. [pmid: 21502557].
44 Kitamura H, Tsukamoto T, Shibata T, et al. Randomised phase III study of neoadjuvant chemotherapy with methotrexate, doxorubicin, vinblastine and cisplatin followed by radical cystectomy compared with radical cystectomy alone for muscle-invasive bladder cancer: Japan Clinical Oncology Group Study JCOG0209. Ann Oncol. Jun. 2014;25(6):1192-8. [pmid: 24669010].
45 Malmstrom PU, Rintala E, Wahlqvist R, et al. Five-year followup of a prospective trial of radical cystectomy and neoadjuvant chemotherapy: Nordic Cystectomy Trial I. The Nordic Cooperative Bladder Cancer Study Group. J Urol. Jun. 1996;155(6):1903-6. [pmid: 8618283].
46 Rintala E, Hannisdahl E, Fossa SD, et al. Neoadjuvant chemotherapy in bladder cancer: a randomized study. Nordic Cystectomy Trial I. Scand J Urol Nephrol. 1993;27(3):355-62. [pmid: 8290916].
47 Sengelov L, von der Maase H, Lundbeck F, et al. Neoadjuvant chemotherapy with cisplatin and methotrexate in patients with muscle-invasive bladder tumours. Acta Oncologica. 2002;41(5):447-56. [pmid: 12442921].
48 Sherif A, Rintala E, Mestad O, et al. Neoadjuvant cisplatin-methotrexate chemotherapy for invasive bladder cancer -- Nordic cystectomy trial 2. Scand J Urol Nephrol. 2002;36(6):419-25. [pmid: 12623505].
49 Freiha F, Reese J, Torti FM. A randomized trial of radical cystectomy versus radical cystectomy plus cisplatin, vinblastine and methotrexate chemotherapy for muscle invasive bladder cancer. J Urol. Feb. 1996;155(2):495-9. discussion 9–500. [pmid: 8558644].
50 Cognetti F, Ruggeri EM, Felici A, et al. Adjuvant chemotherapy with cisplatin and gemcitabine versus chemotherapy at relapse in patients with muscle-invasive bladder cancer submitted to radical cystectomy: an Italian, multicenter, randomized phase III trial. Ann Oncol. Mar. 2012;23(3):695-700. [pmid: 21859900].
51 Skinner DG, Daniels JR, Russell CA, et al. The role of adjuvant chemotherapy following cystectomy for invasive bladder cancer: a prospective comparative trial. J Urol. Mar. 1991;145(3):459-64. discussion 64–7. [pmid: 1997689].
52 Bono AV, Benvenuti C, Gibba A, et al. Adjuvant chemotherapy in locally advanced bladder cancer. Final analysis of a controlled multicentre study. Acta Urologica Italica. 1997;11(1):5-8. PMID: No PMID.
53 Fairey AS, Daneshmand S, Quinn D, et al. Neoadjuvant chemotherapy with gemcitabine/cisplatin vs. methotrexate/vinblastine/doxorubicin/cisplatin for muscle-invasive urothelial carcinoma of the bladder: a retrospective analysis from the University of Southern California. Urol Oncol. Nov. 2013;31(8):1737-43. [pmid: 23141776].
54 Pal SK, Ruel NH, Wilson TG, et al. Retrospective analysis of clinical outcomes with neoadjuvant cisplatin-based regimens for muscle-invasive bladder cancer. Clin Genitourin Cancer. Dec. 2012;10(4):246-50. [pmid: 22981208].
55 Yeshchina O, Badalato GM, Wosnitzer MS, et al. Relative efficacy of perioperative gemcitabine and cisplatin versus methotrexate, vinblastine, adriamycin, and cisplatin in the management of locally advanced urothelial carcinoma of the bladder. Urology. Feb. 2012;79(2):384-90. [pmid: 22196406].
56 Millikan R, Dinney C, Swanson D, et al. Integrated therapy for locally advanced bladder cancer: final report of a randomized trial of cystectomy plus adjuvant M-VAC versus cystectomy with both preoperative and postoperative M-VAC. J Clin Oncol. Oct. 15. 2001;19(20):4005-13. [pmid: 11600601].
57 Wosnitzer MS, Hruby GW, Murphy AM, et al. A comparison of the outcomes of neoadjuvant and adjuvant chemotherapy for clinical T2-T4aN0-N2M0 bladder cancer. Cancer. Jan. 15. 2012;118(2):358-64. [pmid: 21717438].
58 Matsubara N, Mukai H, Naito Y, et al. Comparison between neoadjuvant and adjuvant gemcitabine plus cisplatin chemotherapy for muscle-invasive bladder cancer. Asia Pac J Clin Oncol. Dec. 2013;9(4):310-7. [pmid: 23127231].
59 Dash A, Pettus JAt, Herr HW, et al. A role for neoadjuvant gemcitabine plus cisplatin in muscle-invasive urothelial carcinoma of the bladder: a retrospective experience. Cancer. Nov. 1. 2008;113(9):2471-7. [pmid: 18823036].
60 Pabla N, D Z. Cisplatin nephrotoxicity: Mechanisms and renoprotective strategies. Kidney Int. 2008;73:994-1007. PMID: No PMID. [pmid: 18272962].
61 Gakis G, Efstathiou J, Lerner SP, et al. ICUD-EAU International Consultation on Bladder Cancer 2012: Radical cystectomy and bladder preservation for muscle-invasive urothelial carcinoma of the bladder. Eur Urol. Jan. 2013;63(1):45-57. [pmid: 22917985].
62 Bruins HM, Veskimae E, Hernandez V, et al. The Impact of the Extent of Lymphadenectomy on Oncologic Outcomes in Patients Undergoing Radical Cystectomy for Bladder Cancer: A Systematic Review. Eur Urol. 2014. Jul. 26. [pmid: 25074764].
63 Mandel P, Tilki D, Eslick GD. Extent of lymph node dissection and recurrence-free survival after radical cystectomy: A meta-analysis. Urol Oncol. 2014. Jul. 11. [pmid: 25027683].
64 Winquist E, Kirchner TS, Segal R, et al. Neoadjuvant chemotherapy for transitional cell carcinoma of the bladder: a systematic review and meta-analysis. J Urol. Feb. 2004;171(2 Pt 1):561-9. [pmid: 14713760].
65 Advanced Bladder Cancer Overview Collaboration. Neo-adjuvant chemotherapy for invasive bladder cancer. Cochrane Database of Syst Rev. 2004. CD006018. [pmid: 15846746].
66 Meeks JJ, Bellmunt J, Bochner BH, et al. A systematic review of neoadjuvant and adjuvant chemotherapy for muscle-invasive bladder cancer. Eur Urol. Sep. 2012;62(3):523-33. [pmid: 22677572].
67 Vale CL. Adjuvant chemotherapy for invasive bladder cancer (individual patient data). Cochrane Database of Systematic Reviews. 2006;(2). CD006018. [pmid: 16625650].
68 Mitin T, Shipley WU, Efstathiou JA, et al. Trimodality therapy for bladder conservation in treatment of invasive bladder cancer. Curr Urol Rep. Apr. 2013;14(2):109-15. [pmid: 23341373].
69 Song F, Khan KS, Dinnes J, et al. Asymmetric funnel plots and publication bias in meta-analyses of diagnostic accuracy. Int J Epidemiol. Feb. 2002;31(1):88-95. [pmid: 11914301].
70 Deeks JJ, Macaskill P, Irwig L. The performance of tests of publication bias and other sample size effects in systematic reviews of diagnostic test accuracy was assessed. J Clin Epidemiol. Sep. 2005;58(9):882-93. [pmid: 16085191].
71 Parkinson JP, Konety BR. Health related quality of life assessments for patients with bladder cancer. J Urol. Dec. 2004;172(6 Pt 1):2130-6. [pmid: 15538218].
72 Kim SP, Karnes RJ. Standard or Extended Lymphadenectomy in Radical Cystectomy: What Metric of Surgical Quality for Lymph Node Dissections Matters in Improving Patient Outcomes?. Eur Urol. 2011;60(5):953-4. PMID: No PMID. [pmid: 21855207].
73 Plimack ER, Hoffman-Censits JH, Viterbo R, et al. Accelerated methotrexate, vinblastine, doxorubicin, and cisplatin is safe, effective, and efficient neoadjuvant treatment for muscle-invasive bladder cancer: results of a multicenter phase II study with molecular correlates of response and toxicity. J Clin Oncol. Jun 20. 2014;32(18):1895-901. [pmid: 24821881].
74 Choueiri TK, Jacobus S, Bellmunt J, et al. Neoadjuvant dose-dense methotrexate, vinblastine, doxorubicin, and cisplatin with pegfilgrastim support in muscle-invasive urothelial cancer: pathologic, radiologic, and biomarker correlates. J Clin Oncol. Jun. 20. 2014;32(18):1889-94. [pmid: 24821883].
75 Southwest Oncology Group T. S1314, Co-expression Extrapolation (COXEN) Program to Predict Chemotherapy Response in Patients with Bladder Cancer. 2014. PMID: No PMID.
76 Southwest Oncology Group T. S1011 Standard of Extended Pelvic Lymphaddenectomy in Treating Patients Undergoing Surgery for Invasive Bladder Cancer. A Phase III Surgical Trial to Evaluate the Benefit of a Standard Versus an Extended Pelvic Lymphadenectomy Performed at Time of Radical Csytectomy for Muscle Invasive Urothelial Cancer. https://clinicaltrials.gov/show/NCT01224665. on April 22nd, 2015.
77 Tilki D, Brausi M, Colombo R, et al. Lymphadenectomy for bladder cancer at the time of radical cystectomy. Eur Urol. Aug. 2013;64(2):266-76. [pmid: 23648149].