# Methods

This comparative effectiveness review (CER) follows the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter “AHRQ Methods Guide”).17 All methods were determined a priori.

## Topic Development and Refinement

AHRQ initially received this topic as a nomination via the Effective Healthcare Website (www.effectivehealthcare.ahrq.gov/index.cfm/submit-a-suggestion-for-research/). The Scientific Resource Center (SRC) developed preliminary Key Questions based on input from the topic nominator. The Pacific Northwest Evidence-based Practice Center (EPC) revised the Key Questions and developed eligibility criteria to identify the populations, interventions, comparators, outcomes, timing, and study designs (PICOTS) of interest. The EPC further refined the Key Questions and PICOTS based on input from interviews with eight Key Informants. Key Informants included experts in urology (including experts in urinary biomarkers and urologic oncology), medical oncology, and radiation oncology, as well as patient representatives and payers. Key Informants disclosed financial and other conflicts of interest prior to participation. The AHRQ Task Order Officer and the investigators reviewed the disclosures and determined that the Key Informants had no conflicts of interest that precluded participation. The Key Questions were posted for public comment from February 6, 2014 through February 26, 2014, and comments were received from four individuals.

After reviewing the public comments and obtaining additional input from a Technical Expert Panel (TEP) convened for this report, the research team revised the Key Questions. The TEP consisted of 8 experts, specializing in urology (including urinary biomarkers and urologic oncology), radiation oncology, and medical oncology. The procedure for reviewing potential conflicts of interests of TEP members was similar to the procedure used for the Key Informants. The research team developed the final protocol with input from the TEP and AHRQ, and it was posted on the AHRQ Web site on July 21, 2014 (www.effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=1940). The protocol was also registered in the PROSPERO international database of prospectively registered systematic reviews.

## Searching for the Evidence

A research librarian experienced in conducting literature searches for CERs searched in Ovid MEDLINE (January 1990–October 2014), Cochrane Central Register of Controlled Trials (through September 2014), Cochrane Database of Systematic Reviews (through September 2014), Health Technology Assessment (through third quarter 2014), National Health Sciences Economic Evaluation Database (through third quarter 2014), and Database of Abstracts of Reviews of Effects (through third quarter 2014) to capture both published and grey literature. See Appendix A for the full search strategies. We searched for unpublished studies in clinical trial registries (ClinicalTrials.gov, Current Controlled Trials, ClinicalStudyResults.org and the WHO International Clinical Trials Registry Platform) and regulatory documents ( Drugs@FDA.gov and FDA Medical Devices Registration and Listing). Reference lists of relevant studies and previous systematic reviews were hand-searched for additional studies. Scientific information packets were solicited from drug and device manufacturers and via a notice published in the Federal Register that invited interested parties to submit relevant published and unpublished studies using the publicly accessibly AHRQ Effective Health Care online scientific information packet portal.

Literature search updates were performed while the draft report was posted for public comment. Literature identified during the update search was assessed using the same process of dual review as used for studies identified during the initial searches. Pertinent new literature meeting inclusion criteria was incorporated before the final submission of the report.

## Study Selection

We developed criteria for inclusion and exclusion of studies based on the Key Questions and PICOTS approach, in accordance with the AHRQ Methods Guide.17 Inclusion and exclusion criteria are summarized below and available in more detail in Appendix B. Abstracts were reviewed by two investigators, and all citations deemed appropriate for inclusion by at least one of the reviewers was retrieved. Two investigators independently reviewed all full-text articles for inclusion. Discrepancies were resolved by discussion and consensus. A list of the included studies can be found in Appendix C; excluded studies and primary reason for exclusion can be found in Appendix D.

### Population and Condition of Interest

For all Key Questions, we included studies of adults with node-negative, nonmetastatic muscle-invasive bladder cancer. This includes TNM staging of T2, T3 or T4a, N0, M0. Patients staged clinically could have occult metastasis.

### Interventions, Comparisons, and Study Designs of Interest

For Key Questions 1 and 4, we included studies of bladder-preserving chemotherapy, radiation therapy (external beam or interstitial radiation therapy), partial cystectomy, or maximal transurethral resection of bladder tumor (TURBT) compared with radical cystectomy alone, radical cystectomy in combination with chemotherapy, or to the other included bladder-preserving approaches.

For Key Question 2, we included studies of regional lymph node dissection in conjunction with radical cystectomy or partial cystectomy compared with radical cystectomy without lymph node dissection, or studies of more extensive versus more limited regional lymph node dissection.

For Key Questions 3 and 4, we included studies of radical cystectomy plus neoadjuvant and/or adjuvant chemotherapy versus radical cystectomy alone. We focused on chemotherapeutic regimens recommended in clinical practice guidelines11 and currently used in clinical practice: cisplatin and gemcitabine; cisplatin, methotrexate and vinblastine (CMV); methotrexate, vinblastine, doxorubicin and cisplatin (MVAC); and carboplatin and gemcitabine. However, we also included trials of other cisplatin-based combination regimens. We excluded trials that evaluated chemotherapy with a single agent.

For Key Questions 1, 3, and 4 we included randomized controlled trials (RCTs) and nonrandomized controlled clinical trials and nonrandomized cohort studies with concurrent comparators (referred to simply as “cohort studies” throughout this report) when RCTs were not available. We excluded uncontrolled observational studies, case-control studies, case series, and case reports, as these studies are less informative than studies with a control group. We restricted inclusion to studies published in or after 1990, given changes in surgical techniques and other medical practices over time.

### Outcomes of Interest

Clinical outcomes evaluated were mortality, recurrence of bladder cancer, progression or metastasis of bladder cancer, quality of life, and functional status. For harms (Key Question 4), we included studies reporting complications or adverse effects related to treatment with chemotherapy, radiation therapy and radical cystectomy, with or without regional lymph node dissection.

### Timing and Setting of Interest

For all Key Questions, we included studies conducted in inpatient or outpatient settings, with any duration of followup.

## Data Extraction and Data Management

We extracted the following information into evidence tables: study design, setting, inclusion and exclusion criteria, dose and duration of treatment for experimental and control groups, duration of followup, number of subjects screened, eligible and enrolled, population characteristics (including age, race/ethnicity, sex, stage of disease and functional status), results, adverse events, withdrawals due to adverse events, and sources of funding. When data were available, we calculated relative risks and associated 95% confidence intervals (CI) based on the sample sizes and incidence of outcomes in each intervention group. We noted discrepancies between calculated and reported results when present. Data extraction for each study was completed by one investigator and independently reviewed for accuracy and completeness by a second investigator. See Appendix E for evidence tables containing extracted data.

## Assessment of the Risk of Bias of Individual Studies

We assessed the risk of bias for RCTs and observational studies using criteria adapted from those developed by the U.S. Preventive Services Task Force.18 These criteria were applied in conjunction with the approach recommended in the AHRQ Methods Guide for medical interventions.17

Two investigators independently assessed the risk of bias of each study. Discrepancies were resolved through discussion and consensus.

Each study was rated as “low,” “medium,” or “high” risk of bias.17 We rated the quality of each RCT based on the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; whether attrition was adequately reported and acceptable; similarity in use of cointerventions; compliance to allocated treatments; the use of intent-to-treat analysis; and avoidance of selective outcomes reporting.18

We rated the quality of each cohort study based on whether it enrolled a consecutive or random sample of patients meeting inclusion criteria; whether it evaluated comparable groups; whether rates of loss to followup were reported and acceptable; whether it used accurate methods for ascertaining exposures, potential confounders, and outcomes; and whether it performed adjustment for important potential confounders (defined as a minimum of age, sex, tumor stage, and tumor grade).18

Studies rated “low risk of bias” were considered to have no more than very minor methodological shortcomings and their results are likely to be valid. Studies rated “medium risk of bias” have some methodological shortcomings, but no flaw or combination of flaws judged likely to cause major bias. In some cases, the article did not report important information, making it difficult to assess its methods or potential limitations. The medium risk of bias category is broad and studies with this rating vary in their strengths and weaknesses; the results of some studies assessed to have medium risk of bias are likely to be valid, while others may be only possibly valid. Studies rated “high risk of bias” have significant flaws that may invalidate the results. They have a serious or “fatal” flaw or combination of flaws in design, analysis, or reporting; large amounts of missing information (including publication of only preliminary results in a subgroup of patients randomized); or serious discrepancies in reporting. An example of a fatally flawed study would be one with very high loss to followup (e.g., >50%), failure to perform intention-to-treat analysis, lack of blinding and failure to adequately describe randomization procedures. The results of high risk of bias studies are at least as likely to reflect flaws in the study design as the differences between the compared interventions. We did not exclude studies rated as having high risk of bias a priori, but they were considered the least reliable when synthesizing the evidence, particularly when discrepancies between studies were present.

For further details about the assessment of the risk of bias see Appendix F.

## Assessing Applicability

We recorded factors important for understanding the applicability of studies, such as whether the publication adequately described the study sample, the country in which the study was conducted, the characteristics of the patient sample (e.g., age, sex, race/ethnicity, risk factors for bladder cancer, presenting symptoms, and medical comorbidities), tumor characteristics (e.g., stage and grade, primary or recurrent, unifocal or multifocal lesions), the characteristics of the diagnostic tests (e.g., specific test evaluated and cutoffs used) and interventions (e.g., treatment dose, duration and interval) used, and the magnitude of effects on clinical outcomes.17 We also recorded the funding source and role of the sponsor.

Applicability depends on the particular question and the needs of the user of the review. There is no generally accepted universal rating system for applicability. In addition, applicability depends in part on context. Therefore, a rating of applicability (such as “high” or “low”) was not assigned because applicability may differ based on the user of this report. The funding source was also recorded.

## Data Synthesis

We synthesized data qualitatively for the comparisons and outcomes addressed by each Key Question, based on the risk of bias, consistency, precision, and directness. We did not perform meta-analysis due to the small number of RCTs and the heterogeneity of the populations and interventions included.

## Grading the Strength of Evidence for Each Key Question

We assessed the strength of evidence for each Key Question and outcome using the approach described in the AHRQ Methods Guide,17 based on the overall quality of each body of evidence, based on the risk of bias (graded low, medium, or high); the consistency of results across studies (graded consistent, inconsistent, or unable to determine when only one study was available); the directness of the evidence linking the intervention and health outcomes (graded direct or indirect); the precision of the estimate of effect, based on the number and size of studies and confidence intervals for the estimates (graded precise or imprecise), and reporting bias (suspected of undetected)

Assessments of reporting bias were based on whether studies defined and reported primary outcomes, identification of relevant unpublished studies, and when available, by comparing published results to results reported in trial registries.

We graded the strength of evidence for each Key Question using the four key categories recommended in the AHRQ Methods Guide.17 A “high” grade indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect. A “moderate” grade indicates moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate. A “low” grade indicates low confidence that the evidence reflects the true effect and further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. An “insufficient” grade indicates evidence either is unavailable or is too limited to permit any conclusion, due to the availability of only poor-quality studies, extreme inconsistency, or extreme imprecision.

See Appendix G for the strength of evidence table.

## Peer Review and Public Commentary

Experts in urology, urologic surgery, urologic oncology, and medical and radiation oncology, were invited to provide peer review of the draft report. The AHRQ Task Order Officer and an Evidence-based Practice Center Associate Editor also provided comments and editorial review. The draft report was posted on the AHRQ Web site for 3 weeks to obtain public comment. A disposition of comments report with authors’ responses to the peer and public review comments will be posted after publication of the final CER on the public Web site.