# Technical Expert Panel

In designing the review questions and methodology at the outset of this report, the EPC consulted several technical and content experts, reflecting a variety of viewpoints relevant to this topic. Technical experts consulted are expected to have divergent and possibly conflicting opinions. This diversity is helpful in achieving a well-rounded report. The study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Karim Chamie, M.D.
  Ronald Reagan University of California, Los Angeles Medical Center
  Santa Monica, CA
- Sam S. Chang, M.D., FACS
  Vanderbilt-Ingram Cancer Center
  Nashville, TN
- Yair Lotan, M.D.
  University of Texas Southwestern Medical Center
  Dallas, TX
- Raj Pruthi, M.D., FACS
  University of North Carolina School of Medicine
  Chapel Hill, NC
- Howard Sandler, M.D., M.S., FASTRO
  Cedars-Sinai Medical Center
  Los Angeles, CA
- Seth Strope, M.D., M.P.H.
  Washington University School of Medicine
  St. Louis, MO
- Yu-Ning Wong, M.D., M.S.C.E.
  Fox Chase Cancer Center
  Philadelphia, PA