# Discussion

## Key Findings and Strength of Evidence

The key findings of this review are summarized in the summary of evidence table (Table 8) and the factors used to determine the overall strength of evidence grades are summarized in Appendix G.

Table 8 Summary of evidence

Key Question | Outcome | Strength-of-Evidence Grade | Conclusion
1. For patients with nonmetastatic muscle-invasive bladder cancer, what is the effectiveness of bladder-preserving treatments (chemotherapy, external beam or interstitial radiation therapy, partial cystectomy, and/or maximal transurethral resection of bladder tumor) for decreasing mortality or improving other outcomes (e.g., recurrence, metastasis, quality of life, functional status) compared with cystectomy alone or cystectomy in combination with chemotherapy? | Mortality | Insufficient | One RCT with high risk of bias found no difference between bladder-preserving external beam radiation therapy (60 Gray) vs. radical cystectomy plus radiation therapy (40 Gray) in median survival duration (18 vs. 20 months; p = 0.21).
| Local recurrence | Low | One RCT with high risk of bias found increased risk of local or regional recurrence (35.8% vs. 6.8%) for bladder-preserving external beam radiation therapy vs. radical cystectomy.
| Overall mortality, bladder–cancer-specific mortality | Insufficient | There was insufficient evidence from cohort studies and a nonrandomized controlled clinical trial to evaluate effects of bladder-preserving therapies vs. radical cystectomy on risk of overall or bladder-specific mortality (7 studies) because of methodological shortcomings in the studies, inconsistent results, and imprecise estimates.
| Recurrence | Insufficient | There was insufficient evidence from 3 cohort studies to evaluate effects of bladder-preserving therapies vs. radical cystectomy on risk of local or regional recurrence because of methodological shortcomings in the studies and inconsistent results.
| Quality of life | Insufficient | No study evaluated effects of bladder-sparing therapy vs. radical cystectomy on quality of life.
1a. Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers? | Effectiveness | Insufficient | No study evaluated how estimates of effectiveness of bladder-sparing therapy vs. radical cystectomy vary in subgroups defined by tumor characteristic, such as stage, grade, size, or molecular or genetic markers.
1b. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease? | Effectiveness | Insufficient | No study evaluated how estimates of effectiveness of bladder-sparing therapy vs. radical cystectomy vary in subgroups defined by patient characteristics, such as age, sex, race/ethnicity, performance status, or comorbidities (including chronic kidney disease).
1c. What is the comparative effectiveness of various combinations of agents and/or radiation therapy used for bladder-preserving chemotherapy? | Effectiveness | Insufficient | No study compared the effectiveness of different combinations of chemotherapeutic agents and/or radiation treatment.
1d. What is the effectiveness of different bladder-preserving treatments (chemotherapy, external beam or interstitial radiation therapy, partial cystectomy and/or maximal transurethral resection of bladder tumor) compared with one another? | Mortality | Low | One randomized trial found external beam radiation therapy with synchronous chemotherapy to be associated with trends toward decreased risk of overall (52% vs. 65%; HR, 0.82; 95% CI, 0.63 to 1.09) and bladder–cancer-specific mortality (42% vs. 51%; HR, 0.77; 95% CI, 0.57 to 1.05) vs. radiation therapy alone.
| Recurrence | Low | One randomized trial found external beam radiation therapy with synchronous chemotherapy to be associated with lower likelihood of 2-year locoregional recurrence (33% vs. 46%; HR, 0.68; 95% CI, 0.48 to 0.95) and 5-year metastasis (HR, 0.72; 95% CI, 0.53 to 0.99) vs. radiation therapy alone.
2. For patients with clinically nonmetastatic muscle-invasive bladder cancer that is treated with cystectomy, does regional lymph node dissection improve outcomes compared with cystectomy alone? | Mortality | Low | Three cohort studies found regional lymph node dissection to be associated with lower risk of mortality than no lymph dissection; 2 cohort studies examined the same population-based database, and 1 did not perform statistical adjustment for potential confounders.
2a. Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers? | Mortality | Low | One study found increased risk of 10-year cancer-specific mortality and overall mortality for all stages of bladder cancer for patients who underwent no lymph node dissection.
2b. Does the comparative effectiveness differ according to the extent of the regional lymph node dissection (e.g., as measured by the number of lymph nodes removed or the anatomic extent of dissection)? | Mortality | Low | Eleven cohort studies found more extensive lymph node dissection to be associated with improved all-cause or bladder–cancer-specific mortality vs. less extensive lymph node dissection, but studies had methodological limitations, there was variability in the lymph node dissection techniques evaluated, and there was some inconsistency in results.
| Recurrence, progression | Low | Six cohort studies found that more extensive lymph node dissection was associated with lower risk of bladder cancer recurrence or progression, but most studies had serious methodological limitations and there was some inconsistency in results.
3. For patients with nonmetastatic muscle-invasive bladder cancer that is treated with cystectomy, does neoadjuvant or adjuvant chemotherapy improve outcomes compared with cystectomy alone? | Neoadjuvant chemotherapy: mortality | Moderate | Six trials found NAC to be associated with decreased risk, or a trend toward decreased risk, of mortality vs. no NAC. Three trials evaluated standard chemotherapy regimens (CMV and MVAC), and 3 trials used cisplatin-based regimens not commonly used in clinical practice (cisplatin and doxorubicin or cisplatin and methotrexate).
3. For patients with nonmetastatic muscle-invasive bladder cancer that is treated with cystectomy, does neoadjuvant or adjuvant chemotherapy improve outcomes compared with cystectomy alone? | Neoadjuvant chemotherapy: likelihood of metastasis or death | Low | Three trials found NAC (CMV, MVAC, or cisplatin and methotrexate) to be associated with lower risk of disease progression; the largest trial and the only one to show a statistically significant effect found neoadjuvant CMV to be associated with lower likelihood of metastasis or death versus no NAC after 4 years (45% vs. 53%; HR, 0.79; 95% CI, 0.66 to 0.93).
3. For patients with nonmetastatic muscle-invasive bladder cancer that is treated with cystectomy, does neoadjuvant or adjuvant chemotherapy improve outcomes compared with cystectomy alone? | Neoadjuvant chemotherapy: recurrence | Moderate | Three trials found that NAC was not superior to no NAC in risk of locoregional bladder cancer recurrence.
3. For patients with nonmetastatic muscle-invasive bladder cancer that is treated with cystectomy, does neoadjuvant or adjuvant chemotherapy improve outcomes compared with cystectomy alone? | Adjuvant chemotherapy: mortality | Low | Four trials found AC to be associated with decreased risk of mortality vs. no AC, but no trial reported a statistically significant effect and there was some inconsistency in findings.
3. For patients with nonmetastatic muscle-invasive bladder cancer that is treated with cystectomy, does neoadjuvant or adjuvant chemotherapy improve outcomes compared with cystectomy alone? | Adjuvant chemotherapy: progression | Insufficient | One trial found that AC was not superior to no AC in risk of bladder cancer progression.
3. For patients with nonmetastatic muscle-invasive bladder cancer that is treated with cystectomy, does neoadjuvant or adjuvant chemotherapy improve outcomes compared with cystectomy alone? | Adjuvant chemotherapy: recurrence | Insufficient | There was insufficient evidence to determine effects of AC vs. no AC on risk of locoregional recurrence because of imprecise estimates and inconsistency between studies.
3a. What is the comparative effectiveness of various combinations of agents used for neoadjuvant or adjuvant chemotherapy? | Effectiveness | Insufficient | Evidence from 3 cohort studies of neoadjuvant or adjuvant MVAC vs. cisplatin and gemcitabine was too unreliable to evaluate comparative effectiveness because of serious methodological limitations.
3b. Does the comparative effectiveness of various combinations of agents used for neoadjuvant or adjuvant chemotherapy differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers? | Neoadjuvant chemotherapy: effectiveness | Low | Four trials found no clear differences in estimates of effectiveness of NAC vs. no NAC in subgroups based on tumor stage or grade.
| Adjuvant chemotherapy: effectiveness | Low | Two trials found no clear differences in estimates of effectiveness of AC vs. no AC in subgroups based on nodal status or tumor stage.
3c. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease? | Subgroup—patient age: effectiveness | Low | Five trials found no clear interaction between age and estimates of effectiveness of NAC vs. no NAC.
3c. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease? | Subgroups—sex, performance status, renal function: effectiveness | Low | One trial found no interaction between sex or performance status on effectiveness of NAC vs. no NAC, but found NAC to be more effective than no NAC in patients with better renal function.
3d. Does the comparative effectiveness of neoadjuvant or adjuvant chemotherapy differ according to dosing frequency and/or the timing of its administration relative to cystectomy? | Adjuvant vs. neoadjuvant MVAC: overall survival, bladder–cancer-specific survival | Low | One trial and 2 cohort studies found that neither adjuvant nor neoadjuvant MVAC was superior for overall or bladder–cancer-specific survival.
3d. Does the comparative effectiveness of neoadjuvant or adjuvant chemotherapy differ according to dosing frequency and/or the timing of its administration relative to cystectomy? | Adjuvant vs. neoadjuvant gemcitabine plus cisplatin: recurrence | Insufficient | There was insufficient evidence from 1 small cohort study with methodological shortcomings of adjuvant vs. neoadjuvant gemcitabine plus cisplatin to determine effects on bladder cancer recurrence.
3d. Does the comparative effectiveness of neoadjuvant or adjuvant chemotherapy differ according to dosing frequency and/or the timing of its administration relative to cystectomy? | Adjuvant cisplatin plus gemcitabine on day 2 vs. day 15: 5-year survival | Low | One trial found that neither administration of adjuvant cisplatin plus gemcitabine on day 2 nor day 15 was superior for 5-year survival.
4. What are the comparative adverse effects of treatments for nonmetastatic muscle-invasive bladder cancer? | Bladder-sparing therapies vs. radical cystectomy: adverse events | Insufficient | There was insufficient evidence from 4 studies of bladder-sparing therapies vs. radical cystectomy to determine comparative risk of harms because of poor reporting of harms data and methodological limitations in the studies.
4. What are the comparative adverse effects of treatments for nonmetastatic muscle-invasive bladder cancer? | Extended lymph node dissection vs. standard lymph node dissection: operative time | Insufficient | One cohort study found extended lymph node dissection to be associated with longer operative time than standard lymph node dissection (median, 330 vs. 277 minutes).
4. What are the comparative adverse effects of treatments for nonmetastatic muscle-invasive bladder cancer? | Neoadjuvant chemotherapy vs. no neoadjuvant chemotherapy: surgical complications, perioperative deaths | Low | In 3 trials, NAC was not associated with increased risk of surgical complications or perioperative deaths vs. no NAC.
4. What are the comparative adverse effects of treatments for nonmetastatic muscle-invasive bladder cancer? | Neoadjuvant chemotherapy: grade 3 or 4 hematological adverse events | Low | In 2 trials, NAC was associated with grade 3 or 4 hematological adverse events.
4. What are the comparative adverse effects of treatments for nonmetastatic muscle-invasive bladder cancer? | Adjuvant chemotherapy vs. no adjuvant chemotherapy: adverse events | Insufficient | Harms were poorly reported in 3 trials of AC vs. no AC.
4. What are the comparative adverse effects of treatments for nonmetastatic muscle-invasive bladder cancer? | Neoadjuvant vs. adjuvant MVAC: mortality related to chemotherapy toxicity | Low | One trial found no difference between neoadjuvant vs. adjuvant MVAC in risk of mortality related to chemotherapy toxicity.
4a. How do adverse effects of treatment vary by patient characteristics, such as age, sex, race/ethnicity, performance status, or medical comorbidities such as chronic kidney disease? | Effectiveness | Insufficient | No trial evaluated how estimates of harms associated with NAC or AC vary in subgroups defined by patient characteristics, such as age, sex, race/ethnicity, performance status, or comorbidities.

AC = adjuvant chemotherapy; CI=confidence interval; CMV = cisplatin, methotrexate, vinblastine; HR = hazard ratio; MVAC = methotrexate, vinblastine, doxorubicin, cisplatin; NAC = neoadjuvant chemotherapy; NLR = negative likelihood ratio; OR=odds ratio; PLR=positive likelihood ratio; SOE = strength of evidence

We found limited evidence with which to evaluate the effectiveness of bladder-preserving therapies for muscle-invasive bladder cancer versus radical cystectomy. The only randomized controlled trial (RCT) of bladder-preserving therapy versus radical cystectomy had important methodological limitations, used lower doses of radiation therapy than in current practice, did not use radiation therapy in combination with chemotherapy, and may have used outdated surgical techniques, as patients were treated in the early 1980’s.19 It found no difference between bladder preserving external beam radiation therapy (60 Gray) versus radical cystectomy plus radiation therapy (40 Gray) in median survival duration, though bladder-preserving treatment was associated with increased risk of local or regional recurrence (35.8% vs. 6.8%) (strength of evidence [SOE]: low). Cohort studies of bladder-preserving treatments versus radical cystectomy had methodological shortcomings and reported inconsistent results, precluding reliable conclusions (SOE: insufficient). Although a potential advantage of bladder-preserving therapy is on subsequent quality of life, no study evaluated quality of life. Harms were also poorly reported (SOE: insufficient). The most commonly-evaluated bladder-preserving therapy was radiation therapy, with or without systemic chemotherapy. Only one study evaluated bladder-preserving therapy with maximal transurethral resection of bladder tumor (TURBT).22 It reported high 5-year mortality rates that were similar for radiation therapy and maximal TURBT, and did not attempt to adjust for potential confounders. One RCT found external beam radiation therapy with synchronous chemotherapy associated with trends towards decreased risk of overall (52% vs. 65%, HR 0.82, 95% CI 0.63 to 1.09) and bladder cancer-specific mortality (42% vs. 51%, HR 0.77, 95% CI 0.57 to 1.05) versus radiation therapy alone, suggesting that if bladder-preserving treatment is used, combination therapies may be more effective than single modality therapy.28

Some evidence from cohort studies suggested that more extensive lymph node dissection with cystectomy might be more effective than less extensive lymph node dissection at improving survival and decreasing risk of recurrence (SOE: low). However, studies had methodological limitations (including failure to adequately adjust for confounders and comparisons of patients who underwent different lymph node dissection techniques in different countries36, 39), there was variability in the lymph node dissection techniques evaluated, and there was some inconsistency in results. In addition, although a standard lymph node dissection template was associated with decreased mortality compared with a limited lymph node dissection template, additional benefits of extended or super extended versus standard lymph node dissection templates was unclear. More extensive lymph node dissection was associated with longer operative times in one study (SOE: low),34 but other harms were poorly reported.

Evidence was somewhat stronger on the effects of neoadjuvant and adjuvant chemotherapy in patients with muscle-invasive bladder cancer. Six RCTs consistently found neoadjuvant chemotherapy (NAC) associated with decreased risk, or a trend towards decreased risk, of mortality versus no NAC (SOE: moderate). Three trials evaluated currently recommended chemotherapy regimens (cisplatin, methotrexate, and vinblastine [CMV] and methotrexate, vinblastine, doxorubicin, and cisplatin [MVAC])41, 42, 44 and three trials evaluated other cisplatin-based combination regimens (cisplatin with methotrexate or doxorubicin).46-48 There was limited evidence of similar estimates of effectiveness of NAC in subgroups based on tumor or patient characteristics. Compared with evidence on NAC, evidence on benefits of adjuvant chemotherapy (AC) was not as strong. Although four trials found AC associated with decreased risk of mortality versus no AC, no trial reported a statistically significant effect and there was some inconsistency in findings (SOE: low). Three cohort studies compared effects of neoadjuvant or adjuvant chemotherapy with MVAC versus cisplatin and gemcitabine, but had serious methodological limitations including failure to adjust for confounders or nonconcurrent comparisons, precluding reliable conclusions (SOE: insufficient).53-55 One trial and two cohort studies found neither neoadjuvant nor adjuvant MVAC superior for overall or bladder cancer-specific survival (SOE: low).55-57 Although NAC was not associated with an increased risk of complications related to cystectomy, chemotherapy was associated with an increased risk of hematological adverse events (SOE: low). Renal adverse events were not well-reported in the studies included in this review, despite known nephrotoxic effects of cisplatin.60 No study compared benefits or harms of cisplatin versus carboplatin-based chemotherapy regimens.

## Findings in Relationship to What Is Already Known

Our findings regarding bladder-preserving therapy are consistent with a recent review conducted to inform an International Consultation on Urological Diseases/European Association of Urology guideline on radical cystectomy and bladder-preserving therapy61 that concluded that open radical cystectomy remains the standard of treatment for muscle invasive bladder cancer. However, it also concluded that bladder-preserving therapy is a valid alternative to radical cystectomy in selected patients, based largely on cross-study comparisons of survival rates in series of patients who underwent radical cystectomy and bladder preservation using multiple modalities.

Our findings are also consistent with systematic reviews that found lymph node dissection associated with better outcomes than no lymph node dissection, and more extensive lymph node dissection associated with better outcomes than less extensive dissection. Like our review, prior reviews found serious methodological shortcomings in the evidence,62, 63 precluding strong conclusions.

Our findings are also consistent with prior systematic reviews that found platinum-based neoadjuvant chemotherapy associated with improved survival versus no neoadjuvant chemotherapy,64-66 despite some differences between the methods used to conduct the reviews. For example, prior reviews included studies of patient who received cisplatin monotherapy, which is not used in clinical practice, as well as non-cisplatin combination regimens, whereas we restricted our analysis to patients who received cisplatin combination regimens and carboplatin/gemcitabine. Prior reviews support our decision to exclude trials of cisplatin monotherapy, as benefits were not observed in this subgroup of trials.65 Other differences in the methods used by prior reviews include access to and analysis of individual patient data, unpublished data, and trials published only as abstracts.65 Our findings are also consistent with systematic reviews that found less definitive evidence that adjuvant chemotherapy is more effective than no adjuvant chemotherapy.66, 67 Although one review based on individual patient data found adjuvant chemotherapy associated with reduced risk of mortality (HR 0.75, 95% CI 0.60 to 0.96), it noted methodological issues that could have biased estimates, including early stopping of trials, nonreceipt of allocated treatments, and nonreceipt of salvage chemotherapy.67

## Applicability

Some issues could impact the applicability of our findings. The only RCT of bladder-sparing therapy was conducted in the early 1980’s and used doses of radiation therapy that are lower than employed in current practice.19 Surgical techniques may have also been outdated. Among the available cohort studies, few evaluated currently recommended tri-modality regimens (radiation therapy, cisplatin-based chemotherapy, and TURBT).68

Techniques for lymph node dissection varied, as did methods and definitions used to define the extent of regional lymph node dissection. Some studies were conducted in Europe, where techniques for lymph node dissection may vary from U.S. surgical practices.36, 39

For chemotherapy regimens, few trials evaluated currently recommended cisplatin-based chemotherapy regimens (MVAC, CMV, cisplatin, and gemcitabine). No trial evaluated adjuvant or neoadjuvant therapy with carboplatin versus cisplatin, which may be used in clinical practice in patients with baseline renal dysfunction.

We also identified issues that could limit applicability of our findings to specific populations of interest. Although bladder-preserving therapies are of potential relevance for older patients or patients with substantial comorbidities in whom the risk of radical cystectomy might be increased, there was insufficient evidence to determine the effectiveness of bladder-sparing therapy in these populations. For patients with renal dysfunction, carboplatin may be considered because it is less nephrotoxic than cisplatin, but there were insufficient data to evaluate the effectiveness of cisplatin- versus carboplatin-based regimens in patients with underlying renal dysfunction.

## Implications for Clinical and Policy Decisionmaking

Our review has implications for clinical and policy decisionmaking. We found no evidence that bladder-sparing therapies are more effective than radical cystectomy, and some studies suggesting that bladder-sparing therapies are less effective. Radical cystectomy is recommended as first line therapy for muscle invasive bladder cancer in European guidelines.11 Research indicates that radical cystectomy is not performed in a substantial proportion of patients with muscle-invasive bladder cancer, indicating discordance between practice guidelines and clinical practice.15

We also found evidence to support regional lymph node dissection with radical cystectomy and some evidence to support more extensive lymph node dissection. However, some evidence suggests that lymph node dissection is not always performed in patients undergoing radical cystectomy for muscle-invasive bladder cancer.31

Our review also supports recommendations for NAC in patients undergoing radical cystectomy using cisplatin-based combination regimens. Although we found limited evidence of no difference between NAC versus AC, evidence showing effectiveness of AC was more limited than for NAC.

## Limitations of the Review Process

Our review has some limitations. We were unable to perform meta-analysis, due to variability in the bladder-preserving therapies, lymph node dissection methods, and chemotherapy regimens evaluated, as well as in other factors, such as the patient populations evaluated. Therefore, we synthesized the evidence qualitatively. Although pooling may not have been suitable, a potential disadvantage of qualitative synthesis is the inability to detect potential effects of interventions in individual studies due to lack of statistical power. Because we did not perform meta-analysis, we were also unable to assess for publication bias using formal graphical or statistical methods. However, such methods are not recommended when the number of studies is small, as in our review, since they can be misleading.69, 70

We excluded non-English language articles and did not search for studies published only as abstracts. However, results of systematic reviews that were not restricted to English language and that included unpublished studies reported findings that were similar to our review.65, 67

We also did not have access to individual patient data, but findings of systematic reviews with access to such data reported findings similar to our review.65, 67

Our review did not address all potentially important questions related to management of muscle-invasive bladder cancer, such as the comparative effectiveness and harms of different surgical techniques (e.g., robotic versus open approach), effects of timing of radical cystectomy on clinical outcomes, comparative effectiveness and harms of different followup strategies, or effectiveness of treatment strategies in patients who are upstaged or have high-risk disease (e.g., node-positive or positive surgical margins) after surgery, though evidence for each of these areas appears to be sparse.

## Limitations of the Evidence Base

The evidence base had a number of important limitations that made it difficult to draw strong conclusions. For assessing the effects of bladder-sparing therapy versus radical cystectomy on clinical outcomes and the effects of extent of lymph node dissection, almost all of the evidence was restricted to observational studies. Furthermore, the observational studies had important limitations, including failure to adequately adjust for potential confounders. Some observational studies had serious methodological limitations because of how the comparison groups were selected. For example, two studies that compared effects of the extent of lymph node dissection on clinical outcomes evaluated patients who underwent more extensive lymph node dissection in one country with patients who underwent less extensive lymph node dissection in another country.36, 39

Although RCTs were available on the effects of neoadjuvant and adjuvant chemotherapy, all trials had methodological shortcomings. In addition, variability in the chemotherapy regimens evaluated—with few trials evaluating regimens recommended in current guidelines—complicates interpretation of findings. For example, estimates of harms were primarily based on older trials that did not use the antiemetics and growth factors that are often utilized in current practice.

Other limitations of the evidence base included poor or suboptimal reporting of harms, little evidence with which to determine how patient and tumor characteristics impact estimates of effectiveness, and limited evidence directly comparing the effectiveness of different bladder-sparing treatments and chemotherapy regimens.

## Research Gaps

Additional research is needed to more reliably address all of the Key Questions evaluated in this review. Well-conducted studies that compare effects of bladder-sparing therapies versus radical cystectomy in well-defined patient groups would help to clarify situations in which bladder-sparing therapy is an acceptable alternative. Addressing previous limitations of observational studies, such as failure to adequately measure and adjust for potential confounders or to analyze clearly defined inception cohorts of patients with clinically nonmetastatic disease (i.e., not exclude patients who undergo radical cystectomy and undergo pathological upstaging), would help to make them more informative. Research is also needed to understand the role of maximal TURBT as a potential option for bladder-preserving therapy. Research on bladder-preserving therapies should also address effects on quality of life71 and harms, which have been poorly studied to date.

Randomized controlled trials that evaluate more versus less extensive regional lymph node dissection using standardized definitions and techniques are needed (e.g., based on the lymph node dissection template rather than the node yield, which can be highly variable using similar methods)72 and should also more fully address comparative harms. Trials that compare currently recommended cisplatin-based and carboplatin-based chemotherapy regimens would be helpful for clarifying their relative effectiveness, particularly for patients with renal dysfunction in whom cisplatin might be associated with higher risk. Trials are also needed to evaluate the effectiveness and harms of newer, dose-dense chemotherapy regimens (to date only evaluated in noncomparative studies73, 74) versus traditional dose chemotherapy regimens; one ongoing trial is designed to determine which patients are more likely to benefit from dose-dense regimens.75 A number of ongoing trials are evaluating noncisplatin-based chemotherapy regimens66 and trials of extended versus standard lymph node dissection are also in progress or have recently been completed.76, 77

## Conclusions

Neoadjuvant chemotherapy with cisplatin-based regimens improves survival in patients with muscle-invasive bladder cancer, and extended lymph node dissection during cystectomy might be more effective than standard lymph node dissection for improving survival. More research is needed to clarify the effectiveness of bladder-sparing therapies versus radical cystectomy and define patient subgroups in which such therapies are a potential option.