# Strength of Evidence

Table G1 Strength of evidence

Key Question Outcome | Study Design Number of Studies (N) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade
1. For patients with non-metastatic muscle-invasive bladder cancer, what is the effectiveness of bladder- preserving treatments (chemotherapy, external beam or interstitial radiation therapy, partial cystectomy, and/or maximal transurethral resection of bladder tumor) for decreasing mortality or improving other outcomes (e.g., recurrence, metastasis, quality of life, functional status) compared with cystectomy alone or cystectomy in combination with chemotherapy?
Bladder preserving external beam radiation therapy (60 Gray) versus radical cystectomy plus radiation therapy (40 Gray): Median survival duration, local recurrence, regional recurrence | 1 RCT10 | High | Cannot determine | Direct | Imprecise | Undetected | Insufficient
Bladder-preserving therapies versus radical cystectomy: Overall survival, bladder-specific mortality | 7 cohort studies2, 3, 4, 6, 7, 8, 9 | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Bladder-preserving therapies versus radical cystectomy: Local recurrence, regional recurrence | 3 cohort studies6, 7, 10 | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Bladder-sparing therapy versus radical cystectomy: Quality of life | No studies | - | - | - | - | | Insufficient
1a. Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers?
Bladder-sparing therapy versus radical cystectomy: Effectiveness | No studies | - | - | - | - | - | Insufficient
1b. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, ethnicity, performance status, or medical comorbidities such as chronic kidney disease?
Bladder-sparing therapy versus radical cystectomy: Effectiveness | No studies | - | - | - | - | - | Insufficient
1c. What is the comparative effectiveness of various combinations of agents and/or radiation therapy used for bladder-preserving chemotherapy?
Different combinations of chemotherapeutic agents and/or radiation treatment: Effectiveness | No studies | - | - | - | - | - | Insufficient
1d. What is the effectiveness of different bladder- preserving treatments (chemotherapy, external beam or interstitial radiation therapy, partial cystectomy and/or maximal transurethral resection of bladder tumor) compared with one another?
One type of bladder-preserving treatment versus another: Mortality and recurrence | 1 RCT5 | High | Cannot determine | Direct | Imprecise | Undetected | Low
2. For patients with clinically non-metastatic muscle- invasive bladder cancer that is treated with cystectomy, does regional lymph node dissection improve outcomes compared with cystectomy alone?
Regional lymph node dissection: Mortality | 3 cohort studies12,16, 18 | Moderate | Consistent | Direct | Precise | Undetected | Low
2a. Does the comparative effectiveness differ according to tumor characteristics, such as histology, stage, grade, size, or molecular/genetic markers?
Radical cystectomy with versus without regional lymph node dissection: Mortality | 1 cohort study12 | Moderate | Cannot determine | Direct | Precise | Undetected | Low
2b. Does the comparative effectiveness differ according to the extent of the regional lymph node dissection (e.g., as measured by the number of lymph nodes removed or the anatomic extent of dissection)?
More extensive lymph node dissection versus less extensive or standard lymph node dissection: All-cause mortality, bladder cancer-specific mortality | 11 cohort studies 12,14,15,16,17,18,19,20, 21,22,23 | Moderate | Inconsistent | Direct | Precise | Undetected | Low
Extent of lymph node dissection: Bladder cancer recurrence or progression | 6 cohort studies15,16,17,19,20,23 | Moderate | Inconsistent | Direct | Imprecise | Undetected | Low
3. For patients with non-metastatic muscle-invasive bladder cancer that is treated with cystectomy, does neoadjuvant or adjuvant chemotherapy improve outcomes compared with cystectomy alone?
Neoadjuvant chemotherapy vs. no neoadjuvant chemotherapy: Mortality | 6 RCTs1,31,37,29,32,33,38 | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Neoadjuvant CMV vs. no neoadjuvant chemotherapy: Likelihood of metastasis, likelihood of death | 3 RCTs1,31,37 | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Neoadjuvant chemotherapy vs. no neoadjuvant chemotherapy: Locoregional bladder cancer recurrence | 3 RCTs1,30,32,38 | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Adjuvant chemotherapy vs. no adjuvant chemotherapy: Mortality | 4 RCTs24,25,28,39 | Moderate | Inconsistent | Direct | Precise | Undetected | Low
Adjuvant chemotherapy vs. no adjuvant chemotherapy: Bladder cancer progression | 1 RCT24 | Moderate | Cannot determine | Direct | Imprecise | Undetected | Insufficient
Adjuvant chemotherapy vs. no adjuvant chemotherapy: Locoregional recurrence | 3 RCTs25,28,39 | Moderate | Consistent | Direct | Imprecise | Undetected | Insufficient
3a. What is the comparative effectiveness of various combinations of agents used for neoadjuvant or adjuvant chemotherapy?
Adjuvant MVAC versus cisplatin and gemcitabine: Comparative effectiveness | 3 cohort studies27,36,41 | High | Consistent | Direct | Imprecise | Undetected | Insufficient
3b. Does the comparative effectiveness of various combinations of agents used for neoadjuvant or adjuvant chemotherapy differ according to tumor characteristics, such as histology, stage, grade, size,
Neoadjuvant chemotherapy vs. no neoadjuvant chemotherapy: Effectiveness | 4 RCTs30,31,32,38 | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Adjuvant chemotherapy vs. no adjuvant chemotherapy: Effectiveness | 2 RCTs25,28 | Moderate | Consistent | Direct | Imprecise | Undetected | Low
3c. Does the comparative effectiveness differ according to patient characteristics, such as age, sex, ethnicity, performance status, or medical comorbidities such as chronic kidney disease?
Neoadjuvant chemotherapy vs. no neoadjuvant chemotherapy in subgroups based on patient age: Effectiveness | 5 RCTs1,31,37,29,32 | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Neoadjuvant chemotherapy vs. no neoadjuvant chemotherapy in subgroups of sex, performance status, renal function: Effectiveness | 1 RCT1 | Moderate | Cannot determine | Direct | Imprecise | Undetected | Low
3d. Does the comparative effectiveness of neoadjuvant or adjuvant chemotherapy differ according to dosing frequency and/or the timing of its administration relative to cystectomy?
Adjuvant vs. neoadjuvant MVAC: Overall survival, bladder-cancer specific survival | 1 RCT35 2 cohort studies40,41 | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Adjuvant vs. neoadjuvant gemcitabine plus cisplatin: Recurrence | 1 cohort study34 | High | Cannot determine | Direct | Imprecise | Undetected | Insufficient
Adjuvant cisplatin plus gemcitabine on day 2 vs. day 15: 5-year survival | 1 RCT25 | Moderate | Cannot determine | Direct | Imprecise | Undetected | Low
4. What are the comparative adverse effects of treatments for non-metastatic muscle-invasive bladder cancer?
Bladder-sparing therapies versus radical cystectomy: Adverse events | 4 cohort studies4, 6,10,11 | High | Cannot determine (harms reported inconsistently) | Direct | Imprecise | Undetected | Insufficient
Extended lymph node dissection vs. standard lymph node dissection: Operative time | 1 cohort study13 | High | Cannot determine | Direct | Imprecise | Undetected | Insufficient
Neoadjuvant chemotherapy vs. no neoadjuvant chemotherapy: Surgical complications, perioperative deaths | 3 RCTs1,29,32 | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Neoadjuvant chemotherapy: Grade 3 or 4 hematological adverse events | 2 RCTs1,29 | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Adjuvant chemotherapy vs. no adjuvant chemotherapy: Adverse events | 3 RCTs24,28,39 | High | Consistent | Direct | Imprecise | Undetected | Insufficient
Neoadjuvant vs. adjuvant MVAC: Mortality related to chemotherapy toxicity | 1 RCT35 | Moderate | Cannot determine | Direct | Imprecise | Undetected | Low
4a. How do adverse effects of treatment vary by patient characteristics, such as age, sex, ethnicity, performance status, or medical comorbidities such as chronic kidney disease?
Adverse effects | No studies | - | - | - | - | - | Insufficient

CMV = cisplatin, methotrexate, vinblastine; MVAC, Methotrexate, Vinblastine, Doxorubicin, Cisplatin; RCT = randomized controlled trial.

## References for Appendix G

1 International Collaboration of Trialists. Neoadjuvant cisplatin, methotrexate, and vinblastine chemotherapy for muscle-invasive bladder cancer: a randomised controlled trial. International collaboration of trialists. [Erratum appears in Lancet 1999 Nov 6;354(9190):1650]. Lancet. Aug. 14. 1999;354(9178):533-40. [pmid: 10470696].
2 Bekelman JE, Handorf EA, Guzzo T, et al. Radical cystectomy versus bladder-preserving therapy for muscle-invasive urothelial carcinoma: examining confounding and misclassification biasin cancer observational comparative effectiveness research. Value in Health. Jun. 2013;16(4):610-8. [pmid: 23796296].
3 Goossens-Laan CA, Leliveld AM, Verhoeven RHA, et al. Effects of age and comorbidity on treatment and survival of patients with muscle-invasive bladder cancer. International Journal of Cancer. Aug. 15. 2014;135(4):905-12. [pmid: 24420527].
4 Holmang S, Hedelin H, Anderstrom C, et al. Long-term followup of all patients with muscle invasive (stages T2, T3 and T4) bladder carcinoma in a geographical region. Journal of Urology. Aug. 1997;158(2):389-92. [pmid: 9224309].
5 James ND, Hussain SA, Hall E, et al. Radiotherapy with or without chemotherapy in muscle-invasive bladder cancer. New England Journal of Medicine. Apr. 19. 2012;366(16):1477-88. [pmid: 22512481].
6 Kalogeras D, Lampri E, Goussia A, et al. Radical therapy for muscle-infiltrating bladder cancer (cystectomy or radiotherapy): does age affect the final therapeutic benefit for the patient?. Journal of B.U.ON. Jul-Sep. 2008;13(3):353-8. [pmid: 18979549].
7 Kotwal S, Choudhury A, Johnston C, et al. Similar treatment outcomes for radical cystectomy and radical radiotherapy in invasive bladder cancer treated at a United Kingdom specialist treatment center. International Journal of Radiation Oncology, Biology, Physics. Feb. 1. 2008;70(2):456-63. [pmid: 17904301].
8 Nieuwenhuijzen JA, Pos F, Moonen LMF, et al. Survival after bladder-preservation with brachytherapy versus radical cystectomy; a single institution experience. European Urology. Aug. 2005;48(2):239-45. [pmid: 16005375].
9 Rincon Mayans A, Rosell Costa D, Zudaire Bergera JJ, et al. Response and progression-free survival in T2 to T4 bladder tumors treated with trimodality therapy with bladder preservation. Actas Urologicas Espanolas. Oct. 2010;34(9):775-80. [pmid: 20843454].
10 Sell A, Jakobsen A, Nerstrom B, et al. Treatment of advanced bladder cancer category T2 T3 and T4a. A randomized multicenter study of preoperative irradiation and cystectomy versus radical irradiation and early salvage cystectomy for residual tumor. DAVECA protocol 8201. Danish Vesical Cancer Group. Scandinavian Journal of Urology & Nephrology Supplementum. 1991;138:193-201. [pmid: 1785004].
11 Solsona E, Climent MA, Iborra I, et al. Bladder preservation in selected patients with muscle-invasive bladder cancer by complete transurethral resection of the bladder plus systemic chemotherapy: long-term follow-up of a phase 2 nonrandomized comparative trial with radical cystectomy. European Urology. Apr. 2009;55(4):911-9. [pmid: 18722046].
12 Abdollah F, Sun M, Schmitges J, et al. Stage-specific impact of pelvic lymph node dissection on survival in patients with non-metastatic bladder cancer treated with radical cystectomy. BJU International. Apr. 2012;109(8):1147-54. [pmid: 21883849].
13 Brossner C, Pycha A, Toth A, et al. Does extended lymphadenectomy increase the morbidity of radical cystectomy?. BJU International. Jan. 2004;93(1):64-6. [pmid: 14678370].
14 Brunocilla E, Pernetti R, Schiavina R, et al. The number of nodes removed as well as the template of the dissection is independently correlated to cancer-specific survival after radical cystectomy for muscle-invasive bladder cancer. International Urology & Nephrology. Jun. 2013;45(3):711-9. [pmid: 23666588].
15 Dhar NB, Klein EA, Reuther AM, et al. Outcome after radical cystectomy with limited or extended pelvic lymph node dissection. Journal of Urology. Mar. 2008;179(3):873-8. discussion 8. [pmid: 18221953].
16 Herr HW, Bochner BH, Dalbagni G, et al. Impact of the number of lymph nodes retrieved on outcome in patients with muscle invasive bladder cancer. Journal of Urology. Mar. 2002;167(3):1295-8. [pmid: 11832716].
17 Herr HW, Faulkner JR, Grossman HB, et al. Surgical factors influence bladder cancer outcomes: a cooperative group report. Journal of Clinical Oncology. Jul. 15. 2004;22(14):2781-9. [pmid: 15199091].
18 Konety BR, Joslyn SA, O'Donnell MA. Extent of pelvic lymphadenectomy and its impact on outcome in patients diagnosed with bladder cancer: analysis of data from the Surveillance, Epidemiology and End Results Program data base. Journal of Urology. Mar. 2003;169(3):946-50. [pmid: 12576819].
19 Leissner J, Hohenfellner R, Thuroff JW, et al. Lymphadenectomy in patients with transitional cell carcinoma of the urinary bladder; significance for staging and prognosis. BJU International. May. 2000;85(7):817-23. [pmid: 10792159].
20 Poulsen AL, Horn T, Steven K. Radical cystectomy: extending the limits of pelvic lymph node dissection improves survival for patients with bladder cancer confined to the bladder wall. Journal of Urology. Dec. 1998;160(6 Pt 1):2015-9. discussion 20. [pmid: 9817313].
21 Shirotake S, Kikuchi E, Matsumoto K, et al. Role of pelvic lymph node dissection in lymph node-negative patients with invasive bladder cancer. Japanese Journal of Clinical Oncology. Mar. 2010;40(3):247-51. [pmid: 19887521].
22 Simone G, Papalia R, Ferriero M, et al. Stage-specific impact of extended versus standard pelvic lymph node dissection in radical cystectomy. International Journal of Urology. Apr. 2013;20(4):390-7. [pmid: 22970939].
23 Zehnder P, Studer UE, Skinner EC, et al. Super extended versus extended pelvic lymph node dissection in patients undergoing radical cystectomy for bladder cancer: a comparative study. Journal of Urology. Oct. 2011;186(4):1261-8. [pmid: 21849183].
24 Bono AV, Benvenuti C, Gibba A, et al. Adjuvant chemotherapy in locally advanced bladder cancer. Final analysis of a controlled multicentre study. Acta Urologica Italica. 1997;11(1):5-8. PMID: No PMID.
25 Cognetti F, Ruggeri EM, Felici A, et al. Adjuvant chemotherapy with cisplatin and gemcitabine versus chemotherapy at relapse in patients with muscle-invasive bladder cancer submitted to radical cystectomy: an Italian, multicenter, randomized phase III trial. Annals of Oncology. Mar. 2012;23(3):695-700. [pmid: 21859900].
26 Dash A, Pettus JAt, Herr HW, et al. A role for neoadjuvant gemcitabine plus cisplatin in muscle-invasive urothelial carcinoma of the bladder: a retrospective experience. Cancer. Nov. 1. 2008;113(9):2471-7. [pmid: 18823036].
27 Fairey AS, Daneshmand S, Quinn D, et al. Neoadjuvant chemotherapy with gemcitabine/cisplatin vs. methotrexate/vinblastine/doxorubicin/cisplatin for muscle-invasive urothelial carcinoma of the bladder: a retrospective analysis from the University of Southern California. Urol Oncol. Nov. 2013;31(8):1737-43. [pmid: 23141776].
28 Freiha F, Reese J, Torti FM. A randomized trial of radical cystectomy versus radical cystectomy plus cisplatin, vinblastine and methotrexate chemotherapy for muscle invasive bladder cancer. Journal of Urology. Feb. 1996;155(2):495-9. discussion 9-500. [pmid: 8558644].
29 Grossman HB, Natale RB, Tangen CM, et al. Neoadjuvant chemotherapy plus cystectomy compared with cystectomy alone for locally advanced bladder cancer. [Erratum appears in N Engl J Med. 2003 Nov 6;349(19):1880]. New England Journal of Medicine. Aug. 28. 2003;349(9):859-66. [pmid: 12944571].
30 International Collaboration of Trialists, Medical Research Council Advanced Bladder Cancer Working P, European Organisation for R, et al. International phase III trial assessing neoadjuvant cisplatin, methotrexate, and vinblastine chemotherapy for muscle-invasive bladder cancer: long-term results of the BA06 30894 trial. Journal of Clinical Oncology. Jun. 1. 2011;29(16):2171-7. [pmid: 21502557].
31 Kitamura H, Tsukamoto T, Shibata T, et al. Randomised phase III study of neoadjuvant chemotherapy with methotrexate, doxorubicin, vinblastine and cisplatin followed by radical cystectomy compared with radical cystectomy alone for muscle-invasive bladder cancer: Japan Clinical Oncology Group Study JCOG0209. Annals of Oncology. Jun. 2014;25(6):1192-8. [pmid: 24669010].
32 Malmstrom PU, Rintala E, Wahlqvist R, et al. Five-year followup of a prospective trial of radical cystectomy and neoadjuvant chemotherapy: Nordic Cystectomy Trial I. The Nordic Cooperative Bladder Cancer Study Group. Journal of Urology. Jun. 1996;155(6):1903-6. [pmid: 8618283].
33 Rintala E, Hannisdahl E, Fossa SD, et al. Neoadjuvant chemotherapy in bladder cancer: a randomized study. Nordic Cystectomy Trial I. Scandinavian Journal of Urology & Nephrology. 1993;27(3):355-62. [pmid: 8290916].
34 Matsubara N, Mukai H, Naito Y, et al. Comparison between neoadjuvant and adjuvant gemcitabine plus cisplatin chemotherapy for muscle-invasive bladder cancer. Asia-Pacific Journal of Clinical Oncology. Dec. 2013;9(4):310-7. [pmid: 23127231].
35 Millikan R, Dinney C, Swanson D, et al. Integrated therapy for locally advanced bladder cancer: final report of a randomized trial of cystectomy plus adjuvant M-VAC versus cystectomy with both preoperative and postoperative M-VAC. Journal of Clinical Oncology. Oct. 15. 2001;19(20):4005-13. [pmid: 11600601].
36 Pal SK, Ruel NH, Wilson TG, et al. Retrospective analysis of clinical outcomes with neoadjuvant cisplatin-based regimens for muscle-invasive bladder cancer. Clinical Genitourinary Cancer. Dec. 2012;10(4):246-50. [pmid: 22981208].
37 Sengelov L, von der Maase H, Lundbeck F, et al. Neoadjuvant chemotherapy with cisplatin and methotrexate in patients with muscle-invasive bladder tumours. Acta Oncologica. 2002;41(5):447-56. [pmid: 12442921].
38 Sherif A, Rintala E, Mestad O, et al. Neoadjuvant cisplatin-methotrexate chemotherapy for invasive bladder cancer -- Nordic cystectomy trial 2. Scandinavian Journal of Urology & Nephrology. 2002;36(6):419-25. [pmid: 12623505].
39 Skinner DG, Daniels JR, Russell CA, et al. The role of adjuvant chemotherapy following cystectomy for invasive bladder cancer: a prospective comparative trial. Journal of Urology. Mar. 1991;145(3):459-64. discussion 64-7. [pmid: 1997689].
40 Wosnitzer MS, Hruby GW, Murphy AM, et al. A comparison of the outcomes of neoadjuvant and adjuvant chemotherapy for clinical T2-T4aN0-N2M0 bladder cancer. Cancer. Jan. 15. 2012;118(2):358-64. [pmid: 21717438].
41 Yeshchina O, Badalato GM, Wosnitzer MS, et al. Relative efficacy of perioperative gemcitabine and cisplatin versus methotrexate, vinblastine, adriamycin, and cisplatin in the management of locally advanced urothelial carcinoma of the bladder. Urology. Feb. 2012;79(2):384-90. [pmid: 22196406].