# Risk of Bias Ratings

Table F1 Key Question 1: Randomized controlled trials risk of bias

Author, Year | Randomization Adequate? | Allocation Concealment adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked? | Patient Masked? | Attrition Reported? | Overall Loss to Followup <20%? Differential Attrition <10%? | Intention-to-Treat Analysis? | Postrandomization Exclusions | Outcomes Prespecified? | Risk of Bias | Comments
James, 2012^5^ | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | Yes | Yes | Yes (4 patients randomized to chemotherapy) | Yes | Medium
Sell, 1991^10^ | Yes | No | No | Yes | No | No | No | Yes | Unclear | Yes | Yes (11 patients in EBRT switched to cystoscopy) | Yes | High | Antiquated treatment regimens not used in contemporary practice

EBRT = external beam radiation therapy

Table F2 Key Question 1: Cohort studies risk of bias

Author, Year | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria? | Were the groups comparable at baseline on key prognostic factors (age, sex, race, smoking status-if available, bladder cancer stage; e.g., by restriction or matching)? | Did the study maintain comparable groups through the study period? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the article report attrition? | Did the study perform appropriate statistical analyses on potential confounders? | Overall loss to followup <20%? Differential attrition <10%? | Were outcomes prespecified and defined, and ascertained using accurate methods? | Risk of Bias
Bekelman, 2013^2^ | Yes | No (but similar in propensity adjusted analysis) | Unclear | Yes | Unclear | Yes (censoring) | Yes | Unclear | Yes | Medium
Goosens-Laan,2014^3^ | Yes | No | No | Yes | Unclear | No | Yes | No | Yes | High
Holmang, 1997^4^ | Yes | Unclear | Unclear | Yes | Unclear | No | No | Unclear | Yes | High
Kalogeras, 2008^6^ | Unclear | No | Unclear | Unclear | Unclear | Yes (censoring) | No | Unclear | Yes | High
Kotwal, 2008^7^ | Unclear | No | Unclear | No | NR | Yes (censoring) | Unclear (reported in text) | Yes, Yes | Yes | High
Nieuwenhuijzen,2005^8^ | Unclear | No | Unclear | Unclear | Unclear | Yes (censoring) | Yes | Unclear | Yes | Medium
Rincon Mayans,2010^9^ | Unclear | Unclear | Unclear | Unclear | Unclear | No | No | Unclear | Yes | High
Solsona, 2009^11^ | Unclear | Yes | Unclear | Yes | Unclear | Yes | No | Unclear | Yes | High

Table F3 Key Question 2: Cohort studies risk of bias

Author, Year | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria? | Were the groups comparable at baseline on key prognostic factors (age, sex, race, smoking status-if available, bladder cancer stage; e.g., by restriction or matching)? | Did the study maintain comparable groups through the study period? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the article report attrition? | Did the study perform appropriate statistical analyses on potential confounders? | Overall loss to followup <20%? Differential attrition <10%? | Were outcomes prespecified and defined, and ascertained using accurate methods? | Risk of Bias
Abdollah, 2012^12^ | Yes | No, differed on age, sex, tumor stage, tumor grade and year of surgery | Unclear | Yes | Unclear | No | Yes | Unclear | Yes | Medium
Brossner, 2004^13^ | Yes | Yes | Unclear | Unclear | Unclear | No | No | Unclear | Unclear | High
Brunocilla, 2013^14^ | Yes | No, differed on age | Unclear | Yes | Unclear | No | No | Unclear | Yes | Medium
Dhar, 2008^15^ | Unclear | Unclear | Unclear | Unclear | Unclear | No | No | Unclear | Yes | High
Herr, 2002^16^ | No, single group | NA | NA | No | Unclear | Yes | No | Yes, Yes | Yes | High
Herr, 2004^17^ | Yes, derived from SWOG RCT | Unclear | Unclear | Yes | Unclear | NA | Yes | Yes, Yes | Yes | Medium
Konety, 2003^18^ | Yes | Unclear | Unclear | Yes | Unclear | No | Yes | Unclear | Yes | Medium
Leissner, 2000^19^ | No, single group | NA | NA | Yes | Unclear | Yes | Yes | Yes, Yes | Yes | High
Poulsen, 1998^20^ | Yes | Unclear | Unclear | Yes | Unclear | No | No | Unclear | Unclear | High
Shirotake, 2010^21^ | Yes | Unclear | Unclear | Yes | Unclear | No | Yes | Unclear | Yes | Medium
Simone, 2013^22^ | Unclear | Yes | Unclear | Unclear | Unclear | No | Yes | Unclear | Yes | Medium
Zehnder, 2011^23^ | Yes | Yes | Unclear | Unclear | Unclear | No | No | Unclear | Yes | High

NA = not applicable, RCT = randomized controlled trial

Table F4 Key Question 3: Randomized controlled trials risk of bias

Author, Year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? (age, sex, race, smoking status-if available, bladder cancer stage) | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked? | Patient Masked? | Attrition Reported? | Overall Loss to Followup <20%? Differential Attrition <10%? | Intention-to- Treat Analysis? | Postrandomization Exclusions? | Outcomes Prespecified? | Risk of Bias
Bono, 1997^24^ | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | Yes Unclear | Unclear | Unclear | Yes | Medium
Cognetti,2012^25^ | Yes | Yes | Yes | Yes | Unclear | No | No | Yes | Yes Yes | Yes | Yes, 5.6% lost and not | Yes | Medium
Freiha,1996^28^ | Unclear | No | Age: No (59 vs. 64) Sex: Yes smoking status: Unclear Bladder cancer stage: No | Yes | Unclear | No | No | No | Unclear | Unclear | Yes total (5/55 = 9%) | Yes | Medium
Grossman,2003^29^ | Yes | Yes | Age: Yes Sex: Yes Smoking status: Unclear Bladder cancer stage: Yes | Yes | Unclear | No | No | No | Unclear Unclear | Yes | No (total 10/317, 5 vs.5) | Yes | Medium
International Collaboration of Trialists,1999^1^ | Unclear | Yes | Age: Yes Sex: Yes Smoking status: Unclear Bladder cancer stage: Yes | Yes | Unclear | No | No | No | Overall: Yes (6/976 total lost to follow) Differential: Yes (4 vs. 2) | Yes | Unclear | Yes | Medium
International Collaboration of Trialists,2011^30^ | Unclear. "minimization method for randomly assigning patients was used". Patients stratified by institution, choice of definitive treatment and tumor stage.Each institution selected its preferred definitive local treatment option (cystectomy vs. radiation therapy) | Yes | Unclear | Yes | Unclear | No | No | No Refusal to continue CMV therapy noted at 14/491 but no reports of study withdrawal for either group | Overall: Yes (6/976 total lost to follow) Differential: Unclear | Unclear | Unclear | Yes | Medium
Kitamura,2014^31^ | Yes (minimization method) | Yes | Age: Yes Sex: Yes Smoking status: Unclear Bladder cancer stage: Yes | Yes | Unclear | No | No | Yes | Overall: Yes Differential: Yes | Yes | Yes (6/130) | Yes | Medium
Malmstrom,1996^32^Rintala,1993^33^ | Unclear | No | Age: Yes Sex: Yes Smoking status: Unclear Bladder cancer stage: No (T1G3 27 vs. 31, T2 52 vs. 64, T3 69 vs. 55, T4 3 vs. 10) | Yes | Unclear | No | No | Yes | Overall: Yes (total 2/311) Differential: unclear | Yes | No (total 14/325) | Yes | Medium
Millikan,2001^35^ | Unclear | No | Yes | Yes | Unclear | No | No | No | Overall: Unclear Differential: Unclear | Unclear | Unclear | Yes | Medium
Sengelov, 2002^37^ | Yes | No | Unclear | Yes | Unclear | Unclear | Unclear | No | Unclear Unclear | Yes | Unclear | Yes | Medium
Sherif,2002^38^ | Unclear | No | Age: Yes Sex: No (male 116 (75%) vs.133 (86%)) smoking status: Unclear Bladder cancer stage: Yes | Yes | Unclear | No | No | No | Unclea Unclear | Yes, for survival No, for tumor downstaging | No (total 8/317) | Yes | Medium
Skinner,1991^39^ | Yes | Unclear | Age: Yes Sex: Yes Smoking status: Unclear Bladder cancer stage: Yes | Yes | Unclear | No | No | No | Unclear Unclear | Unclear | Unclear | Yes | Medium

CMV, cisplatin, methotrexate, vinblastine; G3, Grade 3; T1, Tumor stage 1; T2, Tumor stage 2; T3, Tumor stage 3; T4, Tumor stage 4.

Table F5 Key Question 3: Cohort studies risk of bias

Author, Year | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria, or a random sample (inception cohort)? | Were the groups comparable at baseline on key prognostic factors (age, sex, race, smoking status-if available, bladder cancer stage; e.g., by restriction or matching)? | Did the study maintain comparable groups through the study period? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the article report attrition? | Did the study perform appropriate statistical analyses on potential confounders? | Overall loss to followup <20%? Differential attrition <10%? | Were outcomes prespecified and defined, and ascertained using accurate methods? | Risk of Bias
Dash, 2008^26^ | Yes | Yes | Unclear | Unclear | Unclear | No | No | Unclear | Yes | High
Fairey, 2013^27^ | Yes | No. | Yes | Yes | Unclear | No | Yes | Unclear | Yes | High
Matsubara, 2013^34^ | Yes | No | Yes | Unclear | Unclear | No | No | Unclear | Yes | High
Pal, 2012^36^ | Unclear | Yes | Unclear | Yes | Unclear | No | Unclear | Unclear | Yes | High
Wosnitzer, 2012^40^ | Yes | No | Unclear | Yes | Unclear | No | Yes | Unclear | Yes | Medium
Yeshchina, 2012^41^ | Yes | Yes | Unclear | Unclear | Unclear | No | No | Unclear | Yes | High