# Evidence Tables

Table E1 Key Question 1: Included studies

Table E2 Key Question 2: Included studies

Table E3 Key Question 3: Included studies