# Excluded Studies

Abol-Enein H. Neo-adjuvant chemotherapy in the treatment of invasive transitional bladder cancer. A controlled, prospective randomized study. Br J Urol. 1997;79(Suppl. 4):43. PMID: No PMID. Excluded: not a study. [pmid: 9043495].
Abol-Enein H, El-Baz M, Abd El-Hameed MA, et al. Lymph node involvement in patients with bladder cancer treated with radical cystectomy: a patho-anatomical study--a single center experience. J Urol. 2004;172(5 Pt 1):1818-21. Excluded: wrong comparator. [pmid: 15540728].
Abratt RP, Barnes DR, Pontin AR, et al. Radical radiation and oral and intra-vesical misonidazole for bladder cancer. Int J Radiat Oncol Biol Phys. 1987;13(7):1053-5. Excluded: too old. [pmid: 3597148].
Abratt RP, Craighead P, Reddi VB, et al. A prospective randomised trial of radiation with or without oral and intravesical misonidazole for bladder cancer. Br J Cancer. 1991;64(5):968-70. Excluded: wrong intervention. [pmid: 1931628].
Advanced Bladder Cancer Meta-analysis C. Adjuvant chemotherapy for invasive bladder cancer (individual patient data). Cochrane Database Syst Rev. 2006;(2):CD006018. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 16625650].
Advanced Bladder Cancer Meta-analysis Collaboration. Neo-adjuvant chemotherapy for invasive bladder cancer. Cochrane Database Syst Rev. 2004;(2). Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 15846746].
Advanced Bladder Cancer Meta-analysis Collaboration. Adjuvant chemotherapy in invasive bladder cancer: a systematic review and meta-analysis of individual patient data Advanced Bladder Cancer (ABC) Meta-analysis Collaboration. Eur Urol. 2005;48(2):189-99. discussion 99-201. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 15939530].
Advanced Bladder Cancer Meta-analysis Collaboration. WITHDRAWN: Neoadjuvant cisplatin for advanced bladder cancer. Cochrane Database Syst Rev. 2011;(6). CD001426. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 21678333].
Advanced Bladder Cancer Overview C. Neoadjuvant chemotherapy for invasive bladder cancer. Cochrane Database Syst Rev. 2005;(2). CD005246. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 15846746].
Akin Y, Celik O, Ates M, et al. Evaluation of open and laparoscopic radical cystoprostatectomy combined with orthotopic neobladder: a single-surgeon experience. Urol Int. 2013;90(3):348-53. Excluded: wrong intervention. [pmid: 23406677].
Albers P, Park S-I, Niegisch G, et al. Randomized phase III trial of 2nd line gemcitabine and paclitaxel chemotherapy in patients with advanced bladder cancer: short-term versus prolonged treatment. [German Association of Urological Oncology (AUO) trial AB 20/99]. Ann Oncol. 2011;22(2):288-94. Excluded: wrong intervention. [pmid: 20682548].
Ali-el-Dein B, el-Baz M, Aly AN, et al. Intravesical epirubicin versus doxorubicin for superficial bladder tumors (stages pTa and pT1): a randomized prospective study. J Urol. 1997;158(1):68-73. discussion -4. Excluded: wrong intervention. [pmid: 9186325].
Alva AS, Tallman CT, He C, et al. Efficient delivery of radical cystectomy after neoadjuvant chemotherapy for muscle-invasive bladder cancer: a multidisciplinary approach. Cancer. 2012;118(1):44-53. Excluded: wrong comparator. [pmid: 21598245].
Anderstrom C, Johansson S, Nilsson S, et al. A prospective randomized study of preoperative irradiation with cystectomy or cystectomy alone for invasive bladder carcinoma. Eur Urol. 1983;9(3):142-7. Excluded: wrong intervention. [pmid: 6861819].
Angulo Cuesta J, Flores Corral N. Systemic chemotherapy with cisplatin, methotrexate, and vinblastine, and bladder preservation in T2/T3a bladder cancer. Actas Urol Esp. 1997;21(1):28-33. Excluded: not English language, but possibly relevant. [pmid: 9182442].
Aota Y, Yoshida K. Intra-arterial chemotherapy for locally advanced bladder cancer. Hinyokika Kiyo. 1999;45(2):149-53. Excluded: not English language, but possibly relevant. [pmid: 10212791].
Azuma H, Inamoto T, Ibuki N, et al. Utility of the novel bladder preservation therapy, BOAI-CDDP-radiation (OMC-regimen), for elderly patients with invasive bladder cancer. Int J Oncol. 2011;38(1):13-24. Excluded: wrong intervention. [pmid: 21109921].
Azuma H, Inamoto T, Takahara K, et al. A great option for elderly patients with locally invasive bladder cancer, BOAI-CDDP-radiation (OMC regimen). Int J Oncol. 2013;43(4):1087-94. Excluded: wrong intervention. [pmid: 23934264].
Bajorin DF. Plenary debate of randomized phase III trial of neoadjuvant MVAC plus cystectomy versus cystectomy alone in patients with locally advanced bladder cancer. J Clin Oncol. 2001;19(18 Suppl):17S-20S. Excluded: not a study. [pmid: 11560966].
Bassi P. Dose Response of Bacillus Calmette-Guerin (BCG) in superficial bladder cancer: a phase III randomized tial low-dose vs standard-dose BCG regimen. J Urol. 1992;146:32-5. PMID: No PMID. Excluded: not a study. [pmid: 2056600].
Bassi P. Neoadjuvant MVAC chemotherapy of invasive bladder cancer: results of a multicenter phase III trial. J Urol. 1999;161(Suppl. 4):264. PMID: No PMID. Excluded: not a study.
Bellmunt Molins J, Ribas A, Albanell J, et al. Preliminary results of a phase II randomized controlled trial comparing M-VAC and M-CAVI in patients with bladder cancer (T2-4 N0-1 M0). Arch Esp Urol. 1996;49(5):465-72. Excluded: not English language, but possibly relevant. [pmid: 8766083].
Berian Polo JM, Zudaire Bergera JJ, Robles Garcia JE, et al. Infiltrating bladder carcinoma: influence of complementary treatment on local control and survival. Actas Urol Esp. 18 Suppl. 1994:520-6. Excluded: not English language, but possibly relevant. [pmid: 8073942].
Birkenhake S, Martus P, Kuhn R, et al. Radiotherapy alone or radiochemotherapy with platin derivatives following transurethral resection of the bladder. Organ preservation and survival after treatment of bladder cancer. Strahlenther Onkol. 1998;174(3):121-7. Excluded: wrong comparator. [pmid: 9524620].
Blank LECM, Koedooder K, van Os R, et al. Results of bladder-conserving treatment, consisting of brachytherapy combined with limited surgery and external beam radiotherapy, for patients with solitary T1-T3 bladder tumors less than 5 cm in diameter. Int J Radiat Oncol Biol Phys. 2007;69(2):454-8. Excluded: wrong population. [pmid: 17560734].
Böhm M, Vom Dorp F, Schostak M, et al. Urine cytology - Update 2013: A systematic review of recent literature. Urinzytologie - Update 2013: Eine systematische Übersicht der neueren Literatur. 2013;52(9):1207-24. Excluded: not English language, but possibly relevant. [pmid: 24026058].
Bongiovanni L, Pirozzi F, Guidi F, et al. Bradeion (SEPT4) as a urinary marker of transitional cell bladder cancer: a real-time polymerase chain reaction study of gene expression. J Urol. 2012;187(6):2223-7. Excluded: wrong intervention. [pmid: 22503047].
Brod JL, Kuhn R, Schafhauser W, et al. Radiochemotherapy in locally invasive non-metastatic carcinoma of the bladder. Adv Exp Med Biol. 2003;539(Pt A):143-53. Excluded: wrong study design for Key Question. [pmid: 15088903].
Caffo O, Fellin G, Graffer U, et al. Gemcitabine and radiotherapy plus cisplatin after transurethral resection as conservative treatment for infiltrating bladder cancer: Long-term cumulative results of 2 prospective single-institution studies. Cancer. 2011;117(6):1190-6. Excluded: wrong comparator. [pmid: 20960501].
Cam K, Yildirim A, Ozveri H, et al. The efficacy of neoadjuvant chemotherapy in invasive bladder cancer. Int Urol Nephrol. 2002;33(1):49-52. Excluded: wrong study design for Key Question. [pmid: 12090338].
Chahal R, Sundaram SK, Iddenden R, et al. A study of the morbidity, mortality and long-term survival following radical cystectomy and radical radiotherapy in the treatment of invasive bladder cancer in Yorkshire. Eur Urol. 2003;43(3):246-57. Excluded: wrong population. [pmid: 12600427].
Choi W, Porten S, Kim S, et al. Identification of distinct basal and luminal subtypes of muscle-invasive bladder cancer with different sensitivities to frontline chemotherapy. Cancer Cell. 2014;25(2):152-65. Excluded: wrong study design for Key Question. [pmid: 24525232].
Choueiri TK, Jacobus S, Bellmunt J, et al. Neoadjuvant dose-dense methotrexate, vinblastine, doxorubicin, and cisplatin with pegfilgrastim support in muscle-invasive urothelial cancer: pathologic, radiologic, and biomarker correlates. J Clin Oncol. 2014;32(18):1889-94. Excluded: wrong comparator. [pmid: 24821883].
Chung PWM, Bristow RG, Milosevic MF, et al. Long-term outcome of radiation-based conservation therapy for invasive bladder cancer. Urol. 2007;25(4):303-9. Excluded: wrong comparator. [pmid: 17628296].
Clark PE, Stein JP, Groshen SG, et al. The management of urethral transitional cell carcinoma after radical cystectomy for invasive bladder cancer. J Urol. 2004;172(4 Pt 1):1342-7. Excluded: wrong study design for Key Question. [pmid: 15371837].
Cole CJ, Pollack A, Zagars GK, et al. Local control of muscle-invasive bladder cancer: preoperative radiotherapy and cystectomy versus cystectomy alone. Int J Radiat Oncol Biol Phys. 1995;32(2):331-40. Excluded: wrong intervention. [pmid: 7751174].
Coppin CM, Gospodarowicz MK, James K, et al. Improved local control of invasive bladder cancer by concurrent cisplatin and preoperative or definitive radiation. The National Cancer Institute of Canada Clinical Trials Group. J Clin Oncol. 1996;14(11):2901-7. Excluded: wrong population. [pmid: 8918486].
Croswell J, Fall B. Screening for bladder cancer. Am Fam Physician. 2012;85(4):401-2. Excluded: not a study. [pmid: 22335321].
Culp SH, Dickstein RJ, Grossman HB, et al. Refining patient selection for neoadjuvant chemotherapy before radical cystectomy. J Urol. 2014;191(1):40-7. Excluded: wrong comparator. [pmid: 23911605].
Damrauer JS, Hoadley KA, Chism DD, et al. Intrinsic subtypes of high-grade bladder cancer reflect the hallmarks of breast cancer biology. Proc Natl Acad Sci U S A. 2014;111(8):3110-5. Excluded: wrong comparator. [pmid: 24520177].
Danesi DT, Arcangeli G, Cruciani E, et al. Conservative treatment of invasive bladder carcinoma by transurethral resection, protracted intravenous infusion chemotherapy, and hyperfractionated radiotherapy: long term results. Cancer. 2004;101(11):2540-8. Excluded: wrong intervention. [pmid: 15481058].
Davis R, Jones JS, Barocas DA, et al. Diagnosis, evaluation and follow-up of asymptomatic microhematuria (AMH) in adults: AUA guideline. J Urol. 2012;188(6 SUPPL):2473-81. Excluded: not a study. [pmid: 23098784].
De Castro F, Sanchez PL, Aguera LG, et al. Infiltrating carcinoma of the bladder: preliminary results of multidisciplinary protocols with radiotherapy and neoadjuvant chemotherapy. Actas Urol Esp. 1992;16(2):127-32. Excluded: not English language, but possibly relevant. [pmid: 1590087].
De Neve W, Lybeert ML, Goor C, et al. T1 and T2 carcinoma of the urinary bladder: long term results with external, preoperative, or interstitial radiotherapy. Int J Radiat Oncol Biol Phys. 1992;23(2):299-304. Excluded: wrong intervention. [pmid: 1587750].
De Santis M, Bellmunt J, Mead G, et al. Randomized phase II/III trial assessing gemcitabine/carboplatin and methotrexate/carboplatin/vinblastine in patients with advanced urothelial cancer who are unfit for cisplatin-based chemotherapy: EORTC study 30986. J Clin Oncol. 2012;30(2):191-9. Excluded: wrong population. [pmid: 22162575].
Donat SM, Siegrist T, Cronin A, et al. Radical cystectomy in octogenarians--does morbidity outweigh the potential survival benefits?. J Urol. 2010;183(6):2171-7. Excluded: wrong intervention. [pmid: 20399461].
Droller MJ. Neoadjuvant cisplatin, methotrexate, and vinblastine chemotherapy for muscle-invasive bladder cancer: a randomised controlled trial. J Urol. 2000;163(5):1602-3. Excluded: not a study. [pmid: 10798921].
Droller MJ. Chemoradiotherapy for muscle invading bladder carcinoma. Final report of a single institutional organ-sparing program. J Urol. 2002;167(5):2297-8. Excluded: not a study. [pmid: 11956495].
Dunst J, Sauer R, Schrott KM, et al. Organ-sparing treatment of advanced bladder cancer: a 10-year experience. Int J Radiat Oncol Biol Phys. 1994;30(2):261-6. Excluded: wrong comparator. [pmid: 7928455].
Durkan GC, Nutt JE, Marsh C, et al. Alteration in urinary matrix metalloproteinase-9 to tissue inhibitor of metalloproteinase-1 ratio predicts recurrence in nonmuscle-invasive bladder cancer. Clin Cancer Res. 2003;9(7):2576-82. Excluded: wrong intervention. [pmid: 12855633].
Durkan GC, Nutt JE, Rajjayabun PH, et al. Prognostic significance of matrix metalloproteinase-1 and tissue inhibitor of metalloproteinase-1 in voided urine samples from patients with transitional cell carcinoma of the bladder. Clin Cancer Res. 2001;7(11):3450-6. Excluded: wrong intervention. [pmid: 11705862].
Efstathiou JA, Bae K, Shipley WU, et al. Late pelvic toxicity after bladder-sparing therapy in patients with invasive bladder cancer: RTOG 89-03, 95-06, 97-06, 99-06. J Clin Oncol. 2009;27(25):4055-61. Excluded: wrong comparator. [pmid: 19636019].
Eijan AM, Sandes E, Puricelli L, et al. Cathepsin B levels in urine from bladder cancer patients. Oncol Rep. 2000;7(6):1395-9. Excluded: wrong intervention. [pmid: 11032951].
Eijsten A, Knonagel H, Hotz E, et al. Reduced bladder capacity in patients receiving intravesical chemoprophylaxis with mitomycin C. Br J Urol. 1990;66(4):386-8. Excluded: wrong comparator. [pmid: 2121309].
El-Monim HA, El-Baradie MM, Younis A, et al. A prospective randomized trial for postoperative vs. preoperative adjuvant radiotherapy for muscle-invasive bladder cancer. Urol. 2013;31(3):359-65. Excluded: wrong comparator. [pmid: 21353794].
El-Shazli S, Anwar H, Ramzy S, et al. Extended lymphadenectomy to the lower paraaortic nodes during radical cystectomy. J Egypt Natl Canc Inst. 2004;16(1):22-8. Excluded: wrong outcome. [pmid: 15716994].
Ennis RD, Petrylak DP, Singh P, et al. The effect of cystectomy, and perioperative methotrexate, vinblastine, doxorubicin and cisplatin chemotherapy on the risk and pattern of relapse in patients with muscle invasive bladder cancer. J Urol. 2000;163(5):1413-8. Excluded: wrong population. [pmid: 10751847].
Faba OR, Palou J, Urdaneta G, et al. Invasive bladder cancer in the eighties: transurethral resection or cystectomy?. Int Braz J Urol. 2011;37(1):49-55. discussion -6. Excluded: wrong comparator. [pmid: 21385480].
Fahmy NM, Mahmud S, Aprikian AG. Delay in the surgical treatment of bladder cancer and survival: systematic review of the literature. Eur Urol. 2006;50(6):1176-82. Excluded: wrong outcome. [pmid: 16846680].
Fechner G, Siener R, Reimann M, et al. Randomised phase II trial of gemcitabine and paclitaxel second-line chemotherapy in patients with transitional cell carcinoma (AUO Trial AB 20/99). Int J Clin Pract. 2006;60(1):27-31. Excluded: wrong intervention. [pmid: 16409425].
Fedeli U, Fedewa SA, Ward EM. Treatment of muscle invasive bladder cancer: evidence from the National Cancer Database, 2003 to 2007. J Urol. 2011;185(1):72-8. Excluded: wrong outcome. [pmid: 21074192].
Fiorito C, Gontero P. Adverse events after intravesical therapy: are we always ready to recognize and prevent them?. Urologia. Suppl 21. 2013;80:27-32. Excluded: not English language, but possibly relevant. [pmid: 23559132].
Fleischmann A, Thalmann GN, Markwalder R, et al. Extracapsular extension of pelvic lymph node metastases from urothelial carcinoma of the bladder is an independent prognostic factor. J Clin Oncol. 2005;23(10):2358-65. Excluded: wrong study design for Key Question. [pmid: 15800327].
Fossa SD, Aass N, Ous S, et al. Survival after curative treatment of muscle-invasive bladder cancer. Acta Oncol. Suppl 8. 1996;35:59-65. Excluded: wrong comparator. [pmid: 9073049].
Froehner M, Brausi MA, Herr HW, et al. Complications following radical cystectomy for bladder cancer in the elderly. Eur Urol. 2009;56(3):443-54. Excluded: not a study. [pmid: 19481861].
Gakis G, Efstathiou J, Lerner SP, et al. ICUD-EAU International Consultation on Bladder Cancer 2012: Radical cystectomy and bladder preservation for muscle-invasive urothelial carcinoma of the bladder. Eur Urol. 2013;63(1):45-57. Excluded: not a study. [pmid: 22917985].
Garcia-Baquero R, Puerta P, Beltran M, et al. Methylation of a novel panel of tumor suppressor genes in urine moves forward noninvasive diagnosis and prognosis of bladder cancer: a 2-center prospective study. J Urol. 2013;190(2):723-30. Excluded: wrong intervention. [pmid: 23485510].
Gondo T, Yoshioka K, Nakagami Y, et al. Robotic versus open radical cystectomy: prospective comparison of perioperative and pathologic outcomes in Japan. Jpn J Clin Oncol. 2012;42(7):625-31. Excluded: wrong comparator. [pmid: 22581913].
Gore JL, Litwin MS, Lai J, et al. Use of radical cystectomy for patients with invasive bladder cancer. J Natl Cancer Inst. 2010;102(11):802-11. Excluded: wrong comparator. [pmid: 20400716].
Gray PJ, Fedewa SA, Shipley WU, et al. Use of potentially curative therapies for muscle-invasive bladder cancer in the United States: results from the National Cancer Data Base. Eur Urol. 2013;63(5):823-9. Excluded: wrong outcome. [pmid: 23200811].
Gruschwitz T, Grimm MO. Studieearly recognition in urology. Früherkennung in der urologie. 2012;18(3):243-7. PMID: No PMID. Excluded: not English language, but possibly relevant.
Hall R. Neo-adjuvant CMV chemotherapy and cystectomy of radiotherapy in muscle invasive bladder cancer. First analysis of MRC/EORTC intercontinental trial. Proc Ann Meet Am Soc Clin Oncol. 1996;15:A612. PMID: No PMID. Excluded: not a study.
Haresh KP, Julka PK, Sharma DN, et al. A prospective study evaluating surgery and chemo radiation in muscle invasive bladder cancer. J Cancer Res Ther. 2007;3(2):81-5. Excluded: wrong comparator. [pmid: 17998728].
Harland SJ. Electromotive drug delivery and bladder cancer. [Erratum appears in Lancet Oncol. 2006 Feb;7(2):105]. Lancet Oncol. 2006;7(1):6-7. Excluded: wrong intervention. [pmid: 16389175].
Hashine K, Miura N, Numata K, et al. Health-related quality of life after bladder preservation therapy for muscle invasive bladder cancer. Int J Urol. 2008;15(5):403-6. Excluded: wrong comparator. [pmid: 18384578].
Henningsohn L, Wijkstrom H, Dickman PW, et al. Distressful symptoms after radical radiotherapy for urinary bladder cancer. Radiother Oncol. 2002;62(2):215-25. Excluded: wrong outcome. [pmid: 11937249].
Henningsohn L, Wijkstrom H, Steven K, et al. Relative importance of sources of symptom-induced distress in urinary bladder cancer survivors. Eur Urol. 2003;43(6):651-62. Excluded: wrong population. [pmid: 12767367].
Henriksson R, Franzen L, Littbrand B. Prevention of irradiation-induced bowel discomfort by sucralfate: a double-blind, placebo-controlled study when treating localized pelvic cancer. Am J Med. 1991;91(2A):151S-7S. Excluded: wrong intervention. [pmid: 1882903].
Henriksson R, Franzen L, Littbrand B. Effects of sucralfate on acute and late bowel discomfort following radiotherapy of pelvic cancer. J Clin Oncol. 1992;10(6):969-75. Excluded: wrong intervention. [pmid: 1588377].
Herr HW, Dotan Z, Donat SM, et al. Defining optimal therapy for muscle invasive bladder cancer. J Urol. 2007;177(2):437-43. Excluded: not a study. [pmid: 17222605].
Hirabayashi N. Long-term results of short-course preoperative radiotherapy and radical cystectomy for bladder cancer. Nippon Hinyokika Gakkai Zasshi. 1997;88(5):528-34. Excluded: not English language, but possibly relevant. [pmid: 9184445].
Holzbeierlein JM, Lopez-Corona E, Bochner BH, et al. Partial cystectomy: a contemporary review of the Memorial Sloan-Kettering Cancer Center experience and recommendations for patient selection. J Urol. 2004;172(3):878-81. Excluded: wrong comparator. [pmid: 15310988].
Honma I, Masumori N, Sato E, et al. Removal of more lymph nodes may provide better outcome, as well as more accurate pathologic findings, in patients with bladder cancer--analysis of role of pelvic lymph node dissection. Urology. 2006;68(3):543-8. Excluded: wrong study design for Key Question. [pmid: 16979723].
Horstmann M. Bladder cancer: Screening in risk groups or symptom-based urological diagnosis?. Blasenkrebs: Screening in Risikogruppen oder symptombasierte urologische Diagnostik?. 2011;18(1):20-2. PMID: No PMID. Excluded: not English language, but possibly relevant.
Horwich A. Commentary 1. Radiotherapy. 1999:236-8. PMID: No PMID. Excluded: not a study.
Housset M, Maulard C, Chretien Y, et al. Combined radiation and chemotherapy for invasive transitional-cell carcinoma of the bladder: a prospective study. J Clin Oncol. 1993;11(11):2150-7. Excluded: wrong comparator. [pmid: 8229129].
Hsieh C-H, Chung S-D, Chan P-H, et al. Intensity modulated radiotherapy for elderly bladder cancer patients. Radiat. 2011;6:75. Excluded: wrong comparator. [pmid: 21679408].
Huang GJ, Stein JP. Open radical cystectomy with lymphadenectomy remains the treatment of choice for invasive bladder cancer. Curr Opin Urol. 2007;17(5):369-75. Excluded: not a study. [pmid: 17762633].
Huddart RA, Hall E, Hussain SA, et al. Randomized noninferiority trial of reduced high-dose volume versus standard volume radiation therapy for muscle-invasive bladder cancer: results of the BC2001 trial (CRUK/01/004). Int J Radiat Oncol Biol Phys. 2013;87(2):261-9. Excluded: wrong comparator. [pmid: 23958147].
Huncharek M, Muscat J, Geschwind JF. Planned preoperative radiation therapy in muscle invasive bladder cancer; results of a meta-analysis. Anticancer Res. 1998;18(3B):1931-4. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 9677446].
Hussain M, Daignault S, Agarwal N, et al. A randomized phase 2 trial of gemcitabine/cisplatin with or without cetuximab in patients with advanced urothelial carcinoma. Cancer. 2014;120(17):2684-93. Excluded: wrong population. [pmid: 24802654].
Institute of Applied Health S. Systematic review of the clinical and cost-effectiveness, and economic evaluation, of photodynamic diagnosis and novel urine biomarker tests in the detection and follow-up of bladder cancer (Project record). Health Technology Assessment Database. 2013;(4). PMID: No PMID. Excluded: not a study.
Iwai A, Koga F, Fujii Y, et al. Perioperative complications of radical cystectomy after induction chemoradiotherapy in bladder-sparing protocol against muscle-invasive bladder cancer: a single institutional retrospective comparative study with primary radical cystectomy. Jpn J Clin Oncol. 2011;41(12):1373-9. Excluded: wrong intervention. [pmid: 21994208].
Izawa JI, Chin JL, Winquist E. Timing cystectomy and perioperative chemotherapy in the treatment of muscle invasive bladder cancer. Can J Urol. Suppl 3. 2006;13:48-53. Excluded: not a study. [pmid: 16818012].
Jensen JB, Ulhoi BP, Jensen KM. Lymph node mapping in patients with bladder cancer undergoing radical cystectomy and lymph node dissection to the level of the inferior mesenteric artery. BJU Int. 2010;106(2):199-205. Excluded: wrong outcome. [pmid: 20002670].
Joung JY, Han KS, Kim TS, et al. Single institutional experience of bladder-preserving trimodality treatment for muscle-invasive bladder cancer. J Korean Med Sci. 2008;23(4):598-603. Excluded: wrong study design for Key Question. [pmid: 18756044].
Kageyama Y, Yokoyama M, Sakai Y, et al. Favorable outcome of preoperative low dose chemoradiotherapy against muscle-invasive bladder cancer. Am J Clin Oncol. 2003;26(5):504-7. Excluded: wrong comparator. [pmid: 14528080].
Karl A, Carroll PR, Gschwend JE, et al. The impact of lymphadenectomy and lymph node metastasis on the outcomes of radical cystectomy for bladder cancer. Eur Urol. 2009;55(4):826-35. Excluded: not a study. [pmid: 19150582].
Kaufman DS, Shipley WU, Griffin PP, et al. Selective bladder preservation by combination treatment of invasive bladder cancer. N Engl J Med. 1993;329(19):1377-82. Excluded: wrong comparator. [pmid: 8413433].
Kawamura N, Matsushita M, Okada T, et al. Relative efficacy of neoadjuvant gemcitabine and cisplatin versus methotrexate, vinblastine, adriamycin, and cisplatin in the management for muscle-invasive bladder cancer. Hinyokika Kiyo. 2013;59(5):277-81. Excluded: not English language, but possibly relevant. [pmid: 23719134].
Kim PH, Cha EK, Sfakianos JP, et al. Genomic Predictors of Survival in Patients with High-grade Urothelial Carcinoma of the Bladder. Eur Urol. 2014. Excluded: wrong comparator. [pmid: 25092538].
Kinjo M, Okegawa T, Horie S, et al. Detection of circulating MUC7-positive cells by reverse transcription-polymerase chain reaction in bladder cancer patients. Int J Urol. 2004;11(1):38-43. Excluded: wrong intervention. [pmid: 14678183].
Kitagawa Y, Izumi K, Miwa S, et al. Retrospective analysis of the efficacy of two cycles of M-VAC neoadjuvant chemotherapy followed by radical cystectomy for muscle-invasive bladder cancer. Anticancer Res. 2013;33(10):4497-503. Excluded: wrong study design for Key Question. [pmid: 24123021].
Koga F, Kihara K, Fujii Y, et al. Favourable outcomes of patients with clinical stage T3N0M0 bladder cancer treated with induction low-dose chemo-radiotherapy plus partial or radical cystectomy vs immediate radical cystectomy: a single-institutional retrospective comparative study. BJU Int. 2009;104(2):189-94. Excluded: wrong study design for Key Question. [pmid: 19154452].
Kolaczyk W, Dembowski J, Lorenz J, et al. Evaluation of the influence of systemic neoadjuvant chemotherapy on the survival of patients treated for invasive bladder cancer. BJU Int. 2002;89(6):616-9. Excluded: wrong study design for Key Question. [pmid: 11942977].
Konety BR, Joyce GF, F W. Bladder and upper tract urothelial cancer. Washington, DC. US Government Printing Office. 2007;07-5512. Excluded: wrong outcome. [pmid: 17437776].
Koppie TM, Vickers AJ, Vora K, et al. Standardization of pelvic lymphadenectomy performed at radical cystectomy: can we establish a minimum number of lymph nodes that should be removed?. Cancer. 2006;107(10):2368-74. Excluded: wrong study design for Key Question. [pmid: 17041887].
Kotb AF, Kovac E, Kassouf W, et al. Radical cystectomy for clinically muscle invasive bladder cancer: does prior non-invasive disease affect clinical outcomes?. World J Urol. 2012;30(6):761-7. Excluded: wrong intervention. [pmid: 22293934].
Kozak KR, Hamidi M, Manning M, et al. Bladder preservation for localized muscle-invasive bladder cancer: the survival impact of local utilization rates of definitive radiotherapy. Int J Radiat Oncol Biol Phys. 2012;83(2):e197-204. Excluded: wrong comparator. [pmid: 22401916].
Krause FS, Feil G, Zumbragel A, et al. Molecular genetic methods in the diagnosis of invasive bladder cancer. Anticancer Res. 2000;20(6D):5015-21. Excluded: wrong intervention. [pmid: 11326660].
Krogsbøll LT. Guidelines for screening with urinary dipsticks differ substantially - A systematic review. Danish Medical Journal. 2014;61(2). Excluded: wrong population. [pmid: 24495888].
Kuten A, Baz M, Rubinov R, et al. Treatment of muscle invasive bladder cancer. Is there a role for neoadjuvant chemotherapy?. Strahlenther Onkol. 1994;170(9):524-30. Excluded: wrong study design for Key Question. [pmid: 7524174].
Larré S, Catto JWF, Cookson MS, et al. Screening for bladder cancer: Rationale, limitations, whom to target, and perspectives. Eur Urol. 2013;63(6):1049-58. Excluded: wrong population. [pmid: 23313034].
Lee CT, Dunn RL, Ingold C, et al. Early-stage bladder cancer surveillance does not improve survival if high-risk patients are permitted to progress to muscle invasion. Urology. 2007;69(6):1068-72. Excluded: wrong comparator. [pmid: 17572188].
Lehmann J, Retz M, Wiemers C, et al. Adjuvant cisplatin plus methotrexate versus methotrexate, vinblastine, epirubicin, and cisplatin in locally advanced bladder cancer: results of a randomized, multicenter, phase III trial (AUO-AB 05/95). J Clin Oncol. 2005;23(22):4963-74. Excluded: wrong comparator. [pmid: 15939920].
Leibovici D, Kassouf W, Pisters LL, et al. Organ preservation for muscle-invasive bladder cancer by transurethral resection. Urology. 2007;70(3):473-6. Excluded: sample size too small. [pmid: 17905099].
Leissner J, Ghoneim MA, Abol-Enein H, et al. Extended radical lymphadenectomy in patients with urothelial bladder cancer: results of a prospective multicenter study. J Urol. 2004;171(1):139-44. Excluded: wrong outcome. [pmid: 14665862].
Leliveld AM, Doornweerd BHJ, Bastiaannet E, et al. Treatment and outcome in muscle invasive bladder cancer: a population-based survey. World J Urol. 2010;28(4):439-44. Excluded: wrong comparator. [pmid: 20383640].
Lerner SP, Skinner DG, Lieskovsky G, et al. The rationale for en bloc pelvic lymph node dissection for bladder cancer patients with nodal metastases: long-term results. J Urol. 1993;149(4):758-64. discussion 64-5. Excluded: wrong population. [pmid: 8455238].
Li Y-J, Zheng B-Z, Zhou Z-L. Association of uPA and uPAR expression with invasive behaviors of urinary transitional cell carcinoma. Ai Zheng. 2004;23(6):704-6. Excluded: not English language, but possibly relevant. [pmid: 15191676].
Liedberg F, Anderson H, Mansson W. Treatment delay and prognosis in invasive bladder cancer. J Urol. 2005;174(5):1777-81. discussion 81. Excluded: wrong comparator. [pmid: 16217282].
Liew MS, Azad A, Tafreshi A, et al. USANZ: Time-trends in use and impact on outcomes of perioperative chemotherapy in patients treated with radical cystectomy for urothelial bladder cancer. BJU Int. Suppl 2. 2013;112:74-82. Excluded: sample size too small. [pmid: 24127680].
Lin C-C, Hsu C-H, Cheng JC, et al. Induction cisplatin and fluorouracil-based chemotherapy followed by concurrent chemoradiation for muscle-invasive bladder cancer. Int J Radiat Oncol Biol Phys. 2009;75(2):442-8. Excluded: wrong comparator. [pmid: 19307067].
Lin YL, Sun G, Liu XQ, et al. Clinical significance of CDH13 promoter methylation in serum samples from patients with bladder transitional cell carcinoma. J Int Med Res. 2011;39(1):179-86. Excluded: wrong intervention. [pmid: 21672320].
Lin Y-L, Liu X-Q, Li W-P, et al. Promoter methylation of H-cadherin is a potential biomarker in patients with bladder transitional cell carcinoma. Int Urol Nephrol. 2012;44(1):111-7. Excluded: wrong intervention. [pmid: 21516472].
Loo RK, Lieberman SF, Slezak JM, et al. Stratifying risk of urinary tract malignant tumors in patients with asymptomatic microscopic hematuria. Mayo Clin Proc. 2013;88(2):129-38. Excluded: wrong population. [pmid: 23312369].
Lorusso V. A phase II randomized trial of paclitaxel, gemcitabine and cisplatin versus gemcitabine - cisplatin in advanced transitional cell carcinoma of the urinary tract (TCC). A cooperative study of the IBCG (Italian Bladder Cancer Group). Genito-urinary turmours. 2002:93-4. PMID: No PMID. Excluded: not a study.
Mameghan H, Fisher RJ, Watt WH, et al. The management of invasive transitional cell carcinoma of the bladder. Results of definitive and preoperative radiation therapy in 390 patients treated at the Prince of Wales Hospital, Sydney, Australia. Cancer. 1992;69(11):2771-8. Excluded: wrong study design for Key Question. [pmid: 1571908].
Managadze GL, Khvadagiani GG, Tsintsadze OV, et al. Extended lymphadenectomy in radical cystectomy: margins, scope, methodology. Urologiia. 2006(3):31-6. Excluded: not English language, but possibly relevant. [pmid: 16889087].
Manoharan M, Katkoori D, Kishore TA, et al. Outcome after radical cystectomy in patients with clinical T2 bladder cancer in whom neoadjuvant chemotherapy has failed. BJU Int. 2009;104(11):1646-9. Excluded: wrong comparator. [pmid: 19466944].
March Villalba JA, Martinez Jabaloyas JM, Pastor Hernandez F, et al. Radical cystectomy as a muscle-invasive bladder cancer treatment in elderly patients. Actas Urol Esp. 2008;32(7):696-704. Excluded: not English language, but possibly relevant. [pmid: 18788485].
Martinez-Pineiro JA, Gonzalez Martin M, Arocena F, et al. Neoadjuvant cisplatin chemotherapy before radical cystectomy in invasive transitional cell carcinoma of the bladder: a prospective randomized phase III study. J Urol. 1995;153(3 Pt 2):964-73. Excluded: wrong comparator. [pmid: 7853584].
Martini T, Mayr R, Wehrberger C, et al. Comparison of radical cystectomy with conservative treatment in geriatric (>80) patients with muscle-invasive bladder cancer. Int Braz J Urol. 2013;39(5):622-30. Excluded: wrong intervention. [pmid: 24267105].
Matsui Y, Nishiyama H, Watanabe J, et al. The current status of perioperative chemotherapy for invasive bladder cancer: a multiinstitutional retrospective study in Japan. Int J Clin Oncol. 2005;10(2):133-8. Excluded: wrong study design for Key Question. [pmid: 15864700].
May M, Fritsche HM, Gilfrich C, et al. Influence of older age on survival after radical cystectomy due to urothelial carcinoma of the bladder: survival analysis of a German multi-centre study after curative treatment of urothelial carcinoma of the bladder. Urologe A. 2011;50(7):821-9. Excluded: not English language, but possibly relevant. [pmid: 21340593].
May M, Herrmann E, Bolenz C, et al. Association between the number of dissected lymph nodes during pelvic lymphadenectomy and cancer-specific survival in patients with lymph node-negative urothelial carcinoma of the bladder undergoing radical cystectomy. Ann Surg Oncol. 2011;18(7):2018-25. Excluded: wrong study design for Key Question. [pmid: 21246405].
May M, Herrmann E, Bolenz C, et al. Lymph node density affects cancer-specific survival in patients with lymph node-positive urothelial bladder cancer following radical cystectomy. Eur Urol. 2011;59(5):712-8. Excluded: wrong comparator. [pmid: 21296488].
Meeks JJ, Bellmunt J, Bochner BH, et al. A systematic review of neoadjuvant and adjuvant chemotherapy for muscle-invasive bladder cancer. Eur Urol. 2012;62(3):523-33. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 22677572].
Mian C, Lodde M, Comploj E, et al. The value of the ImmunoCyt/uCyt+ test in the detection and follow-up of carcinoma in situ of the urinary bladder. Anticancer Res. 2005;25(5):3641-4. Excluded: wrong population. [pmid: 16101194].
Mian C, Lodde M, Haitel A, et al. Comparison of the monoclonal UBC-ELISA test and the NMP22 ELISA test for the detection of urothelial cell carcinoma of the bladder. Urology. 2000;55(2):223-6. Excluded: wrong population. [pmid: 10688083].
Mills RD, Fleischmann A, Studer UE. Radical cystectomy with an extended pelvic lymphadenectomy: rationale and results. Surg Oncol Clin N Am. 2007;16(1):233-45. Excluded: not a study. [pmid: 17336246].
Milonas D, Mickevicius J, Mickevicius R, et al. Treatment of superficial transitional cell bladder carcinoma. Long-term results of trial comparing transurethral resection alone and adjuvant chemotherapy with Doxorubicin. Medicina (Kaunas). Suppl 1. 2002;38:79-83. Excluded: not English language, but possibly relevant. [pmid: 12556642].
Mitin T, Hunt D, Shipley WU, et al. Transurethral surgery and twice-daily radiation plus paclitaxel-cisplatin or fluorouracil-cisplatin with selective bladder preservation and adjuvant chemotherapy for patients with muscle invasive bladder cancer (RTOG 0233): a randomised multicentre phase 2 trial. Lancet Oncol. 2013;14(9):863-72. Excluded: wrong comparator. [pmid: 23823157].
Monica B, Larosa M, Frattini A, et al. Neoadjuvant chemotherapy in advanced-stage bladder carcinoma. A randomized prospective study comparing MVAC and MVEEC. Arch Ital Urol Androl. 1994;66(5):235-43. Excluded: not English language, but possibly relevant. [pmid: 7812302].
Monzo Gardiner JI, Herranz Amo F, Cabello Benavente R, et al. Response to adjuvant chemotherapy after radical cystectomy in patients with infiltrative bladder: Analysis of 397 cases. Arch Esp Urol. 2009;62(4):275-82. Excluded: wrong study design for Key Question. [pmid: 19717877].
Morales A, Nickel JC, Wilson JW. Dose-response of bacillus Calmette-Guerin in the treatment of superficial bladder cancer. J Urol. 1992;147(5):1256-8. Excluded: wrong population. [pmid: 1569662].
Mori Y, Arima M, Shimada K, et al. Treatment of 300 patients with bladder cancer. Hinyokika Kiyo. 1991;37(10):1235-41. Excluded: not English language, but possibly relevant. [pmid: 1755417].
Moskovitz B, Halachmi S, Moskovitz M, et al. 10-year single-center experience of combined intravesical chemohyperthermia for nonmuscle invasive bladder cancer. Fut Oncol. 2012;8(8):1041-9. Excluded: wrong population. [pmid: 22894675].
Moskovitz B, Meyer G, Kravtzov A, et al. Thermo-chemotherapy for intermediate or high-risk recurrent superficial bladder cancer patients. Ann Oncol. 2005;16(4):585-9. Excluded: wrong population. [pmid: 15734775].
Moussa O, Abol-Enein H, Bissada NK, et al. Evaluation of survivin reverse transcriptase-polymerase chain reaction for noninvasive detection of bladder cancer. J Urol. 2006;175(6):2312-6. Excluded: wrong population. [pmid: 16697865].
Moyano Calvo JL, Romero Diaz JA, Ortiz Gamiz A, et al. Randomized prospective study comparing BCG and BCG plus oral tegafur in the prevention of stage T1 superficial tumors of the bladder. Results after 2.5 years. Actas Urol Esp. 1999;23(10):843-7. Excluded: not English language, but possibly relevant. [pmid: 10670125].
Moyer VA. Screening for bladder cancer: U.S. preventive services task force recommendation statement. Annals of Internal Medicine. 2011;155(4):246-51. Excluded: wrong population. [pmid: 21844550].
Mulders PF, Meyden AP, Doesburg WH, et al. Prognostic factors in pTa-pT1 superficial bladder tumours treated with intravesical instillations. The Dutch South-Eastern Urological Collaborative Group. Br J Urol. 1994;73(4):403-8. Excluded: wrong population. [pmid: 8199828].
Natale RB. Randomized Phase III Trial of Neoadjuvant MVAC + Cystectomy Versus Cystectomy Alone in Patients with Locally Advanced Bladder Cancer. Paper presented at: Plenary Presentation. Mon 1:00 pm - 3:30 pm 2011. U Colorado, Denver, CO. Excluded: not a study.
National Institute for Health and Clinical Excellence. Laparoscopic cystectomy (of the urinary bladder) (Structured abstract). Health Technology Assessment Database. 2013;(4). PMID: No PMID. Excluded: not a study.
Nazeri N. Incidental sonographic detection of non-muscle-invasive papillary urothelial carcinoma in a low-risk patient. Journal of Diagnostic Medical Sonography. 2014;30(1):34-8. PMID: No PMID. Excluded: wrong study design for Key Question.
Neulander EZ, Kaneti J. Long-term outcomes of a randomized controlled trial comparing thermochemotherapy with mitomycin-C alone as adjuvant treatment for non-muscle-invasive bladder cancer (NMIBC). BJU Int. 2011;107(10):1685. author reply -6. Excluded: not a study. [pmid: 21518420].
NHSC. NMP22 BladderChek proteomic assay for the detection of bladder cancer - horizon scanning technology note (Structured abstract). Health Technology Assessment Database. 2013;(4). PMID: No PMID. Excluded: not a study.
Niedersuss-Beke D. Systemic therapy of muscle invasive bladder cancer - an update. Wien Med Wochenschr. 2011;161(15-16):371-3. Excluded: not English language, but possibly relevant. [pmid: 21953426].
Nilsson S, Ragnhammar P, Glimelius B, et al. A systematic overview of chemotherapy effects in urothelial bladder cancer. Acta Oncol. 2001;40(2-3):371-90. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 11441942].
Nomi M, Gohji K, Okamoto M, et al. Results of transurethral resection plus adjuvant intravesical chemotherapy for superficial bladder cancer. Int J Urol. 1998;5(6):534-9. Excluded: wrong population. [pmid: 9855120].
O'Connor RC, Alsikafi NF, Steinberg GD. Therapeutic options and treatment of muscle invasive bladder cancer. Expert Rev Anticancer Ther. 2001;1(4):511-22. Excluded: not a study. [pmid: 12113083].
Oeda T, Manabe D. The usefulness of urinary FDP in the diagnosis of bladder cancer: comparison with NMP22, BTA and cytology. Nippon Hinyokika Gakkai Zasshi. 2001;92(1):1-5. Excluded: not English language, but possibly relevant. [pmid: 11235137].
Ogawa H, Nishimura T, Hori N, et al. 10-year survival rate in 92 patients with invasive bladder carcinoma treated by bladder sparing methods. Nippon Ika Daigaku Zasshi. 1997;64(5):446-54. Excluded: wrong comparator. [pmid: 9366149].
Ohlmann CH, De Santis M. Neoadjuvant, inductive or adjuvant chemotherapy of bladder cancer. Urologe A. 2013;52(11):1534-8. 40. Excluded: not English language, but possibly relevant. [pmid: 24197083].
Okegawa T, Kinjo M, Horie S, et al. Detection of mucin 7 gene expression in exfoliated cells in urine from patients with bladder tumor. Urology. 2003;62(1):182-6. Excluded: wrong population. [pmid: 12837463].
Oliva E, Pinheiro NF, Heney NM, et al. Immunohistochemistry as an adjunct in the differential diagnosis of radiation-induced atypia versus urothelial carcinoma in situ of the bladder: a study of 45 cases. Hum Pathol. 2013;44(5):860-6. Excluded: wrong population. [pmid: 23199526].
Ollesch J, Drees SL, Heise HM, et al. FTIR spectroscopy of biofluids revisited: an automated approach to spectral biomarker identification. Analyst. 2013;138(14):4092-102. Excluded: wrong population. [pmid: 23712384].
Ondrus D, Hornak M, Bardos A, et al. Systemic chemotherapy for muscle invasive bladder cancer. Neoplasma. 1994;41(5):263-8. Excluded: wrong comparator. [pmid: 7854496].
Onishi T, Sasaki T, Hoshina A, et al. Continuous saline bladder irrigation after transurethral resection is a prophylactic treatment choice for non-muscle invasive bladder tumor. Anticancer Res. 2011;31(4):1471-4. Excluded: wrong population. [pmid: 21508405].
Orsola A, Cecchini L, Raventos CX, et al. Risk factors for positive findings in patients with high-grade T1 bladder cancer treated with transurethral resection of bladder tumour (TUR) and bacille Calmette-Guerin therapy and the decision for a repeat TUR. BJU Int. 2010;105(2):202-7. Excluded: wrong population. [pmid: 19558557].
Panteliadou M, Touloupidis S, Giatromanolaki A, et al. Concurrent administration of liposomal doxorubicin improves the survival of patients with invasive bladder cancer undergoing hypofractionated accelerated radiotherapy (HypoARC). Med Oncol. 2011;28(4):1356-62. Excluded: wrong comparator. [pmid: 20424934].
Parkinson JP, Konety BR. Health related quality of life assessments for patients with bladder cancer. J Urol. 2004;172(6 Pt 1):2130-6. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 15538218].
Perdona S, Autorino R, Damiano R, et al. Bladder-sparing, combined-modality approach for muscle-invasive bladder cancer: a multi-institutional, long-term experience. Cancer. 2008;112(1):75-83. Excluded: wrong comparator. [pmid: 18008364].
Peyromaure M, Slama J, Beuzeboc P, et al. Concurrent chemoradiotherapy for clinical stage T2 bladder cancer: report of a single institution. Urology. 2004;63(1):73-7. Excluded: wrong comparator. [pmid: 14751352].
Philip J, Manikandan R, Venugopal S, et al. Orthotopic neobladder versus ileal conduit urinary diversion after cystectomy--a quality-of-life based comparison. Ann R Coll Surg Engl. 2009;91(7):565-9. Excluded: wrong outcome. [pmid: 19558757].
Plimack ER. Next-generation sequencing to identify molecular alterations in DNA repair and chromatin maintenance genes associated with pathologic complete response (pT0) to neoadjuvant accelerated methotrexate, vinblastine, doxorubicin, and cisplatin (AMVAC) in muscle-invasive bladder cancer (MIBC). J Clin Oncol. 2014;35(5s). abstr 4538. PMID. Excluded: not a study.
Plimack ER, Hoffman-Censits JH, Viterbo R, et al. Accelerated methotrexate, vinblastine, doxorubicin, and cisplatin is safe, effective, and efficient neoadjuvant treatment for muscle-invasive bladder cancer: results of a multicenter phase II study with molecular correlates of response and toxicity. J Clin Oncol. 2014;32(18):1895-901. Excluded: wrong comparator. [pmid: 24821881].
Porpiglia F, Renard J, Billia M, et al. Open versus laparoscopy-assisted radical cystectomy: results of a prospective study. J Endourol. 2007;21(3):325-9. Excluded: wrong comparator. [pmid: 17444780].
Raj GV, Karavadia S, Schlomer B, et al. Contemporary use of perioperative cisplatin-based chemotherapy in patients with muscle-invasive bladder cancer. Cancer. 2011;117(2):276-82. Excluded: wrong comparator. [pmid: 20830767].
Resorlu B, Turkolmez K, Ergun G, et al. The role of adjuvant chemotherapy in patients with locally advanced (pT3, pT4a) and/or lymph node-positive bladder cancer. Int Urol Nephrol. 2010;42(4):959-64. Excluded: wrong study design for Key Question. [pmid: 20405206].
Richards B, Bastable JR, Freedman L, et al. Adjuvant chemotherapy with doxorubicin (Adriamycin) and 5-fluorouracil in T3, NX, MO bladder cancer treated with radiotherapy. Br J Urol. 1983;55(4):386-91. Excluded: wrong comparator. [pmid: 6349744].
Rink M, Zabor EC, Furberg H, et al. Impact of smoking and smoking cessation on outcomes in bladder cancer patients treated with radical cystectomy. Eur Urol. 2013;64(3):456-64. Excluded: wrong comparator. [pmid: 23206854].
Rodel C, Grabenbauer GG, Kuhn R, et al. Combined-modality treatment and selective organ preservation in invasive bladder cancer: long-term results. J Clin Oncol. 2002;20(14):3061-71. Excluded: wrong comparator. [pmid: 12118019].
Rosenblatt R, Sherif A, Rintala E, et al. Pathologic downstaging is a surrogate marker for efficacy and increased survival following neoadjuvant chemotherapy and radical cystectomy for muscle-invasive urothelial bladder cancer. Eur Urol. 2012;61(6):1229-38. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 22189383].
Ruggeri EM, Giannarelli D, Bria E, et al. Adjuvant chemotherapy in muscle-invasive bladder carcinoma: a pooled analysis from phase III studies. Cancer. 2006;106(4):783-8. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 16419069].
Ruoppolo M, Bellorofonte C, Gritti A, et al. Neoadjuvant chemotherapy of locally advanced tumors of the bladder: preliminary experience. Arch Ital Urol Nefrol Androl. 1990;62(2):243-8. Excluded: not English language, but possibly relevant. [pmid: 2142808].
Sagaster P, Flamm J, Flamm M, et al. Neoadjuvant chemotherapy (MVAC) in locally invasive bladder cancer. Eur J Cancer. 1996;32A(8):1320-4. Excluded: wrong study design for Key Question. [pmid: 8869093].
Sangar VK, McBain CA, Lyons J, et al. Phase I study of conformal radiotherapy with concurrent gemcitabine in locally advanced bladder cancer. Int J Radiat Oncol Biol Phys. 2005;61(2):420-5. Excluded: wrong comparator. [pmid: 15667962].
Sapre N, Anderson P, Foroudi F. Management of local recurrences in the irradiated bladder: a systematic review. BJU Int. Suppl 4. 2012;110:51-7. Excluded: not a study. [pmid: 23194126].
Sarkis AS, Bajorin DF, Reuter VE, et al. Prognostic value of p53 nuclear overexpression in patients with invasive bladder cancer treated with neoadjuvant MVAC. J Clin Oncol. 1995;13(6):1384-90. Excluded: wrong intervention. [pmid: 7751883].
Sauer R, Birkenhake S, Kuhn R, et al. Efficacy of radiochemotherapy with platin derivatives compared to radiotherapy alone in organ-sparing treatment of bladder cancer. Int J Radiat Oncol Biol Phys. 1998;40(1):121-7. Excluded: wrong comparator. [pmid: 9422567].
Scattoni V, Da Pozzo L, Nava L, et al. Five-year results of neoadjuvant cisplatin, methotrexate and vinblastine chemotherapy plus radical cystectomy in locally advanced bladder cancer. Eur Urol. 1995;28(2):102-7. Excluded: wrong study design for Key Question. [pmid: 8529731].
Schrag D, Mitra N, Xu F, et al. Cystectomy for muscle-invasive bladder cancer: patterns and outcomes of care in the Medicare population. Urology. 2005;65(6):1118-25. Excluded: wrong comparator. [pmid: 15922428].
Scrimger RA, Murtha AD, Parliament MB, et al. Muscle-invasive transitional cell carcinoma of the urinary bladder: a population-based study of patterns of care and prognostic factors. Int J Radiat Oncol Biol Phys. 2001;51(1):23-30. Excluded: wrong study design for Key Question. [pmid: 11516847].
See WA, Dreicer R, Forest PK, et al. Continuous infusion, intravesical doxorubicin for the treatment of regionally advanced bladder cancer: a phase I-II trial. Am J Clin Oncol. 1997;20(4):331-7. Excluded: wrong study design for Key Question. [pmid: 9256884].
Segal R, Winquist E, Lukka H, et al. Adjuvant chemotherapy for deep muscle-invasive transitional cell bladder carcinoma - a practice guideline. Can J Urol. 2002;9(5):1625-33. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 12431323].
Segati R, Bari M, Azzarello G, et al. Carboplatin monochemotherapy in elderly patients with nonoperable transitional cell carcinoma of the bladder: a two-stage, phase II study. Eur Urol. 1996;29(3):312-6. discussion 7. Excluded: wrong population. [pmid: 8740038].
Serretta V, Lo Greco G, Pavone C, et al. The fate of patients with locally advanced bladder cancer treated conservatively with neoadjuvant chemotherapy, extensive transurethral resection and radiotherapy: 10-year experience. J Urol. 1998;159(4):1187-91. Excluded: wrong study design for Key Question. [pmid: 9507829].
Sharp VJ, Barnes KT, Erickson BA. Assessment of asymptomatic microscopic hematuria in adults. Am Fam Physician. 2013;88(11):747-54. Excluded: not a study. [pmid: 24364522].
Shelley M, Barber J, Wilt TJ, et al. Surgery versus radiotherapy for muscle invasive bladder cancer. Cochrane Database Syst Rev. 2012;(4). PMID: No PMID. Excluded: systematic review or meta-analysis used as source document only to identify individual studies.
Shelley M, Cleves A, Wilt TJ, et al. Gemcitabine for unresectable, locally advanced or metastatic bladder cancer. Cochrane Database Syst Rev. 2011(4). Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 21491413].
Shelley MD, Barber J, Wilt T, et al. Surgery versus radiotherapy for muscle invasive bladder cancer. Cochrane Database Syst Rev. 2002(1). CD002079. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 11869621].
Shelley MD, Jones G, Cleves A, et al. Intravesical gemcitabine therapy for non-muscle invasive bladder cancer (NMIBC): a systematic review. BJU Int. 2012;109(4):496-505. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 22313502].
Shelley MD, Wilt TJ, Barber J, et al. A meta-analysis of randomised trials suggests a survival benefit for combined radiotherapy and radical cystectomy compared with radical radiotherapy for invasive bladder cancer: are these data relevant to modern practice?. Clin Oncol (R Coll Radiol). 2004;16(3):166-71. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 15191002].
Sherif A, Holmberg L, Rintala E, et al. Neoadjuvant cisplatinum based combination chemotherapy in patients with invasive bladder cancer: a combined analysis of two Nordic studies. Eur Urol. 2004;45(3):297-303. Excluded: no original data, duplicate data. [pmid: 15036674].
Shiba M, Takatera H, Fujii T, et al. Intraarterial chemotherapy with bladder preservation in patients with invasive bladder carcinoma. Hinyokika Kiyo. 2004;50(1):15-9. Excluded: not English language, but possibly relevant. [pmid: 15032009].
Shipley WU, Winter KA, Kaufman DS, et al. Phase III trial of neoadjuvant chemotherapy in patients with invasive bladder cancer treated with selective bladder preservation by combined radiation therapy and chemotherapy: initial results of Radiation Therapy Oncology Group 89-03. J Clin Oncol. 1998;16(11):3576-83. Excluded: wrong comparator. [pmid: 9817278].
Shipley WU, Zietman AL, Kaufman DS, et al. Invasive bladder cancer: treatment strategies using transurethral surgery, chemotherapy and radiation therapy with selection for bladder conservation. Int J Radiat Oncol Biol Phys. 1997;39(4):937-43. Excluded: not a study. [pmid: 9369144].
Siefker-Radtke AO, Dinney CP, Shen Y, et al. A phase 2 clinical trial of sequential neoadjuvant chemotherapy with ifosfamide, doxorubicin, and gemcitabine followed by cisplatin, gemcitabine, and ifosfamide in locally advanced urothelial cancer: final results. Cancer. 2013;119(3):540-7. Excluded: wrong intervention. [pmid: 22914978].
Skinner DG, Daniels JR, Russell CA, et al. Adjuvant chemotherapy following cystectomy benefits patients with deeply invasive bladder cancer. Semin Urol. 1990;8(4):279-84. Excluded: wrong intervention. [pmid: 2284533].
Soga N, Arima K, Sugimura Y. Adjuvant methotrexate, vinblastine, adriamycin, and cisplatin chemotherapy has potential to prevent recurrence of bladder tumors after surgical removal of upper urinary tract transitional cell carcinoma. Int J Urol. 2008;15(9):800-3. Excluded: wrong population. [pmid: 18651862].
Sonpavde G, Goldman BH, Speights VO, et al. Quality of pathologic response and surgery correlate with survival for patients with completely resected bladder cancer after neoadjuvant chemotherapy. Cancer. 2009;115(18):4104-9. Excluded: wrong outcome. [pmid: 19517476].
Sonpavde G, Khan MM, Lerner SP, et al. Disease-free survival at 2 or 3 years correlates with 5-year overall survival of patients undergoing radical cystectomy for muscle invasive bladder cancer. J Urol. 2011;185(2):456-61. Excluded: wrong study design for Key Question. [pmid: 21167527].
Soukup V, Babjuk M, Bellmunt J, et al. Follow-up after surgical treatment of bladder cancer: a critical analysis of the literature. Eur Urol. 2012;62(2):290-302. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 22609313].
Splinter TA, Pavone-Macaluso M, Jacqmin D, et al. A European Organization for Research and Treatment of Cancer--Genitourinary Group phase 2 study of chemotherapy in stage T3-4N0-XM0 transitional cell cancer of the bladder: evaluation of clinical response. J Urol. 1992;148(6):1793-6. Excluded: wrong study design for Key Question. [pmid: 1433610].
Stadler WM, Lerner SP, Groshen S, et al. Phase III study of molecularly targeted adjuvant therapy in locally advanced urothelial cancer of the bladder based on p53 status. J Clin Oncol. 2011;29(25):3443-9. Excluded: wrong intervention. [pmid: 21810677].
Startsev VI, Karelin MI. Combined therapy for patients with invasive bladder cancer. Vopr Onkol. 2003;49(2):235-8. Excluded: not English language, but possibly relevant. [pmid: 12785212].
Startsev VY. The role of combined method in organ-sparing treatment of muscle-invasive bladder cancer recurrences. Arch Ital Urol Androl. 2002;74(2):54-6. Excluded: wrong comparator. [pmid: 12161935].
Stein JP. The role of lymphadenectomy in patients undergoing radical cystectomy for bladder cancer. Curr Oncol Rep. 2007;9(3):213-21. Excluded: not a study. [pmid: 17430693].
Stejskal D, Fiala RR. Evaluation of serum and urine clusterin as a potential tumor marker for urinary bladder cancer. Neoplasma. 2006;53(4):343-6. Excluded: wrong population. [pmid: 16830064].
Stejskal D, Humenanska V, Hanulova Z, et al. Evaluation of urine N1,N12-Diacetylspermine as potential tumor marker for urinary bladder cancer. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. 2006;150(2):235-7. Excluded: wrong population. [pmid: 17426784].
Sternberg CN. Perioperative chemotherapy in muscle-invasive bladder cancer to enhance survival and/or as a strategy for bladder preservation. Semin Oncol. 2007;34(2):122-8. Excluded: not a study. [pmid: 17382795].
Sternberg CN, Apolo AB. Everything old is new again! Neoadjuvant chemotherapy in the treatment of muscle-invasive bladder cancer. J Clin Oncol. 2014;32(18):1868-70. Excluded: no original data, duplicate data. [pmid: 24821880].
Sternberg CN, Pansadoro V, Calabro F, et al. Neo-adjuvant chemotherapy and bladder preservation in locally advanced transitional cell carcinoma of the bladder. Ann Oncol. 1999;10(11):1301-5. Excluded: wrong study design for Key Question. [pmid: 10631456].
Stewart AB, Mostafid H. Re: A single immediate postoperative instillation of chemotherapy decreases the risk of recurrence in patients with stage Ta T1 bladder cancer: a meta-analysis of published results of randomized clinical trials. J Urol. 2005;173(4):1433. author reply. Excluded: not a study. [pmid: 15758827].
Stockle M, Meyenburg W, Wellek S, et al. Adjuvant polychemotherapy of nonorgan-confined bladder cancer after radical cystectomy revisited: long-term results of a controlled prospective study and further clinical experience. J Urol. 1995;153(1):47-52. Excluded: wrong population. [pmid: 7966789].
Stockle M, Wellek S, Meyenburg W, et al. Radical cystectomy with or without adjuvant polychemotherapy for non-organ-confined transitional cell carcinoma of the urinary bladder: prognostic impact of lymph node involvement. Urology. 1996;48(6):868-75. Excluded: wrong population. [pmid: 8973669].
Studer UE, Bacchi M, Biedermann C, et al. Adjuvant cisplatin chemotherapy following cystectomy for bladder cancer: results of a prospective randomized trial. J Urol. 1994;152(1):81-4. Excluded: wrong intervention. [pmid: 8201695].
Sumiyoshi Y, Yano M, Yokota K, et al. Intra-arterial infusion chemotherapy in bladder cancer. Gan To Kagaku Ryoho. 1990;17(8 Pt 2):1697-700. Excluded: not English language, but possibly relevant. [pmid: 2389958].
Sun X, Hu J, Yang Q. Combined modality therapy following bladder conservation surgery for bladder cancers. Chin Med J. 2002;115(10):1548-51. Excluded: wrong comparator. [pmid: 12490108].
Svatek RS, Karam J, Karakiewicz PI, et al. Role of urinary cathepsin B and L in the detection of bladder urothelial cell carcinoma. J Urol. 2008;179(2):478-84. discussion 84. Excluded: wrong population. [pmid: 18076936].
Sylvester R, Sternberg C. The role of adjuvant combination chemotherapy after cystectomy in locally advanced bladder cancer: what we do not know and why. Ann Oncol. 2000;11(7):851-6. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 10997813].
Tanaka T, Miyazawa K, Tsukamoto T, et al. Pathobiology and chemoprevention of bladder cancer. Journal of Oncology. 2011. Excluded: not a study. [pmid: 21941546].
Tilki D, Brausi M, Colombo R, et al. Lymphadenectomy for bladder cancer at the time of radical cystectomy. Eur Urol. 2013;64(2):266-76. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 23648149].
Tsujii H, Akaza H, Ohtani M, et al. Preliminary results of bladder-preserving therapy with definitive radiotherapy and intraarterial infusion of chemotherapy. Strahlenther Onkol. 1994;170(9):531-7. Excluded: wrong comparator. [pmid: 7940124].
Tunio MA, Hashmi A, Qayyum A, et al. Whole-pelvis or bladder-only chemoradiation for lymph node-negative invasive bladder cancer: single-institution experience. Int J Radiat Oncol Biol Phys. 2012;82(3):e457-62. Excluded: wrong comparator. [pmid: 21945107].
Tunio MA, Hashmi A, Rafi M, et al. Bladder preservation by neoadjuvant chemotherapy followed by concurrent chemoradiation for muscle-invasive bladder cancer: experience at Sindh Institute of Urology & Transplantation (SIUT). JPMA J Pak Med Assoc. 2011;61(1):6-10. Excluded: wrong comparator. [pmid: 22368893].
Vale CL. Adjuvant chemotherapy for invasive bladder cancer (individual patient data). Cochrane Database Syst Rev. 2011;(4). PMID: No PMID. Excluded: systematic review or meta-analysis used as source document only to identify individual studies.
Van Allen EM, Mouw KW, Kim P, et al. Somatic ERCC2 mutations correlate with cisplatin sensitivity in muscle-invasive urothelial carcinoma. Cancer Discov. 2014;4(10):1140-53. Excluded: wrong comparator. [pmid: 25096233].
van der Steen-Banasik E, Ploeg M, Witjes JA, et al. Brachytherapy versus cystectomy in solitary bladder cancer: a case control, multicentre, East-Netherlands study. Radiother Oncol. 2009;93(2):352-7. Excluded: wrong population. [pmid: 19457565].
van Hemelrijck M, Thorstenson A, Smith P, et al. Risk of in-hospital complications after radical cystectomy for urinary bladder carcinoma: population-based follow-up study of 7608 patients. BJU Int. 2013;112(8):1113-20. Excluded: wrong comparator. [pmid: 23906011].
von der Masse H. Long-Term Survival Results of a Randomized Trial Comparing Germcitabine Plus Cisplatin, With Methotrexate, Vinblastine, Doxorubicin, Plus Cisplatin in Patients with Bladder Cancer. J Clin Oncol. 2005;23(21):4602-8. Excluded: wrong population. [pmid: 16034041].
Wallace DM, Bloom HJ. The management of deeply infiltrating (T3) bladder carcinoma: controlled trial of radical radiotherapy versus preoperative radiotherapy and radical cystectomy (first report). Br J Urol. 1976;48(7):587-94. Excluded: wrong study design for Key Question. [pmid: 797427].
Wallace DM, Raghavan D, Kelly KA, et al. Neo-adjuvant (pre-emptive) cisplatin therapy in invasive transitional cell carcinoma of the bladder. Br J Urol. 1991;67(6):608-15. Excluded: wrong intervention. [pmid: 2070206].
Walz J, Shariat SF, Suardi N, et al. Adjuvant chemotherapy for bladder cancer does not alter cancer-specific survival after cystectomy in a matched case-control study. BJU Int. 2008;101(11):1356-61. Excluded: wrong population. [pmid: 18454792].
Washino S, Hirai M, Terauchi F, et al. Intra-arterial chemotherapy for bladder preservation in patients with locally advanced bladder cancer. Nippon Hinyokika Gakkai Zasshi. 2009;100(3):486-94. Excluded: not English language, but possibly relevant. [pmid: 19348188].
Winquist E, Kirchner TS, Segal R, et al. Neoadjuvant chemotherapy for transitional cell carcinoma of the bladder: a systematic review and meta-analysis. J Urol. 2004;171(2 Pt 1):561-9. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 14713760].
Woolcott CG, Kolonel LN. Regarding measures of impact: Diabetes and urothelial cancer. Cancer Epidemiology. 2012;36(6):581. PMID: No PMID. Excluded: not a study.
Wright JL, Lin DW, Porter MP. The association between extent of lymphadenectomy and survival among patients with lymph node metastases undergoing radical cystectomy. Cancer. 2008;112(11):2401-8. Excluded: wrong population. [pmid: 18383515].
Yuh BE, Ruel N, Wilson TG, et al. Pooled analysis of clinical outcomes with neoadjuvant cisplatin and gemcitabine chemotherapy for muscle invasive bladder cancer. J Urol. 2013;189(5):1682-6. Excluded: systematic review or meta-analysis used as source document only to identify individual studies. [pmid: 23123547].
Zaid HB, Patel SG, Stimson CJ, et al. Trends in the utilization of neoadjuvant chemotherapy in muscle-invasive bladder cancer: results from the National Cancer Database. Urology. 2014;83(1):75-80. Excluded: wrong comparator. [pmid: 24231210].
Zapatero A, Martin de Vidales C, Arellano R, et al. Updated results of bladder-sparing trimodality approach for invasive bladder cancer. Urol. 2010;28(4):368-74. Excluded: wrong comparator. [pmid: 19362865].
Zapatero A, Martin De Vidales C, Arellano R, et al. Long-term results of two prospective bladder-sparing trimodality approaches for invasive bladder cancer: neoadjuvant chemotherapy and concurrent radio-chemotherapy. Urology. 2012;80(5):1056-62. Excluded: wrong comparato. [pmid: 22999456].