# PICOTS

Table B1 PICOTS

PICOTS | Include
Populations | - Patients with node-negative, non-metastatic muscle-invasive bladder cancer (stages T2, T3, T4a)
Interventions | - Bladder-preserving chemotherapy and/or radiation therapy [KQ 1, KQ 4]; - Partial cystectomy [KQ 1; KQ 4]; - Maximal TURBT [KQ 1; KQ 4]; - Regional lymph node excision in conjunction with cystectomy or partial cystectomy [KQ 2]; - Cystectomy plus Neoadjuvant and/or adjuvant chemotherapy [KQ 3; KQ 4]; - Include: Chemotherapy Regimens: carboplatin and gemcitabine; cisplatin and gemcitabine; “CMV” (cisplatin, methotrexate, and vinblastine) and “MVAC” (methotrexate, vinblastine, doxorubicin, and cisplatin); trials of other cisplatin-based combination regimens. Exclude: Trials that evaluate chemotherapy with a single agent.
Comparators | - Cystectomy alone [KQ 1; KQ 3; KQ 4]; - Cystectomy in combination with chemotherapy [KQ 1; KQ 4]; - Bladder-preserving chemotherapy, radiation therapy (external beam or interstitial radiation therapy), partial cystectomy, and/or maximal transurethral resection of bladder tumor [KQ 2]
Outcomes | - Mortality, disease-specific and all-cause (primary outcome) [KQ 1; KQ 2; KQ 3]; - Recurrence of bladder cancer [KQ 1; KQ 2; KQ 3]; - Progression or metastasis of bladder cancer [KQ 1; KQ 2; KQ 3]; - Quality of life [KQ 1; KQ 2; KQ 3]; - Functional status [KQ 1; KQ 2; KQ 3]; - Complications or adverse effects related to treatment [KQ 4]
Timing | - Any duration of followup
Setting | - Any settings
Study Design | - RCTs, cohort studies must be comparative; - Systematic reviews must evaluate quality of individual studies

CMV, cisplatin, methotrexate, and vinblastine; KQ=key question; MVAC, methotrexate, vinblastine, doxorubicin, and cisplatin; PICOTS=populations, interventions, comparators, outcomes, timing, setting; RCTs, randomized controlled trials; T2, tumor stage 2; T3, tumor stage 3; T4a, tumor stage 4a; TURBT, transurethral resection of bladder tumor.