# Abbreviations

Abbreviation: Term
AC: Adjuvant chemotherapy
AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
CMV: Cisplatin, methotrexate, and vinblastine
EPC: Evidence-based Practice Center
MVAC: Methotrexate, vinblastine, doxorubicin, and cisplatin
NAC: Neoadjuvant chemotherapy
PICOTS: Populations, interventions, comparators, outcomes, timing, and study designs
RCT: Randomized controlled trial
SOE: Strength of evidence
SRC: Scientific Resource Center
TEP: Technical Expert Panel
TURBT: Transurethral resection of bladder tumor
WHO: World Health Organization