# Results

## Results of Literature Searches

We identified 3266 nonduplicative titles or abstracts with potential relevance, with 920 proceeding to full text review (Figure 2). We excluded 844 studies at full text review and included 68 unique studies (76 publications) in the review. We present findings by intervention and outcome area where possible under each Key Question (KQ). Comparative studies and case series that provided harms or data on successful controlling of bleeding are also described in more detail in summary tables in each KQ. We tabulated success rates reported in studies of procedures and surgical approaches in which we could extract data on the effectiveness of the intervention as the initial second-line intervention (i.e., first intervention following routine conservative management) and defined success as controlling of bleeding without need for additional procedures or surgeries.

Figure 2 Disposition of studies identified for this review

Abbreviations: KQ = Key Question; n = number.

^a^ Numbers next to each KQ indicate number of unique studies addressing the question. Studies could address more than one KQ.

^b^ Numbers do not tally as studies could be excluded for multiple reasons.

This figure outlines the flow of studies identified for the review. We identified and screened 3266 titles and abstracts and excluded 2346. We assessed the full-text of 920 studies and excluded 844, primarily due to study design and lack of outcomes of interest. We included 76 publications, comprising 68 unique studies, in the review. Fifty-one studies addressed Key Question 1; no studies addressed Key Question 2; 50 addressed Key Question 3; two addressed Key Question 4; and nine addressed Key Question 5.

We integrate discussion of subquestions within that for each KQ because there was not adequate distinction in the literature to address them separately. Harms of interventions for postpartum hemorrhage (PPH) are described under KQ3. Transfusion as an intervention for anemia following stabilization of PPH is addressed under KQ4, and transfusion as an intervention to manage ongoing PPH is described under KQ1. We also briefly summarize the strength of the evidence (SOE) for interventions and key outcomes in each Key Points section and describe SOE more fully in the Discussion section.

## Description of Included Studies

The 68 unique studies included in the review comprise four randomized controlled trials (RCTs), two prospective and 14 retrospective cohort studies, 10 pre-post studies (defined as studies that compare PPH management and/or outcomes before and after an intervention, such as introduction of a new protocol), four case-control studies, and 34 case series. Most studies were conducted in Europe (n = 33), and 18 were conducted in the United States or Canada, 13 in Asia, and three in Australia or New Zealand and one in Argentina (Table 5). No studies were of good quality for effectiveness outcomes. We considered 23 studies as fair quality for effectiveness outcomes and 38 as poor quality (including case series, which we considered poor quality by default). Seven studies (one retrospective cohort, two case-control, four case series) provided only harms data.60-66 Among the 50 studies reporting harms of interventions for management of PPH, we considered 11 as good quality for harms reporting and the remainder as poor quality.

Table 5 Characteristics of included studies addressing effectiveness and harms

Characteristic | RCTs^a^ | Prospective Cohort Studies | Retrospective Cohort Studies | Pre-Post Studies | Case-Control Studies | Population-Based Case Series | Retrospective Case Series | Total Literature^b^
Intervention
Pharmacologic | 1 | 1 | 5 | 0 | 1 | 5 | 0 | 13
Transfusion for supportive management of ongoing PPH | 0 | 0 | 3 | 1 | 0 | 1 | 2 | 7
Uterine balloon tamponade | 0 | 0 | 1 | 1 | 0 | 1 | 2 | 5
Uterine artery embolization | 0 | 2 | 5 | 0 | 1 | 0 | 12 | 20
Uterine and other pelvic artery ligation | 0 | 1 | 1 | 0 | 0 | 0 | 3 | 5
Uterine compression sutures | 0 | 1 | 1 | 0 | 2 | 0 | 1 | 5
Hysterectomy | 0 | 1 | 2 | 0 | 0 | 4 | 3 | 10
Combined interventions | 0 | 0 | 2 | 0 | 0 | 0 | 2 | 4
Interventions for anemia once PPH is stabilized | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2
Systems-level interventions | 1 | 0 | 0 | 8 | 0 | 0 | 0 | 9
Population Characteristics
Study population
U.S./Canada | 0 | 0 | 3 | 4 | 1 | 4 | 6 | 18
Europe | 3 | 2 | 6 | 6 | 2 | 4 | 10 | 33
Asia | 0 | 0 | 5 | 0 | 1 | 0 | 7 | 13
Other | 1 | 0 | 0 | 0 | 0 | 2 | 1 | 4
Total N participants (where reported) | 737 | 477 | 142309^c^ | 5726^d^ | 359 | 3757 | 3049 | 156414

Abbreviations: PPH = postpartum hemorrhage; RCT= randomized controlled trial; rFVIIa = recombinant activated factor VIIa

a Does not include N participants in one systems-level RCT.37

b Total across interventions exceeds 68 as some interventions were addressed in multiple studies.

c One cohort study using data from a utilization database includes 139,617 women exposed to methylergonovine during hospitalization for birth.

d Does not include N participants in 2 pre-post studies.67, 68

While a number of studies were classified as prospective or retrospective studies using our study classification algorithm (Appendix G), few cohort studies provided comparative analyses, and many were confounded by indication in that women who received interventions such as massive transfusion or hysterectomy likely had more severe cases of PPH. Additionally, initial management of PPH using first-line interventions such as uterotonics and uterine massage differed across studies and across women as each study generally included a number of patients transferred from other hospitals. Thus, populations were heterogeneous in terms of severity and level of stabilization prior to second-line interventions. Given the lack of data from randomized or controlled studies of PPH management, we present data from cohort studies and case series and note potential confounding.

## KQ1 Effectiveness of Interventions for Management of PPH

### Studies of Medical Interventions

#### Pharmacologic Interventions

##### Key Points

- Six small, single studies of fair and poor quality addressed various pharmacologic interventions not including recombinant activated factor VIIa (rFVIIa) with mixed results.
- In one fair quality retrospective cohort study assessing oxytocin and other uterotonics, bleeding was controlled with uterotonic medications without need for further procedures/surgeries in 45 of 91 women (49% success rate).
- In one RCT of tranexamic acid (TXA), blood loss, progression to severe PPH, and need for transfusion were reduced in the TXA arm compared with the non-TXA control arm, but need for further interventions did not differ.
- Need for transfusion or further interventions did not differ in a retrospective cohort study comparing misoprostol and methylergonovine maleate.
- In a small, population-based case series, sulprostone stopped bleeding in 83 percent of participants without need for further intervention.
- Carboprost tromethamine controlled bleeding in 88 percent of women in a small, population-based case series.
- Blood loss and transfusion in women with PPH and disseminated intravascular coagulation (DIC) did not differ in a retrospective study comparing women who received recombinant thrombomodulin with matched controls who did not receive the drug.
- Six small studies of rFVIIa also had mixed results. In one retrospective cohort study, women in the rFVIIa group required more blood products and had greater blood loss than women not receiving the treatment. Differences in change in prothrombin time were not significant between women treated with rFVIIa and those who were not in a case-control study. rFVIIa used as a second-line intervention controlled bleeding without need for further procedures or surgeries in 27 to 31 percent of women in one cohort study, a rate that was similar to treatment with other second-line interventions in that study. In registry studies bleeding was considered improved after one or multiple doses of rFVIIa in 64 to 80 percent of women after the final dose. No study included more than 177 women receiving rFVIIa.
- Strength of the evidence is insufficient for all outcomes of oxytocin and other uterotonics, misoprostol, tranexamic acid, carboprost tromethamine, thrombomodulin, and rFVIIa for PPH management due to the study sizes and lack of studies addressing each agent.

##### Overview of the Literature

Twelve studies addressed pharmacologic agents for the treatment of PPH:69-80one RCT,69 five cohort studies,72, 73, 77-79 one case-control study,74 and five population-based case series or registry studies.70, 71, 75, 76, 80 Studies were conducted in France,69, 70 the United States,71, 78 Finland,73 Ireland,74 Japan,72 the United Kingdom,77 Hong Kong,79and Australia and New Zealand.76, 80 These studies from Australia and New Zealand report on data collected from one registry over differing time periods, but because the overlap in data is not clear, we have presented results from both studies but note that the populations likely overlap to some extent. Another registry study reported data from various northern European countries.75

Six of these studies (two cohort studies,73, 77one case-control,74 and three registry studies75, 76, 80) addressed rFVIIa. Atony accounted for many of the cases of PPH in studies reporting etiology (range = 18 to 56% of cases).

Other agents were each addressed in one study: tranexamic acid (one RCT, n = 144),69 oxytocin and other (unspecified) uterotonics (one retrospective cohort, n=49),79 misoprostol compared with methylergonovine maleate (one retrospective cohort, n = 58),78 sulprostone (one population-based case series, n = 1,370),70 carboprost tromethamine (one registry study, n = 236),71 and recombinant human soluble thrombomodulin (rTM; one cohort study, n = 36).72 Two studies included only women with atonic PPH,70, 71 and, where reported, atony accounted for 27 to 65 percent of cases. We rated the RCT as poor quality for all effectiveness outcomes and the five cohort and case-control studies as fair quality. The case series were considered poor quality by default. Table 6 provides an overview of key outcomes in studies with comparison groups. We note that one additional cohort study reported only harms of methylergonovine maleate and is discussed in KQ3.^60^

Table 6 Key outcomes in comparative studies of pharmacologic agents

Author, Year Country Groups (n) Quality | Age, Years Parity | Key Outcomes
Chan et al. 2013^79^ Hong Kong G1: Oxytocin only (33) G1a: Oxytocin ± other uterotonics (16) G2: Uterine compression sutures (21) G3: Embolization alone (4) G4: Uterine balloon tamponade (11) G5: Two second-line therapies (6) Quality: Fair | Age, mean ± SD G1-G5: 33.3±4.6 Parity, median G1-G5: 0 (range: 0-3) | - 1/33 women receiving oxytocin alone required subsequent hysterectomy; - 3/16 receiving oxytocin plus other uterotonics required subsequent hysterectomy; - Estimated blood loss among all 49 women=1.8 liters (range 1.5-15); median 3 units (range 0-39) red blood cells transfused; - Median LOS=6 days (range: 3-29); 24.5% required ICU admission
Ducloy-Bouthers et al. 2011^69^ France G1: Tranexamic acid (78) G2: Control (74) Quality: Poor/High risk of bias for all outcomes | Age, mean ± SD G1: 29 ± 4 G2: 28.5 ± 5 Primipara, n (%) G1: 46 (64) G2: 50 (69) | - Blood loss for G1 was significantly lower vs. G2 (G1: median 170 mL vs. G2: median 221 mL); - Bleeding duration was shorter for G1: n = 28 (36%) with persistent bleeding after 6 hours vs. G2: n = 37 (50%), p = 0.03
Baruah et al., 2008^78^ US G1: Misoprostol (40) G2: Methylergonovine maleate (18) Quality: Fair | Age, n (%) Under 20 G1: 6 (15) G2:1(5.5) 20-29 G1: 14 (35) G2: 9 (50) 30-39 G1: 19 (47.5) G2: 8 (44.4) ≥ 40 G1:1(2.5) G2: 0 Primipara, n (%) G1: 14 (35) G2: 6 (33) | - 5 women in G1 needed transfusion and none in G2, p = 0.11; - Need for third line medical or surgical therapy was comparable G1: 27 (67.5%) vs, G2: 14 (77.8%); - One woman in each group had hysterectomy
Sugawara et al. 2013^72^ Japan G1: Recombinant thrombomodulin (10) G2: No thrombomodulin (26) Quality: Fair | Age, Mean ± SEM G1: 33.2 ± 1.7 G2: 31.7 ± 1.1 Parity NR | - Participants did not differ at baseline on blood loss, transfusions, obstetrical complications; shock index (PPH severity) significantly greater in G1 vs. G2 (p < .05); - G1 received 380 U/kg/day thrombomodulin for 3.0 ± 0.6 days + blood products as needed; incidence of undefined bleeding symptoms was not significantly less in G1 vs. G2 (22.2% vs. 42.3% at day 1 and 11.1% vs. 19.2% at day 2, p = .28); - No adverse events associated with either group were reported

Abbreviations: G = group; ICU = intensive care unit; LOS = length of stay; n = number; NR = not reported; SD = standard deviation; SEM = standard error of the mean

##### Detailed Analysis

###### Oxytocin and Other Uterotonics

One fair quality retrospective cohort study reported on 91 women (mean age=33.3±4.6, median parity=0, range 0-3) undergoing treatment for massive PPH (defined as estimated blood loss of ≥1500ml within 24 hours after birth).79 PPH was due to atony in 41.8 percent of cases. Women were initially treated with intravenous oxytocin (n=33 receiving oxytocin only) and other uterotonic agents (n=16 receiving oxytocin plus other agents). Other uterotonics used could have included carboprost, rectal misoprostol, and sulprostone, though the study does not specify which agents were actually administered. Among the 49 women who received oxytocin and other uterotonics only (i.e., PPH resolved without need for additional procedures or surgeries), atony accounted for 26.5 percent of cases, and “other causes” (uterine rupture, coagulopathy, retained placenta) accounted for 42.9 percent. Causes of PPH differed significantly among women receiving uterotonics only and those requiring second-line therapies (n=42) to control bleeding (p<.001), in whom atony and placenta previa or accreta accounted for most cases. Among the 33 women treated with oxytocin only, bleeding was controlled in 32, and one required subsequent hysterectomy (97% success rate). Among those 16 treated with oxytocin plus other uterotonics, bleeding was controlled in 13, and three required hysterectomy (81% success). Thus, bleeding was controlled without need for further procedures/surgeries in 45 of 91 women receiving oxytocin alone or with other uterotonics (49% success rate). Women receiving only conservative management had a median length of stay of 6 days (range 3-29), and 12 (24.5%) were admitted to the ICU. Length of stay and ICU admissions appear to be similar among the 42 women who received second-line therapies (length of stay ranging from 4 to 54 days, number admitted to ICU ranging from 3 to 8 women), but the study does not report analytic comparisons.

###### Tranexamic Acid

A single RCT (rated poor quality for all efficacy outcomes) with 144 participants reported reduction of blood loss in women with PPH treated with high-dose TXA (n = 72).69 The RCT was an open-label trial at multiple centers in France and included women with PPH > 800 mL following vaginal birth. All women received packed red blood cells (PRBCs) and colloids as ordered by clinicians. The use of additional procoagulant treatments was permitted only in cases involving intractable bleeding. The treatment group received TXA in a loading dose of 4 g over 1 hour, then infusion of 1 g/hour over 6 hours. Women in the control group did not receive TXA, and groups did not differ on maternal or obstetric characteristics at baseline. The primary outcome was efficacy of TXA in the reduction of blood loss as measured using collection pouches. The volume of blood loss between enrollment and 6 hours later was significantly lower in the TXA group (median = 173 mL; first to third quartiles, 59 to 377) than in the control group (median = 221 mL; first to third quartiles 105 to 564, p = 0.041).

Secondary outcomes included PPH duration, anemia, transfusion, and the need for invasive interventions. In the TXA group, bleeding duration was shorter and progression to severe PPH and PRBC transfusion was less frequent than in the control group (p < 0.03). PPH stopped after only uterotonics and PRBC transfusion in 93 percent of the women who received TXA versus 79 percent of the women in the control group (p = 0.016). There was no significant difference between the groups in the ratio of invasive interventions performed.

###### Misoprostol Versus Methylergonovine Maleate

A fair quality retrospective cohort study compared intramuscular methylergonovine maleate versus rectal misoprostol for patients who had a clinical diagnosis of PPH and were treated between 2000 and 2005.^78^ Inclusion criteria were gestational age at birth of 37 to 42 weeks, singleton pregnancy, a “clinical diagnosis of PPH” in the medical record, and the patient “required something more than standard oxytocin.” Fifty-eight records were included for review. Forty patients received misoprostol, and 18 received methylergonovine maleate. The study reported no differences between the groups in age, gestational age, or type of birth. There were no differences in the need for blood transfusion, “third-level” medical treatment, or surgical interventions. However, the number of participants was small; therefore, the apparent lack of difference in outcomes could be due to Type II error. Furthermore, the assignment to intervention was by provider choice, which introduced selection bias.

###### Sulprostone

One retrospective population-based case series reports outcomes following sulprostone administration in women with PPH (defined as blood loss of ≥ 500mL of blood loss necessitating manual placenta removal and/or uterine examination) who were treated at one of 106 French maternity hospitals.70 Outcomes related to a multifaceted educational intervention conducted in these hospitals with the aim of lowering PPH rates are described under KQ5.^37, 81^ Among the 9,365 cases of PPH occurring in the study period (2004-2006), 4,038 women had clinically assessed atonic PPH, of whom 1370 received sulprostone (995 after vaginal birth, 375 after cesarean birth). Women received additional treatments including uterine cavity or genital tract examination (n = 1634), oxytocin (n = 1297), and vascular volume expansion (n = 653). Among women who received sulprostone, bleeding stopped without the need for additional procedures or surgeries in 83.4 percent. Need for embolization, surgery, or hysterectomy was more common after cesarean birth compared with vaginal birth (26.1% vs. 13%, p < .01).

###### Carboprost Tromethamine

A retrospective population-based case series reviewed carboprost tromethamine for PPH in 236 women (237cases of PPH) at 12 U.S. obstetrics units.71 The women (mean age 25.3 ± 5.7 years) were given either 125 micrograms or 250 micrograms of carboprost tromethamine (range one to five doses), preceded in 96 percent of cases by oxytocics. The decision to administer carboprost tromethamine was made at the discretion of independent practitioners. Hemorrhage was controlled in 208 of 237 cases (87.8%). In 17 cases, PPH was controlled with additional oxytocics. Second-line treatments in the 12 women in which carboprost tromethamine failed included nine arterial ligations (followed by hysterectomy in four cases) and immediate hysterectomy in three women. Twenty-seven percent of women received transfusions, but the timing of transfusion (pre- or post-carboprost tromethamine) is not clear.

###### Recombinant Human Soluble ThromboModulin (rTM)

A fair quality retrospective cohort of the use of rTM in 10 consecutive patients with severe PPH complicated by DIC reported no significant difference in total blood loss or transfusion requirements between those treated with rTM and matched controls.72 All 36 patients were admitted to a single tertiary center. The primary outcome was the efficacy of recombinant human soluble thrombomodulin (rTM) in disseminated intravascular coagulation (DIC) associated with severe PPH. Ten consecutive patients with DIC associated with severe PPH were treated with rTM. Twenty-six patients with DIC associated with severe PPH were chosen for comparison. The baseline characteristics of the control group were described as “similar” to the treated group. On day 2 following treatment, D-dimer decrease from baseline was significantly greater in the rTM group compared with the control group (p<.05). The intervention is targeted for DIC, and is not a treatment for PPH without the presence of DIC.

###### Recombinant Activated Factor VIIa (rFVIIa)

A fair quality retrospective cohort study in Finland compared the effectiveness of rFVIIa versus standard management (no rFVIIa) among women with PPH (defined as loss of 1.5 times patient's blood volume).73 Eligible participants were identified using medical records at a single tertiary referral hospital. Of the 48 women identified, 26 were treated with rFVIIa and 22 were not. There were no statistically significant differences in age, body mass index (BMI), obstetrical course (cause of PPH, mode of birth, length of hospital stay after birth), lowest hemoglobin, or lowest platelet count between the two groups. Activated partial thromboplastin time, liters of total bleeding (11.3 vs. 8.0, p = 0.005), units of RBC (20 vs. 13, p = 0.003), units of platelets (23 vs. 14, p = 0.014), and number with fibrinogen concentrate transfused (15 vs. 5, p = 0.014) were significantly greater among women treated with rFVIIa than among untreated women. There was no statistical comparison of maternal or fetal outcomes between the groups.

A retrospective case-control study in Ireland compared the effectiveness of rFVIIa in reversing coagulopathy associated with massive PPH versus standard management (no rFVIIa) between 2003 and 2006.^74^ Twenty-eight women with massive PPH (defined as transfusion of > 5 units of PRBC in 24 hours) were identified using medical records at a single Irish hospital. Of these, six women who were treated with rFVIIa and had a prolonged prothrombin time (PT) were matched with six women with the largest number of PRBC units transfused and prolonged PTs who were not treated with rFVIIa. There were no statistically significant differences in age, obstetrical factors (gestation, parity, cause of massive PPH, or number of hysterectomies), or coagulopathy factors (PRBC, platelets, fresh frozen plasma [FFP], or cryoprecipitate transfused, or worst PT or fibrinogen levels) between the two groups. The PT improved with management in both groups, and there was no significant difference in the magnitude or absolute value of improvement (p = 0.9). There was no statistical comparison of maternal or fetal outcomes between the groups.

One fair quality cohort study used data from the U.K. Obstetric Surveillance System (UKOSS). The UKOSS includes all hospitals with a consultant-led maternity unit in the United Kingdome. Clinicians in these hospitals reported data on PPH cases and treatment to the UKOSS using case notification cards completed monthly. UKOSS personnel also followed up with hospitals to identify potential missed cases. In this study, 31 women received rFVIIa as the initial second-line therapy after failure of conservative PPH management approaches. Sixteen received rFVIIa after uterotonic failure, and 15 received it after failure of uterotonics plus intrauterine balloon tamponade (either with balloon or packing). Among the 16 who had received only uterotonics plus rFVIIa, 11 had successful cessation of bleeding. One required compression sutures, two had ligations, one had interventional radiology, and seven required hysterectomy to control bleeding. Thus, the success rate (control of bleeding without further procedures or surgeries) for rFVIIa was 31 percent. Among the 15 who had rFVIIa after intrauterine tamponade with balloon or packing plus uterotonics, seven required hysterectomy while interventional radiology controlled bleeding after rFVIIa in four (27% success rate for rFVIIa plus uterine tamponade).77

Three registry studies also assessed use of rFVIIa. A voluntary registry study described outcomes of treatment of PPH with rFVIIa in nine Northern European countries.75 Eligible women (128 total identified, 108 included in the analysis) were identified differently in each country, with most identified by physicians or pharmacists who responded to requests for information about use of rFVIIa for treatment of PPH. In Finland and the Netherlands, information was collected for national surveys prior to initiation of this study, and those data were provided to the study group. Information on study endpoints was gathered retrospectively via standardized surveys completed by local practitioners in some instances and via national survey data in others. The registry gathered information on hematologic parameters after the use of rFVIIa as the primary treatment for PPH and as secondary prophylaxis if other interventions were used prior to rFVIIa. Clinicians noted improvements in bleeding after a single dose in 80 percent of the 92 women receiving rFVIIa to treat PPH and in 75 percent of the 16 women receiving it as secondary prophylaxis. Clinicians judged rFVIIa as failing to control bleeding in 15 cases overall (13.8%) Hemoglobin increased in 51 percent of cases in which bleeding was reduced after rFVIIa and showed no significant change in 32 percent of cases. Hemoglobin levels dropped post-administration in 17 percent of cases.

Two comprehensive registry studies were performed to describe outcomes of off-label use of rFVIIa for treatment of PPH in Australia and New Zealand.76, 80 Cases were identified between 2002 and 2008 from the Australian and New Zealand Haemostasis Registry (developed using unrestricted educational grant funds from Novo Nordisk Pharmaceuticals, the maker of rFVIIa), representing 38 hospitals in those countries. Data were collected via standardized data forms from 105 case medical records and treating clinicians of women with acute obstetric hemorrhage who received rFVIIa. Overall, bleeding stopped or decreased in 76 percent of women. Most (78%) women received a single dose of rFVIIa, and 64 percent of these women had decrease or cessation of bleeding. Median dose of rFVIIa was 92 micrograms/kg (range 9 to 139). Most women (76%) required < 6 units PRBC transfusion after receiving rFVIIa, and 13 women (21%) required hysterectomy after rFVIIa failed to control bleeding.

In the second registry study, which includes some of the same women in study summarized above, cases with off-label use of rFVIIa (non-hemophilia indications) were identified at 96 hospitals between 2000 and 2009 in the Australian and New Zealand Haemostasis Registry.80 The registry included 95 percent of off-license use of rFVIIa during that time frame. Of 3,446 cases of off-label rFVIIa use identified, 177 were obstetric cases from 175 women with PPH. Data were collected both retrospectively (2000-2005) and prospectively (2005-2009) by trained data collectors, and were validated by central registry staff. A single dose of rFVIIa was used in 134 (76%) of women, and bleeding stopped or decreased in 99 (56%) of women after a single dose, and 114 (64%) of women after the final dose was given. Table 7 outlines key outcomes in comparative studies.

Table 7 Key outcomes in comparative studies of rFVIIa

Author, Year Country Groups (n) Quality | Age Parity | Key Outcomes
Ahonen et al., 2007^73^ Finland G1: rFVIIa (26) G2: control (22) Quality: Fair | Age, mean ± SD G1: 33 ± 4 G2: 35 ± 4 Nulliparous, n (%): G1:.12 (46) G1: 12 (54.5) | - Response to rFVIIa was considered good (n = 17, 65%), moderate (n = 3, 12%), and poor (n = 6, 23%); - Blood loss (liters) was significantly greater in G1 (mean 11.3 ± 4.5) vs. G2 (mean 8.0 ± 3.1)
McMorrow et al., 2008^74^ Ireland G1: rFVIIa (6) G2: control (6) Quality: Fair | Age, mean ± SD G1: 34 ± 2.8 G2: 31 ± 4.6 Parity, mean ± SD: G1: 2 ± 0.5 G1: 1 ± 0.75 | - Prothrombin time improved in both groups with no significant differences between the groups (p = 0.09); - Women in both groups received uterotonics (oxytocin, ergometrine, misoprostol, carboprost tromethamine), and uterine massage; - The number of hysterectomies performed was comparable in G1: 50% and G2: 67%
Kayem et al. 2011^77, 82^ UK G1: Uterine compression sutures (199) G2: Pelvic vessel ligation (20) G3: Interventional radiology (embolization, arterial balloon) (22) G4: rFVIIa (31) Quality: Fair | Age < 35, n (%) G1: 128 (64) G2: 12 (60) G3: 12 (55) G4: 21 (68) > 35, n (%) G1: 71 (36) G2: 8 (40) G3: 10 (45) G4: 10 (32) Nulliparous, n (%) G1: 92 (46) G2: 3 (15) G3: 6 (27) G4: 9 (29) | - Among all women receiving these second-line therapies, 205 had prior uterotonic therapy (oxytocin, ergometrine, carboprost tromethamine, misoprostol) alone, 67 had prior uterotonics and intrauterine tamponade; - rFVIIa was successful in controlling bleeding in 5/16 women who received only uterotonics and in 4/15 who had uterotonics and tamponade as a first-line therapy; - 14 women who received rFVIIa ultimately required hysterectomy

Abbreviations: G = group; n = number; rFVIIa = recombinant activated factor VIIa; SD = standard deviation

#### Studies of Other Medical Interventions

##### Transfusion for Supportive Management of Ongoing PPH

###### Key Points

- No good quality studies addressed transfusion for supportive management of PPH.
- In one retrospective cohort study, women receiving combination blood products compared with whole blood or PRBC only for supportive management of PPH had a greater level of transfusion, greater likelihood of intensive care unit (ICU) stay, and greater risk of adverse outcomes.
- Estimated blood loss, blood products transfused, and mean length of stay did not differ between groups in a retrospective cohort study comparing outcomes following cryoprecipitate or fibrinogen transfusion for supportive management of PPH. In a pre-post study, use of blood products was reduced after the introduction of fibrinogen.
- Strength of the evidence for outcomes related to transfusion for supportive management of PPH is insufficient. While there were three fair quality studies of transfusion for this purpose, two of these were so confounded that we could not confidently ascertain their outcomes.

###### Overview of the Literature

Three fair quality retrospective cohort studies and one poor quality pre-post study addressed transfusion as a therapy for management of PPH. Studies that address transfusion as an intervention for anemia once PPH is stabilized are summarized under KQ4. Transfusion in these studies was evaluated as a method of supportive management of the complications of PPH (e.g. coagulopathy, anemia, hypovolemia), rather than to reverse the underlying cause of PPH. Cohort studies were conducted in the United States,83 Ireland,84 and Korea85 and included a total of 1,700 women. The pre-post study was conducted in the UK and included 93 women. Causes of PPH, where reported, included atony (range = 2.5 to 38%), placental abruption or placenta previa (8-17%), chorioamnionitis (21%), and placenta accreta (14%). Studies assessed different aspects of transfusion for supportive management of PPH: whole blood vs. PRBC vs. a combination of products,83 massive transfusion vs. no massive transfusion,85 cryoprecipitate vs. fibrinogen concentrate,84 and use of fresh frozen plasma vs. fibrinogen concentrate. 86 One additional Canadian case series,63one French case series,61 and one case series from Italy65 reported only on harms of transfusion and are described in KQ3.

###### Detailed Analysis

A fair quality, single-center, retrospective cohort study conducted in the United States compared complication rates between whole blood transfusion, PRBC transfusion alone, and combination blood product transfusion for supportive management of PPH.83 Eligible participants with PPH (defined as hypovolemia sufficient to provoke hemodynamic instability) were identified using a database of obstetric and neonatal outcomes. Of 1,540 women identified, 659 received whole blood transfusion, 593 received PRBC only, and 288 received a combination of blood products. There were no statistically significant differences between groups in age, race, or parity, but women in the combination blood product group were more likely to have perineal trauma, placenta previa or abruption, and hysterectomy than the other groups. Mean units of blood product transfused was significantly greater among women getting a combination of blood products when compared with women receiving whole blood or PRBC only (5.5, 2.2, and. 2.3 units in the combination blood products, whole blood, and PRBC groups, respectively, p < 0.001). Women in the combination transfusion group were also significantly more likely to be transferred to the ICU (23%, 4%, and 7% in the combination blood products, whole blood, and PRBC alone groups, respectively, p < 0.05) and to die (2%, 0%, and 1% in the combination blood products, whole blood, and PRBC alone groups, respectively, p = 0.03) than women in the other two groups.

Another fair quality, single-center, retrospective cohort study used electronic medical records at a Korean academic hospital to determine whether patients with an elevated shock index at the time of presentation with PPH would be more likely to require massive transfusion.85 Women with PPH (defined as blood loss ≥ 500 mL) were identified as part of the massive transfusion group (defined as receiving transfusion of ≥ 10 units PRBC within 24 hours of birth, n=26) or the non-massive transfusion group (n=100). Groups did not differ in terms of age, parity, mode of birth, bleeding time. Significantly fewer women in the massive transfusion group had an alert mental status (18 vs. 95, p < 0.01) and underwent embolization (22 vs. 36, p < 0.01), and significantly more women in this group required ICU stay (11 vs. 5, p < 0.01) and died (3 vs. 0, p < 0.01). Additionally the median systolic and diastolic blood pressures and hemoglobin levels were significantly lower (5.9 vs. 9.5, p < 0.01), and the median shock index (1.3 vs. 0.8, p < 0.01) and length of hospital stay (4.0 vs. 2.0, p < 0.01) were significantly higher in the massive transfusion group than in the non-massive transfusion group. Transfusion requirements were significantly higher in the first 24 hours and during the hospitalization among the massive transfusion group than the non-massive transfusion group (18.0 units and 3.0 units in the first 24 hours, respectively, and 20.0 units and 4.0 units during the hospitalization, respectively). These finding are confounded by indication as the massive transfusion group was presumably experiencing more severe PPH given their lower median hemoglobin and lower median systolic and diastolic blood pressures than the non-massive transfusion group.

A fair quality, single-center, retrospective cohort study from Ireland compared the effectiveness of transfusion with cryoprecipitate (n = 14) versus fibrinogen concentrate (n = 20) for supportive management of PPH.84 Women were identified for inclusion in a major obstetric hemorrhage database if they experienced PPH (defined as blood loss of ≥ 2.5 L, transfusion of ≥ 5 units PRBC, or treatment of a coagulopathy in the acute event). Eligible participants from the database were women treated with either cryoprecipitate or fibrinogen concentrate between 2009 and 2011. There were no statistically significant differences between groups in age, race, BMI, parity, gestation at birth, birth weight, or cause of PPH, but women in the cryoprecipitate group were more likely have previous cesarean birth. There was no statistically significant difference between groups in mean estimated blood loss; number of units of PRBC, Octaplas/fresh frozen plasma, or platelets transfused; medical and surgical treatments administered; and mean length of hospital stay.

Finally, one poor quality pre-post study from the United Kingdom compared the effectiveness of fibrinogen concentrate (n=51) versus fresh frozen plasma (n=42) for management of PPH-associated coagulopathy.86 Eligible participants were identified within a single hospital if they had major obstetric blood loss (defined as > 1500 mL) associated with coagulopathy between April 2011 and June 2013, with participants treated between April 2011 and March 2012 receiving treatment with a major obstetric hemorrhage algorithm that included fresh frozen plasma, and participants included from July 2012 through June 2013 receiving treatment with fibrinogen concentrate. Women treated with fibrinogen concentrate received significantly fewer total blood components (3.0 vs 8.0, for the fibrinogen concentrate group vs. the plasma group, p= 0.0004), pooled bags of cryoprecipitate (numbers not reported), total quantity of fibrinogen (0 vs. 3.2, for the fibrinogen concentrate group vs. the fresh frozen plasma group, p= 0.0005), and doses of platelets (numbers not reported). Units of red blood cells given to the two groups did not differ significantly, nor did ICU admission, transfusion-related acute lung injury (n=0 in both periods), or hysterectomy. There was a significantly higher rate of transfusion-associated circulatory overload in the fresh frozen plasma group (p=.04). Table 8 outlines key outcomes.

Table 8 Key outcomes in comparative studies of transfusion for supportive management of PPH

Author, Year Country Groups (n) Quality | Age, Years Parity | Key Outcomes
Alexander et al., 2009^83^ US Groups: G1: Whole blood only (659) G2: PRBC only (593) G3: Combinations of blood products (208) Quality: Fair | Age, year, n (%): 17 or less G1: 54 (8) G2: 39 (7) G3: 28 (10) 35 or older G1: 66 (10) G2: 54 (9) G3: 34 (12) Nulliparous, n (%) G1: 333 (51) G2: 306 (52) G3: 135 (47) | - Mean units of blood transfused was 2.2 units for G1, 2.3 units for G2, and 5.5 units for G3 (p < 0.001); - G3 more likely than G1 and G2 to be transferred to the ICU (23%, 4%, and 7%, respectively, p < 0.05) and to die (2%, 0%, and 1%, respectively, p = 0.03)
Sohn et al. 2013^85^ Korea G1: Massive transfusion requiring 10 or more units of PRBCs (26) G2: Received < 10 units PRBCs (100) Quality: Fair | Age, median (IQR range) G1: 31 (29.8-34.5) G2: 31 (29-34) Primiparous, n (%) G1: 17 (65.4) G2: 56 (56) Multiparous, n (%) G1: 9 (34.6) G2: 44 (44) | - Women in G1 had greater length of stay and need for ICU care compared with G2 (p < 0.01); - Findings confounded by indication
Ahmed et al., 2012^84^ Ireland G1: Cryoprecipitate (14) G2: Fibrinogen (20) Quality: Fair | Age, mean G1: 32.8 G2: 31.0 Nulliparous, n (%) G1: 6 (43) G2: 6 (30) | - Cryoprecipitate was used prior to July 2009 and then replaced with fibrinogen; - Hypofibrinogenemia was resolved with both treatments; - The two groups had comparable hemoglobin, hematocrit, and platelet counts
Mallaiah et al., 2014^86^ United Kingdom G1: Fresh frozen plasma (42) G2: Fibrinogen concentrate (51) Quality: Poor | Age NR Parity NR | - FFP used in massive PPH algorithm prior to June 2012, and was then replaced with fibrinogen concentrate.; - Use of fibrinogen concentrate resulted in transfusion of significantly fewer total blood components and units of FFP and cryoprecipitate vs. use of FFP.; - The groups had similar outcomes, with similar rates of ICU admission and hysterectomy, and there were no deaths.

Abbreviations: FFP = fresh frozen plasma; G = group; ICU = intensive care unit; IQR = interquartile range; n = number; NR = not reported; PPH = postpartum hemorrhage; PRBC = packed red blood cells

### Studies of Procedures

#### Uterine Balloon Tamponade

##### Key Points

- No good quality studies addressed uterine balloon tamponade.
- In one fair quality pre-post study, 86% of women who had balloon tamponade did not require further procedures or surgeries.
- Case series reported a decrease or cessation of bleeding in 75 to 98 percent of patients treated with a balloon tamponade device, with and without prior or subsequent surgeries or procedures.
- Strength of the evidence for outcomes related to uterine balloon tamponade is insufficient given the small number of studies and small sample sizes.

##### Overview of the Literature

Five studies, one pre-post study, one retrospective cohort study, two retrospective case series, and one population-based case series, addressed the use of intrauterine balloon tamponade for the management of PPH.79, 87-90 The pre-post study was conducted in France, cohort study in Hong Kong, and case series in the United States, Finland, and Italy. Many of the women in these studies had atony (100% in pre-post study, 57.2% in the cohort study, and 16%-72.7% in case series). A total of 208 women had intrauterine tamponade using Bakri,87, 90Sengstaken-Blakemore,79 Rusch,89 or Belfort-Dildy Obstetrical Tamponade System88 balloons. .

##### Detailed Analysis

One fair quality pre-post study examined the rate of invasive procedures (embolization and surgery) after adding balloon tamponade to the protocol for PPH management in a maternity unit at a tertiary care university hospital in France.87 The new protocol required that intrauterine balloon tamponade be performed prior to any invasive intervention in cases of PPH due to uterine atony that were nonresponsive to sulprostone. Data were collected prospectively for 30 months after implementation of the new protocol. The patients in the control group (n = 290, none of whom had balloon tamponade) were identified from electronic medical records as women admitted to the hospital with PPH due to atony requiring sulprostone therapy in the 30 months prior to the new protocol implementation. During the study period, 395 women with PPH required sulprostone therapy, which was unsuccessful in 72 women. Of these women who needed additional procedures or surgeries, 43 had intrauterine balloon tamponade as the initial second-line therapy. No additional procedures or surgeries were required after balloon tamponade in 92% (11/12) of the women who had cesarean births and 84% (26/31) of the women who had vaginal births. Among the six women for whom balloon tamponade was unsuccessful, three had embolization, two had conservative surgical interventions (defined as artery ligations and/or uterine compression sutures), and one had hysterectomy. The overall success rate of balloon tamponade was 86% (37/43 women). Adding balloon tamponade to the protocol decreased the rates of arterial embolization (8.2% pre vs. 2.3% post, p = 0.006, OR 0.26, 95 percent CI: 0.09-0.72) and conservative surgical procedures (5.1% pre vs. 1.4% post, p = 0.029, OR 0.26, 95% CI: 0.07-0.95) among women with vaginal births. Hysterectomy and transfusion rates were unchanged. Rates of invasive interventions and transfusion were unchanged among women with cesarean births (Table 9).

Table 9 Key outcomes in studies of uterine balloon tamponade

Author, Year, Country Study Design Groups (N) Study Quality | Age, Years Parity | Key Outcomes
Laas et al. 2012^87^ France Pre-post G1: Women with PPH due to atony and nonresponsive to sulprostone admitted to the maternity service after implementation of new protocol using intrauterine balloon tamponade as first-line therapy after medication failure (395) G2: Control group, had PPH requiring sulprostone during the 30 months before implementation of new protocol (290) Quality: Fair | Age, median (range) G1: 30 (27-34) G2: 31 (26-34) Nulliparous, n (%) G1: 212 (53.7) G2: 160 (55.2) | - In G1, 72 women required interventions beyond medication and 43 of these had intrauterine balloon tamponade; - No additional procedures or surgeries were required after balloon tamponade in 92% (11/12) of women who had cesareans and 84% (26/31) of women who had vaginal births; - The rates of invasive interventions among women who had vaginal births were significantly lower after introduction of new protocol
Chan et al. 2013^79^ Hong Kong Cohort study G1: Oxytocin only (33) G1a: Oxytocin ± other uterotonics (16) G2: Uterine compression sutures (21) G3: Embolization alone (4) G4: Uterine balloon tamponade (11) G5: Two second-line therapies (6) Quality: Fair | Age, mean ± SD G1-G5: 33.3±4.6 Parity, mean ± SD G1-G5: 21.6±3.2 | - 2/12 women receiving uterine balloon tamponade required hysterectomy. 1/12 required embolization.; - Estimated blood loss among 11/12 women=12.3 liters (range 1.5-8.7); median 10 units (range 3-34) RBC transfused; - Median LOS=8 days (range: 4-12); 72.7% required ICU admission
Dildy et al. 2013^88^ US Case series G1: Dual-balloon tamponade (51) | Age, median (range) G1: 33 (19-47) Parity NR | - 77% required red blood cell transfusion; - 24% were admitted to the ICU; - Bleeding was considered to be decreased or stopped in 98% of cases; - 16% required surgical interventions after balloon tamponade
Ferrazzani et al. 2014^89^ Italy Case series G1: Rusch uterine balloon tamponade (52) | Age, mean ± SD G1: 34.4±4.4 Multiparous, n (%) G1: 20 (38.5) | - Total , mean ± SD estimated blood loss=1759,± 1011 mL; mean ± SD days of hospital admission=6.2±3.0; - Uterine tamponade successful in controlling bleed in 20/24 cases of PPH due to atony, 3/7 cases due to atony+ placenta previa or accreta, 9/11 cases due to placenta previa, 5/5 cases of placenta accreta, 2/5 cases due to placenta previa-accreta (39/52 cases overall)
Gronvall et al. 2012^90^ Finland Case series G1: Bakri uterine balloon tamponade (50) | Age, mean (range) G1: 31.3 (19-47) Parity, n 0: 30 1-2: 16 ≥3: 4 | - Uterine balloon tamponade successfully controlled bleeding in 43/50 cases, in 4 cases women had concomitant ligation or sutures; - Mean blood loss after balloon insertion=525 mL (range=0-3250 mL).; - Mean inflation volume of balloon=367 mL (range 30-500mL)

Abbreviations:; G = group; ICU = intensive care unit; LOS = length of stay; mL = milliliter; n = number; NR = not reported; PPH = postpartum hemorrhage; RBC = red blood cells; SD = standard deviation

In a fair quality cohort study (see full description in Oxytocin and Other Uterotonics section above), 42 of 91 women with massive PPH required second-line procedures or surgeries to control bleeding.79 Procedures included balloon tamponade (n=12), embolization (n=5), and sutures (n=26), and women receiving second-line therapies did not differ in terms of age, BMI, parity, mode of birth, or causes of PPH. Twelve women received uterine balloon tamponade with a Sengstaken-Blakemore tube, with successful control of bleeding in 9 (75%). One woman required subsequent embolization, and two required hysterectomy to control bleeding.

One population-based case series examined the outcomes of women with PPH treated with a dual-balloon catheter tamponade device, the Belfort-Dildy Obstetrical Tamponade System, using postmarketing surveillance data from medical records and clinician interviews at 11 hospitals in the United States.88 During the study period (September 2010 – October 2012), 51 women with PPH were treated with the balloon tamponade device. Of these, 28 women had vaginal births and 23 had cesarean births. The median time interval between birth and insertion of the balloon was 2.2 hours (range 0.3-210 hours). Estimated median blood loss was 2000mL (range 855-8700). Thirty-nine (77%) patients required PRBC transfusion, and 12 (24%) were admitted to the ICU. Bleeding was considered to be decreased in 22 (43%) women and stopped in 28 (55%). Eight patients (16%) required additional procedures or surgeries after the balloon placement including hysterectomy (n = 4), uterine artery embolization (n = 4), and surgical repair (n = 3); some required more than one intervention. The overall success rate of balloon tamponade in controlling or decreasing bleeding was 98% (50/51 women, who also had prior medical or surgical interventions). Table 9 outlines key outcomes in studies of uterine balloon tamponade.

A retrospective case series evaluated uterine tamponade conducted with a Rusch balloon between 2002 and 2012 at one Italian center.89 All 52 women who had balloon tamponade (mean age=34.4±4.4, 39% multiparous, 60% with atony) received initial uterotonics and other conservative management. Oxytocin was continuously infused in conjunction with tamponade (20 IU for 24 hours). Tamponade balloons were filled with 200 mL in cases of abnormal placentation and 400mL in cases of atony. Women also received antibiotics for 24 hours, and those receiving balloon tamponade after vaginal birth had vaginal packing. Balloons were left in place for a mean of 23.1±9.0 hours (range: 3.5-40 hours). Sixty-three percent of women also received red blood cell transfusion. Balloon tamponade as the initial second-line procedure successfully controlled bleeding in 39 of 52 women (75%, success in 11 of 14 cases of PPH following vaginal birth and 28 of 38 cesarean births). Two women had subsequent uterine artery ligation, one had compression sutures, and 10 had hysterectomies. More failures of balloon tamponade requiring hysterectomy occurred in cases of PPH due to placenta previa and accreta (success in 2 of 5 cases) and in cases due to atony accompanied by placenta previa and/or accreta (success in 3 of 7 cases).

A final retrospective case series reported on 50 women with PPH (n=44) or at risk of PPH (n=6) receiving a Bakri uterine balloon after conservative management including uterotonics, laceration repair, and curettage as needed.90 Overall, 29 women had vaginal births and 21 had cesarean births (N primigravid=30). PPH was most often due to placental retention (30% of cases) or vaginal rupture/paravaginal hematoma (22%). Uterine balloons were inserted in the vagina or lower uterine segment and left in situ for a mean of 12.7 hours (range 1-28 hours). Four women had compression sutures or ligation concomitantly with uterine balloon tamponade, and the study reports data on successful control for all women (i.e., not separately for those women who received tamponade alone). In all, uterine balloon tamponade successful controlled bleeding in 43 of 50 women (86%). Three women required subsequent embolization, two required supravaginal uterine amputation, one required compression sutures plus supravaginal uterine amputation, and one had embolization followed by hysterectomy. Because success data are not extractable for women who received uterine balloon tamponade alone, this study is not included in Table 10, which reports rates of successful control of bleeding following uterine tamponade.

Table 10 Success rates after uterine balloon tamponade as the initial second-line procedure

Study Design | Study Country | Quality | Total N Treated | Total N Successful | % Success
Pre-Post Studies | Laas 2012^87^ France | Fair | 43 | 37 | 86.1
Cohort Studies | Chan 2013^79^ Hong Kong | Fair | 12 | 9 | 75
Case Series | Ferrazzani 2014^89^ Italy | Poor | 52 | 39 | 75
| Total | NA | 107 | 85 | Range: 75-86% Median Success Rate: 75%

Abbreviations: n = number; NA = not applicable

Note: Success = control of bleeding without further procedure or surgery

Table 10 reports rates of successful control of bleeding after uterine tamponade.

#### Embolization

##### Key Points

- No good quality studies addressed embolization.
- Embolization materials, arteries embolized, and interventions used prior to and concomitantly with embolization varied across studies.
- Success (control of bleeding without further procedures or surgeries) rates for embolization as the initial procedure after conservative management ranged from 58 to 98 percent (success in 1251/1435 women), with a median rate of 89 percent.
- Strength of the evidence is low for embolization controlling bleeding without additional procedures or surgeries.

##### Overview of the Literature

Nineteen studies addressed embolization to treat PPH.49, 77, 79, 91-108 Seven studies had explicit comparison groups: one poor quality case-control study91 and six fair quality cohort studies (reported in multiple publications), five of which were retrospective49, 79, 92-96 and one prospective.77 Four studies were conducted in France in tertiary care hospitals,91, 92, 95, 96one in Korea,49 in a hospital that serves Jehovah's Witnesses, one in the United Kingdom,77 which reported data collected via the UKOSS (described in the section on rFVIIa), and one in Hong Kong.79 Ten women in one cohort study also had concomitant vessel ligation and/or uterine compression sutures,92-94 one woman in each of two studies had prior or concomitant artery ligation,49, 95 and three in another study77 also had intra-arterial balloon placement along with embolization. Eighty-one percent of the cases of PPH reported in the case-control study were due to atony.91 Rates of atony in the cohort studies ranged from 9 to 69.5 percent. Other causes in all populations included placenta accreta, percreta, and/or previa (range: 9.4 to 22%); thrombus, vascular anomaly, or coagulopathy (range: 2 to 10%); and genital tract lacerations or uterine tears (range: 1to 14%). The case-control study and two retrospective cohort studies reported primarily on longer-term fertility with followup of participants at ≥ 12 months post-embolization (fertility data reported in KQ3).91, 92, 95 The prospective cohort study reported primarily success of embolization and the need for additional second-line interventions77 as did one retrospective cohort study.96 Remaining studies also reported primarily on the rate of success (i.e., controlling bleeding without further procedures or surgical interventions) of embolization.

Twelve retrospective case series also addressed embolization.97-108 Studies were conducted in France (n = 4), Asia (n = 7), the United States (n = 1). Most cases of PPH were due to atony (range = 43 to 100%), and most studies reported primarily on rates of success. One study107 reported on embolization to control secondary PPH, and one case series included 50 women in who embolization was performed because of high risk for PPH.108

##### Detailed Analysis

One fair quality retrospective cohort study reported in three publications92-94 included all 101 women who had pelvic artery embolization for PPH from 1994 to 2007 at a tertiary care facility in France. Embolization failed to control bleeding in 11 of 101 women, seven of whom required a postpartum hysterectomy. Failure was associated with increased blood loss as 100 percent of failed cases had blood loss greater than 1500 ml (p < .001). Failure was also associated with increased rate of transfusion with 90 percent of women in whom embolization failed receiving more than 5 units PRBC compared with 43 percent of the successful embolizations (p < .004). Cases of failed embolization were more likely to be complicated by wound infection (27% vs. 6 % in the success group, p < .04).

A second fair quality retrospective cohort study conducted in France assessed outcomes in 52 women undergoing selective embolization using gelfoam (n = 41, mean age = 29.2 ± 4.65 years, 9 primiparous, 11 vaginal births), hysterectomy (n = 6, mean age = 30.1 ± 4.11, 2 primiparous, 2 vaginal births), or both embolization and hysterectomy (n = 5, mean age = 36.6 ± 4.56, 0 primiparous, 0 vaginal births).95 All women were treated between 1996 and 2005, and atony was the most frequent cause of PPH across groups (69.5%). All women had medical management (oxytocin, manual placenta removal, uterine massage, prostaglandins, transfusion) prior to embolization or hysterectomy. Embolization successfully stopped bleeding in 41 of 46 cases (89.1%). Five women required additional embolization procedures (insertion of coil to correct injury sustained in cesarean birth, ovarian artery embolization, embolization beyond gluteal artery, embolization of internal iliac artery, embolization of ligated hypogastric arteries). Among five women proceeding to hysterectomy following failed embolization, two women had placenta accreta, one had percreta, and one had sustained arterial injury during embolization. The study also assessed fertility in women who had had embolization (n = 37 available for followup) 2 to 11 years earlier: of the 16 women who desired a future pregnancy, all became pregnant 1 to 11 months following the decision to try to conceive (total of 19 pregnancies in the followup period).

In one fair quality retrospective cohort study reporting outcomes after embolization, ligation, or hysterectomy (see full study description in Ligation section), eight of 61 women with PPH underwent embolization using gelatin sponge or coils as the first secondary procedure.96 Embolization failed in three cases: one woman undergoing embolization also required methotrexate, one required subsequent ligation, and one required hysterectomy (63% success rate for embolization alone). This study also reported intervention by cause of PPH: among eight cases treated with primary embolization, three women had PPH due to atony (one cesarean birth). Embolization failed in one case, which resulted in hysterectomy and subsequent death. Embolization was successful in two cases of PPH due to accreta (one cesarean birth) and in one case due to placental abruption (vaginal birth). The procedure failed in one case of PPH due to genital tract laceration (instrumented vaginal birth), leading to subsequent ligation, and successfully controlled bleeding in another case following lacerations.96

Another fair quality retrospective cohort study reported outcomes after second-line procedures (see full description in the Oxytocin and Other Uterotonics section) in 42 women with PPH.79 Procedures included balloon tamponade (n=12), embolization (n=5), and sutures (n=26), and women receiving second-line therapies did not differ in terms of age, BMI, parity, mode of birth, or causes of PPH. Although five women underwent embolization after the failure of conservative management including oxytocin and other uterotonics, the paper reports etiology only for the four women who had embolization alone (i.e., not followed by another second-line approach). Two women had atony, one had placenta previa, and one had placenta accreta. Embolization successfully controlled bleeding without need for further procedure or surgery in three of the five women receiving embolization (60%). One woman required subsequent compression sutures and one required hysterectomy to control bleeding.

One poor quality case-control study conducted in France assessed the effects of embolization on fertility in 53 women exposed to embolization following PPH and 106 women who had not undergone embolization and were matched on date of birth, age, gravidity and parity, fertility assistance, and mode of birth.91 Women (mean age = 34.3, range 19-44) had undergone embolization (78.5% using absorbable gelatin, 1.8% using coils, 7.1% using microparticles, 12.6% using gelatin+other) between 2000 and 2006, and the primary cause of PPH was atony (81.1%). Embolization successfully controlled bleeding in 100 percent of women, but three required more than one embolization procedure.

One fair quality prospective cohort study reported UKOSS data collected between 2007 and 2009.^77^ The study reported an analysis of outcomes of second-line therapies (i.e., interventions received after uterotonics alone or with intrauterine tamponade via balloon or packing). Second-line interventions included interventional radiology (defined as embolization or occlusion with an intra-arterial balloon), ligation (of any of the internal iliac, uterine, hypogastric, or ovarian arteries), compression sutures (including B-lynch, modified B-lynch, multiple vertical or horizontal sutures, squared compression sutures, and others), or rFVIIa. Among an estimated 1,237,385 births in the study period, 272 women had PPH treated with the interventions of interest as a second-line intervention. More than 50 percent of PPH cases (53%) were primarily due to atony. Other causes included placenta previa (9%), placenta accreta (10%), uterine tears (13%), and other (15%, includes placental abruption, genital bleeding, amniotic fluid embolism, infection, clotting abnormalities, undetermined causes). Women who had a cesarean birth (n = 230) were treated with a surgical method in 199 (87%) of the cases, and those who gave birth vaginally (n = 42) were more likely to be treated by interventional radiology or rFVIIa (52%, p < 0.001). Among the 272 cases of PPH, 205 women received uterotonics alone, and 67 had uterotonics plus intrauterine tamponade as first-line procedures. Data for each of the second-line therapies addressed in the study are reported under the appropriate intervention type (suture, etc.). Among the 22 women treated with interventional radiology, 19 had embolization alone, two had embolization plus balloon, and one had balloon only. Fourteen of the 22 women received uterotonics prior to interventional radiology. The interventional radiology procedures failed to control bleeding in two women (14%; 95% CI: 0 to 43), who required hysterectomy. Among the eight of 22 women who received uterotonics and intrauterine tamponade prior to interventional radiology, bleeding was controlled in seven cases, and one woman (12%, 95% CI: 0 to 53) required an additional (unstated) intervention. The study does not report the success of embolization alone but only the success of both interventional radiology procedures together.

One fair quality retrospective cohort conducted at a hospital that treated Jehovah's Witnesses in Korea reported results from women treated with embolization or hysterectomy between 2002 and 2009 (see Hysterectomy section for results from that arm).49 All women were initially treated with uterotonics (oxytocin, ergots, prostaglandins), uterine massage, transfusion (in patients who were not Jehovah's Witnesses), and fluid replacement. Among the 124 women (eight Jehovah's Witnesses) experiencing primary PPH, 60 (mean age 31.0 ± 4.8 years, 17 primiparous, 23 vaginal births) underwent selective embolization using gelfoam. PPH was most frequently due to atony (92.4%), and mean blood loss prior to embolization was 676.7 ml. Embolizations were performed by the same two interventionists across the study period. Mean ICU stay in the embolization group was 5 days (mean overall LOS = 8.6 days). Two women in the embolization group required hysterectomy due to continued bleeding from the cesarean uterine wound and from vaginal and cervical lacerations after vaginal birth.

In case series, rates of success (control of bleeding after embolization without further procedures or surgeries) ranged from 58 to 98 percent. In some cases, women had a procedure such as ligation or balloon tamponade prior to embolization. Five studies also reported on resumption of menses and/or pregnancies achieved (see discussion in KQ3).

One population-based case series reported on 211 women undergoing embolization either to control ongoing PPH (n=161, mean age=32.4±4.8 years, primipara=47.2%) or prophylactically (n=50, mean age=30.1±6.1 years, primipara=50%).108 Of note, this study included 56 women (37 in the emergency embolization group and 19 in the prophylactic group) who were <22 weeks gestation at the time of treatment. Most cases of prophylactic embolization were performed for retained placenta (n=37), while most cases of emergency embolization were for atony (n=73). Embolic materials included gelatin sponge in most cases (n=193 cases), but metal coils (n=11) and other materials including N-butyl-2-cyanoacrylate (n=7) were also used. Embolization successfully controlled bleeding in 181 of 211 women (86%); 12 women required a second embolization procedure, and 18 required hysterectomies. Because the study does not clearly report how women who had second embolizations also had hysterectomies, we do not include this study in the success rates in Table 12.One retrospective case series reported on 117 cases of embolization (mean age=32.0±5.0, 69 vaginal births, 56 primiparous) for PPH performed between 2006 and 2013 at a Korean hospital.106 More than half of the cases of PPH in the embolization group (54.7%) were due to atony, and women were treated initially with fluids, uterotonics, uterine massage, suture of lacerations, and uterine evacuation as needed. Embolization was performed with gelatin particles, coils, glue, or polyvinyl alcohol particles and was successful overall at controlling bleeding without further procedural or surgical intervention in 103 of 117 women (88%). Ten women required additional embolization, and four had hysterectomies. Embolization failure was associated with DIC (OR 3.364, 95% CI: 0.838 to 13.503, p=.08), greater than 10 RBC units transfused (OR 8.011, (95% CI: 1.531 to 41.912, p=.014), and embolization of uterine and ovarian arteries (OR 20.472, (95% CI: 2.715 to 154.365, p=.003). Nineteen of the 117 cases of PPH were secondary (12 cesarean births, p=.03 compared with primary PPH group), and embolization successfully controlled bleeding in 18 of these cases. This study includes data on 20 women who underwent hysterectomy but no outcomes of interest for the current review were reported; thus we did not include the hysterectomy data.

Table 12 Success rates after embolization as the initial second-line procedure

| Study Country | Quality | Total N Treated | Total N Successful | % Success
Cohort Studies | Kim 2013^49^ Korea | Fair | 60 | 58 | 96.67
Cohort Studies | Chan 2013^79^ Hong Kong | Fair | 5 | 3 | 60
Cohort Studies | Zwart 2010^109^ Netherlands^a^ | Fair | 114 | 94 | 82.46
Cohort Studies | Chaleur 2008^95^ France | Fair | 46 | 41 | 89.13
Cohort Studies | Ledee 2001^96^ France | Fair | 8 | 5 | 62.50
Case-Control | Hardeman 2010^91^ France | Poor | 53 | 50 | 94.34
Case Series | Cheong 2014^106^ Korea | Poor | 117 | 103 | 88.03
Case Series | Yamasaki 2013^104^ Japan | Poor | 55 | 46 | 83.64
Case Series | Lee 2013^105^ Korea | Poor | 176 | 158 | 89.77
Case Series | Kim 2013^100^ Korea | Poor | 248 | 226 | 91.13
Case Series | Sentilhes 2011^94^ France | Poor | 100 | 89 | 89.00
Case Series | Ganguli 2011^97^ US | Poor | 66 | 63 | 95.45
Case Series | Lone 2010^110^ U.K. | Poor | 229 | 201 | 87.77
Case Series | Fiori 2009^97^ France | Poor | 56 | 55 | 98.21
Case Series | Touboul 2008^103^ France | Poor | 102 | 59 | 57.84
Case Series | Total | NA | 1435 | 1251 | Range: 58-98% Median Success Rate: 89.00%

Note: Success = control of bleeding without further procedure or surgery

a Outcomes of this study described in section on embolization and hysterectomy

Abbreviations: N = number; NA = not applicable

One retrospective case series included 56 women (median age = 33 years, median gravida = 2, median para = 2) with severe PPH (defined as ≥ 1000mL blood loss via clinical estimation or weighing of blood collecting bag; ≥ 500mL blood loss with poor clinical signs; continued bleeding; need for transfusion; or DIC) undergoing embolization at a French tertiary care hospital between 1995 and 2005.^97^ All women received initial medical treatment including suturing of vaginal or cervical lesions, oxytocin, uterine massage, and sulprostone. Thirty births were vaginal without instrumentation (54.5%), nine were instrumented vaginal (16.5%), and 16 were cesarean (29%). All women had atony, and 36 required transfusion (64.3%). Embolization was performed with gelfoam or sponge. Embolization successfully stopped bleeding in 55 cases (98% success rate). One woman required a second embolization session to control bleeding, and none needed further surgical interventions for bleeding.

Another French retrospective case series including 113 women (mean age = 31 years, 67 cesarean births) reported on menses and fertility outcomes and success of the embolization procedure.98 PPH was most frequently due to atony (75% of cases), and all women received medical management prior to embolization. Embolization materials included gelatin sponge, powder, and microparticles. Eighteen women required surgery prior to embolization (sutures, n = 11; ligation, n = 7). Embolization successfully controlled bleeding in 111 cases (results not reported for women who had embolization without a prior surgical procedure). Two women required hysterectomy post-embolization.

In a Korean retrospective case series reporting on 251 women with primary PPH (mean age 32 ± 4 years, 139 nulliparous, 141 vaginal births), most cases of PPH were due to atony (78.9%).101 The study reviewed data from women treated between 2000 and 2011. All women had medical management prior to embolization, and 22 had surgical interventions prior to embolization (hysterectomy, n = 15; uterine artery ligation, n = 2; laparotomy, n = 2; suture or uterine wall repair, n = 2; dilatation and curettage, n = 1). Embolization was performed with gelatin sponge or multiple particles. Embolization successfully controlled bleeding in 201 of the 229 women for whom embolization was the first second-line procedure (88%). Among all 251 women, embolization successfully controlled bleeding in 217 (87%). Twelve women required a repeat embolization (success in nine cases, one hysterectomy, one laparotomy, one death), nine required hysterectomy, six required laparotomy (one death), three required additional conservative management, one required uterine artery ligation, and three died after the first embolization session. Successful embolization was associated with vaginal birth, absence of DIC, and absence of need for transfusion of > 10 PRBC units (p values < .05).

A retrospective review of embolization for PPH conducted at two Korean hospitals between 2006 and 2011 included data from 176 women (mean age = 33.9 years, 105 vaginal births, 73 primiparous) undergoing 189 embolization procedures.105 Women who had cesarean births were significantly older than those with vaginal births (p = 0.035). Twenty-five cases of PPH were secondary, and overall, PPH was most frequently due to atony (57.6% of cases). Embolizations were done with gelatin sponge, particles, coils, or a combination. Bleeding successfully stopped after embolization in 158 cases (89.7%). Twelve women needed a repeat embolization, 11 needed a surgical procedure (five hysterectomies), and one needed vascular ligation.

One retrospective case series reporting data from a U.S. tertiary care hospital included 76 women (mean age = 33 years, 18 cesarean births) who had PPH.99 Ten women were excluded from analysis because they had interventions prior to or concomitant with embolization or had an ectopic pregnancy. Embolization (performed with gelfoam and/or coils) successfully controlled bleeding without further procedures or surgeries in 63 of 66 women (95%). Three women required a subsequent hysterectomy. Embolization was successful in 98% (49/50) of the women with primary PPH and 88% (14/16) of the women who had secondary PPH (presentation 4 to 72 days post-birth, mean = 25 days). Women required a mean 0.4 units PRBC after embolization, and the mean hospital stay overall was 3.5 days (range 1-12 days). Among those with primary PPH, mean hospital stay was 3.9 days and was 2 days in the secondary PPH group.

One Japanese retrospective case series included data from 55 women (median age 33 years, 34 vaginal births, median parity = 1, range 0-3) with PPH treated with embolization between 2003 and 2013.^104^ Most cases of PPH were due to atony (n = 41), and all women had initial conservative management including uterine massage, packing, and uterotonics. The embolization material was gelatin sponge, and embolization successfully stopped bleeding without an additional intervention in 46 women (84%). Bleeding stopped in two women who went on to hysterectomy after embolization due to uterine necrosis. The study does not report the interventions performed for the other seven women who required another procedure after embolization. Advanced maternal age and retained placenta were independent risk factors for failure of embolization (OR 1.46, 95% CI: 1.12 to 2.18 and OR 15.48, 95% CI: 2.04 to 198.12, respectively).

One French retrospective case series reported outcomes among 102 women (mean age 31.8 ± 5.9 years, 82 vaginal births, mean parity 2.01 ± 1.11) undergoing embolization at an academic medical center between 1998 and 2002.^103^ Women may have had medical management including uterine massage and oxytocin prior to embolization. PPH was due to atony in 43 percent of women. Mean ICU stay was 2.07 ± 1.2 days, and units of whole blood, platelets, and fresh frozen plasma transfused ranged from 0 to 31. Embolization was successful without further surgical procedure in 59 women. Fourteen women required a second embolization to control bleeding, and 29 required surgery (nine laparotomies, two uterine artery ligations, seven hysterectomies, 11 genital tear repairs plus subsequent embolization). Embolization was more successful in women with vaginal births (success in 63/81 vaginal births) compared with cesarean (success in 11/21 cesarean births, p = 0.017; OR for poor outcome associated with cesarean birth: 0.16, 95% CI: 0.04 to 0.5). Atony as the cause of PPH was also associated with greater success (success in 39/44 women; OR 4.13, 95% CI: 1.35 to 12.6).

Another retrospective case series conducted in a French tertiary care hospital reported on success rates for embolization in 98 women with PPH (33 considered “major” PPH, defined as change in peripartum hemoglobin level of ≥ 4 g/dL and/or hemodynamic instability and/or hypovolemic shock).102 All women had treatment (resuscitation, uterotonics, manual placenta removal, surgical repair of tears as indicated) prior to embolization, and most cases of PPH were due to atony. Forty-five women had vaginal births, 14 had instrumented vaginal births, and 28 had cesarean births. Embolization was performed with gelatin sponge pledgets and coils as needed. Twenty-six women had a surgical procedure prior to embolization (vaginal or cervical suture, n = 17; uterine suture, n = 1; artery ligation, n = 3; hysterectomy, n = 9; packing, n = 2). Embolization successfully controlled bleeding in 90 of the 98 cases of PPH. Women in whom PPH failed to control bleeding required subsequent uterine suture (n = 4), laparotomy for vessel ligation (n = 2), and repair of genital tears (n = 2). Embolization plus uterine sutures failed in three cases, leading to hysterectomy.

In another large retrospective case series from Korea, 257 women (mean age = 32 years, 162 primiparas, 112 cesarean births) underwent embolization for PPH between 2004 and 2011.^100^ PPH was most often caused by atony (n = 156 cases), and embolization materials included gelatin sponge, N-butyl-cyanoacrylate, or both. Nineteen cases of PPH were secondary. Nine women had a surgical procedure prior to embolization (eight hysterectomies, one artery ligation). Embolization successfully stopped bleeding in 233 women overall (91%). In the 248 women for whom embolization was the first second-line procedure, embolization was successful in 226 (91%). Women for whom embolization failed to control bleeding were more likely to have DIC (OR 6.57, 95% CI: 1.60 to 26.9, p = .009), and the rate of major complications was significantly greater among failed embolizations vs. successful (9.4% vs. 37.5%, p < .01).

Finally, one retrospective case series conducted in Korea included 52 women (mean age 31.6 years, range=25-40) with secondary PPH.107 Bleeding began a median 10 days post-birth (range 1-39 days) and was most frequently related to retained placental tissue (44.2% of cases). All women had initial conservative management prior to embolization, which was conducted with gelatin particles, N-butyl cyanoacrylate, and/or microcoils. Embolization successfully controlled bleeding without further procedure or surgery in 47 of 52 women (90.4%). In univariate analyses, successful control of bleeding was not associated with obstetric characteristics, mode of birth, onset of bleeding post-birth, length of stay, amount of transfusion, or cause of bleeding (all p values=ns). One woman needed repeat embolization, one had further conservative management, and three women had subsequent hysterectomy. In the 44 women available for followup at a mean of 12.6 months post-procedure (range 1-62 months), all women had regular menstruation and five had pregnancies, although the number desiring pregnancy was not reported. The investigators note that no complications occurred. Table 11 outlines key outcomes in all studies of embolization.

Table 11 Key outcomes in studies of embolization

Study Design | Author, Year Country Groups (n) Quality | Age, Years Parity | Key Outcomes
Cohort Studies | Sentilhes et al. 2010^92-94^ France G1: Embolization alone (58 at followup) G2: Embolization + vessel ligation and/or suture (10 at followup) Quality: Fair | Age NR Parity NR | - Bleeding not controlled by embolization in 11/101 women; - 7 women required hysterectomy; - 100% percent of failed cases had blood loss greater than 1500 ml (p < .001); - 90% of women in whom embolization failed received more than 5 units PRBC compared with 43% of successful embolizations (p < .004).; - Cases of failed embolization were more likely to be complicated by wound infection (27% vs. 6 % in the success group, p < .04)
Cohort Studies | Chaleur et al. 2008^95^ France G1: Embolization (41) G2: Hysterectomy (6) G3: Embolization and hysterectomy (5) Quality: Fair | Age, mean ± SD G1: 29.2 ± 4.65 G2: 30.1 ± 4.11 G3: 36.6 ± 4.56 Primiparous, n (%) G1: 9 (21.9) G2: 2 (33) G3: 0 | - All patients had had medical management prior to procedure; - 5 second-line hysterectomies (G3) were performed due to embolization failure; - Among 16 women in G1 desiring future pregnancy, all were able to conceive 1-11 months after beginning to try to conceive
Cohort Studies | Ledee et al. 2001^96^ France G1: Hysterectomy (10) G2: Bilateral hypogastric artery ligation (48) G3: Embolization (9) Quality: Fair | Age NR Parity NR | - All women underwent bimanual compression, oxytocin and prostaglandin IV administration, and resuscitation before further intervention; - Embolization was primary procedure in 8 cases and secondary in 1. In 3 cases, an additional intervention was needed to control bleeding
Cohort Studies | Chan et al. 2013^79^ Hong Kong G1: Oxytocin only (33) G1a: Oxytocin ± other uterotonics (16) G2: Uterine compression sutures (21) G3: Embolization alone (4) G4: Uterine balloon tamponade (11) G5: Two second-line therapies (6) Quality: Fair | Age, mean ± SD G1-G5: 33.3±4.6 Parity, mean ± SD G1-G5: 21.6±3.2 | - Mean estimated blood loss in 4 women undergoing only embolization=5.1 liters (range 1.5-15 liters); mean PRBC transfused=20 packs (range 2-32); - 3 women (75%) admitted to ICU; - Embolization successful in 3/5 women; 1 woman required subsequent hysterectomy to control bleeding
Cohort Studies | Kayem et al. 2011^77, 82^ UK G1: Uterine compression sutures (199) G2: Pelvic vessel ligation (20) G3: Interventional radiology (embolization, arterial balloon) (22) G4: RFVIIa (31) Quality: Fair | Age < 35, n (%) G1: 128 (64) G2: 12 (60) G3: 12 (55) G4: 21 (68) > 35, n (%) G1: 71 (36) G2: 8 (40) G3: 10 (45) G4: 10 (32) Nulliparous, n (%) G1: 92 (46) G2: 3 (15) G3: 6 (27) G4: 9 (29) | - Among all women receiving these second-line therapies, 205 had had prior uterotonic therapy (oxytocin, ergometrine, carboprost tromethamine, misoprostol) alone, 67 had had uterotonics and intrauterine tamponade; - 19 women had embolization only, 2 had occlusion with intra-arterial balloon and embolization, and 1 had balloon only; - Interventional radiology after uterotonics alone was successful as first second-line therapy in 12/14 women; 2 went on to hysterectomy.; - Interventional radiology was successful as first second-line therapy after uterotonics+ tamponade in 7/8 cases. 1 women required an additional (unstated) intervention; - Overall, 71 women had hysterectomy(47 after failure of second-line therapy, 24 after failure of uterotonics/tamponade and subsequent treatments)
Cohort Studies | Kim et al. 2013^49^ Korea G1: Embolization (60) G2: Hysterectomy (61) Quality: Fair | Age, mean ± SD G1: 31.0 ± 4.8 G2: 31.8 ± 4.0 Primiparous, n G1: 17 G2: 22 | - Primary cause of hemorrhage in both groups = atony; - 8 women in study were Jehovah's Witnesses-4 in each group; - All women in G1 and G2 received uterotonics (G1: oxytocin = 100%, sulprostone = 68%, Ervin = 36%; G2: oxytocin = 100%, sulprostone = 60.6%; Ervin = 19.6%). 25 women in G1 and 36 in G2 required transfusion prior to procedure; - Embolization was successful in 96% of G1; 2 women required hysterectomy due to continued bleeding from cesarean uterine wound and vaginal and cervical lacerations; - Mean days in ICU in G1 = 5 days (5 women). ICU days not reported in G2 but 39 women required ICU care; LOS in hospital was 8.60 days in G1 and 11.5 in G2
Case-Control | Hardeman et al. 2010^91^ France G1: Embolization (53) G2: No embolization (106) Quality: Poor | Age, mean (range) G1: 34 (19-44) G2: NR Parity, mean (range) G1: 2.02 (1-5) | - 43 cases of PPH due to atony; - Embolization successful in controlling bleeding without additional procedure or surgery in 50/53 cases; - Three women required a second embolization, which was successful in all cases
Case Series | Inoue et al. 2014^108^ Japan G1a: Emergency embolization (161) G1b: Prophylactic embolization (50) | Age, mean ± SD G1a: 32.4 ± 4.8 G1b: 30.1 ± 6.1 Primiparous, n (%) G1a: 76 (47.2) G1b: 25 (50) | - One of more embolization procedures successfully controlled bleeding in 91.9% of G1a and 96% of G1b; - 12 women required more than on embolization procedure, and 18 had hysterectomy; - Among 113 women followed for 3 months to 3 years post-procedure, 106 resumed menses
Case Series | Cheong et al. 2014^106^ Korea G1: Embolization (117) | Age, mean G1: 32 Primiparous, n (%) G1: 56 (47.9) | - Among 117 women undergoing embolization, 19 (16.2%) had secondary PPH; - 36.8% of women required >10 red blood cell units; - 14 women required another embolization and/or hysterectomy to control bleeding
Case Series | Fiori et al. 2009^97^ France G1: Embolization (56) | Age, median G1: 33 Parity, median (range) G1: 2 (1-4) | - Embolization successful in 55/56 cases (98%); - Regular menses in 30/34 available for followup
Case Series | Gaia et al. 2009^98^ France G1: Embolization (113) | Age, mean G1: 33 Parity NR | - Embolization successfully controlled bleeding in 111 cases; 2 women required hysterectomy post-embolization; - 99/107 with available fertility data had resumed menses, normal menses in 66 (menorrhagia = 10, oligomenorrhea = 23, amenorrhea = 6); - 29 women desired future pregnancy, 18 conceptions (mean conception delay 11 months from decision to try to conceive)
Case Series | Lee et al. 2012^101^ Korea G1: Embolization (251) | Age, mean ± SD G1: 32 ± 4 Nulliparous, n (%) G1: 139 (55) | - 22 women had surgical procedure before embolization; embolization successful in controlling bleeding as the first second-line procedure in 201/229 women (88%); - Success rate among all 251 women = 86.5%; - Success associated with vaginal birth, absence of DIC, absence of massive transfusion (all p values < .05); - Among 113 women with ≥ 6 months followup, 110 had regular menses
Case Series | Lee et al. 2009^105^ Korea G1: Embolization (176) | Age, mean G1: 33.9 Primiparous, n G1: 73 | - Bleeding successfully stopped after embolization in 158 cases (89.7%); - 12 women had repeat embolization, 11 had surgical procedure (5 hysterectomies), and 1 had vascular ligation (some women had more than 1 procedure)
Case Series | Ganguli et al. 2011^99^ US G1: Embolization (66) | Age, mean G1: 33 Parity, mean (range) G1: 1.8 (0-9) | - Embolization successfully controlled bleeding without further procedures or surgeries in 63 of 66 women overall (95%).; - Embolization successful in 14/16 women with secondary PPH (88%); - Embolization successful in 49/50 cases of primary PPH (98%); - Women required a mean 0.4 units PRBC after embolization; - Mean hospital stay overall was 3.5 days (range 1-12 days)
Case Series | Yamasaki et al. 2013^104^ Japan G1: Embolization (55) | Age, mean G1: 33 Parity, median (range) G1: 1 (0-3) | - Successful controlling of bleeding without further procedures or surgeries in 46/55; - Bleeding stopped in two women who went on to hysterectomy after embolization due to uterine necrosis; - Advanced maternal age (OR 1.46 95% CI: 1.12 to 2.18 ) and retained placenta were independent risk factors for failure of embolization (15.48 95% CI: 2.04 to 198.12)
| Touboul et al. 2008^103^ France G1: Embolization (102) | Age, mean ± SD G1: 31.8 ± 5.9 Parity, mean ± SD G1: 2.01 ± 1.11 | - Embolization successful without further surgical procedure in 59/102 cases; - Embolization more successful in women with vaginal births (success in 63/81) compared with cesarean (success in 11/21, p = 0.017; OR for poor outcome associated with cesarean birth: 0.16, 95% CI: 0.04 to 0.5); - Atony associated with greater success (success in 39/44 women; OR 4.13, 95% CI: 1.35 to 12.6); - Mean ICU stay 2.07 ± 1.2 days; - Units of whole blood, platelets, and fresh frozen plasma transfused ranged from 0 to 31
Case Series | Poujade et al. 2012^102^ France G1: Embolization (98) | Age, mean ± SD Successful embolization: 32.3 ± 5.7 Failed embolization: 31.2 ± 6.4 Parity, mean ± SD Successful embolization: 2.1 ± 1.3 Failed embolization: 2.1 ± 1.7 | - Embolization successfully controlled bleeding in 90 of the 98 women, 26 of whom also had surgical procedure prior to embolization; - Women in whom PPH failed to control bleeding required subsequent uterine suture (n = 4), laparotomy for vessel ligation (n = 2), and repair of genital tears (n = 2). Embolization plus uterine sutures failed in three cases, leading to hysterectomy
Case Series | Kim et al. 2013^100^ Korea G1: Embolization (257) | Age, mean G1: 32 Primiparous, n G1: 162 | - Embolization successful in 233/257 women overall; - Success rate in the 248 women for whom embolization was the first second-line procedure = 91%; - Overall, women for whom embolization failed to control bleeding were more likely to have DIC (OR 6.57, 95% CI: 1.60 to 26.9, p = .009)
Case Series | Park et al. 2014^107^ Korea G1: Embolization for secondary PPH (52) | Age, mean (range) G1: 31.6 (25-40) Parity, primiparous, n (%) G1: 35 (67.3) | - Mean time to onset of PPH post-birth=13.3 days (range 1-39 days); - Most cases due to retained placenta (n=23); - Bleeding successfully controlled in 47/52 women. One woman required repeat embolization, 3 had hysterectomy, 1 had conservative management; - In women followed up for 1-62 months, normal menstruation returned in 100%; 5 subsequent pregnancies; - Success of embolization not significantly associated with maternal characteristics, mode of birth, bleeding onset post-birth, length of stay, cause of bleeding or transfusion requirements

Abbreviations: CI = confidence interval; DIC = disseminated intravascular coagulation; G = group; ICU =intensive care unit; LOS = length of stay; n = number; NR = not reported; OR = odds ratio; PRBC = packed red blood cells; PPH = postpartum hemorrhage; SD = standard deviation

#### Embolization Success Rates

As noted earlier, we tabulated success rates reported in studies of embolization in which we could extract data on the effectiveness of the procedure as the initial second-line procedure (i.e., women routinely had first-line conservative management prior to the procedure). Some studies only reported rates in combination with other procedures/interventions or after an initial procedure or intervention, thus not all studies addressing embolization are represented. Success rates for embolization, which was performed using different materials and on different arteries across studies, ranged from 58 to 98 percent (success in 1251/1435 women), with a median rate of 89 percent (Table 12).

### Studies of Surgical Interventions

#### Uterine Compression Sutures

##### Key Points

- No good quality studies addressed uterine compression sutures.
- In one fair-quality prospective cohort study, sutures were effective in controlling bleeding without further procedures or surgeries in 140 of 199 women, all of whom received uterotonics and/or intrauterine balloon tamponade prior to sutures (70% success rate). Sutures were successful in 15 of 21 women in another study (71%).
- Strength of the evidence is insufficient for the success of uterine compression sutures in controlling bleeding given the few studies available.

##### Overview of the Literature

Three studies addressed uterine compression sutures, one prospective cohort study (reported in two publications), one retrospective cohort study, and two retrospective case series.77, 79, 82, 111 The prospective cohort study, rated as fair quality, reported data collected via the UKOSS.77, 82 Two-hundred and eleven cases of PPH were treated with sutures in the study period. One retrospective cohort study reported on 26 women with massive PPH in Hong Kong.79 The case series reported data from interventions performed by a single surgeon in Argentina111 The study reports on 539 cases of PPH treated with ligation or suture and does not clarify how many women received each technique. Two additional studies of compression sutures reported harms outcomes only and are described under KQ3.^62, 66^

##### Detailed Analysis

One fair quality prospective cohort study reported UKOSS data collected between 2007 and 2009.^77^ The study reported an analysis of outcomes of second-line therapies (i.e., interventions received after uterotonics alone or with intrauterine tamponade via balloon or packing. Among women who were initially treated with uterotonics alone, 161 went on to require compression sutures, which were successful in controlling bleeding in 120 cases (74.53% success rate). Twenty-five women required hysterectomy (without another intervening procedure) after sutures. Three women had ligation after suture; seven had either embolization or balloon placement (three of these went on to require hysterectomy); and six had rFVIIa (four ultimately required hysterectomy). Thus, compression sutures with or without subsequent procedures failed to control bleeding in 32 women, leading to hysterectomy. Among 38 women who required sutures after failure of uterotonics plus intrauterine tamponade, 14 went on to require hysterectomy (eight immediately, two after ligation and/or rFVIIa, two after interventional radiology and/or rFVIIa, and two after rFVIIa alone). Overall (among women who received uterotonics and intrauterine tamponade), sutures successfully controlled bleeding in 70 percent of cases (n = 140/199 cases)77

Another publication from this study,82which includes data from the majority (n = 199/211) of the participants who received sutures described above,77 reported on 211 women receiving compression sutures (B-lynch, n = 79; modified B-lynch, n = 48; other, including square sutures or combination sutures, n = 32; unspecified, n = 52) to treat PPH in the study period. The most common reason for the hemorrhage was uterine atony (n = 129, 61%). As in the first study, all women had prior uterotonic treatment either for prophylaxis or treatment of PPH. Ten women had embolization or ligation, 41 had uterine balloon or packing, and two had rFVIIa prior to sutures. Embolization or ligation following sutures was required in 18 cases, rFVIIa in nine, and uterine packing or balloon in 25. Overall, sutures as the initial second-line therapy failed to control bleeding, leading to subsequent hysterectomy, in 46 cases and successfully controlled hemorrhage in 153 cases (sutures were not the initial second-line therapy in 12 cases). Fifty-two women (25%) of all women (those who received sutures as the initial second-line therapy and those who received sutures in combination with or after another second-line procedure) required hysterectomy to control bleeding. More women who required an additional second-line intervention went on to require hysterectomy (OR 3.09, 95% CI: 1.46 to 6.56).

In a fair quality retrospective cohort study (see full description in Oxytocin and Other Uterotonics section), 42 of 91 women with massive PPH required second-line procedures or surgeries to control bleeding.79 A total of 26 women received sutures (including B-Lynch, Hwu, Cho square, and Hayman), 21 of whom received sutures alone, and five of whom also had sequential embolization. In the 21 women receiving sutures alone, bleeding was successfully controlled in 15 (71.4%). Six women required subsequent hysterectomy. None of the women who had both sutures and embolization required hysterectomy. One retrospective case series reported data on 539 cases of PPH treated with either uterine sutures or arterial ligation in hospitals in Argentina between 1989 and 2009.^111^ Sutures were placed by a single surgeon, and suture types included B-lynch, Cho, Hayman, and Pereira. The number of sutures compared with ligations, and potential overlap between interventions, is not clear. Overall, the study reports cessation of bleeding in 499 cases. Forty women required hysterectomy, but whether this occurred after suture or ligation or a combination is not clear. B-lynch sutures were reported as successful in 81 of 86 cases, Hayman sutures in 34 of 37, Cho sutures in 281 of 313 cases, and Pereira in 11 of 11 cases, but again, prior or subsequent interventions are not clear. Because the number of women who received sutures as the initial second-line intervention is clearly reported in only two studies,77, 79, 82 we do not include a success rate table for uterine compression sutures. Table 13 outlines data from studies with comparison groups.

Table 13 Key outcomes in studies of uterine compression sutures

Author, Year Country Study Design Groups (n) Quality | Age, Years Parity | Key Outcomes
Kayem et al. 2011^77, 82^ UK Cohort study G1: Uterine compression sutures (199) G2: Pelvic vessel ligation (20) G3: Interventional radiology (embolization, arterial balloon) (22) G4: RFVIIa (31) Quality: Fair | Age < 35, n (%) G1: 128 (64) G2: 12 (60) G3: 12 (55) G4: 21 (68) > 35, n (%) G1: 71 (36) G2: 8 (40) G3: 10 (45) G4: 10 (32) Nulliparous, n (%) G1: 92 (46) G2: 3 (15) G3: 6 (27) G4: 9 (29) | - Among all women receiving these second-line therapies, 205 had had prior uterotonic therapy (oxytocin, ergometrine, carboprost tromethamine, misoprostol) alone, 67 had had uterotonics and uterine tamponade; - Compression sutures used more often in PPH caused by atony (63%, interventional radiology used more often for cases related to genital or ligament bleeding or clotting abnormalities); - Sutures as the first second-line therapy were successful in 120/161 women who received prior uterotonics only; 25 required immediate hysterectomy, 3 required ligation (no subsequent hysterectomy), 7 interventional radiology (3 subsequent hysterectomies), 6 rFVIIa (4 subsequent hysterectomies). In total 32 went on to hysterectomy; - Among women who received uterotonics plus intrauterine tamponade, sutures were successful in 20/38 cases; - Overall (across all groups) 71 women had hysterectomy(47 after failure of second-line therapy, 24 after failure of tamponade and subsequent treatments)
Chan et al. 2013^79^ Hong Kong Cohort study G1: Oxytocin only (33) G1a: Oxytocin ± other uterotonics (16) G2: Uterine compression sutures alone (21) G3: Embolization alone (4) G4: Uterine balloon tamponade (11) G5: Two second-line therapies (6) Quality: Fair | Age, mean ± SD G1-G5: 33.3±4.6 Parity, mean ± SD G1-G5: 21.6±3.2 | - 11/26 women receiving sutures required subsequent hysterectomy or embolization (58% success rate); - Estimated blood loss among 21 women who received sutures not followed by hysterectomy=2.0 liters (range 1.5-20.0); median 4 units (range 0-77) RBC transfused. Median LOS=7 days (range: 4-31); 38.1% required ICU admission
Palacios-Jaraquemada 2011^111^ Argentina Case series G1: Arterial ligation or uterine suture (539) | Age NR Parity NR | - Review of 539 cases of ligation or suture for PPH conducted by single surgeon; - Techniques successful in controlling bleeding in 499 cases; 40 women required subsequent hysterectomy; - Suture (B-lynch, Hayman, Cho, Pereira) appears to have been successful in 431 cases but denominator not clearly presented, nor are procedures received prior to or in conjunction with sutures clearly reported

Abbreviations: G = group; ICU = intensive care unit; LOS = length of stay; n= number; NR = not reported; PPH = postpartum hemorrhage; RBC = red blood cells; rFVIIa = recombinant activated factor VIIa; SD = standard deviation

#### Uterine and Other Pelvic Artery Ligation

##### Key Points

- No good quality studies addressed uterine and other pelvic artery ligation (hereafter, ligation).
- Rates of successful control of bleeding without further procedures or surgeries ranged from 36 to 96 percent with a median of 92 percent in three studies.
- Strength of the evidence is low for ligation controlling bleeding without further procedures or surgeries.

##### Overview of the Literature

Five studies reported data on ligation.77, 96, 111-113 Studies include two fair quality cohort studies, one conducted in the U.K.,77 and one in France.96 In the prospective study of ligation of pelvic vessels (unspecified), 25 percent of cases of PPH were due to atony, 30 percent due to uterine tears, 20 percent due to accreta, and 25 percent due to other causes, and most women were under age 35 (60%).77 Nearly 40 percent of cases of PPH in the retrospective cohort study, which included cases of bilateral hypogastric artery ligation, were due to atony, and participant age was not reported.96 Studies primarily reported rates of success for ligation. Three retrospective case series also reported data on ligation: one reported cases of bilateral uterine artery ligation or selective pelvic pedicle ligation, performed by a single surgeon in Argentina,111 one reported on outcomes after uterine artery ligations over 30 years in a U.S. center,112 and the final study reported on triple uterine artery ligation conducted over 9 years in France113. Case series primarily reported success rates and provide little data on participant characteristics.

##### Detailed Analysis

Outcomes of ligation were reported in a fair quality UKOSS cohort study described fully above.77 Fourteen women required vessel ligation as second-line procedure following uterotonics alone. Ligation successfully controlled bleeding in five women, and five required sutures (followed by hysterectomy in three), two required rFVIIa (followed by hysterectomy in one), and two required hysterectomy immediately after ligation. Six women had ligation after uterotonics and intrauterine tamponade failure, and three went on to hysterectomy to control bleeding (two after sutures plus rFVIIa, one after sutures alone).77

Another fair quality retrospective cohort study reported data from women with PPH admitted to a French ICU between 1983 and 1998 and included some data on future fertility.96 Sixty-one cases of PPH occurred in the time period, 48 of which were treated with bilateral ligation of the hypogastric arteries, eight with embolization using gelatin sponge or coils, and five with hysterectomy as the primary procedure. Across groups, 39 women required transfusion of four or more blood units. Most of the 56 women requiring either ligation or embolization as a primary procedure had cesarean births (n = 41). The women requiring primary hysterectomy all had hemorrhagic shock. The primary procedure failed in eight cases (described under each intervention). Among the 48 women undergoing primary ligation, four required hysterectomy to correct bleeding (92% success rate for primary ligation). This study also reported intervention by cause of PPH: 20 women had PPH due to atony and received ligation as the primary intervention. Nineteen of these 20 had cesarean births (elective or emergency). Ligation was successful in controlling bleeding in 18 of 20 cases, with two women requiring subsequent hysterectomy (one vaginal birth and one cesarean birth). Eleven women (10 cesarean births) had PPH due to accreta. Ten ligations were successful in this group; one woman who had a cesarean birth required hysterectomy and subsequently died. Seven women had PPH due to genital tract laceration (seven vaginal births, 4 instrumented), and ligation was successful in all cases. Six women had placental abruption (six cesarean births), and ligation was successful in all cases. Two women had uterine rupture or pre-rupture (two cesarean births) with bleeding controlled successfully by ligation in both cases. Two women had PPH due to uterine artery injury, presumably incurred during cesarean birth. Ligation successfully controlled bleeding in one case, and the other women died. Finally, one woman with a cesarean birth had PPH related to placenta previa. Ligation failed to control bleeding, leading to subsequent hysterectomy.96

One French retrospective case series included 56 women with PPH (median age=31.5, median parity=0.5) who underwent triple uterine artery ligation with (n=43) or without (n=13) concomitant uterine compression sutures.113 The PPH treatment protocol in the hospital studied included oxytocin followed by sulprostone followed by ligation as needed, sutures as needed, and other procedures including hysterectomy or embolization if bleeding remained uncontrolled. Most cases (80.4%) of PPH were due to atony. All women received initial oxytocin, and 83.9 percent also received sulprostone. Overall, ligation alone and ligation with suture controlled bleeding in 51 of 56 women (91.1%). Four women had a subsequent hysterectomy and one required embolization. Failure of ligation with or without suture occurred more often in cases of PPH due to accreta (4 cases) compared with atony (1 case, p=.0004, [OR for failure of ligation ± suture=15.07, 95% CI: 1.12 to 201.9, p=.041]). Ligation with or without suture was also significantly less likely to fail when women had first received sulprostone (p=.025).

One retrospective case series reported data on 539 cases of PPH treated with either uterine sutures or arterial ligation in hospitals in Argentina between 1989 and 2009.^111^ Interventions were conducted by a single surgeon. The number of sutures compared with ligations, and potential overlap between interventions, is not clear. Overall, the study reports cessation of bleeding in 499 cases. Forty women required hysterectomy, but whether this occurred after suture or ligation or a combination is not clear. Ligation was reported as successful in 68 of 105 cases, but again, prior or subsequent interventions are not clear.

Another retrospective case series reviewed data from 29 years (1963-1992) of ligations performed in a U.S. hospital.112 Women received initial medical therapy including uterotonics, and 265 underwent bilateral uterine artery ligation after cesarean birth. Atony accounted for most cases of PPH across the study period (n = 135), and the rate of PPH treated with ligation declined across decades (n = 124, 60, 81 per each decade from 1963-1992). Overall, ligation failed to control bleeding in 10 women, eight of whom had abnormal placentation. Six of these 10 women had total hysterectomies, three had sutures, and one had ovarian artery ligation. Most treatment failures (n = 7) occurred in the first decade reviewed. The study reports that menstrual flow was not affected, but method and timing of followup is not clear. Table 14 outlines key outcomes of studies.

Table 14 Key outcomes in studies of uterine and other pelvic artery ligation

Study Design | Author, Year Country Groups (n) Quality | Age, Years Parity | Key Outcomes
Cohort Studies | Kayem et al. 2011^77, 82^ UK G1: Uterine compression sutures (199) G2: Pelvic vessel ligation (20) G3: Interventional radiology (embolization, arterial balloon) (22) G4: rFVIIa (31) Quality: Fair | Age < 35, n (%) G1: 128 (64) G2: 12 (60) G3: 12 (55) G4: 21 (68) > 35, n (%) G1: 71 (36) G2: 8 (40) G3: 10 (45) G4: 10 (32) Nulliparous, n (%) G1: 92 (46) G2: 3 (15) G3: 6 (27) G4: 9 (29) | - Among all women receiving these second-line therapies, 205 had had prior uterotonic therapy (oxytocin, ergometrine, carboprost tromethamine, misoprostol) alone, 67 had had uterotonics and intrauterine tamponade; - Ligation as the initial second-line therapy was successful in 5/14 women, 2 went on to immediate hysterectomy, 5 required sutures (3 subsequent hysterectomies), 2 required rFVIIa (1 subsequent hysterectomy). In total, 6 women had hysterectomies.; - Overall, 71 women had hysterectomy(47 after failure of second-line therapy, 24 after failure of uterotonics/tamponade and subsequent treatments)
Cohort Studies | Ledee et al. 2001^96^ France G1: Hysterectomy (10) G2: Bilateral hypogastric artery ligation (48) G3: Embolization (9) Quality: Fair | Age NR Parity NR | - All women underwent bimanual compression, oxytocin and prostaglandin IV administration, and resuscitation before further intervention; - Ligation was primary procedure in 48 women and secondary in 1; ligation failed to control bleeding in 4 cases, which all required hysterectomy
Case Series | Blanc et al. 2012^113^ France G1: Triple uterine artery ligation (56) | Age, median (range) G1: 31.5 (17-44) Parity, median (range) G1: 0.5 (0-8) | - Mean red blood cells =4.1 units, mean 2.25 units of fresh frozen plasma.; - 7 women required ICU admission; - Ligation with or without concomitant Cho sutures controlled bleeding in 91.1% of women (51/56)
Case Series | Palacios-Jaraquemada 2011^111^ Argentina G1: Arterial ligation or uterine suture (539) | Age NR Parity NR | - Review of 539 cases of ligation or suture for PPH conducted by single surgeon; - Techniques successful in controlling bleeding in 499 cases; 40 women required subsequent hysterectomy; Ligation appears to have been successful in 68 cases but denominator not clearly reported, nor are procedures received prior to or in conjunction with ligation
Case Series | O'Leary 1995^112^ US G1: Uterine artery ligation (265) | Age NR Parity NR | - 265 cases of PPH treated over 30 years; ligation failed in 10 cases leading to hysterectomy (6 cases), placental site ligation (3 cases), ovarian artery ligation (1 case); - Menstrual flow reportedly not affected but followup not clearly described

Abbreviations: G = group; ICU = intensive care unit; n = number; NR = not reported; PPH = postpartum hemorrhage; rFVIIa = recombinant activated factor VIIa

##### Ligation Success Rates

Ligation was performed on multiple sites (e.g., internal iliac, uterine arteries) within and across studies, and rates of successful control of bleeding ranged from 36 to 96 percent with a median of 92 percent (Table 15).

Table 15 Success rates after uterine and other pelvic artery ligation as the initial second-line procedure

Study Design | Study Country | Quality | Total N Treated | Total N Successful* | % Success^a^
Cohort Studies | Kayem 2011^77^ UK | Fair | 14 | 5 | 35.71
Cohort Studies | Ledee 2001^96^ France | Fair | 48 | 44 | 91.67
Case Series | O'Leary 1995^112^ US | Poor | 265 | 255 | 96.23
Case Series | Total | NA | 422 | 372 | Range: 36-96% Median success rate: 91.67%

a Success = control of bleeding without further procedure or surgery

Abbreviations: NA = not applicable

#### Embolization and Hysterectomy

##### Key Points

- One study compared embolization and hysterectomy.
- Embolization failed to control bleeding in 20 cases (18%), leading to 17 hysterectomies.
- Women in the hysterectomy group had significantly more ICU admissions compared with the embolization group (RR 1.6, 95% CI: 1.1 to 2.4) and had a greater median length of stay (LOS, 10 days vs. 7 days).
- Strength of the evidence was low for embolization controlling bleeding without additional procedures or surgeries and insufficient for the effects of hysterectomy.

##### Overview of the Literature

One fair quality prospective cohort study conducted in the Netherlands109 compared outcomes following embolization or hysterectomy. The 205 women in the study most frequently had PPH related to atony (33%), and 43.4 percent were age 40 or older.

##### Detailed Analysis

One fair quality cohort study (Table 16) conducted in the Netherlands (LEMMoN: Nationwide Study into Ethnical Determinants of Maternal Morbidity in the Netherlands) prospectively collected data on severe maternal morbidity from all 98 Dutch maternity hospitals between 2004 and 2006 using a standardized collection form.109 Two hundred and five women required either embolization (n = 114) or hysterectomy (n = 108) or both (n=17) during the study period. More than 40 percent (43.4%) of women in both groups were age 35 or older, 39.5 percent were nulliparous, and 49.8 percent had cesarean births. The most frequent cause of PPH in the embolization arm was atony (33%) and disorders of placentation (placenta previa, morbidly adherent placenta) in the hysterectomy group (35%). Women in both arms had other interventions prior to either embolization or hysterectomy including oxytocin ( > 80% of both groups); sulprostone ( > 50% of both groups); plasma replacement, frozen plasma, or red blood cell transfusion ( > 78% of both groups); and other surgical interventions including arterial ligation, B-lynch suture, inspection (6 women in embolization and 11 in hysterectomy groups).

Table 16 Key outcomes in studies of embolization and hysterectomy

Author, Year Country Groups (n) Quality | Age, Years Parity | Key Outcomes
Zwart et al. 2010^109^ G1: Embolization (114) G2: Hysterectomy (108) Quality: Fair | Age, greater than 35, % G1+G2: 43.4 Nulliparity, % G1+G2: 39.5 Parity ≥ 3: G1+G2: 7.3 | - Women in both groups had additional interventions including misoprostol (13% in both groups), sulprostone (G1: 67%, G2: 86%), transfusion (98% of both groups), balloon therapy G1: 21%, G2: 30%), ligation or suture (G1: 10%, G2: 6%); - 17 women in G1 went on to have hysterectomy, 1 went on to balloon tamponade after embolization; - Women in G2 required more massive transfusions ( ≥ 8 units red blood cells) than G1 (RR:1.5, 95% CI: 1.1 to 2.1) but the timing of transfusion (pre- or post-procedure) is not clear; - Women in G2 more often admitted to ICU than women in G1 (RR: 1.6, 95% CI: 1.1 to 2.4); 67 women in G1 admitted to ICU (number NR for G2); - Median length of hospitalization for G1 = 7 days (range 1-38) vs. 10 days (range 2-65) for G2

Abbreviations: CI = confidence interval; G = group; ICU = intensive care unit; n = number; NR = not reported; RR = relative risk

Embolization failed to control bleeding in 20 cases (18%): 17 women in the embolization group also ultimately required hysterectomy to control PPH (two of these were due to uterine necrosis) and one case was resolved with balloon tamponade. In sub-analyses of these failed cases, embolization had a failure rate of 25 percent following cesarean birth. Women in the hysterectomy group required more transfusions (median 14 vs. 10, p = 0.002) and more massive transfusions (≥ eight units of red blood cells) compared with women undergoing embolization (RR 1.5, 95% CI: 1.1 to 2.1); however, timing of transfusion (i.e., pre- or post-embolization or hysterectomy) is not clear. Women in the hysterectomy group also had significantly more ICU admissions compared with the embolization group (RR 1.6, 95% CI: 1.1 to 2.4) and had a greater median LOS (10 days vs. 7 days).109

#### Hysterectomy

##### Key Points

- Two of eight studies reported data to calculate control of bleeding without additional procedures or surgeries. In these two studies bleeding was controlled after hysterectomy as the initial second-line intervention in a median of 57 percent of cases.
- In one case series analyzing data by hospital volume, there was no difference in transfusion, intraoperative injury, length of stay, or medical complications based on hospital volume after adjusting for age, race, hospital size, year of diagnosis, and hospital type.
- Strength of the evidence is insufficient for all hysterectomy outcomes given the few studies available.

##### Overview of the Literature

Eight studies reported outcomes of hysterectomy.45, 49, 96, 110, 114-117 Studies included two retrospective cohort studies of fair quality, one conducted in France (n=10)96 and the other in Korea (total n = 61).49 Atony accounted for 75 percent of the 61 cases in one study,49 while PPH in the 10 women undergoing hysterectomy in the second was due to genital tract lacerations in three cases, atony in three cases, placenta accreta or previa or placenta abruption in three cases, and uterine rupture in the final case. Four population-based case series also reported on outcomes following hysterectomy. Case series were conducted in Canada,114 Denmark,115 the U.K.,116 and the United States.45. One retrospective case series reported on 55 peripartum hysterectomies conducted at one U.S. hospital.117 Finally, another retrospective case series conducted at a university hospital in the U.K. and including data from 52 cases of PPH also reported risk factors for hysterectomy.110Participant ages ranged from 14 to 54 years in the studies reporting age,45, 110, 114 and PPH was typically due to atony (range 30 to 56% of cases) or placenta previa or accreta (range: 20 to 38% of cases). One additional case series assessing hysterectomy reported only harms data and is addressed in KQ3.^64^

##### Detailed Analysis

In one fair quality cohort study including women undergoing embolization (results described in embolization section) or hysterectomy, all women were initially treated with uterotonics (oxytocin, ergots, prostaglandins), uterine massage, transfusion (in patients who were not Jehovah's Witnesses) and fluid replacement.49 Among the 124 women (eight Jehovah's Witnesses) experiencing primary PPH, 61 (mean age 31.8 ± 4.0 years, 22 primiparous, 33 vaginal deliveries) underwent hysterectomy. PPH was most frequently due to atony (75.4%), and mean blood loss prior to procedure was 1288.3 ml. Significantly more women in the hysterectomy group had DIC, hypotension, elevated heart rate, greater blood loss before intervention, and greater total transfusion requirements than in the comparison arm of women undergoing embolization (all p values < 0.001). Mean total LOS was 11.5 days. Thirty-nine women in the hysterectomy group required ICU care; however, the study does not report mean ICU stay. Fifty-seven women in the hysterectomy group required transfusion after surgery, and four also required embolization post-hysterectomy.

In another fair quality retrospective cohort study reporting outcomes after embolization, ligation, or hysterectomy (see full study description in Ligation section above), five of 61 women received hysterectomy as the primary procedure. The women requiring primary hysterectomy all had hemorrhagic shock, and the procedure was not successful at controlling bleeding in four cases. One woman also required subsequent embolization. This study also reported intervention by cause of PPH: hysterectomy was the primary procedure in three cases of PPH due to genital tract laceration (three vaginal births). As noted, one woman required subsequent embolization, and the other two died. Similarly, one woman who had a cesarean birth died after hysterectomy for PPH due to uterine rupture. Hysterectomy successfully controlled bleeding in one case of PPH due to placental abruption.96

One population-based case series reported on outcomes following peripartum hysterectomy due to PPH.116 In this study there were 315 cases of PPH that resulted in hysterectomy identified via UKOSS between 2005 and 2006. The median ICU stay was 2 days. Sixty-two women had a return to the operating room for a second surgery after hysterectomy. Fourteen percent of these women had a second surgery due to continued bleeding and 6 percent had return due to damage to other organs during hysterectomy. The median number of blood units transfused ranged from nine to 12 depending on etiology of transfusion.

Another population-based case series from the United States was conducted with data from a nationwide validated database that collected quality and resource utilization data (Perspective) data from 500 facilities in the United States.45 The main hypothesis of this study was that hospital volume affects outcomes of postpartum hysterectomy. Among the 2,209 patients identified, overall maternal mortality was 1.2 percent among low, intermediate, and high volume facilities, reoperation rates were 3.2 to 6.4 percent (p = 0.02). Intensive care use rates were 45 percent, 39.6 percent and 27.4 percent for low, medium and high-volume institutions, respectively (p < 0.001). The mean length of stay was 3.5 to 4.1 days. After adjusting for age, race, hospital size, year of diagnosis and hospital type, there was no difference in transfusion or length of stay based on hospital volume. Perioperative death was higher at low volume facilities (1.8% compared with 0.9 and 0.8% at medium and high volume hospitals, p = 0.02). Adjusted OR for perioperative death was 0.22 at high volume facilities.

A population-based case series in Denmark collected peripartum hysterectomy data from 1995 to 2004 using the Danish Medical Birth Register, which records information on all births in the country since 1973.^115^ Peripartum hysterectomy was defined in this study as a hysterectomy taking place immediately after and up to one month after birth. Out of 653,482 births, there were 152 peripartum hysterectomies to control hemorrhage; thirty percent of cases of PPH were due to atony. Prior to hysterectomy, 80 percent of women received oxytocin, 73 percent prostaglandins, 43 percent misoprostol, and 43 percent ergot alkaloid. Ligation was performed in 21 percent of patients and B-lynch suture was also done in 21 percent prior to hysterectomy. Hysterectomy was more often performed after cesarean birth (n = 101, RR for hysterectomy after cesarean compared with vaginal birth = 11.1, 95% CI: 7.9 to 15.6, p < .0001). Sixteen women (11%) needed reoperation.

An additional population-based case series reported on all cases of postpartum hysterectomy done between 1999 and 2006 in a Canadian hospital.114 All obstetric care in the region is linked to a regional database. Investigators identified all hysterectomies that occurred within 24 hours of birth. A total of 87 peripartum hysterectomies were performed in the study period, a rate of 0.8 per 1,000 births. Thirty-four percent of women in the series had placenta previa or accreta. All women received uterotonics prior to hysterectomy, and 86 percent received blood transfusion. Pelvic vessels were ligated in 33 percent of cases. B-lynch suture was done 3 times. Forty-six women (53%) were admitted to the ICU, and mean length of stay after birth was 6 days (range 2 to 16). Eighty-one percent of hysterectomies took place after cesarean birth (n = 70).

Two retrospective case series reported on emergency hysterectomy outcomes and were conducted in the U.K.110 and the U.S.117 In the U.K. series, most (n=50/52) women had primary PPH and all had numerous interventions, including uterotonics, packing, balloon tamponade, and sutures, prior to hysterectomy to control bleeding.110 In multivariate analyses, multiparity, placenta previa, primary PPH, and failed induction were significant risk factors for hysterectomy (all p values <.02). The U.S. series reported on 55 peripartum hysterectomies (17 vaginal births, 38 cesarean; mean age=29 ± 6.8), typically for PPH due to atony (56.4% of cases).117 Mean overall length of stay was 11 ± 7.9 days, mean number units transfused was 6.9±5.3, and mean estimated blood loss was 3325.6 ± 1839.2 mL. Table 17 outlines outcomes.

Table 17 Key outcomes in studies of hysterectomy

| Author, Year Country Groups (n) Quality | Age, Years Parity | Key Outcomes
Cohort Studies | Kim et al. 2013^49^ Korea G1: Embolization (60) G2: Hysterectomy (61) Quality: Fair | Age, mean ± SD G1: 31.0 ± 4.8 G2: 31.8 ± 4.0 Primiparous, n G1: 17 G2: 22 | - Primary cause of hemorrhage in both groups was atony; - 8 women in study were Jehovah's Witnesses-4 in each group; - All women in G1 and G2 received uterotonics (G1: oxytocin = 100%, sulprostone = 68%, Ervin = 36%; G2: oxytocin = 100%, sulprostone = 60.6%; Ervin = 19.6%). 25 women in G1 and 36 in G2 required transfusion prior to procedure; - Embolization was successful in 96% of G1; 2 women required hysterectomy due to continued bleeding from cesarean uterine wound and vaginal and cervical lacerations; - Hysterectomy was successful in 93% of G2. 4 women required embolization following hysterectomy for extrauterine vaginal bleeding or continued bleeding of ligated vessels; - 57 women required transfusion post-hysterectomy in G2; - Mean days in ICU in G1 = 5 days (5 women). ICU days not reported in G2 but 39 women required ICU care; LOS in hospital was 8.60 days in G1 and 11.5 in G2
Cohort Studies | Ledee et al. 2001^96^ France G1: Hysterectomy (10) G2: Bilateral hypogastric artery ligation (48) G3: Embolization (9) Quality: Fair | Age NR Parity NR | - All women underwent bimanual compression, oxytocin and prostaglandin IV administration, and resuscitation before further intervention; - Hysterectomy was the primary procedure in 5 women (all with hemorrhagic shock) and secondary in 5; - Hysterectomy as a primary procedure failed to control bleeding in 4 cases—3 deaths, 1 subsequent embolization
Case Series | Knight et al. 2008^116^ UK G1: Hysterectomy (315) | Age NR Parity NR | - Median ICU stay = 2 days; - Need for further procedure or surgery in 62 cases; 14% due to continued bleeding, 6% due to organ damage incurred during hysterectomy; - Median number of blood units transfused ranged from 9 to 12 depending on etiology
Case Series | Wright et al. 2010^45^ US G1: Hysterectomy (2209) | Age, n (%) < 30 years: 673 (30.5) ≥ 30 years: 1536 (69.5) (overall median = 33, range = 14 to 50) Parity NR | - 35% of cases of PPH due to atony, 35% due to placenta accreta; - Reoperation rates were 3.2% to 6.4% (p = 0.02 among low, intermediate, high volume hospitals); - Intensive care use was 45%, 39.6%, and 27.4% for low, medium and high-volume institutions, respectively (p < 0.001), mean length of stay was 3.5 to 4.1 days; - No difference in transfusion, intraoperative injury, length of stay, or medical complications based on hospital volume in adjusted analyses; - Perioperative death was higher at low volume facilities (1.8% compared with 0.9% and 0.8% at medium and high volume hospitals, p = 0.02). Adjusted OR for perioperative death was 0.22 at high volume facilities
Case Series | Sakse et al. 2007^115^ Denmark G1: Hysterectomy (152) | Age G1: NR Nulliparous, n G1: 36 | - Most hysterectomies performed after cesarean birth (n = 101); RR for hysterectomy after cesarean birth compared with vaginal = 11.1, 95% CI: 7.9 to 15.6, p < .0001; - Women generally received initial medical management; - Ligation was performed in 21% and B-lynch suture in 21% prior to hysterectomy; - 16 women (11%) needed reoperation
Case Series | Glaze et al. 2008^114^ Canada G1: Hysterectomy (87) | Age, mean ± SD G1: 34 ± 5 Primiparous, n (%) G1: 37 (43) | - All women received uterotonics prior to hysterectomy; 86% had blood transfusion; 33% had pelvic vessel ligation; - 53% admitted to ICU; - Mean LOS 6 days (SD = 3, range = 2-16)
Case Series | Lone et al. 2010^110^ UK G1: Hysterectomy (52) | Age, mean (range) G1: 29.4 (14-54) Parity, mean G1: 1.35 | - Most women had multiple interventions prior to hysterectomy: bimanual compression, n = 46; oxytocin, n = 52; arterial ligation, n = 28; uterine packing, n = 18; intrauterine balloon, n = 17; B-lynch suture, n = 15; rfVIIa, n = 2; - Primary PPH, induction, placenta previa were significant risk factors for hysterectomy in multivariate analyses
Case Series | Forna et al. 2004^117^ US G1: Hysterectomy (55) | Age, mean ± SD G1: 29.0±6.8 Parity, mean G1: 3.3±2.8 | - Mean LOS=11±7.9 days; - 15 women had uterine artery ligation prior to hysterectomy, 1 had hypogastric artery ligation; - Women had a mean 2.1±1.2 postoperative complications

Abbreviations: CI = confidence interval; G = group; ICU = intensive care unit; LOS = length of stay; n = number; NR = not reported; OR = odds ratio; PPH = postpartum hemorrhage; rFVIIa = recombinant activated factor VIIa; SD = standard deviation

### Studies of Combined Approaches

#### Key Points

- One cohort study of women with primary PPH reported greater need for transfusion, ICU admission, and hospital length of stay in women undergoing procedures and/or surgery compared with women who were medically managed.
- In three studies of women with secondary PPH, interventions included medical and surgical interventions. In one study, curettage resolved bleeding in 92 percent of women.
- Strength of the evidence for studies of combination interventions and length of stay was insufficient given the small sample sizes and inconsistency in interventions.

#### Overview of the Literature

Four studies addressed combination approaches and reported data in such a way that findings for individual interventions could not be isolated.118-121 Studies included two fair quality retrospective cohort studies118, 119 and two case series120, 121 that were conducted in France,118 Israel,119 the United States,121 and the United Kingdom.120Three studies included women with secondary PPH, typically defined as bleeding occurring ≥ 24 hours after birth and up to 12 weeks later.119-121Studies of secondary PPH included a total of 413 women, and all studies typically reported on success of interventions to control bleeding.

#### Detailed Analysis

One fair quality French retrospective cohort study compared outcomes in women initially treated for PPH medically (n = 147) or using “advanced interventional procedures” (n = 110), which included uterine artery embolization (n = 85), embolization plus surgery (n = 11), or surgery alone (n = 14; surgery included peritoneal packing, arterial ligation, hysterectomy, or combination of all three).118 Women (median age = 31 years) were treated between 2004 and 2005. Twelve women required hysterectomy: four in the medically managed group and eight in the advanced procedures group (p = NS). Both groups required transfusion, with the procedures group requiring significantly more units of RBC (2.8 vs. 1.2, p = 0.0004) and fresh frozen plasma (1.6 vs. 0.6, p = 0.003). Six women in the medical group and 31 in the advanced group were admitted to the ICU (p < 0.0001), and the median length of stay in the hospital was significantly greater in the procedures group (3.2 days vs. 1.0, p < .0001). However, the procedures group was likely experiencing more severe PPH given their lower median hemoglobin and systolic and diastolic blood pressures than the medically managed group. The study identified five factors that predicted the need for an advanced procedure: abnormalities of placental implantation, prothrombin time < 50 percent, fibrinogen < 2 g/l, troponin detectable, and heart rate > 115 beats per minute.

Three studies, one fair quality retrospective cohort study and two case series, focused on secondary PPH.119-121 The cohort study, conducted in Israel and including data from 1990 to 2002, compared initial surgical evacuation of the uterus (n = 50, mean age = 29.9, 4 cesarean births) or primary medical treatment (n = 118, mean age = 28.5, 16 cesarean births) with regard to immediate complications and future reproduction.119 The study defined secondary PPH as occurring 24 hours after the end of the third stage of labor and up to 12 weeks later. More women in the medical group also had primary PPH compared with the surgical group (15 vs. 14, p = .03), and more women in the surgical group had manual separation of the placenta than did women in the medical group (8 vs.5, p = .02). Need for blood transfusion, antibiotics, hysterectomy, uterine perforation, readmission, hospitalization > 2 days, and hemoglobin drop of > 20g/L did not differ significantly between groups. One woman in the surgical group required a hysterectomy (0 in the medical group, p = NS). More women in the medical group required a secondary surgical evacuation than in the surgical group (31 vs. 4, p = .01).

A case series conducted in the U.K. reported on 132 women with secondary PPH (excessive vaginal blood loss or lochial discharge occurring ≥ 24 hours after the end of third stage of labor and up to 6 weeks following), 33 of whom had had primary PPH.120 More than half of the women presented with secondary PPH in the first two weeks postpartum (19% at ≤ 7 days after birth, 41% at 8-14 days, 23% at 15-21 days, 12% at 22-28 days, and 5% at > 28 days). Initially, 57 women had conservative management and 75 women had uterine evacuation. Most women (97%) received antibiotics as an initial treatment, 17 percent had blood transfusion, and overall 63 percent had uterine evacuation. The majority of the women were hospitalized (84%), and the mean length of stay was 3.5 ± 2.3 days. Women who were initially managed conservatively were more likely to be readmitted to the hospital than women who had surgical evacuation (OR 7.8, 95 per CI: 1.2-28.8) One woman required a hysterectomy after uterine perforation.

The second case series reports on cases of secondary PPH (defined as vaginal bleeding post-discharge severe enough to require readmission or surgery) over a 10-year period (1981-1991) at two tertiary hospitals in the United States.121 One-hundred and thirteen women had secondary PPH (mean age = 26, range = 16-39, 10 cesarean births, 22 cases of prior PPH) occurring at a mean of 18 days postpartum. Eleven percent of bleeding occurred > 6 weeks after birth. Two-thirds of the women required hospitalization (67%, mean LOS = 4 days) and one-third had transfusion (35%, mean PRBC = 3 units). Bleeding resolved in 12% of women with conservative management. The majority of women (88%) had curettage, which was successful for 92%. Of the nine women who required additional surgical intervention to control bleeding, six had hysterectomy, one had ligation, and one had laparotomy. Table 18 outlines outcomes.

Table 18 Key outcomes in studies of combined interventions

Author, Year Country Groups (n) Quality | Age, Years Parity | Key Outcomes
Gayat et al. 2011^118^ France G1: Advanced interventions (embolization, ligation, surgery, packing, hysterectomy) (110) G2: Medical management (147) Quality: Fair | Age, median (first to third quartile) G1: 32 (30-36) G2: 31 (27-35) Primiparous, n (%) G1: 32 (29) G2: 57 (39) | - Women in both groups received transfusion, sulprostone ( > 80% in each group) prior to procedure; - Women in G1 received embolization (n = 85), surgery only (n = 14), or embolization + surgery (n = 11). Surgery included one or combination of peritoneal packing, ligation of arteries, hysterectomy. 12 women had a hysterectomy and 11 women had ligation before transfer to study hospital. 14 of these women were still actively bleeding on arrival to study hospital; - ICU and LOS in obstetric unit significantly longer in G1 vs. G2 (ICU: median 31 days vs. 6 days, p < .0001, LOS in unit: median 3.2 vs. 1.0 days, p < .0001)
Feigenberg et al. 2009^119^ Israel G1: Initial medical treatment for secondary PPH(118) G2: Surgical evacuation of uterus for secondary PPH (50) Quality: Fair | Age, mean G1: 28.5 G2: 29.9 Mean pregnancies prior to PPH G1: 3 G2: 2.7 | - All women had secondary PPH—mean time to admission post-birth was 16.8 days in G1 and 27.9 days in G2 (p = .0003); - 48 women in G1 and 22 in G2 required > 2 days hospitalization, p = ns; - 1 woman in G2 required hysterectomy (0 in G1), p = ns
Hoveyda et al. 2001^120^ UK G1: Medical and surgical management for secondary PPH (132) | Age NR Nulliparous, n (%) G1: 56 (42.4) | - Initial management of women with secondary PPH was conservative (n = 57) or surgical evacuation (n = 75); 84% were hospitalized; - More women initially treated conservatively required readmission compared with women initially treated with evacuation (OR 7.8, 95% CI: 2.1 to 28.8); - Mean LOS = 3.5 ± 2.3 days
Boyd et al. 1995^121^ US G1: Medical and surgical management for secondary PPH (113) | Age, mean (range) G1: 26 (16-39) Nulliparous, % G1: 39 | - Bleeding resolved in 91/99 women treated with curettage; 6 had hysterectomy, 1 had ligation, 1 had laparotomy; - Bleeding resolved in 12/99 treated conservatively; - Mean LOS = 4 days, range 1-19 days

Abbreviations: CI = confidence interval; G = group; ICU = intensive care unit; LOS = length of stay; n = number; NR = not reported; OR = odds ratio; PPH = postpartum hemorrhage; rFVIIa = recombinant activated factor VIIa

## KQ2 Evidence for Choosing One Intervention Over Another and Proceeding to Subsequent Interventions

We did not identify any studies addressing this question.

## KQ3 Harms of Interventions for Management of PPH

### Key Points

- Fifty studies reported harms of interventions for management of PPH. Eleven of these were assessed as good quality for harms reporting and the remainder as poor quality.
- In four of the five studies that reported harms related to rFVIIa, 2 to 9 percent of women who received rFVIIa had thrombotic complications. None of the women in the two of these studies that had comparator groups had thromboembolic events; however, this may be due to the small sample sizes rather than evidence of an adverse effect of the medication.
- Sixteen studies reported harms in women who underwent embolization; however, the harms reported in these studies are diverse and few studies report the same harms. The most frequently reported adverse events were infertility (0-43%), PPH in subsequent pregnancy (5%-23%), spontaneous abortion in subsequent pregnancy (5%-21%), and hematoma at puncture site (1%-6%).
- Nine studies reported diverse harms among women who had hysterectomy. The most frequently reported adverse events were ureter lesion (0.4%-41%), reoperation (1.8%-29%), infection (7%-54.6%), and bladder lesion (6%-12%).
- Multiple studies reported harms of transfusion (seven studies), intrauterine balloon tamponade (three studies), uterine and other pelvic artery ligation (two studies), curettage (two studies), and combined approaches (two studies); however, they did not report comparable adverse events.
- Two case-control studies reported on adverse pregnancy outcomes following uterine compression sutures to control PPH in the index pregnancy and noted no significantly greater incidence of preterm birth among women who had sutures compared with women in the control group.
- Harms for tranexamic acid, sulprostone, methylergonovine maleate, and carboprost tromethamine were only reported in one study per intervention. Most side effects were mild.
- Strength of the evidence for harms of interventions was typically insufficient given the diversity of harms reported in single studies. Strength of the evidence was low for hematoma, infertility, and menstrual changes associated with embolization and low for a lack of association between embolization and spontaneous abortion. Strength of the evidence was also low for the association of hysterectomy and operative organ damage and reoperation due to the greater number of studies and more consistent reporting of adverse events.

### Overview of the Literature

Fifty unique studies (reported in 55 publications) reported harms of interventions for management of PPH.37, 45, 49, 60-66, 69-71, 73-77, 80, 81, 82 , 83, 84, 86, 87, 89-95, 97-106, 108-117, 119-121 These include two RCTs,37, 69, 70, 81with harms data from one RCT reported in subsequent case series publications; two prospective cohort studies;77, 109 nine retrospective cohort studies;49, 60, 73, 83, 84, 92-96, 119 four case-control studies;62, 66, 74, 91 two pre-post studies;86, 87 nine population-based case series;45, 61, 71, 75, 76, 80, 114-116 and 23 retrospective case series.63-65, 89, 90, 97-106, 108, 110-113, 117, 120, 121 Eleven studies were assessed as good quality for harms reporting; 45, 60, 62, 65, 66, 69, 76, 100, 105, 117, 119 the remaining were of poor quality. Thirteen studies were conducted in France,37, 61, 69, 70, 81, 87, 91-98, 102, 103, 113 nine in the United States,45, 60, 66, 71, 83, 99, 112, 117, 121 six in Korea,49, 62, 100, 101, 105, 106 five in the United Kingdom,77, 86, 110, 116, 120 three in Canada,63, 64, 114 two in Ireland,74, 84 two in Japan,108, 122 two (with unclear overlap of participants) in Australia and New Zealand,76, 80 two in Italy,65, 89 two in Finland,73, 90 and one each in Argentina, 111 Israel,119 the Netherlands,109 Denmark,115 and multiple European countries.75

In most studies, authors differentiated harms that seemed to be related to the intervention from those that were thought to be due to complications of PPH. When that is the case, we report only those harms attributed to the intervention. When that distinction was not made, we report all harms listed in the study. In almost all cases of maternal mortality, the authors provided detailed explanations that made it clear that the deaths were due to the PPH and its sequelae rather than the intervention. In this section, we have only reported deaths for which there was no detail about the cause and thus we could not distinguish if it was attributable to the intervention, the hemorrhage, or some other etiology.

### Detailed Analysis

#### Medical Interventions

##### Pharmacologic Interventions

Tranexamic acid. In an RCT that compared women who received tranexamic acid with women who did not (n = 72 per group), serious side effects did not differ between the two groups. Two women in the tranexamic acid group and one in the control group had deep vein thrombosis (p = 0.37). None of the women experienced renal failure, seizures, or death. Mild, transient adverse effects occurred more often in the tranexamic acid group than in the control group (24% vs. 6%, p = 0.03). These side effects included nausea and vomiting (15% vs. 2%, p = 0.002), phosphenes (11% vs. 3%, p = 0.02), and dizziness (6% vs. 4%, p = 0.28). The trial was not adequately powered to report safety but was good quality for harms reporting.69

Sulprostone. In one population-based case series of 1,370 women treated with sulprostone, 51 women (3.7%) experienced at least one side effect.70 These side effects included digestive effects (n = 34), hyperthermia and chills (n = 7), cardiac effects (n = 5), high blood pressure (n = 2), respiratory effects (n = 2), and dizziness (n = 2). The cardiac side effects (tachycardia, n = 1; atypical chest pain, n = 1; ischemia, n = 3) were considered severe by the investigators and resolved with cessation of sulprostone. Other severe harms included acute hypertension in one woman and acute cyanosis in a woman with asthma, both of which also resolved with cessation of sulprostone. This study, which is part of family of studies reporting on a systems-level intervention for PPH,37, 70, 81 was rated as poor quality for harms reporting.

Methylergonovine maleate. One cohort study (rated good quality for harms reporting) used data from U.S. hospital admissions collected over 4 years to identify women who had been given methylergonovine maleate during hospitalization for birth (n = 139,617) and those who had not (n = 2,094,013).60 The study compared rates of myocardial ischemia and infarction in the exposed and unexposed women. Six women in the methylergonovine maleate group and 52 in the non-methylergonovine maleate group had an acute coronary syndrome (composite of acute myocardial infarction and unstable angina). The adjusted relative risk of developing an acute coronary syndrome associated with methylergonovine maleate exposure was 1.67 (95% CI: 0.40 to 6.97), and the risk difference was 1.44 per 100,000 patients (95% CI: -2.56 to 5.45). Four women in the methylergonovine maleate group and 44 in the non-exposed group had an acute myocardial infarction (RR for infarction associated with methylergonovine maleate = 1.00m 95% CI: 0.20 to 4.95, risk difference per 100,000 patients = 0, 95% CI: -3.47 to 3.47).

Carboprost tromethamine. One-fifth (n = 48/237) of the participants in a population-based case series experienced a side effect attributed to the drug. Harms reported included diarrhea (11.4%), elevated blood pressure (6.8%), vomiting (6.8%), elevated temperature (2.1%), flushing (1.7%), and tachycardia (1.7%). Quality for the reporting of harms was assessed as poor.71

Recombinant activated factor VIIa (rFVIIa). Five studies (one good76 and four poor quality for harms reporting73-75, 80) with rFVIIa as an intervention reported harms. Two women who received rFVIIa in a retrospective cohort study73 (n = 26) experienced adverse events that may be related to the medication. These included pulmonary edema (n = 1) and PE (n = 1). Neither of these events occurred in women who did not receive rFVIIa (n = 22), but this may be due to the small sample size rather than evidence of an effect of the medication.73 One case-control study reported one case of acute respiratory distress syndrome (ARDS) among the six women who received rFVIIa. There were no long term sequelae, though exact long term complications of interest were not described.74 In a population-based case series, adverse events potentially related to rFVIIa in the 92 women to whom it was administered included thromboembolism (n = 4; 2 had PE, one had bilateral ovarian vein thrombosis, and one had a thrombus involving the jugular and subclavian vein, upper arm, and axilla that was not thought to be related to rFVIIa), myocardial infarction (n = 1), and allergic reaction (n = 1). None of these events occurred in women who did not receive rFVIIa (n = 16), but this may be due to the small sample size.75

Two studies reported data from the same rFVIIa registry for differing time periods; however, because the overlap between studies is not clear, we report these studies separately. In one study, rated as good quality for harms reporting, and including 105 women with PPH, adverse events potentially related to rFVIIa included cerebrovascular accident (n = 1), deep venous thrombosis (n = 1), and pulmonary embolism (n = 1).76 The other study reporting data from this registry included 175 cases of rFVIIa use for PPH and reported that 15 women (8.6%) had thromboembolic adverse events, the most common of which were venous thrombosis among five women (2.9%), disseminated intravascular coagulation in nine (5.1%), and other thrombosis in three (1.7%). There were two arterial thrombotic events including one (0.6%) myocardial infarction. 80

##### Transfusion for Supportive Management of PPH

Seven studies reported harms of transfusion for PPH management.37, 61, 63, 65, 70, 81, 83, 84, 86 One retrospective cohort study included 659 women who received whole blood transfusion, 593 who received packed red blood cells (PRBC) only, and 288 who received a combination of blood products. There was a significant difference in the number of women who experienced acute tubular necrosis (0.3% whole blood only vs. 2% PRBC only vs. 4% combinations), acute respiratory distress (0.5% vs. .3% vs. 2%), pulmonary edema (7% vs. 4% vs. 14%), and hypofibrinogenemia (0.2% vs. 0.3% vs. 16%).83 In another retrospective cohort study, there were no thrombotic complications or adverse reactions to cryoprecipitate or fibrinogen concentrate among 34 women receiving either treatment.84 In a population-based case series addressing the thromboembolic risk associated with severe PPH and blood replacement therapies in 317 women with severe PPH (defined as uterine bleeding in the first 24 hours after birth, persisting after manual exploration of the uterine cavity and requiring IV uterotonics with a decrease of hemoglobin > 40g/l^-1^, or > 4 U RBCs, hemostatic intervention or death), none of the women developed symptomatic deep vein thrombosis (DVT) or PE.61 Three women developed superficial venous thrombosis (SVT). Severe PPH or packed RBC unit transfusions were found to be a risk factor for SVT. Other variables, such as cesarean birth, absence of low molecular weight heparin use, pre-eclampsia, severe pre-eclampsia, HELLP syndrome, placenta abruption, pregnancy loss, unexplained pregnancy loss, or F12C46T polymorphism were found to be significant risk factors for SVT. In one report from a larger, systems-level RCT 37, 70, 81 that included 660 women who received a transfusion, five transfusion-related adverse events (not described) occurred. The investigators considered one case of pulmonary edema to be a severe harm.81 A pre-post study comparing transfusion with a combination of red blood cells, fresh frozen plasma, and platelets vs. a combination of red blood cells, platelets, and fibrinogen concentrate in 93 women with PPH reported the development of transfusion-associated circulatory overload in four women in the non-fibrogen period and none in the fibrinogen period (p=.04).86

Another retrospective case series including 104 women requiring transfusion for PPH reported pulmonary complications in 2.8 percent of women and cardiac complications in 1 percent but did not describe complications further.63 A final series included 71 women with PPH and assessed the risk of developing transfusion-related acute lung injury (TRALI) associated with transfusion.65 Of these 71 women, 13 met criteria for a diagnosis of TRALI as they developed new-onset hypoxemia within 6 hours of transfusion without cardiogenic or other cause, and one woman met criteria for possible TRALI with the same symptoms but an alternative risk factor as a possible cause of symptoms. Women with pregnancy-related hypertensive disorders were more likely to develop TRALI (36% vs. 5% in the TRALI vs. no TRALI groups, p=0.006). Age, smoking status, pre-existing morbidities, non-pregnancy related hypertensive disorders, parity, caesarean section, and the need for surgical intervention were not associated with the development of TRALI.

We rated one study as good quality for harms reporting,65 and six as poor quality for harms reporting.

#### Procedures

Uterine balloon tamponade. Only one adverse event was reported among 43 women who had intrauterine balloon tamponade (Bakri balloon) in a pre-post study with poor quality for harms reporting. One woman was diagnosed with endometritis, which was successfully treated with antibiotics.87 Harms associated with Rusch balloon tamponade in one retrospective case series (poor quality for harms) included one case of inadvertent discharge of the balloon and two cases of postpartum sepsis. Among the 31 of 42 women who did not have hysterectomy and were available for followup 4 to 108 months after the tamponade procedure, seven had had subsequent pregnancies, with four term births, two early abortions, and one ectopic pregnancy. The study did not report the number of women desiring pregnancy; however, 9 of 31 did not desire pregnancy because of psychological trauma associated with the previous pregnancy, and one had difficulty conceiving.89 Another poor quality case series including 50 women reported two cases of spontaneous expulsion of a Bakri balloon for uterine tamponade and no other complications due to the balloon.90

Embolization. Sixteen studies (in multiple publications) reported harms in women who underwent embolization (Table 19); 49, 91-95, 97-106, 108, 109 however, the harms reported in these studies are diverse and few studies report the same harms. Table 20 summarizes adverse events of embolization that were comparably reported in two or more studies. The most frequently reported adverse events were infertility (0-43%), PPH in subsequent pregnancy (5%-23%), spontaneous abortion in subsequent pregnancy (5%-21%), and hematoma at a puncture site (1-6%). Although authors report PPH in subsequent pregnancy, it is likely related to history of PPH, which increases risk of recurrence, rather than the intervention.123, 124

Table 19 Harms reported in embolization studies

Author Year Country Study Design | Quality | n | Followup n Duration | Reported Harms
Kim et al., 2013 100 Korea Retrospective case series | Good | 257 | 257 NR | - Paresthesia in the posterior thigh (n = 10, 4%); - Uterine abscess (n = 3, 1%); - Postembolization syndrome (n = 2, 1%)
Lee et al., 2013 105 Korea Retrospective case series | Good | 176 | 148 Mean: 22.4 months (range: 2-58) | - Postembolization syndrome (n = 13, 9%); - Hematoma at the arterial puncture site (n = 3, 2%); - Heavier menses (n = 5, 3%); - Lighter menses (n = 17, 11%); - Dysmenorrhea (n = 1, 0.7%); - Uterine infarctions (n = 0); - Ischemic injuries (n = 0); - Neurologic complications (n = 0); - Major complications, not specified (n = 0); - Complications in subsequent pregnancies: preterm birth (n = 2/13, 15%)
Lee et al., 2012 101 Korea Retrospective case series | Poor | 251 | 113 Mean: 30 ± 23 months (range 6-99) | - Dissection of the uterine arteries (n = 2, 0.8%); - Transient numbness of the lower extremities (n = 2, 1%); - Edema of the lower legs (n = 1, 0.4%); - Hematoma at the puncture site (n = 3, 1%); - Irregular menses (n = 2, 2%)
Inoue et al. 2014^108^ Japan Retrospective case series | Poor | 211 | 113 (76 for pregnancy outcomes) 3 months-3 years | - Amenorrhea (n = 7, 6%); - Intrauterine infection (n = 6, 5.3%); - Asherman syndrome (n = 4, 3.5%); - Uterine necrosis (n = 3, 2.7%); - Abnormal menses (n = 2, 1.8%); - “Overall complication rate”=13.3%; - Complications in subsequent pregnancies (n=42 pregnancies in 40 of 76 women followed post-embolization): preterm births (n=4/42, 9.5%), miscarriages (n=9/42, 21.4%), pregnancy terminations (indication not specified, n=3, 7.1%), recurrent PPH (n=7/42, 23.3%), placenta accreta (n=5, 16.7%)
Cheong et al.106 Korea Retrospective case series | Poor | 117 | 117 NR | - Uterine necrosis requiring hysterectomy (n = 3, 2.6%); - Fever >38.5ºC without focus of infection (n = 1, 1.7%); - Puncture site hematoma (n = 1, 1.7%)
Zwart et al., 2010 109 Netherlands Prospective cohort | Poor | 114 | 114 NR | - Infection (n = 9, 8%); - Acute respiratory distress syndrome (n = 1, 1%); - Laparotomy (n = 3, 3%); - Ischemic complaints (n = 2, 2%); - Maternal death (n = 3, 3%), no details provided
Gaia et al., 2008 98 France Retrospective case series | Poor | 113 | 107 Mean ± SD: 46.4 ± 21.8 months (range: 12-84) | - Pulmonary embolism (n = 2, 2%); - Acute pulmonary edema (n = 1, 1%); - Myocardial infarction (n = 1, 1%); - Femoral vein thrombosis (n = 5, 4%); - Urinary disorders (n = 8, 7%); - Vaginal dryness (n = 11, 10%); - Hot flushes (n = 13, 12%); - Dyspareunia (n = 14, 13%); - Menorrhagia (n = 10, 10%); - Oligomenorrhea (n = 23, 21%); - Amenorrhea and diffuse uterine synechiae (n = 6, 6%); - Infertility (n = 11/29 desiring pregnancy, 38%); - Complications in subsequent pregnancies: spontaneous abortion (n = 1/19, 5%), PPH (n = 3/18, 17%)
Touboul et al., 2008 103 France Retrospective case series | Poor | 102 | 102 NR | - Ischemia of the lumbar plexus (n = 1, 1%); - Gluteal pain (n = 1, 1%)
Sentilhes et al., 2011^92-94^ France Retrospective cohort | Poor | 101 | 68 (fertility and psychological outcomes) Mean: 71.4 months (range: 12-152 months) | - Buttock necrosis requiring debridement (n = 1, 1%); - Pulmonary embolism (n = 1, 1%); - Postpartum myocarditis (n = 1, 1%); - Puncture site hematoma (n = 1, 1%); - Postpartum fever (n = 22, 22%); - Endometritis (n = 14, 14%); - Wound infection (n = 8, 8%); - Increased menstruation (n = 11, 16%); - Amenorrhea or decreased menstrual flow (n = 15, 22%); - Synechia (n = 8, 12%); - Ovarian insufficiency (n = 7, 10%); - Infertility (13/30 desiring pregnancy, 43%) although the authors state there was no secondary infertility; - Complications in subsequent pregnancies: miscarriage (n = 4/26, 15%), ectopic pregnancy (n = 1/26, 4%), uteroplacental insufficiency (1/19, 5%), recurrent PPH (n = 6/19, 32%); Psychological outcomes (may be due to PPH or PPH+treatment); - Symptoms requiring psychological care post-PPH (n = 2, 3%); - Fear of death post-PPH (n = 24, 35%); - Negative memory of pain post-PPH (n = 13, 19%); - Negative memory of separation from baby post-PPH (n = 6, 9%); - Complete amnesia about the birth (n = 3, 4%); - Think about event at least once/month (n = 16, 24%); - De novo phobia post-PPH (n = 5, 7%); - Persistent fear of death (n = 5, 7%); - Impossible to have sexual intercourse for ≥ 12 months (n = 4, 6%); - Marital problems considered related to event (n = 3, 4%); - Fear of PPH recurrence that lead to decision to avoid further pregnancy (n = 14, 21%); - Partners' negative feelings about PPH lead to decision to avoid further pregnancy (n = 13, 19%); - Anxiety or depression in subsequent pregnancy related to prior PPH (n = 16, 24%)
Poujade et al., 2012 102 France Retrospective case series | Poor | 98 | 98 NR | - Pulmonary edema (n = 1, 1%); - Uterine necrosis (n = 1, 1%); - Hysterectomy due to UAE-associated uterine necrosis (n = 1, 1%); - Endometritis (n = 11, 11%); - Wound infection (n = 1, 1%)
Ganguli et al., 2011 99 US Retrospective case series | Poor | 66 | 66 NR | - Lower extremity DVT (n = 1, 2%); - Pancreatitis (n = 1, 2%); - Endometritis (n = 1, 2%); - Minor complications, not specified (n = 0)
Kim et al., 2013^49^ Korea Retrospective cohort | Poor | 60 | 60 2 years | - Transient fever > 38.5°C (n = 11, 18%); - Infection per blood culture findings (n = 0); - Ovarian failure (n = 1, 2%)
Fiori et al., 2009 97 France Retrospective case series | Poor | 56 | 34 Median 44.4 months (range: 8.3-118.2) | - Hypomenorrhea due to partial corporeal uterine synechiae: (n = 1, 3%); - Irregular menstrual bleeding (n = 1, 3%); - Infertility (n = 2/15 desiring pregnancy, 13%); - Complications in subsequent pregnancies: spontaneous abortion (n = 3/20, 15%) and ectopic pregnancy (n = 1/20, 5%), preterm birth (n = 1/12, 8%), PPH (n = 1/12, 8%)
Yamasaki et al., 2013 104 Japan Retrospective case series | Poor | 55 | 55 NR | - Fever (n = 6, 11%); - Lower limb neuropathy (n = 1, 2%); - Uterine necrosis (n = 2, 4%); - Hysterectomy due to UAE-associated uterine necrosis and infection (n = 2, 4%)
Hardeman et al., 2010^91^ France Case-control | Poor | 53 | 53 Range:12-70 months | - Pain and fever (n = 19, 36%); - Hematoma/inguinal pain (n = 3, 6%); - Metrorrhagia (n = 2, 4%); - Amenorrhea (n = 3, 6%); - Infertility (2/14 desiring pregnancy, 14%); - Complications in subsequent pregnancies: late miscarriage (n = 1/14, 7%), recurrent PPH (n = 2/12, 17%)
Chauleur et al., 2008^95^ France Retrospective cohort | Poor | 46 | 46 Range: 2-11 years | - Allergy to iodine (n = 1, 2%); - Acute pulmonary edema related to massive volume expansion (n = 1, 2%); - Hematoma from the puncture site resulting in cardiovascular instability (n = 1, 2%); - Major hemoperitoneum related to dissection of the epigastric artery (n = 1, 2%); - Infertility (n = 0/16 desiring pregnancy); - Death from methotrexate-related nephrotoxicity in one woman with placenta percreta given methotrexate in conjunction with embolization; death appears to be related to treatment but not to embolization; - Complications in subsequent pregnancies: spontaneous abortion (n = 1/19, 5%), twin pregnancy with preterm birth and fetal growth restriction (n = 1/19, 5%), PPH (n = 1/19, 5%)

Abbreviations: DVT = deep vein thrombosis; n = number; NR = not reported; PPH = postpartum hemorrhage; SD = standard deviation; UAE = uterine artery embolization

Table 20 Adverse events reported in multiple embolization studies

Adverse Event | Number of Studies | Incidence
Spontaneous abortion in subsequent pregnancy | 6^91, 92, 95, 97, 98, 108^ | 5%-21.4%
Hematoma at puncture site | 6^91, 94, 95, 101, 105, 106^ | 1%-6%
PPH in subsequent pregnancy | 5^91, 95, 97, 98, 108^ | 5%-23.3%
Infertility | 5^91, 92, 95, 97, 98^ | 0-43%
Amenorrhea | 4^91, 92, 98, 108^ | 6%-22%
Preterm birth in subsequent pregnancy | 4^95, 97, 105, 108^ | 5%-15%
Fever | 4^49, 94, 104, 106^ | 1.7%-22%
Uterine necrosis | 4^102, 104, 106, 108^ | 1%-4%
Endometritis or intrauterine infection | 4^94, 99, 102, 108^ | 2%-14%
Lighter menses | 3^97, 98, 105^ | 3%-21%
Heavier menses | 3^92, 98, 105^ | 3%-20%
Irregular menses | 3^91, 97, 101^ | 2%-4%
Infection, not defined or wound infection | 3^94, 102, 109^ | 1%-8%
Thromboembolic event (DVT or PE) | 3^94, 98, 99^ | 1%-4%
Lower extremity neuropathy, including numbness or paresthesia | 3^100, 101, 104^ | 1%-4%
Pulmonary edema | 3^95, 98, 102^ | 1%-2%
Ischemia | 3^103, 105, 109^ | 0-2%
Ectopic pregnancy in subsequent pregnancy | 2^97, 115^ | 4%-5%
Postembolization syndrome | 2^100, 105^ | 1%-9%

Abbreviations: DVT = deep vein thrombosis; PE = pulmonary embolism; PPH = postpartum hemorrhage

#### Surgical Interventions

Uterine compression sutures. One case-control study of good quality for harms compared outcomes in the subsequent pregnancy in women who had PPH treated with multiple square or Hayman sutures in the index pregnancy (n=42, mean age=34.8±3.0 years, nulliparous=39) and age- and parity-matched women who had a cesarean birth (n=139, mean age=33.8±3.2, nulliparous=136).62 Women did not differ significantly in terms of parity, cesarean births, age, interval to next pregnancy, method of conception, or singleton pregnancy. Adverse outcomes did not differ between groups (preterm birth= 2 in suture group vs. 7 in control group; miscarriage=4 in suture group vs. 14 in control group; ectopic pregnancy=1 in suture group vs. 2 in control group; fetal or perinatal loss=1 in suture group vs.1 in control group; chromosomal abnormality=0 in suture group vs. 1 in control group). More women in the suture group had pelvic adhesions in the subsequent pregnancy compared with the control group (34.3% vs. 17.5%, p=.03). Three women in the suture group and two in the control group had PPH in the subsequent pregnancy (p=ns).

Another retrospective case-control study of good quality for harms reporting compared adverse pregnancy outcomes (after 24 weeks gestation) in the subsequent pregnancy in women who had PPH and a B-Lynch suture (n=63) and women who had PPH managed without B-Lynch sutures (n=189).66Women in the non-B-Lynch group were treated with transfusion (n=25), artery ligation (n=7), and uterine artery embolization (n=2). Other treatment modalities were not specified. Groups did not differ at baseline on age, BMI, or adverse outcomes in the index pregnancy, but women in the suture group were less likely to be nulliparous, have greater estimated blood loss, and greater likelihood of blood loss than those who did not receive sutures (all p values<.05). Adverse pregnancy outcomes (abnormal placentation, preeclampsia, preterm birth, impaired fetal growth) did not differ significantly between groups. In analyses adjusted for use of suture in the index pregnancy, blood loss, parity, and prior adverse outcomes, there was no association between use of B-Lynch sutures and risk for any adverse outcome in the next pregnancy.

Uterine and other pelvic artery ligation. One retrospective cohort (poor quality for harms) reported a case of “secondary hysterectomy disunion with sepsis” (not clearly described) following ligation.96 This study also reports fertility outcomes for an unstated number of women who had ligation: among the number followed, 10 planned another pregnancy and seven were able to conceive 1 to 4 years post-ligation. A retrospective case series described 265 women who underwent uterine artery ligation to treat PPH after a cesarean.112 Two of the women who had uterine artery ligation had small broad ligament hematomas. None of the women experienced a major complication or long-term adverse effects. This study was rated poor quality for harms reporting.

Uterine compression sutures and uterine and other pelvic artery ligation. In one poor quality retrospective case series including 56 women with PPH who underwent triple uterine artery ligation with (n=43) or without (n=13) concomitant uterine compression sutures,113 two women developed endometritis requiring antibiotics (3.6%).

In another retrospective case series of poor quality for harms reporting, 539 women underwent a variety of surgeries involving uterine compression sutures and arterial ligation. Five women had inadvertent ligation of the ureters, and one woman developed uterine necrosis. At 6 to 12 months after surgery, 404 women had a hysteroscopy (n = 100) or MRI (n = 304). Endometrial adhesions were present in three of the women who had hysteroscopy. None of the women who had MRI had endometrial adhesions or uterine morphological alterations. The study also notes 116 successful, spontaneous pregnancies in the study period, but the number desiring pregnancy and the method and timing of followup is not clear.111

Hysterectomy. Nine studies reported harms of hysterectomy.45, 49, 64, 109, 110, 114-117 In a prospective cohort study, complications among 108 women who underwent hysterectomy included urinary tract lesions (n = 11, including 8 bladder and 3 ureter lesions), ovarian removal (n = 8), infection/abscess (n = 8), relaparotomy (n = 15, including one case of burst abdomen), Sheehan syndrome (n = 4), paralytic ileus (n = 3), DVT/PE (n = 3), and other (n = 2, exact harm not reported).109

Harms reported in a retrospective cohort study of 61 women who had a hysterectomy included 14 cases of transient fever and two skin wounds. Blood cultures did not identify any infections.49

Reported harms in a retrospective case series of 52 women who had an emergency hysterectomy included ureteric injury (n = 4 women), bladder injury (n = 3), small bowel injury (n = 2), urinary tract infection (n = 4), septicemia (n = 3), wound infection (n = 4), ARDS (n = 9), renal failure (n = 2), DIC (n = 11), repeat surgery (n = 15), and cardiac arrest (n = 2).110 This authors did not distinguish which harms were specific to hysterectomy, but some of the adverse events (e.g., ARDS and renal failure) are likely unrelated to the surgical intervention.

In one population-based case series reporting data from the UKOSS, 18 of 315 women (6%) undergoing hysterectomy had a return to the operating room for a second surgery due to damage to other organs during hysterectomy.116 Damage to organs such as ovaries (n = 28), bladder (n = 38) or ureters (n = 14) was reported in 67 women (21%).

In one U.S. population-based case series reporting on 2,209 peripartum hysterectomies, 715 hysterectomies were performed at low volume, 867 at intermediate volume, and 627 at high volume hospitals.45 Harms included intraoperative injury and surgical and medical complications. Rates of bladder injury ranged from 7 to 9 percent across hospital types; ureteral injury ranged from 2 to 3 percent; intestinal injury from 3 to 4 percent; and vascular and “other” (not defined) injures from 0 to10.7 percent. Rates of intraoperative injuries did not vary significantly across hospital types. Wound complications were higher in low volume hospitals (9.9%, 6.8%, 6.7% in low, intermediate, and high volume hospitals, respectively). Postoperative hemorrhage rates were 4.3 percent at intermediate volume, 5.9 percent at high volume, and 6.9 percent at low volume hospitals (p = ns). Rates of venous thromboembolism ranged from 0.8 to 2.2 percent (p = ns). Pulmonary complications were lowest in high volume hospitals (9.7%) compared with intermediate (12.6%) and low volume hospitals (14.1%), p = .05. Cardiovascular, gastrointestinal, and infectious complications ranged from 4.3 to 6.4 percent, 7.3 to 8.8 percent, and 11.6 to 12.4 percent, respectively and did not differ significantly across hospital types. Volume was not associated with rates of intraoperative injuries or medical complications in analyses adjusted for age, race, year of diagnosis, insurance status, hospital type, and hospital size. The incidence of perioperative surgical complications, however, was lower in high volume hospitals compared with low volume (OR 0.66, 95% CI: 0.47 to 0.93).

A population-based case series from Denmark with 152 women reported the following complications after hysterectomy: reoperation (n = 16), infection (n = 13), bladder lesion (n = 10), oophorectomy (n = 8), ureter lesion (n = 3), abscess (n = 3), death (n = 2), and pulmonary embolism (n = 1).115 No details are provided about the women who died.

In one Canadian retrospective review (rated poor quality for harms) of hysterectomies conducted at one institution over 28 years, 56 women (out of 30290 births) had emergency obstetric hysterectomies.64 Harms reported included febrile morbidity (n=31), ureteric injury (n=23), renal failure (n=19), pulmonary atelectasis (n=18), wound infection (n=17), septicemia (n=13), psychological disturbance (n=13), hypovolemia (n=12), and pelvic abscess (n=9)

In another U.S. case series (good quality for harms) including 55 peripartum hysterectomies, investigators classified complications into hematologic (anemia, coagulopathy), infectious (fever, bacteremia), gastrointestinal (ileus), pulmonary (edema, effusion, emboli), genitourinary (urinary retention, hydronephrosis, tubular necrosis), cardiovascular (cardiomyopathy, pericardial effusion), psychiatric (depression), neurologic (encephalopathy), and other (reoperation, readmission, death, wound dehiscence, hematoma, hypokalemia, thrombosis).117 Women had an average of 2.1±1.2 complications, with most having hematologic (98%) or infectious (54.6%) complications. Eighteen percent of women had other complications, 16 percent of women had pulmonary complications, 10.9 percent had genitourinary, and gastrointestinal, cardiovascular, and psychiatric complications were each experienced by 3.6 percent of women. Less than 2 percent (1.8%) had neurologic complications.

Finally, one Canadian population-based case series reports postoperative complications in 87 women undergoing peripartum hysterectomy: anemia (n = 32), DIC (n = 17), ileus (n = 8), fever (n = 7), depression (n = 1), hematoma (n = 1), and pneumonia (n = 1).114 This study also did not distinguish which adverse events were thought to be related to hysterectomy versus other causes.

Eight of these studies were assessed as poor quality for reporting harms and one was of good quality.117 Table 21 outlines harms reported in more than one study. Reoperation is included in the harms for hysterectomy (and not for other procedures or surgical interventions) because it is typically considered the final surgical intervention and no further procedural or surgical intervention should be expected.

Table 21 Harms reported in multiple hysterectomy studies

Harm | N Studies Reporting | Incidence
Ureter lesion | 6^45, 64, 109, 110, 115, 116^ | 0.4%-41%
Any Infection | 5^45, 64, 109, 110, 115, 117^ | 7%-54.6%
Reoperation^a^ | 5^109, 110, 115-117^ | 1.8%-29%
Bladder lesion | 5^45, 109, 110, 115, 116^ | 6%-12%
Fever | 3^49, 64, 114^ | 8%-55%
DVT/PE | 3^45, 109, 115^ | 1%-3%
Psychological effects | 2^64, 117^ | 3.6%-23%
Ileus | 2^109, 114, 117^ | 3%-10.9%
DIC | 2^110, 114^ | 20%-21%

a Note: reoperation rates in one study117 could have included readmission, death, hematoma, wound dehiscence, hypokalemia, ovarian vein thrombosis.

Abbreviations: DIC = disseminated intravascular coagulation; DVT = deep vein thrombosis; N = number; PE = pulmonary embolism

Curettage. Two retrospective case series, both of poor quality for harms reporting, described women who were treated with curettage for secondary PPH.120, 121 In a series of 99 women, two had documented cases of Asherman syndrome on follow-up and one had uterine perforation from curettage that required repair via laparotomy.121 In a series of 85 women, three had uterine perforation, one of whom underwent hysterectomy.120 These were the only harms reported in these studies.

Combined interventions. One prospective cohort study of 272 women addressing multiple second-line therapies (embolization, uterine compression sutures, ligation, and rFVIIa) reported ARDS (five cases), pulmonary edema (11 cases), and cardiac arrest (six cases). The study also reports six instances of the following harms but does not clarify the number of cases of each: hypoxic brain injury, renal failure, pulmonary embolism, and bladder damage after hysterectomy. The study also does not clarify if any of the reported harms were due to intervention or the PPH itself. This study was assessed as poor quality for harms reporting.77

In a retrospective cohort study including 168 women with secondary PPH treated initially with either medical approaches or surgical evacuation, two women in the surgical group had uterine perforation.119 At followup, 12.1 percent of the medical group (n = 90, mean 88.3 months after PPH) and 30.8 percent of the surgical group (n = 41, mean 81.6 months after PPH) had secondary infertility. (p = .06).The majority of the women (74% of medical group and 65% of surgical group) desired a subsequent pregnancy. More women in the surgical group (28%) than medical group (11%) required infertility treatments, but this difference was not significant. The mean number of births among those who conceived was 1.5 in the medical arm and 2.8 in the surgical arm (p = .004) Miscarriages did not differ between groups, and 3 percent of women in the medical group and 16 percent in the surgical arm required adhesiolysis (p = .003) in the followup period. We rated this study as good quality for harms reporting.

## KQ4 Effectiveness of Interventions To Treat Acute Blood Loss Anemia in Women With Stabilized PPH

### Key Points

- One small RCT reported elevations in hemoglobin in women with anemia after PPH receiving either oral or intravenous iron with no significant between group differences.
- One small RCT reported a decrease in fatigue and improvements in quality of life among women with asymptomatic anemia after PPH treated with transfusion, but differences between groups were not significant.
- Strength of the evidence is insufficient for all outcomes and harms in studies of interventions for anemia after PPH given the few studies, small number of participants, and differences in intervention approaches.

### Overview of the Literature

We identified few studies addressing anemia after PPH is stabilized. Two studies (reported in multiple publications) addressed iron supplementation and transfusion. We did not identify studies of erythropoietin stimulating agents or other interventions. The two RCTs addressing interventions for post-PPH anemia were both rated as poor quality for all effectiveness outcomes and good125, 126 and poor127 quality for harms.125-127Studies were conducted in Australia127 and the Netherlands125, 126 and assessed transfusion and iron supplementation in women with stabilized hemorrhage. The RCTs included a total of 593 women followed for 6 weeks post-birth.

### Detailed Analysis

A randomized non-inferiority trial, rated as poor quality for all effectiveness outcomes and good quality for reporting of harms, conducted in the Netherlands compared the effect of PRBC transfusion versus no intervention on quality of life among women with anemia due to PPH at 37 Dutch university and general hospitals.125, 126 Eligible women were enrolled between 12 and 24 hours after birth, and had a hemoglobin concentration between 4.8 and 7.9 g/dl after experiencing PPH (defined as blood loss of ≥ 1000 mL and/or decrease hemoglobin concentration of ≥ 1.9 g/dl). Women with severe symptoms of anemia were excluded from the study. In total, 521 women were randomized to receive transfusion with PRBC (259 women) or no intervention (262 women). There were no significant differences in baseline characteristics between groups (no p-value reported), and there was no significant difference between baseline hemoglobin concentration (7.3 vs. 7.4 in the transfusion vs. non-intervention groups, p = 0.56). The hemoglobin at discharge was significantly higher among women receiving transfusions than those that did not (9.0 g/dL vs. 7.4 g/dL in the transfusion vs. non-intervention groups, p < 0.001), but there was not a statistically significant difference in hemoglobin concentration between groups at 6 weeks (12.1 g/dL vs. 11.9 g/dL in the transfusion vs. non-intervention groups, p = 0.18). The non-intervention group had greater mean fatigue, but the difference in mean physical fatigue between groups did not meet pre-specified non-inferiority parameters and was negligible overall. There was no significant difference in health-related quality of life between groups after removing questions not answered within the study timeframe. There was also no significant difference between groups in rate of postpartum depression, which was only reported in one woman in the entire study.126There was no difference between the groups in rates of breastfeeding at 6 weeks (64% vs. 71% in the transfusion vs. non-intervention groups, p = 0.30). There was no difference between the transfusion and no transfusion groups in length of stay or in complications (transfusion reactions, thromboembolic events, urinary tract infections, infected surgical wound, infected episiotomy/rupture, endometritis, and total infectious complications [10.5% vs. 11.4% in the transfusion vs. non-transfusion groups, p = 0.90]).

An Australian RCT (rated as poor quality for all outcomes) compared the effectiveness of intravenous versus oral iron supplementation among anemic women with PPH.127 Eligible participants were women with iron-deficiency anemia (hemoglobin < 110 g/L and ferritin < 12 μg/L) after PPH. Women were identified within 72 hours of cesarean or vaginal birth with blood loss > 500mL. Women (74 total) were enrolled over a 2-year period, and were randomized to either two intravenous infusions of 200 mg of iron sucrose (31 women) or daily oral ferrous iron sulfate tablets (43 women, total 160 mg iron daily) for a six-week period following enrollment. Hemoglobin and ferritin levels were measured at baseline and on days 1, 14, and 42, and transfusion of PRBC and drug reactions were documented. There was no statistically significant difference in mean hemoglobin levels at any time point between the intravenous and oral iron supplementation groups (baseline hemoglobin 96 vs. 95, p = 0.5; hemoglobin on day fourteen 115 vs. 118, p = 0.2, and hemoglobin on day forty-two 124 vs. 127, p = 0.7 in the IV intravenous iron vs. oral iron groups, respectively). Ferritin was significantly higher on days 14 and 42 among women in the intravenous iron repletion group than the oral iron repletion group (ferritin on day fourteen 101 vs. 37, p < 0.001; ferritin on day forty-two 46 and 19 and p = 0.01). There was no statistically significant difference in rate of red blood cell transfusion between the treatment groups. The study reports arrhythmia in one participant and notes that no other adverse reactions occurred. Table 22 summarizes key outcomes in these studies.

Table 22 Key outcomes in studies in women with stabilized PPH and anemia

Author, Year Country Groups (n) Quality | Age, Years Parity | Key Outcomes
Prick et al. 2014^125, 126^ Netherlands G1: Red blood cell transfusion following resolved PPH (258) G2: No transfusion (261) Quality: Poor for all outcomes | Age, mean ± SD G1: 30.7 ± 5.0 G2: 30.9 ± 5.3 Nulliparous, n (%) G1: 152 (59) G2: 143 (55) | - 13% of G2 also received transfusion for anemic symptoms, blood loss, endometritis, inability to tolerate parenteral iron; - G1 received a median of 2 red blood cell units and at discharge had a median Hb concentration of 9.0 g/dl ( range: 8.5-9.5) vs. 7.4 (range: 6.8-7.7) in G2, p < .001; - Hb concentration at 6 weeks was not significantly different between groups (12.1 vs. 11.9 g/dl); - LOS did not differ between groups (median 2 days); - Physical fatigue scores were statistically significantly higher in G2 vs. G1 at all time points though the differences were not clinically significant; - Harms in both groups included transfusion reactions, infections, endometritis, thromboembolic events; group differences were not significant
Froessler et al. 2013^127^ Australia G1: IV iron sucrose (31) G2: Oral iron sulfate (43) Quality: Poor for all outcomes | Age, median (range) G1: 28 (26-32) G2: 30 (26-34) Parity NR | - Hb increased significantly in both groups by Day 14 and remained elevated at Day 42; G1: mean at baseline 96 g/dL (range: 87-102) and at Day 42 124 g/dL (118-132); G2: mean at baseline 95 g/dL (range: 89-106) increased to 127 g/dL (range:120-132); - No differences in Hb levels between the groups at any time point; - Increased levels of ferritin in both groups, however time course of changes differed by treatment; levels were significantly increased for G1 from baseline 18 mg/L (range: 11-32), at Day 14 mean 101 (range:82-114) and Day 42 mean = 46 (range: 24-64) while levels for G2 baseline mean = 21 (range:24-52) were increased only at Day 14 = 37 (range: 24-52), and had dropped to by day 42 = 19 (range: 13-33); - Ferritin levels were significantly higher for G1 vs. G2 at Day 14 and Day 42; - Blood loss at birth was comparable for both groups (mean 775 mL for G1 and 800 mL for G2); - No serious drug reactions observed (one patient excluded due to arrhythmia during first iron transfusion but since she had prior occurrence it was deemed not related)

Abbreviations: G = group; Hb = hemoglobin; LOS = length of stay; n = number; NR = not reported; PPH = postpartum hemorrhage; rFVIIa = recombinant activated factor VIIa; SD = standard deviation

## KQ5 Effectiveness of Systems-Level Interventions for Management of PPH

### Key Points

- No clinical trials demonstrate effectiveness of a systems-level intervention for reducing severity of PPH or improving maternal outcomes.
- The sole cluster randomized trial in 106 French maternity units, with more than 146,000 births, used a multicomponent intervention of academic detailing of protocols, local champions, protocol reminders, and peer review compared to passive dissemination. Prevalence of severe PPH did not differ between arms.
- In general, multicomponent systems-level interventions do not reliably reduce severity of PPH.
- Three European pre-post publications used audit of PPH cases with feedback to teams and individual providers. Two reported significantly reduced incidence of severe PPH, in each case by more than 1 percent absolute risk among total births, and in an extended follow-up of one intervention, sustained at 0.6% among vaginal births.
- No U.S. studies relied primarily on audit and feedback.
- One large and diverse hospital system with 32,059 births across the study period used a detailed clinical staging and care algorithm to manage PPH and reduced blood product use by 26 percent.
- A large urban teaching hospital in U.S., that dramatically revised clinical responsibilities of residents and attending physicians, had no maternal mortality from PPH in a 36-month intervention period that followed a 24-month window with two maternal deaths. Overall PPH severity did not change.
- In a subsequent report, this teaching hospital found an increase in PPH diagnosis (p=0.002), increase in mean estimated blood loss (p = 0.014), and increase in the proportion of PPH with estimated blood loss greater than 1500 mL (p=0.010), though use of uterotonics, balloon tamponade, B-Lynch sutures and embolization increased (p ≤ 0.05). Transfusion, postpartum hysterectomy, and ICU admission did not decline (p > 0.05) though length of stay in ICU was shorter.
- Strength of the evidence is moderate for a lack of benefit for systems-level interventions in reducing PPH incidence or severity; preventing hysterectomy; and affecting ICU admissions. Strength of the evidence is moderate for no effect on the need for transfusion and insufficient for effects on mortality.

### Overview of the Literature

We classified research as system-level interventions when an entire administrative unit within a health system was responsible for implementing policies or protocols that were intended to improve management of PPH. The level from which interventions were launched ranged from an entire region of a national health system, to multihospital collaborations, to individual department decisions about labor and delivery routines that encompassed all care providers. Interventions were varied and included broad multicomponent interventions, implementation of emergency response teams, and audit and feedback of outcomes data about severe PPH to groups and individual providers.

We identified a total of nine studies (reported in 11 publications) that were designed to investigate the effectiveness of one or more system-level interventions for reducing severity of PPH or improving specific maternal outcomes.34-37, 67, 68, 128-132 Six were of fair quality,36, 37, 67, 68, 128, 129, 132 and three were of poor quality.34, 35, 130, 131

Because system-level randomized trials are rare, we decided during design of this review that we would include studies that were not randomized but examined the influence of multicomponent systems-level interventions over time. Eight studies compared a baseline period with subsequent trends after implementation of the interventions intended to improve management of PPH and to reduce severity of adverse maternal consequences.34-36, 67, 128-130 Within this group one conducted formal trend analyses across a seven-year window beginning with launch.130, 131

For brevity in tables and text we have called these pre-post assessments. One publication provided outcomes from a randomized trial.37 The trial was conducted in 106 maternity units in defined maternity regions of France.37 Of the remaining pre-post studies, four were conducted in Europe,35, 36, 129-131 and four in the United States.34, 67, 68, 128, 132

When an entire system undertakes a change all the components are working in concert and are typically designed to do so. Given this intentional interaction between parts, the intervention that is being tested is the “bundle” of components that are being conducted together. For example the influence of audit and feedback in the context of an intervention that includes measuring blood loss, mock emergencies practice, and flow charts to track delivery of key treatments at specific intervals is being conducted in a different environment than audit and feedback in an intervention that does not measure blood loss, or use flow charts, but that did incorporate mock emergency practice.

At times in reviews of systems-level approaches the components are similar enough and the trials large enough that we can conduct meta-analyses of trials with well-operationalized outcomes to attempt (while noting the strong influence of context) to partially isolate the influence of a single component on outcomes. In this literature, the lack of a group of strong trials, the variation in implementation of even similar types of components, duplication of populations over time in publications, and wide range of operational definitions of outcomes, made such analysis implausible. We thus considered all components of an intervention as one systems-level intervention in our analyses below.

### Detailed Analysis

The outcomes of systems-levels interventions are summarized in Table 23 in reverse chronological order. We summarize outcomes by study design below.

Table 23 Systems-level interventions to improve management of PPH

Author, Year; Country | Study Type & Time Period | Setting & Population Pre: PPH cases/births Post: PPH cases/births | Management Strategies Addressed by Intervention | Outcomes
Dupont et al. 2014^130, 131^ France | Trend Analysis 2005 - 2012 Pre-Post 2005, 2008 | Level III maternity unit: 2005: 27/2,919 (1.2%) 2006: 25/3,113 (1.0%) 2007: 9/3,213 (0.7%) 2008: 9/3,213 (0.4%) 2009: 16/3,539 (0.6%) 2010: 13/3,966 (0.4%) 2011: 16/4,019 (0.5%) 2012: 18/4,085 (0.6%) 2 maternity units (level III and level II) Pre: 77/4500 (1.71% Post: 42/5112 (0.82) | Quarterly clinical audit meetings for review of all severe PPH after vaginal birth with trend feedback using process control tools Goal: reduce the incidence of severe PPH; with secondary goals of increasing use of four key management components | Severe PPH (defined by EBL>1500 cc or need for specified interventions including transfusion and surgical interventions) decreased by half (p < 0.001) System reached and maintained reduced PPH target in the first quarter of 2009. Trends for use of all four key management components document statistically significant increase in consistency of use. Pre-Post: Severe PPH declined from 1.52% to 0.96% of births at level III hospital (p = 0.048) and from 2.08% to 0.57% at level II hospital (p < 0.001)
Einerson et al. 2014^128, 132^ United States | Pre-Post 2007 - 2011 | Urban tertiary care hospital Pre: 5.3% Post: 6.0% Total cases n = 3105 Total n = 52,819 | Multicomponent evidence-based patient safety program to assist in management of PPH: education of all nursing and physician staff, introduction of a management checklist, universal use of active management of third stage Goal: sustained reduction in maternal morbidity from severe PPH | Increase in PPH diagnosis (p=0.002), increase in mean EBL (p = 0.014), and increase in the proportion of PPH with estimated blood loss greater than 1500 mL (p=0.010) Use of uterotonics, balloon tamponade, B-Lynch sutures and embolization increased (p ≤ 0.05) Transfusion, postpartum hysterectomy, and ICU admission did not decline (p > 0.05) though length of stay in ICU was shorter.
aShields et al. 2014^68^ United States | Pre-Post 2010, 2011 (2 mos prior, 5 and 10 mos after) | 29 hospital health system including range from small rural to large urban facilities | Labor and delivery nursing and physician education, with three progressive stages of intervention implementation via algorithm. Goal: reduce blood transfusion and peri-partum hysterectomy | Blood product use declined 25.9% (p < 0.01) and hysterectomy declined 14.8% but change was not significant (p = 0.2)
Markova et al. 2012^129^ Denmark | Pre-Post 2003, 2005, 2007 | Urban university hospital Pre: NR Post: NR (148 total transfusions for PPH among 10,461 births) | Multi-professional skills training for management of a range of obstetric emergencies including PPH Goal: reduce need for transfusion and shorten interval to PPH interventions | No effect of the intervention on transfusion for PPH and an unchanged delay in management of retained placenta with trend towards longer duration
aShields et al. 2011^67^ United States | Pre-Post 2009, 2011 | Rural hospital Pre: 62/2,939 (2.11%) Post: 148/5,813 (2.55%) | Labor and delivery nursing and physician education, with three progressive stages of intervention implementation via algorithm. Goal: promote early intervention, reduce stage of severity of hemorrhage, promote early use of blood products, and reduce DIC | Severity of PPH declined. After implementation 82% of women with PPH were treated successfully with Stage 1 intervention (supportive measures and uterine massage only or with a single dose of tocolytic) compared to 35% at baseline (p = 0.02)
Deneux-Tharaux et al. 2010^37^ France | Cluster RCT 2004 - 2006 | 106 maternity units Control: 6.37% of 70,707 Intervention: 6.37% of 76,074 | Passive vs. active dissemination of protocol with academic detailing, nurse and physician champions, reminders, and peer review of severe PPH cases Goal: reduce severity of PPH through multi-faceted early intervention | Proportion of women with severe PPH did not differ by intervention group (1.65% control sites and 1.64% intervention sites)
Audureau et al. 2009^36^ France | Pre-Post 2002, 2005 | 19 maternity units Pre: 164/17,664 (0.93%) Post: 166/17,722 (0.94%) | Multifaceted intervention including dissemination of clinical guidelines, local opinion leaders, reminders, and blood collection bags Goal: Primary goals were use of intervention components, reducing prevalence of severe PPH analyzed as secondary outcome | Prevalence of severe PPH remained constant across time periods. Use of transfusion (p = 0.01) and hemostatic surgery increased significantly (p = 0.03)
Skupski et al. 2006^34^ United States | Pre-Post 2000-2001, 2002-2005 | Urban university hospital Major PPH Pre: 12/5811 (0.21%) Post: 49/12,912 (0.38%) | Multicomponent approach including rapid response team, clinical pathways, guidelines, and protocols, dedicated obstetric inpatient service, change in duties, didactic sessions Goal: reduce severity of PPH and improve maternal outcomes | Maternal deaths declined from two deaths in the baseline period to none in the follow-up period (p = 0 .04). Severity of hemorrhage remained unchanged
Rizvi et al., 2004^35^ Ireland | Pre-Post 6 months in 1999 6 months in 2002 | Single hospital Pre: 54/3,176 (1.7%) Post: 15/3,300 (0.45%) | Audit of PPH > 1,000ml and near-miss maternal mortality for departures from guidelines; intervention included review of guidelines, staff training and practice drills Goal: reduce incidence of PPH > 1,000ml | PPH > 1,000ml declined from 1.7% to 0.45% (p < 0.001) with 100% adherence to guidelines in the follow-up period

a Studies used the same intervention tools in a “comprehensive patient safety initiative “but report on different time periods and different numbers of hospitals; thus, we have analyzed as two separate studies.

Abbreviations: DIC = disseminated intravascular coagulation; EBL = estimated blood loss; ICU = intensive care unit; PPH = postpartum hemorrhage

#### Randomized Controlled Trial

In 1998, the French government introduced perinatal networks organized within geographical regions. The networks encompass all public and private hospitals and include at least one tertiary care unit per network. The mandate for networks includes care coordination and quality improvement research. The single clinical trial of multicomponent interventions was a large cluster randomized trial conducted in two large maternity care regions of France representing six networks; 106 of a potential 109 maternity units in these networks participated.37 Sites were stratified within network and by size, then centrally randomized to implement the full intervention or to have the related protocol passively disseminated without programmatic support.

At intervention sites outreach visits were held to plan for implementation and anticipate challenges. A protocol intended to reduce the rate of severe PPH was introduced by usual channels and reinforced through academic detailing by local opinion leaders and by reminders in the maternity units. The intervention proceeded in two phases that allowed sites to consider how to best optimize the quality of implementation at their site, to prepare staff, and to make changes to facilities or resources on hand. All types of care providers were engaged and had roles in the protocol. The second phase included implementation tools such as emergency response kit to hold key drugs, crisis response phone numbers, transfusion and lab order forms, and other items as desired by the units and provision of a “PPH chronological checklist” to track implementation of the protocol, estimate total estimated blood loss, and encourage minimal loss of time in crucial decisions. The intervention also included peer review of all births with severe PPH and critical analysis of the care provided in reference to the protocol guidance.

With a total of more 146,000 births in the two study arms, severe PPH did not differ across sites with an incidence of 1.64 percent at the intervention sites and 1.65 percent at the control comparison sites. Some components of the intervention suggested improvements in practice, such as involving senior staff sooner (p = 0.005), using second-line pharmaceutical options sooner (p = 0.06), and more prompt checks of hematocrit (p = 0.09). However, taken together these differences and the global intervention package did not significantly influence overall maternal outcomes. In a followup case series (n = 9365) from this RCT81 that assessed transfusion practices, only half (n = 423/858, 49%) of women with PPH and a hemoglobin level below 7.0 g/dL received RBC transfusion. These results suggest poor compliance with transfusion recommendations in the national French guidelines.

#### Observational Studies

Eight nonrandomized studies used prospective observational designs in which baseline data about processes of care and patient outcomes were collected for an extended period of time prior to implementation of a policy, protocol, or procedure change,34-36, 67, 68, 128-131 then followup data were collected over time after implementation. One study (published in two papers) used the first quarter of the year of implementation as an anchor for trend analysis.130, 131 Across these studies numerous types of components were implemented and evaluated (Table 24).

Table 24 Components of interventions in systems-level studies

Problem solving/quality improvement stage
Specific protocols in place
Phased roll out
Educational components including training sessions or didactic materials
Clinical champions who assisted locally in engrafting implementation
Multi-professional target group meaning nurses and physicians from obstetrics, anesthesia, and potentially pediatrics were included
Mock events or simulations to allow role play of response to PPH
Documented risk assessments such as risk scores recorded on admission to the labor and delivery unit
Use of tracking tools, checklists, or timelines to support protocol implementation and/or ensure timely response
Emergency response kits such as crash carts with key medications and drapes for measuring estimated blood loss
Tools like fluid collection drapes, approaches to weighing linens for fluid, and/or mandates for tracking estimated blood loss
New staffing response plans to provide additional or more senior staffing in the event of PPH
Audit and feedback in which individuals or groups regularly reviewed data from PPH events to examine trends and responsiveness to protocols

Abbreviations: PPH = postpartum hemorrhage

All systems-level studies evaluated the influence of combinations of these approaches (see Table 25). 34-37, 67, 128-132 Two of the observational studies documented statistically meaningful changes in use of selected intervention components.36, 128, 132 Increases in use of management strategies included use of uterotonics,128, 132 hemostatic sutures at cesarean, 128, 132 hemostatic interventions including embolization and hysterectomy36 and transfusion36 in the period after new protocols were introduced. In neither of these studies were the primary maternal outcomes such as incidence of severe PPH, DIC, hysterectomy, or ICU admission decreased.

Table 25 Summary of components of systems-level interventions

Components of interventions Author, Year | Problem Solving/Quality Improvement Stage | Specific Protocols in Place | Phased Roll Out | Educational Component | Clinical Champions | Multi-Professional Target Group | Mock Events/Simulations | Documented Risk Assessments | Tracking Tools/Checklists to Support Protocols | Emergency Response Kits | Tools/Mandate for Tracking EBL | Staffing Response Plan for PPH | Audit and Feedback
Dupont et. al. 2014 130, 131 | | X | | | | | | | | | | | X
Einerson et al 2014 128, 132 | X | X | | X | | | | | X
Shields et al. 2014^68^ | X | X | X | X | | X | X | X | X | X | X | X
Markova et al. 2012^129^ | | | | X | | X | X
Shields et al., 2011 67 | X | X | X | X | | X | X | X | X | X | X | X
Deneux-Tharaux et al., 2010^37^ | X | X | X | | X | | | | X | X | X | | X
Audureau et al., 2009^36^ | X | X | | X | X | X | | | X | | X
Skupski et al., 2006^34^ | X | X | | X | | X | | X | | X | | X
Rizvi et al., 2004^35^ | | X | | X | | | X | | | | | | X
Total Studies (n) | 6 | 8 | 3 | 7 | 2 | 5 | 4 | 3 | 5 | 4 | 4 | 3 | 3

Abbreviations: EBL = estimated blood loss; PPH = postpartum hemorrhage

Four studies reported reduced severity of PPH after implementation of new multicomponent programs.35, 67, 68, 130, 131 In the most recent of these, reported in the United States, the investigators established a staging system to define severity.67, 68 The staging was linked to the level of intervention ultimately required to control the hemorrhage with higher stages indicating greater morbidity. Use of the comprehensive maternal hemorrhage protocols was described first in a single hospital.67 In the baseline data collection in this hospital before implementation, 35 percent of women giving birth by cesarean or vaginally were successfully treated with only Stage 1 (basic) interventions such as a single dose of uterotonic and uterine massage. This improved to 82 percent after the systems-level intervention program was in place (p = 0.02). The program emphasized vigilant observation, tracking of time course, and formal measurement of estimated blood loss and also allowed for shifting of staff to better match acuity. They then implemented this protocol in a 29-hospital system to test influence on reducing transfusion and peri-partum hysterectomy as the clinical outcomes. Blood product use declined 25.9 percent (p < 0.01), but the decline in hysterectomy (14.8%) was not significant (p = 0.2). Unlike in the initial single site study, in the multisite intervention across the 10 months of follow-up there was an increase in the percentage of Stage 2 and 3 interventions.68

A French study in two maternity units reported in an initial paper130 that the incidence of severe PPH declined in both a level II and level III hospital with the greater reduction in the lower acuity hospital. Incidence in that hospital fell from 2.09 percent to 0.57 percent of all births (p < 0.001) with a significant but less than one percent drop in the level III unit. In an extended follow-up of the program maintained across the level III sites for seven years, they documented achievement and persistence of a meaningfully reduced incidence of severe PPH to less than 0.6% (p < 0.001).131 This program and that of the final study that reports reduced incidence was driven predominantly by a process of systematic audit of the charts of severe PPH cases with feedback to suggest improvements. The earliest group to examine audit and feedback reported similar scope of reductions in severe PPH (defined as > 1,000ml estimated blood loss) from 1.7 percent to 0.45 percent (p = < 0 .001) while noting that compliance with guidelines for intervention improved to 100 percent in the follow-up period. They attribute a portion of this success to training and use of practice drills.

One study in a large urban teaching hospital in the United States examined maternal mortality over a 24-month baseline and a 36-month post-implementation phase.34 They had two deaths in the period that prompted the systems-level intervention and none during the post-phase (p = 0.036). While this intervention included many similar components to others, the authors also report major adjustments to how operations were changed across the entire department to enhance the ability to have dedicated teams focused on laboring and postpartum women. These included separating coverage responsibilities for gynecologic and obstetric inpatients and redefining the oversight role of the covering obstetrician for both public and private patients. Such staffing and organizational changes exceed that in other studies. Subsequent reports from this teaching hospital implementing additional components of intervention found an increase in PPH diagnosis (p=0.002), increase in mean estimated blood loss (p = 0.014), and increase in the proportion of PPH with estimated blood loss greater than 1500 mL (p=0.010) alongside increased use of interventions like uterotonics, balloon tamponade, B-Lynch sutures and embolization (p ≤ 0.05) 128, 132

Four of the eight studies, along with the only systems-level RCT, did not document benefits of the tested intervention packages for reducing PPH severity or complications; this includes the study that reported reduced maternal mortality.34, 36, 128, 129, 132 These studies shared common features among those without evidence of effectiveness as well as among those that reported reduced incidence and/or severity. No clear pattern emerges to suggest an “active ingredient” to these multicomponent interventions.

Audit and feedback was used in two of the three studies that reported reduced severity. In evaluating this evidence it is crucial to underscore that there was no masking of the definitions of severity, of those who assessed severity, or of the overall intent of the research. Because obstetric care providers may use charted estimated blood loss as a proxy for level of concern and desire for vigilance in follow-up assessments, it could be that a shift occurred from labelling someone as high risk by indicating high estimated blood loss at the time of the birth to a lower estimate of estimated blood loss with concerns captured elsewhere in the protocols.

Only the randomized trial conducted any multivariate analysis to take into account secular trends in factors such as proportions of birth by cesarean and vaginal route or scheduled versus emergent cesarean. They detected a statistical trend of falling overall risk of PPH at both control and intervention sites. The reduction was similar over time and did not confound the trial analysis. The authors also used multilevel models to account for clustering within site.

One team reported analyses stratified by potential confounders.36 Two teams used forms of trends analysis including graphical control charts but without adjustment for patient characteristics or route of birth trends.131, 132 Others noted changes in trends that could modify risk, such as proportion of births by cesarean, but did not conduct adjusted analyses. Such factors alongside any changes in the risk profile of women receiving care can both obscure potential effects or introduce the appearance of an effect when there is none.

## Gray Literature

In response to 10 requests for Scientific Information Packets, we received only one document, an unpublished systematic review conducted by a company that markets the Bakri Postpartum Balloon. The document yielded no studies of relevance for this review; all 23 identified studies were case series, typically with less than 20 participants, and a number were conducted in developing nations. Our search of ClinicalTrials.gov did not yield any results not identified in our other searches.