# References

1 Rath WH. Postpartum hemorrhage--update on problems of definitions and diagnosis. Acta Obstet Gynecol Scand. May. 2011;90:421-8. [pmid: 21332452].
2 Kavle JA, Khalfan SS, Stoltzfus RJ, et al. Measurement of blood loss at childbirth and postpartum. Int J Gynaecol Obstet. Oct. 2006;95:24-8. [pmid: 16919628].
3 Stafford I, Dildy GA, Clark SL, et al. Visually estimated and calculated blood loss in vaginal and cesarean delivery. Am J Obstet Gynecol. Nov. 2008;199:519 e1-7. [pmid: 18639209].
4 Schorn MN. Measurement of blood loss: review of the literature. J Midwifery Womens Health. Jan-Feb. 2010;55:20-7. [pmid: 20129226].
5 Carroli G, Cuesta C, Abalos E, et al. Epidemiology of postpartum haemorrhage: a systematic review. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22:999-1012. [pmid: 18819848].
6 Calvert C, Thomas SL, Ronsmans C, et al. Identifying regional variation in the prevalence of postpartum haemorrhage: a systematic review and meta-analysis. PLoS One. 2012;7:e41114. [pmid: 22844432].
7 Ford JB, Roberts CL, Simpson JM, et al. Increased postpartum hemorrhage rates in Australia. Int J Gynaecol Obstet. Sep. 2007;98:237-43. [pmid: 17482190].
8 Joseph KS, Rouleau J, Kramer MS, et al. Investigation of an increase in postpartum haemorrhage in Canada. BJOG. Jun. 2007;114:751-9. [pmid: 17516968].
9 Knight M, Callaghan WM, Berg C, et al. Trends in postpartum hemorrhage in high resource countries: a review and recommendations from the International Postpartum Hemorrhage Collaborative Group. BMC Pregnancy Childbirth. 2009;9:55. [pmid: 19943928].
10 Lutomski JE, Byrne BM, Devane D, et al. Increasing trends in atonic postpartum haemorrhage in Ireland: an 11-year population-based cohort study. BJOG. Feb. 2011;119:306-14. [pmid: 22168794].
11 Rossen J, Okland I, Nilsen OB, et al. Is there an increase of postpartum hemorrhage, and is severe hemorrhage associated with more frequent use of obstetric interventions?. Acta Obstet Gynecol Scand. Oct. 2010;89:1248-55. [pmid: 20809871].
12 Callaghan WM, Kuklina EV, Berg CJ. Trends in postpartum hemorrhage: United States, 1994-2006. Am J Obstet Gynecol. Apr. 2010;202:353 e1-6. [pmid: 20350642].
13 Kramer MS, Berg C, Abenhaim H, et al. Incidence, risk factors, and temporal trends in severe postpartum hemorrhage. Am J Obstet Gynecol. Nov. 2013;209:449 e1-7. [pmid: 23871950].
14 WHO Recommendations for the Prevention and Treatment of Postpartum Haemorrhage. 2012. [pmid: 23586122].
15 Berg CJ, Harper MA, Atkinson SM, et al. Preventability of pregnancy-related deaths: results of a state-wide review. Obstet Gynecol. Dec. 2005;106:1228-34. [pmid: 16319245].
16 Kilpatrick SJ, Prentice P, Jones RL, et al. Reducing maternal deaths through state maternal mortality review. J Womens Health (Larchmt). Sep. 2012;21:905-9. [pmid: 22621323].
17 Della Torre M, Kilpatrick SJ, Hibbard JU, et al. Assessing preventability for obstetric hemorrhage. Am J Perinatol. Dec. 2011;28:753-60. [pmid: 21698554].
18 McLintock C, James AH. Obstetric hemorrhage. J Thromb Haemost. Aug. 2011;9:1441-51. [pmid: 21668737].
19 ACOG Practice Bulletin: Clinical Management Guidelines for Obstetrician-Gynecologists Number 76, October 2006: postpartum hemorrhage. Obstet Gynecol. Oct. 2006;108:1039-47. [pmid: 17012482].
20 Zelop CM. Postpartum hemorrhage: becoming more evidence-based. Obstet Gynecol. Jan. 2010;117:3-5. [pmid: 21173639].
21 Active management of the third stage of labour: prevention and treatment of postpartum hemorrhage: No. 235 October 2009 (Replaces No. 88, April 2000). Int J Gynaecol Obstet. Mar. 2010;108:258-67. [pmid: 20196196].
22 Royal College of Obstetricians and Gynaecologists. Prevention and management of postpartum haemorrhage. RCOG Green-top Guideline No. 52. London. Royal College of O, Gynaecologists. 2009. Available at http://www.rcog.org.uk/womens-health/clinical-guidance/prevention-and-management-postpartum-haemorrhage-green-top-52.
23 International joint policy statement. FIGO/ICM global initiative to prevent post-partum hemorrhage. J Obstet Gynaecol Can. Dec. 2005;26:1100-2. 8. 11. [pmid: 15696639].
24 Lalonde A. Prevention and treatment of postpartum hemorrhage in low-resource settings. Int J Gynaecol Obstet. May. 2012;117:108-18. [pmid: 22502595].
25 California Maternity Care Quality Collaborative : OB Hemorrhage Toolkit Update. 2014. Available at https://www.cmqcc.org/ob_hemorrhage_toolkit_update_2014.
26 Miller S, Ojengbede O, Turan JM, et al. A comparative study of the non-pneumatic anti-shock garment for the treatment of obstetric hemorrhage in Nigeria. Int J Gynaecol Obstet. Nov. 2009;107:121-5. [pmid: 19628207].
27 Miller S, Fathalla MM, Youssif MM, et al. A comparative study of the non-pneumatic anti-shock garment for the treatment of obstetric hemorrhage in Egypt. Int J Gynaecol Obstet. Apr. 2010;109:20-4. [pmid: 20096836].
28 Abdul-Kadir R, McLintock C, Ducloy AS, et al. Evaluation and management of postpartum hemorrhage: consensus from an international expert panel. Transfusion. 2014. Mar. 12. [pmid: 24617726].
29 Soltan MH, Faragallah MF, Mosabah MH, et al. External aortic compression device: the first aid for postpartum hemorrhage control. J Obstet Gynaecol Res. Jun. 2009;35:453-8. [pmid: 19527382].
30 Keogh J, Tsokos N. Aortic compression in massive postpartum haemorrhage--an old but lifesaving technique. Aust N Z J Obstet Gynaecol. May. 1997;37:237-8. [pmid: 9222477].
31 Haeri S, Dildy GA 3rd. Maternal mortality from hemorrhage. Semin Perinatol. Feb. 2012;36:48-55. [pmid: 22280866].
32 Bateman BT, Tsen LC, Liu J, et al. Patterns of Second-Line Uterotonic Use in a Large Sample of Hospitalizations for Childbirth in the United States: 2007-2011. Anesth Analg. 2014. Aug. 27. [pmid: 25166464].
33 Franchini M, Franchi M, Bergamini V, et al. The use of recombinant activated FVII in postpartum hemorrhage. Clin Obstet Gynecol. Mar. 2010;53:219-27. [pmid: 20142658].
34 Skupski DW, Lowenwirt IP, Weinbaum FI, et al. Improving hospital systems for the care of women with major obstetric hemorrhage. Obstet Gynecol. May. 2006;107:977-83. [pmid: 16648399].
35 Rizvi F, Mackey R, Barrett T, et al. Successful reduction of massive postpartum haemorrhage by use of guidelines and staff education. BJOG. May. 2004;111:495-8. [pmid: 15104617].
36 Audureau E, Deneux-Tharaux C, Lefevre P, et al. Practices for prevention, diagnosis and management of postpartum haemorrhage: impact of a regional multifaceted intervention. BJOG. Sep. 2009;116:1325-33. [pmid: 19538416].
37 Deneux-Tharaux C, Dupont C, Colin C, et al. Multifaceted intervention to decrease the rate of severe postpartum haemorrhage: the PITHAGORE6 cluster-randomised controlled trial. BJOG. Sep. 2010;117:1278-87. [pmid: 20573150].
38 Dupont C, Touzet S, Colin C, et al. Incidence and management of postpartum haemorrhage following the dissemination of guidelines in a network of 16 maternity units in France. Int J Obstet Anesth. Oct. 2009;18:320-7. [pmid: 19733052].
39 Mousa HA, Alfirevic Z. Treatment for primary postpartum haemorrhage. Cochrane Database Syst Rev. 2007. CD003249. [pmid: 17253486].
40 Alexander J, Thomas P, Sanghera J. Treatments for secondary postpartum haemorrhage. Cochrane Database Syst Rev. 2002. CD002867. [pmid: 11869640].
41 Tindell K, Garfinkel R, Abu-Haydar E, et al. Uterine balloon tamponade for the treatment of postpartum haemorrhage in resource-poor settings: a systematic review. BJOG. Jan. 2012;120:5-14. [pmid: 22882240].
42 Rossi AC, Lee RH, Chmait RH. Emergency postpartum hysterectomy for uncontrolled postpartum bleeding: a systematic review. Obstet Gynecol. Mar. 2010;115:637-44. [pmid: 20177297].
43 Ferrer P, Roberts I, Sydenham E, et al. Anti-fibrinolytic agents in post partum haemorrhage: a systematic review. BMC Pregnancy Childbirth. 2009;9:29. [pmid: 19604358].
44 Gizzo S, Saccardi C, Patrelli TS, et al. Fertility rate and subsequent pregnancy outcomes after conservative surgical techniques in postpartum hemorrhage: 15 years of literature. Fertil Steril. Jun. 2013;99:2097-107. [pmid: 23498891].
45 Wright JD, Herzog TJ, Shah M, et al. Regionalization of care for obstetric hemorrhage and its effect on maternal mortality. Obstet Gynecol. Jun. 2010;115:1194-200. [pmid: 20502290].
46 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov.
47 Matsubara S, Yano H, Ohkuchi A, et al. Uterine compression sutures for postpartum hemorrhage: an overview. Acta Obstet Gynecol Scand. Apr. 2013;92:378-85. [pmid: 23330882].
48 Merland JJ, Houdart E, Herbreteau D, et al. Place of emergency arterial embolisation in obstetric haemorrhage about 16 personal cases. Eur J Obstet Gynecol Reprod Biol. Mar. 1996;65:141-3. [pmid: 8706947].
49 Kim TH, Lee HH, Kim JM, et al. Uterine artery embolization for primary postpartum hemorrhage. Iran J Reprod Med. Jun. 2014;11:511-8. [pmid: 24639786].
50 Hofmeyr GJ, Gulmezoglu AM, Novikova N, et al. Misoprostol to prevent and treat postpartum haemorrhage: a systematic review and meta-analysis of maternal deaths and dose-related effects. Bull World Health Organ. Sep. 2009;87:666-77. [pmid: 19784446].
51 World Health Organization (WHO). WHO recommendations for the prevention of postpartum haemorrhage WHO. Geneva. 2007. Available at http://whqlibdoc.who.int/hq/2007/WHO_MPS_07.06_eng.pdf.
52 Snelgrove JW. Postpartum haemorrhage in the developing world a review of clinical management strategies. Mcgill J Med. 2009;12:61. [pmid: 21264044].
53 Geller SE, Adams MG, Kelly PJ, et al. Postpartum hemorrhage in resource-poor settings. Int J Gynaecol Obstet. Mar. 2006;92(3):202-11. [pmid: 16427056].
54 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
55 Wells P, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Available at http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
56 National Heart, Lung, and Blood Institute. Quality Assessment Tool for Before-After (Pre-Post) Studies With No Control Group. 2014. Available at http://www.nhlbi.nih.gov/health-pro/guidelines/in-develop/cardiovascular-risk-reduction/tools/before-after.htm.
57 Viswanathan M, Berkman ND, Dryden DM, Hartling L. Assessing Risk of Bias and Confounding in Observational Studies of Interventions or Exposures: Further Development of the RTI Item Bank . Methods Research Report. (Prepared by RTI – UNC Evidence - based Practice Center under Contract No. 290 - 2007 - 10 056 - I) . AHRQ Publication No. 1 3 - EHC106 - EF. Rockville, MD. Agency for Healthcare Research and Quality. August. 2013. www.effectivehealthcare. ahrq.gov/ reports/final.cfm.
58 Santaguida P, Raina P. McMaster Quality Assessment Scale of Harms (McHarm) for primary studies: Manual for use of the McHarm.
59 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2008.
60 Bateman BT, Huybrechts KF, Hernandez-Diaz S, et al. Methylergonovine maleate and the risk of myocardial ischemia and infarction. Am J Obstet Gynecol. Nov. 2013;209:459.e1-.e13. [pmid: 23850529].
61 Chauleur C, Cochery-Nouvellon E, Mercier E, et al. Analysis of the venous thromboembolic risk associated with severe postpartum haemorrhage in the NOHA First cohort. Thromb Haemost. Nov. 2008;100:773-9. [pmid: 18989520].
62 An GH, Ryu HM, Kim MY, et al. Outcomes of subsequent pregnancies after uterine compression sutures for postpartum hemorrhage. Obstet Gynecol. Sep. 2013;122:565-70. [pmid: 23921861].
63 Balki M, Dhumne S, Kasodekar S, et al. Blood transfusion for primary postpartum hemorrhage: a tertiary care hospital review. J Obstet Gynaecol Can. Nov. 2009;30:1002-7. [pmid: 19126281].
64 Akinbiyi AA, Olatunbosun OA. Emergency obstetric hysterectomies (how many are potentially preventable?): A 28-year experience in Saskatoon. Journal of Gynecologic Surgery. Fall. 2004;20:81-7.
65 Teofili L, Bianchi M, Zanfini BA, et al. Acute Lung Injury Complicating Blood Transfusion in Post-Partum Hemorrhage: Incidence and Risk Factors. Mediterr J Hematol Infect Dis. 2014;6(1):e2014069. [pmid: 25408855].
66 Cowan AD, Miller ES, Grobman WA. Subsequent pregnancy outcome after B-lynch suture placement. Obstet Gynecol. Sep. 2014;124(3):558-61. [pmid: 25162256].
67 Shields LE, Smalarz K, Reffigee L, et al. Comprehensive maternal hemorrhage protocols improve patient safety and reduce utilization of blood products. Am J Obstet Gynecol. Oct. 2011;205:368 e1-8. [pmid: 22083059].
68 Shields LE, Wiesner S, Fulton J, et al. Comprehensive maternal hemorrhage protocols reduce the use of blood products and improve patient safety. Am J Obstet Gynecol. 2014. Jul. 12. [pmid: 25025944].
69 Ducloy-Bouthors AS, Jude B, Duhamel A, et al. High-dose tranexamic acid reduces blood loss in postpartum haemorrhage. Crit Care. 2011;15:R117. [pmid: 21496253].
70 Schmitz T, Tararbit K, Dupont C, et al. Prostaglandin E2 analogue sulprostone for treatment of atonic postpartum hemorrhage. Obstet Gynecol. Aug. 2011;118:257-65. [pmid: 21775840].
71 Oleen MA, Mariano JP. Controlling refractory atonic postpartum hemorrhage with Hemabate sterile solution. Am J Obstet Gynecol. Jan. 1990;162:205-8. [pmid: 2405676].
72 Sugawara J, Suenaga K, Hoshiai T, et al. Efficacy of recombinant human soluble thrombomodulin in severe postpartum hemorrhage with disseminated intravascular coagulation. Clin Appl Thromb Hemost. Sep. 2012;19:557-61. [pmid: 22496090].
73 Ahonen J, Jokela R, Korttila K. An open non-randomized study of recombinant activated factor VII in major postpartum haemorrhage. Acta Anaesthesiol Scand. Aug. 2007;51:929-36. [pmid: 17488316].
74 McMorrow RC, Ryan SM, Blunnie WP, et al. Use of recombinant factor VIIa in massive post-partum haemorrhage. Eur J Anaesthesiol. Apr. 2008;25:293-8. [pmid: 18177539].
75 Alfirevic Z, Elbourne D, Pavord S, et al. Use of recombinant activated factor VII in primary postpartum hemorrhage: the Northern European registry 2000-2004. Obstet Gynecol. Dec. 2007;110:1270-8. [pmid: 18055720].
76 Phillips LE, McLintock C, Pollock W, et al. Recombinant activated factor VII in obstetric hemorrhage: experiences from the Australian and New Zealand Haemostasis Registry. Anesth Analg. Dec. 2009;109:1908-15. [pmid: 19923520].
77 Kayem G, Kurinczuk JJ, Alfirevic Z, et al. Specific second-line therapies for postpartum haemorrhage: a national cohort study. BJOG. Jun. 2011;118:856-64. [pmid: 21392247].
78 Baruah M, Cohn GM. Efficacy of rectal misoprostol as second-line therapy for the treatment of primary postpartum hemorrhage. J Reprod Med. Mar. 2008;53:203-6. [pmid: 18441726].
79 Chan LL, Lo TK, Lau WL, et al. Use of second-line therapies for management of massive primary postpartum hemorrhage. Int J Gynaecol Obstet. Sep. 2013;122:238-43. [pmid: 23806248].
80 Zatta A, McQuilten Z, Kandane-Rathnayake R, et al. The Australian and New Zealand Haemostasis Registry: ten years of data on off-licence use of recombinant activated factor VII. Blood Transfus. Jun. 2014;5:1-14. [pmid: 24960661].
81 Bonnet MP, Deneux-Tharaux C, Dupont C, et al. Transfusion practices in postpartum hemorrhage: a population-based study. Acta Obstet Gynecol Scand. Apr. 2012;92:404-13. [pmid: 23215892].
82 Kayem G, Kurinczuk JJ, Alfirevic Z, et al. Uterine compression sutures for the management of severe postpartum hemorrhage. Obstet Gynecol. Jan. 2011;117:14-20. [pmid: 21213474].
83 Alexander JM, Sarode R, McIntire DD, et al. Whole blood in the management of hypovolemia due to obstetric hemorrhage. Obstet Gynecol. Jun. 2009;113:1320-6. [pmid: 19461429].
84 Ahmed S, Harrity C, Johnson S, et al. The efficacy of fibrinogen concentrate compared with cryoprecipitate in major obstetric haemorrhage--an observational study. Transfus Med. Oct. 2012;22:344-9. [pmid: 22994449].
85 Sohn CH, Kim WY, Kim SR, et al. An increase in initial shock index is associated with the requirement for massive transfusion in emergency department patients with primary postpartum hemorrhage. Shock. Aug. 2013;40:101-5. [pmid: 23707978].
86 Mallaiah S, Barclay P, Harrod I, et al. Introduction of an algorithm for ROTEM-guided fibrinogen concentrate administration in major obstetric haemorrhage. Anaesthesia. 2014. Oct. 7. [pmid: 25289791].
87 Laas E, Bui C, Popowski T, et al. Trends in the rate of invasive procedures after the addition of the intrauterine tamponade test to a protocol for management of severe postpartum hemorrhage. Am J Obstet Gynecol. Oct. 2012;207:281 e1-7. [pmid: 23021688].
88 Dildy GA, Belfort MA, Adair CD, et al. Initial experience with a dual-balloon catheter for the management of postpartum hemorrhage. Am J Obstet Gynecol. 2013. Sep. 18. [pmid: 24055586].
89 Ferrazzani S, Iadarola R, Perrelli A, et al. Use of an intrauterine inflated catheter balloon in massive post-partum hemorrhage: a series of 52 cases. J Obstet Gynaecol Res. Jun. 2014;40:1603-10. [pmid: 24888923].
90 Gronvall M, Tikkanen M, Tallberg E, et al. Use of Bakri balloon tamponade in the treatment of postpartum hemorrhage: a series of 50 cases from a tertiary teaching hospital. Acta Obstet Gynecol Scand. Apr. 2012;92:433-8. [pmid: 22913383].
91 Hardeman S, Decroisette E, Marin B, et al. Fertility after embolization of the uterine arteries to treat obstetrical hemorrhage: a review of 53 cases. Fertil Steril. Dec. 2010;94:2574-9. [pmid: 20381035].
92 Sentilhes L, Gromez A, Clavier E, et al. Fertility and pregnancy following pelvic arterial embolisation for postpartum haemorrhage. BJOG. Jan. 2009;117:84-93. [pmid: 19832826].
93 Sentilhes L, Gromez A, Clavier E, et al. Long-term psychological impact of severe postpartum hemorrhage. Acta Obstet Gynecol Scand. Jun. 2011;90:615-20. [pmid: 21370999].
94 Sentilhes L, Gromez A, Clavier E, et al. Predictors of failed pelvic arterial embolization for severe postpartum hemorrhage. Obstet Gynecol. May. 2009;113:992-9. [pmid: 19384113].
95 Chauleur C, Fanget C, Tourne G, et al. Serious primary post-partum hemorrhage, arterial embolization and future fertility: a retrospective study of 46 cases. Hum Reprod. Jul. 2008;23:1553-9. [pmid: 18460450].
96 Ledee N, Ville Y, Musset D, et al. Management in intractable obstetric haemorrhage: an audit study on 61 cases. Eur J Obstet Gynecol Reprod Biol. Feb. 2001;94:189-96. [pmid: 11165724].
97 Fiori O, Deux JF, Kambale JC, et al. Impact of pelvic arterial embolization for intractable postpartum hemorrhage on fertility. Am J Obstet Gynecol. Apr. 2009;200:384 e1-4. [pmid: 19217597].
98 Gaia G, Chabrot P, Cassagnes L, et al. Menses recovery and fertility after artery embolization for PPH: a single-center retrospective observational study. Eur Radiol. Feb. 2008;19:481-7. [pmid: 18766350].
99 Ganguli S, Stecker MS, Pyne D, et al. Uterine artery embolization in the treatment of postpartum uterine hemorrhage. J Vasc Interv Radiol. Feb. 2010;22:169-76. [pmid: 21183360].
100 Kim YJ, Yoon CJ, Seong NJ, et al. Failed pelvic arterial embolization for postpartum hemorrhage: clinical outcomes and predictive factors. J Vasc Interv Radiol. May. 2013;24:703-9. [pmid: 23622042].
101 Lee HY, Shin JH, Kim J, et al. Primary postpartum hemorrhage: outcome of pelvic arterial embolization in 251 patients at a single institution. Radiology. Sep. 2012;264:903-9. [pmid: 22829685].
102 Poujade O, Zappa M, Letendre I, et al. Predictive factors for failure of pelvic arterial embolization for postpartum hemorrhage. Int J Gynaecol Obstet. May. 2012;117:119-23. [pmid: 22361480].
103 Touboul C, Badiou W, Saada J, et al. Efficacy of selective arterial embolisation for the treatment of life-threatening post-partum haemorrhage in a large population. PLoS One. 2008;3:e3819. [pmid: 19043573].
104 Yamasaki Y, Morita H, Miyahara Y, et al. The factors associated with the failure of transcatheter pelvic arterial embolization for intractable postpartum hemorrhage. J Perinat Med. Dec. 2013;5:1-4. [pmid: 24310770].
105 Lee HJ, Jeon GS, Kim MD, et al. Usefulness of pelvic artery embolization in cesarean section compared with vaginal delivery in 176 patients. J Vasc Interv Radiol. Jan. 2013;24:103-9. [pmid: 23273701].
106 Cheong JY, Kong TW, Son JH, et al. Outcome of pelvic arterial embolization for postpartum hemorrhage: A retrospective review of 117 cases. Obstet Gynecol Sci. Jan. 2014;57(1):17-27. [pmid: 24596814].
107 Park HS, Shin JH, Yoon HK, et al. Transcatheter Arterial Embolization for Secondary Postpartum Hemorrhage: Outcome in 52 Patients at a Single Tertiary Referral Center. J Vasc Interv Radiol. 2014. Jun. 27. [pmid: 24985718].
108 Inoue S, Masuyama H, Hiramatsu Y. Efficacy of transarterial embolisation in the management of post-partum haemorrhage and its impact on subsequent pregnancies. Aust N Z J Obstet Gynaecol. 2014. Oct. 28. [pmid: 25350565].
109 Zwart JJ, Dijk PD, van Roosmalen J. Peripartum hysterectomy and arterial embolization for major obstetric hemorrhage: a 2-year nationwide cohort study in the Netherlands. Am J Obstet Gynecol. Feb. 2009;202:150 e1-7. [pmid: 19922900].
110 Lone F, Sultan AH, Thakar R, et al. Risk factors and management patterns for emergency obstetric hysterectomy over 2 decades. Int J Gynaecol Obstet. Apr. 2009;109:12-5. [pmid: 19951818].
111 Palacios-Jaraquemada JM. Efficacy of surgical techniques to control obstetric hemorrhage: analysis of 539 cases. Acta Obstet Gynecol Scand. Sep. 2011;90:1036-42. [pmid: 21564024].
112 O'Leary JA. Uterine artery ligation in the control of postcesarean hemorrhage. J Reprod Med. Mar. 1995;40:189-93. [pmid: 7776302].
113 Blanc J, Courbiere B, Desbriere R, et al. Uterine-sparing surgical management of postpartum hemorrhage: is it always effective?. Arch Gynecol Obstet. Apr. 2011;285:925-30. [pmid: 21932086].
114 Glaze S, Ekwalanga P, Roberts G, et al. Peripartum hysterectomy: 1999 to 2006. Obstet Gynecol. Mar. 2008;111:732-8. [pmid: 18310378].
115 Sakse A, Weber T, Nickelsen C, et al. Peripartum hysterectomy in Denmark 1995-2004. Acta Obstet Gynecol Scand. 2007;86:1472-5. [pmid: 18027114].
116 Knight M. Peripartum hysterectomy in the UK: management and outcomes of the associated haemorrhage. BJOG. Nov. 2007;114:1380-7. [pmid: 17877772].
117 Forna F, Miles AM, Jamieson DJ. Emergency peripartum hysterectomy: a comparison of cesarean and postpartum hysterectomy. Am J Obstet Gynecol. May. 2004;190:1440-4. [pmid: 15167863].
118 Gayat E, Resche-Rigon M, Morel O, et al. Predictive factors of advanced interventional procedures in a multicentre severe postpartum haemorrhage study. Intensive Care Med. Nov. 2011;37:1816-25. [pmid: 21805157].
119 Feigenberg T, Eitan Y, Sela HY, et al. Surgical versus medical treatment for secondary post-partum hemorrhage. Acta Obstet Gynecol Scand. 2009;88:909-13. [pmid: 19565365].
120 Hoveyda F, MacKenzie IZ. Secondary postpartum haemorrhage: incidence, morbidity and current management. BJOG. Sep. 2001;108:927-30. [pmid: 11563461].
121 Boyd BK, Katz VL, Hansen WF. Delayed postpartum hemorrhage: a retrospective analysis. Journal of Maternal-Fetal Medicine. 1995. Jan-Feb. 1995;4:19-23.
122 Meyer NP, Ward GH, Chandraharan E. Conservative approach to the management of morbidly adherent placentae. Ceylon Med J. Mar. 2012;57:36-9. [pmid: 22453709].
123 Buzaglo N, Harlev A, Sergienko R, et al. Risk factors for early postpartum hemorrhage (PPH) in the first vaginal delivery, and obstetrical outcomes in subsequent pregnancy. J Matern Fetal Neonatal Med. Aug. 2014;5:1-6. [pmid: 25023434].
124 Oberg AS, Hernandez-Diaz S, Palmsten K, et al. Patterns of recurrence of postpartum hemorrhage in a large population-based cohort. Am J Obstet Gynecol. Mar. 2014;210(3):229 e1-8. [pmid: 24351791].
125 Prick B, Jansen A, Steegers E, et al. Transfusion policy after severe postpartum haemorrhage: a randomised non-inferiority trial. BJOG. 2014. Jan. 10. [pmid: 24405687].
126 Prick BW, Duvekot JJ, van der Moer PE, et al. Cost-effectiveness of red blood cell transfusion vs. non-intervention in women with acute anaemia after postpartum haemorrhage. Vox Sang. 2014. Jul. 31. [pmid: 25130704].
127 Froessler B, Cocchiaro C, Saadat-Gilani K, et al. Intravenous iron sucrose versus oral iron ferrous sulfate for antenatal and postpartum iron deficiency anemia: a randomized trial. J Matern Fetal Neonatal Med. May. 2012;26:654-9. [pmid: 23130909].
128 Lappen JR, Seidman D, Burke C, et al. Changes in care associated with the introduction of a postpartum hemorrhage patient safety program. Am J Perinatol. Nov. 2013;30:833-8. [pmid: 23359234].
129 Markova V, Sorensen JL, Holm C, et al. Evaluation of multi-professional obstetric skills training for postpartum hemorrhage. Acta Obstet Gynecol Scand. Mar. 2011;91:346-52. [pmid: 22171606].
130 Dupont C, Deneux-Tharaux C, Touzet S, et al. Clinical audit: a useful tool for reducing severe postpartum haemorrhages?. Int J Qual Health Care. Oct. 2011;23:583-9. [pmid: 21733978].
131 Dupont C, Occelli P, Deneux-Tharaux C, et al. Severe postpartum haemorrhage after vaginal delivery: a statistical process control chart to report seven years of continuous quality improvement. Eur J Obstet Gynecol Reprod Biol. Jul. 2014;178:169-75. [pmid: 24813084].
132 Einerson BD, Miller ES, Grobman WA. Does a postpartum hemorrhage patient safety program result in sustained changes in management and outcomes?. Am J Obstet Gynecol. 2014. Jul. 11. [pmid: 25019484].
133 Mousa HA, Blum J, Abou El, Senoun G, et al. Treatment for primary postpartum haemorrhage. Cochrane Database Syst Rev. 2014;2. Cd003249. [pmid: 24523225].
134 Hofmeyr GJ, Gulmezoglu AM, Novikova N, et al. Postpartum misoprostol for preventing maternal mortality and morbidity. Cochrane Database Syst Rev. 2013;7. CD008982. [pmid: 23857523].
135 Olefile KM, Khondowe O, M'Rithaa D. Misoprostol for prevention and treatment of postpartum haemorrhage: A systematic review. Curationis. 2013;36:E1-E10. [pmid: 23718882].
136 Simpson E, Lin Y, Stanworth S, et al. Recombinant factor VIIa for the prevention and treatment of bleeding in patients without haemophilia. Cochrane Database Syst Rev. 2012;3. CD005011. [pmid: 22419303].
137 Doumouchtsis S, Nikolopoulos K, Talaulikar V, et al. Menstrual and fertility outcomes following the surgical management of postpartum haemorrhage: a systematic review. Bjog. 2013. Dec. 9. [pmid: 24321038].
138 Nadisauskiene RJ, Kliucinskas M, Dobozinskas P, et al. The impact of postpartum haemorrhage management guidelines implemented in clinical practice: a systematic review of the literature. Eur J Obstet Gynecol Reprod Biol. Jul. 2014;178:21-6. [pmid: 24792537].