# Methods

In this chapter, we document the procedures that the Vanderbilt Evidence-based Practice Center (EPC) used to produce a comparative effectiveness review (CER) on approaches to treatment of postpartum hemorrhage (PPH). These procedures follow the methods outlined in the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”46

## Topic Refinement and Review Protocol

The topic for this report was nominated by the American College of Obstetricians and Gynecologists in a public process using the Effective Health Care Web site. Working from the nomination, we drafted the initial KQs and analytic framework and refined them with input from key informants representing the fields of obstetrics and gynecology, nursing, midwifery, obstetric anesthesiology, quality improvement, and perinatal safety. All members of the research team were required to submit information about potential conflicts of interest before initiation of the work. No members of the review team had any conflicts.

After review from the AHRQ, the questions and framework were posted online for public comment. No changes to the questions or framework were recommended. We also developed population, interventions, outcomes, timing, and settings (PICOTS) criteria for intervention KQs.

We identified technical experts on the topic to provide assistance during the project. The Technical Expert Panel (TEP), representing the fields of obstetrics and gynecology, midwifery, nursing, patient and perinatal safety, quality improvement, and maternal-fetal medicine, contributed to the AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included seven members serving as technical or clinical experts. To ensure robust, scientifically relevant work, we called on the TEP to review and provide comments as our work progressed. TEP members participated in conference calls and discussions through e-mail to:

- Help to refine the analytic framework and KQs at the beginning of the project;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria; and
- Provide input on the set of studies identified for inclusion.

The final protocol was posted to the AHRQ Effective Health Care web site and registered in the PROSPERO international register of systematic reviews (ID#: CRD42014010123).

## Literature Search Strategy

### Search Strategy

To ensure comprehensive retrieval of relevant studies of therapies for women with PPH, we used three key databases: the MEDLINE^®^ medical literature database via the PubMed^®^ interface, the Cumulative Index of Nursing and Allied Health Literature (CINAHL^®^), and EMBASE (Excerpta Medica Database), an international biomedical and pharmacological literature database via the Ovid^®^ interface. Search strategies applied a combination of controlled vocabulary (Medical Subject Headings [MeSH], CINAHL medical headings, and Emtree headings) to focus specifically on management of PPH and harms of interventions. We restricted literature searches to studies published from 1990 to the present to reflect current standards of care for PPH. Interventions such as the B-Lynch suture were introduced in the late 1990s,47 and embolization techniques were not widely used until the mid- to late-1990s.48, 49 Misoprostol was initially used as a treatment for gastric ulcer and not broadly used for PPH prevention or treatment until the 2000s. The World Health Organization recommended its use for prevention of PPH in 2007.^50, 51^ Given that currently used interventions were not in widespread use prior to 1990, we set 1990 as a conservative lower bound for the search.

We only included studies published in English as a review of non-English citations retrieved by our MEDLINE search identified few studies of relevance. Appendix A lists our search terms and strategies and the yield from each database. Searches were last executed in November 2014.

We carried out hand searches of the reference lists of recent systematic reviews or meta-analyses of therapies for PPH. The investigative team also scanned the reference lists of studies included after the full-text review phase for additional studies that potentially could meet our inclusion criteria.

### Gray Literature

AHRQ's Scientific Resource Center requested Scientific Information Packets (SIPs) from companies that produce medications or devices with U.S. Food and Drug Administration (FDA) approval for management of uterine bleeding (oxytocin [Pitocin^®^], misoprostol [Cytotec^®^], methylergonovine maleate [Methergine^®^], carboprost tromethamine [Hemabate^®^], dinoprostone[Prostin E2^®^], recombinant coagulation factor VIIa [NovoSeven^®^], and tranexamic acid [Cyklokapron^®^]; and devices for PPH including Bakri™ postpartum balloon, non-pneumatic anti-shock garment [NASG], Foley catheter, Sengstaken-Blakemore tube, and the Rusch balloon) and searched for regulatory data for approved products. We also searched ClinicalTrials.gov to assess publication bias and to identify any study results that may not have been identified in our other database searches.

### Inclusion and Exclusion Criteria

Table 3 lists the inclusion/exclusion criteria we used based on our understanding of the literature, key informant and public comment during the topic-refinement phase, input from the TEP, and established principles of systematic review methods.

Table 3 Inclusion criteria

Category | Criteria
Study population | - KQ1-3, 5: Women with postpartum hemorrhage (PPH) immediately post-birth to 12 weeks postpartum following pregnancy > 24 weeks' gestation; - KQ4: Women with stabilized PPH and acute blood loss anemia; - All modes of birth in any setting
Time period | 1990 to present
Publication languages | English only
Country | Very High Human Development countries as indicated by the United Nations Development Programme Human Development Index. Countries as of April 2014 include: Norway, Australia, US, Netherlands, Germany, New Zealand, Ireland, Sweden, Switzerland, Japan, Canada, Republic of Korea, Hong Kong, Iceland, Denmark, Israel, Belgium, Austria, Singapore, France, Finland, Slovenia, Spain, Liechtenstein, Italy, Luxembourg, U.K., Czech Republic, Greece, Brunei Darussalam, Cyprus, Malta, Andorra, Estonia, Slovakia, Qatar, Hungary, Barbados, Poland, Chile, Lithuania, United Arab Emirates, Portugal, Latvia, Argentina, Seychelles, and Croatia
Admissible evidence (study design and other criteria) | [underlined: Admissible designs]; - KQ 1-2, 4: RCT or prospective/ retrospective cohort studies, population-based case series or registry studies with ≥ 50 cases of PPH treatment, case series of procedures (uterine balloon tamponade, uterine artery embolization) or surgical approaches with ≥ 50 women; - KQ3: RCT or prospective/ retrospective cohort studies, case series with ≥ 50 cases addressing interventions for PPH; - KQ5: Pre- and post-studies related to large-scale health systems changes, RCTs, prospective/retrospective cohort studies; [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Studies targeting women with PPH and meet the population criteria as described above; - Studies that address:; ○ Treatment modality aimed at treatment/management of PPH in a relevant population or treatment for acute blood loss anemia following stabilization of PPH; ○ Outcomes related to interventions; primary outcomes of interest include blood loss, transfusion, ICU admission, anemia, length of stay, mortality, uterine preservation, future fertility, breastfeeding, and psychological impact, and harms.; - Studies must include extractable data presented in text or tables (vs. solely in figures) on relevant outcomes; - For KQ5, studies must explicitly assess effects of an systems-level intervention on PPH management as a primary or secondary aim; analytic models must indicate data analysis of the effect of the strategy as it relates to PPH treatment; results data include information about effects of strategy on management of PPH; discussion interprets the strategy as potentially having value/not having value for PPH management

Abbreviations: ICU = intensive care unit; KQ = Key Question; PPH = postpartum hemorrhage; RCT = randomized controlled trial

Case series comprise much of the literature addressing treatments for PPH. We limited inclusion of case series to those with at least 50 cases of PPH in order to balance the need to identify rigorously conducted studies with identifying studies large enough to suggest effects of the interventions. We include effectiveness and harms data from case series of procedural (uterine balloon tamponade, uterine artery embolization) and surgical (arterial ligation, uterine compression sutures, hysterectomy) approaches because they report pertinent evidence for the effects of such interventions that are unlikely to be found in randomized controlled trials (RCTs). These procedural and surgical approaches are rarely addressed in RCTs, and patients who would be receiving these second-line interventions have an unstable and quickly changing health status and typically are not eligible for RCTs.

We also limited studies to those published in English and conducted in Very High Human Development countries as ranked by the United Nations Development Programme Human Development Index (Table 3). In the opinion of our clinical experts, processes of care and interventions available in these countries best reflect the system of health care in the United States. A considerable body of evidence addresses PPH management in developing countries; however, the limited availability of skilled clinicians and treatment options in many of these countries results in different standards of care and clinical approaches than those in the United States. PPH is a complex condition. Treatments are selected not only by PPH etiology and severity but also by factors related to the setting of care, the availability of medications or other therapeutic options, the availability of personnel, and the standards of care in a given treatment center. Treatment availability and feasibility of providing certain treatments differ across developed and developing nations, and even within any given nation. Because the context of care in most developing nations differs significantly from care in the United States,52, 53 we instituted language and country limitations in order to identify studies that are most applicable to guiding care by clinicians in the United States, who are the intended audience for this report.

In order to provide contextual information about effectiveness and harms reported in studies conducted in developing nations, we provide summaries of recent reviews of interventions for PPH, which include studies conducted in any country in the Discussion section (Findings in Relation to What's Known).

### Study Selection

Once we identified articles through the electronic database searches and hand-searching, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated the abstracts for inclusion or exclusion, using an Abstract Review Form (Appendix B). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it. Following abstract review, two reviewers independently assessed the full text of each included study using a standardized form (Appendix B) that included questions stemming from our inclusion/exclusion criteria. Disagreements between reviewers were resolved by a senior reviewer. All abstract and full text reviews were conducted using the DistillerSR online screening application (Evidence Partners Incorporated, Ottawa, Ontario). Appendix C includes a list of excluded studies and the reasons for exclusion.

### Data Extraction

The staff members and clinical experts (including two nurse-midwives, three obstetrician/gynecologists, one hematologist, and two epidemiologists) who conducted this review jointly developed the evidence tables. We designed the tables to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to our Key Questions. Two evidence table templates were employed to facilitate the extraction of data based on study type; one form was designed for case series that reported harms data and one to accommodate all types of comparative studies and population-based case series. We based the format of our evidence tables on successful designs used for prior systematic reviews.

The team was trained to extract data by extracting several articles into evidence tables and then reconvening as a group to discuss the utility of the table design. We repeated this process through several iterations until we decided that the tables included the appropriate categories for gathering the information contained in the articles. All team members shared the task of initially entering information into the evidence tables. A second team member also reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. A senior reviewer reconciled disagreements concerning the information reported in the evidence tables.

The full research team met regularly during the article extraction period and discussed global issues related to the data extraction process (e.g., determining harms of treatment vs. harms of PPH itself). In addition to outcomes related to intervention effectiveness, we extracted all data available on harms. Harms encompass the full range of specific negative effects, including the narrower definition of adverse events. The final evidence tables are presented in their entirety in Appendix D.

## Data Synthesis

We considered conducting a meta-analysis, but the small number of comparative studies of any given intervention and the heterogeneity of interventions and outcomes made a meta-analysis inappropriate. We completed evidence tables for all included studies (Appendix D), and data are presented in summary tables and analyzed qualitatively in the text.

We also tabulated success rates reported in studies of procedures and surgical approaches in which we could extract data on the effectiveness of the first intervention following conservative management. We refer to these as “initial second-line interventions.” Some studies reported success rates for procedures and/or surgeries only in combination or after multiple interventions; therefore, not all studies addressing a given intervention are represented in these tables. When multiple second-line interventions are combined in analysis, it is impossible to determine which of these stopped the bleeding and thus would be reasonable to use initially. We defined success for a specific intervention as control of bleeding without need for subsequent medical or surgical interventions (not including transfusion or iron supplementation). In some cases, bleeding may have ceased, but a participant ultimately died. If death was not considered to be related to the intervention but was thought to be caused by the PPH and its sequelae, we include the case in the estimate of successful control of bleeding.

## Quality (Risk of Bias) Assessment of Individual Studies

We used separate tools appropriate for specific study designs to assess quality of individual studies: the Cochrane Risk of Bias tool for RCTs,54 the Newcastle-Ottawa Quality Assessment Scale for cohort and case-control studies,55 the National Heart, Lung, and Blood Institute's (NHLBI) Quality Assessment Tool for Before-After (Pre-Post) Studies,56 and a tool adapted from questions outlined in the RTI item bank to assess case series.57 We used questions adapted from the RTI item bank and from the McMaster McHarms58 tools to assess reporting of harms.

The Cochrane Risk of Bias tool is designed for the assessment of studies with experimental designs and randomized participants. Fundamental domains include sequence generation, allocation concealment, blinding, completeness of outcome data, and selective reporting bias. The Newcastle-Ottawa Quality Assessment Scale was used to assess the quality of nonrandomized studies and assesses three broad perspectives: the selection of study groups, the comparability of study groups, and the ascertainment of either the exposure or outcome of interest for case-control or cohort studies, respectively. The NHLBI tool considers questions related to study objectives, description of participants and intervention, outcome assessment, length of followup, and statistical analysis and is designed for studies without a control group. Similarly, the case series and harms tools address questions related to participant and outcome assessment and pre-specification of harms.

Quality assessment of each study was conducted independently by two team members using the forms presented in Appendix B. Any discrepancies were adjudicated by the two team members or a senior investigator. Investigators did not rely on the study design as described by authors of individual papers; rather, the methods section of each paper was reviewed to determine which rating tool to employ. The results of these tools were then translated to the Agency for Healthcare Research and Quality standard of “good,” “fair,” and “poor” quality as described below. Appendix E reports quality scoring for each study.

### Determining Quality Ratings

- We required that RCTs receive a positive score (i.e., low risk of bias for RCTs) on all of the questions used to assess quality to receive a rating of good/low risk of bias. RCTs had to receive at least five positive scores to receive a rating of fair/moderate risk of bias, and studies with ≤ four positive ratings were considered poor quality/high risk of bias. We considered a score of “unclear” for a question as a positive score as long as the consensus of the investigators assessing quality was that study outcomes were not likely to be biased by the factor.
- We required that case-control or cohort studies receive positive scores (stars) on all elements to receive a rating of good, ≤ 2 negative ratings for fair, and > 2 negative scores for a rating of poor quality.
- For pre-post studies we required that studies receive positive scores on all questions to receive a rating of good. We considered studies with ≤ four negative ratings as fair quality and those with more than four as poor quality.
- We required that studies assessed for harms reporting receive a positive rating (i.e., affirmative response) on all four questions to receive a rating of good. Studies with at least three positive responses were considered fair quality and those with less than three positive responses as poor quality.
- Case series have inherently high risk of bias and presumptive low quality. Nonetheless, prospective case series that enroll participants consecutively and control for potentially confounding factors may provide evidence to support comparative studies. We assessed case series using questions identified in the AHRQ Effective Health Care program's “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”46 The elements on which they were scored and the results are presented in Appendix E.

## Strength of the Body of Evidence

We applied explicit criteria for rating the overall strength of the evidence for each key intervention-outcome pair for which the overall risk of bias is not overwhelmingly high. We established concepts of the quantity of evidence (e.g., numbers of studies, aggregate ending-sample sizes), the quality of evidence (from the quality ratings on individual articles), and the coherence or consistency of findings across similar and dissimilar studies and in comparison to known or theoretically sound ideas of clinical or behavioral knowledge.

The strength of evidence evaluation is that stipulated in the Effective Health Care Program's “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”46 and in the updated strength of evidence guide59 which emphasizes five major domains: study limitations (low, medium, high level of limitation), consistency (inconsistency not present, inconsistency present, unknown or not applicable), directness (direct, indirect), precision (precise, imprecise), and reporting bias. Study limitations are derived from the quality assessment of the individual studies that addressed the KQ and specific outcome under consideration. Each key outcome for each comparison of interest is given an overall evidence grade based on the ratings for the individual domains.

The overall strength of evidence was graded as outlined in Table 4. Two senior staff members independently graded the body of evidence; disagreements were resolved as needed through discussion or third-party adjudication. We recorded strength of evidence assessments in tables, summarizing results for each outcome. We considered case series in the assessment of strength of the evidence for harms and for success of procedural and surgical interventions as such interventions are not likely to be represented in RCTs given the urgent nature of PPH treatment. We presumed the quality of case series providing data to assess the success of interventions to be low.

Table 4 Strength of evidence grades and definitions^a^

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

a Excerpted from Berkman et al. 2013^59^

## Applicability

We assessed the applicability of findings reported in the included literature to the general population of women who experience PPH by determining the population, intervention, comparator, and setting in each study and developing an overview of these elements for each intervention category. We anticipated that areas in which applicability would be especially important to describe would include the definition and severity of PPH, the age range and parity of the participants, and the setting in which the intervention took place. Applicability tables for each intervention are in Appendix F.

## Peer Review and Public Commentary

Researchers and clinicians with expertise in managing PPH and individuals representing stakeholder and user communities provided external peer review of this report; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revised the text as appropriate, and documented changes and revisions to the report in a disposition of comments report that will be made available 3 months after AHRQ posts the final review on the AHRQ Web site.