# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Debra Bingham, Dr.P.H., R.N., FAAN
  Association of Women's Health, Obstetric & Neonatal Nurses (AWHONN)
  Washington, DC
- Audrey Lyndon, Ph.D., R.N.C., FAAN
  University of California, San Francisco
  San Francisco, CA
- Amy Marowitz, D.N.P., C.N.M.
  Frontier Nursing University
  Hyden, KY
- Susan McDonald, Ph.D., R.M.
  LaTrobe University
  Mercy Hospital for Women
  Melbourne, Australia
- Larry Shields, M.D.
  Marian Regional Medical Center
  Santa Maria, CA
- Daniel W. Skupski, M.D.
  New York Hospital Queens
  Weill Medical College of Cornell University
  New York, NY
- Carolyn Zelop, M.D.
  The Valley Hospital
  Ridgewood, NJ
  New York University School of Medicine
  New York, NY