# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Debra Bingham, Dr.P.H., R.N., FAAN
  Association of Women's Health, Obstetric & Neonatal Nurses (AWHONN)
  Washington, DC
- Deborah B. Karsnitz, D.N.P., C.N.M., FACNM
  Frontier Nursing University
  Hyden, KY
- Valerie King, M.D., M.P.H.
  Oregon Health & Science University
  Portland, OR
- Audrey Lyndon, Ph.D., R.N.C., FAAN
  University of California, San Francisco
  San Francisco, CA
- Amy Marowitz, D.N.P., C.N.M.
  Frontier Nursing University
  Hyden, KY
- David C. Mayer, M.D.
  University of North Carolina
  Chapel Hill, NC
- Carolyn Zelop, MD
  The Valley Hospital
  Ridgewood, NJ
  New York University School of Medicine
  New York, NY