# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Dr. Melissa McPheeters provided valuable input and methodologic insight throughout the review process. Ms. Rachel Walden executed the literature searches and assisted with screening studies and drafting tables. Ms. Sanura Latham and Ms. Jessica Kimber assisted with locating articles and formatting tables. Ms. Katie Worley managed the topic refinement period and assisted with developing the review protocol.