# Study Design Classification Algorithm

Figure G-1 Study design classification

This figure provides a flow chart for determining the classification of the design of a study used in this review. At the highest level, a study may include a comparison of interventions or exposures or no comparison, in which case it may be classified as a case series, case report, or other noncomparative study. Comparative studies are further classified according to whether exposure occurred at the time of the study or was assigned by the investigator. Studies with investigator-assigned exposures may be considered experimental or observational and are broken down further under each category. Experimental studies, for example, may be considered randomized controlled trials or nonrandomized trials. Observational studies may be cohort studies or case-control studies.