# Applicability Tables

## Pharmacologic Interventions

Table F-1 Applicability for tranexamic acid studies

Domain | Description of applicability of evidence compared to question
Population | Study population similar to women with mild-moderate PPH
Intervention | Drug is available, but use for PPH is off-label in the U.S.A. and therefore should be part of a clinical trial with IRB approval
Comparators | Comparisons were standard
Outcomes | Outcomes assessed were those of clinical importance
Setting | Study conducted in a tertiary care hospitals in France

Table F-2 Applicability for oxytocin and misoprostol studies

Domain | Description of applicability of evidence compared to question
Population | Study population similar to women with mild-moderate PPH
Intervention | Drugs are widely available in the USA and approved for use in the treatment of PPH
Comparators | Comparisons were standard
Outcomes | Outcomes assessed were those of clinical importance
Setting | Study conducted in large medical centers in the USA and Hong Kong

Table F-3 Applicability for recombinant human soluble thrombomodulin (rTM) studies

Domain | Description of applicability of evidence compared to question
Population | Study population similar only to women with DIC as a complication of severe PPH
Intervention | Intervention may not be available at many sites in the USA, exact intervention in this study was created in Japan
Comparators | Comparisons were standard
Outcomes | Outcomes assessed were those of clinical importance
Setting | Study conducted in Japan

Table F-4 Applicability for carboprost tromethamine studies

Domain | Description of applicability of evidence compared to question
Population | Study population similar to women with mild-moderate PPH
Intervention | Drug is available in the USA and approved for use in the treatment of PPH
Comparators | Comparisons were standard
Outcomes | Outcomes assessed were those of clinical importance
Setting | Study conducted in a medical center in the USA

Table F-5 Applicability for recombinant activated FVII (rFVIIa) studies

Domain | Description of applicability of evidence compared to question
Population | Registry study populations included women from any obstetric population within nine European countries or Australia and New Zealand, and two other retrospective studies included women from academic centers in Finland and Ireland. Women included in the studies had post-partum hemorrhage treated with rFVIIa and were identified retrospectively through medical charts or through physician and pharmacist response to mailed surveys. There were no specific inclusion/exclusion criteria other than use of rFVIIa in the post-partum period in women without a history of hemophilia.
Intervention | Use of rFVIIa for post-partum hemorrhage.
Comparators | Comparators included placebo and other methods to control PPH (prophylactic rFVIIa, procedures, surgeries)
Outcomes | Outcomes included transfusion and uterine preservation rates, rates of anemia and length of stay. All studies reported harms associated with treatment with rFVIIa (thromboembolic events and adult respiratory distress syndrome (ARDS) were most common) and rates of maternal death. Harms outcomes were not pre-defined in the methods section. There are no reported long term outcomes.
Setting | Studies were conducted in Australia, New Zealand, Finland, Ireland, Denmark, France, Iceland, the Netherlands, Norway, Sweden, and the United Kingdom and included women from any hospital setting (academic and community). The registry studies attempted to be inclusive of all populations, but ultimately included a sample of hospitals in the regions. Generalization of these study findings to general clinical practice may be limited as many hospitals in the regions assessed did not participate in data collection.

Table F-6 Applicability for transfusion studies

Population | The populations from studies examining the efficacy and harms of transfusion of various blood products after post-partum hemorrhage included women with PPH. PPH was defined differently in each study. In one retrospective cohort study women included in the study had PPH (volume not defined) with clinical symptoms of hypovolemia (hypotension, tachycardia, positive “tilt” test, or oliguria)
Intervention | The transfusion studies studied different interventions. Transfusion with whole blood versus packed red blood cells only versus combinations of blood products or transfusion of cryoprecipitate versus fibrinogen concentrates, or massive transfusion (≥ 10 units of blood) versus standard transfusion (< 10 units of blood), transfusion versus no transfusion, and transfusion with fibrinogen
Comparators | Comparators are as above
Outcomes | Outcomes assessed included ICU admission, length of stay, uterine preservation, and volume of transfusion
Setting | All studies were performed at academic hospitals in Korea, Ireland, the Netherlands and the US. Generalization of these study findings to community settings may be limited as they were single center studies at large institutions.

Table F-7 Applicability for studies of uterine tamponade

Domain | Description of applicability of evidence
Population | The study population was women with PPH
Intervention | Uterine balloon tamponade, including Bakri, Belfort-Dildy, Sengstaken-Blakemore, and Rusch balloons. In one pre-post study all comparisons were done between women who reached the 4^th^ step in the protocol (treated with sulprostone) before and after the implementation of a new protocol. Therefore changes in these outcomes do not reflect the impact of the intervention itself (uterine balloon tamponade) but the influence of a new protocol implementation in the overall management of PPH
Comparators | In one pre-post study, controls (before) were identified by searching electronic medical records while data for the study period (after) were collected prospectively.
Outcomes | Outcomes measured were successful control of bleeding, blood loss, transfusion, and hysterectomy. One study also reported rates of invasive surgical procedures before and after protocol implementation.
Setting | Studies were conducted in France, Finland, Italy, the US, and Hong Kong . Studies were conducted in a tertiary care centers or large hospitals and may not be applicable to other birth settings.

Table F-8 Applicability for studies of uterine artery embolization

Domain | Description of applicability of evidence
Population | Women at larger or tertiary care hospitals receiving embolization for PPH treatment, typically after failure of first-line interventions. More cesarean births when reported
Intervention | Arterial embolization using agents such as gelfoam, microparticles, coils, or a combination. The number of arteries and areteries embolized varied across studies. Embolization may not be widely available in smaller community hospitals, thus applicability is somewhat limited.
Comparators | Comparators were no embolization or use of another intervention. Most studies were case series.
Outcomes | Outcomes measured were typically success of intervention, fertility, resumption of menses, and harms. Loss to followup for fertility outcomes was high.
Setting | Studies were conducted in Europe, Korea, United States, Japan, UK, Hong Kong. Eight of 19 studies were conducted in France and 6 in Korea. Hospital settings applicable to tertiary care centers or centers with interventional radiology available in the U.S.

Table F-9 Applicability for studies of uterine and other pelvic artery ligation

Domain | Description of applicability of evidence
Population | Women receiving arterial ligation for PPH treatment, typically after failure of first-line interventions.
Intervention | Ligation sites varied across studies and included uterine, ovarian, and hypogastric arteries. Ligation availability may depend on availability of skilled providers and may not be widely available in smaller community hospitals, thus applicability is somewhat limited.
Comparators | Comparators were no ligation or use of another intervention.
Outcomes | Outcomes measured were typically success of intervention, fertility, resumption of menses, and harms. Loss to followup for fertility outcomes was high.
Setting | Studies were conducted in Europe, United States, and Argentina.

Table F-10 Applicability for studies of uterine compression sutures

Domain | Description of applicability of evidence
Population | The study population was 811 women receiving sutures for PPH treatment, typically after failure of first-line interventions. 230 cesarean and 42 vaginal births in the one study reporting mode.
Intervention | Typres of sutures varied across studies. Skilled personnel may not be widely available in smaller community hospitals, thus applicability is somewhat limited.
Comparators | Comparators were no suture or use of another intervention. Most studies were case series.
Outcomes | Outcomes measured were typically success of intervention, fertility, resumption of menses, and harms. Loss to followup for fertility outcomes was high.
Setting | Studies were conducted in France, the UK and Argentina .

Table F-11 Applicability for studies of hysterectomy

Domain | Description of applicability of evidence
Population | Over 3000 women receiving hysterectomy, preceded by a combination of interventions including uterotonics, ligation, embolization, and sutures
Intervention | Total and subtotal hysterectomy; prior interventions differed across studies, which aligns with typical care as hysterectomy generally the intervention of last resort when possible
Comparators | Most studies were case series
Outcomes | Outcomes measured were typically success of intervention, transfusion rates, ICU stay, and harms
Setting | Studies were conducted Europe, Canada, US, Denmark, Korea, in a variety of hospitals. Some case series/registry studies reported data from across a country or region.

Table F-12 Applicability for studies of combined interventions

Domain | Description of applicability of evidence
Population | Women with primary and secondary PPH (3 studies) receiving interventions including medical, procedural, and surgical approaches.
Intervention | Medical and surgical approaches including curettage, embolization, hysterectomy, surgical evacuation.
Comparators | Comparator was medical/conservative vs. surgical. procedural treatment. Two studies were case series.
Outcomes | Clinically appropriate outcomes including cessation of bleeding, transfusion rates, complications/harms.
Setting | Studies were conducted Europe, Canada, US, Korea, typically in tertiary care hospitals. Some case series/registry studies reported data from varied hospitals across a country or region

Table F-13 Applicability of studies addressing interventions for anemia

Domain | Description of applicability of evidence compared to question
Population | One RCT included women with iron deficiency anemia (Hb <110 g/L and ferritin < 12 µg/L) who were hemodynamically stable after PPH of ≥ 500 mL blood loss. Another RCT included women with PPH and hemoglobin between 4.8-7.9 g/dl post-birth
Intervention | 400 mg of intravenous iron sucrose divided into two 200 mg infusions given a minimum of 24 hours apart or two iron tablets totaling 160 mg elemental iron daily for six weeks following delivery in one study and transfusion vs. no transfusion
Comparators | Intravenous iron supplementation was compared with oral iron supplementation; no transfusion
Outcomes | Outcomes included blood hemoglobin and ferritin levels performed on days 1, 14, and 42 post-partum, quality of life, fatigue
Setting | Studies were conducted in Australia and the Netherlands in a single hospital and in multiple Dutch hospitals. One RCT was conducted at a single hospital outside of a city in Australia. The catchment area of the hospital predominantly included the local neighborhood composed predominantly of women of low educational attainment and socio-economic status, with high levels of unemployment and teen pregnancy.

Table F-14 Applicability of systems-level interventions

Domain | Description of applicability of evidence compared to question
Population | Populations both in the United States and Europe reflect those typical of similar size and type (rural, academic, etc.) obstetric units in current labor and delivery environments in the United States. Overall the systems-level interventions assessed have good applicability to current practice in the United States.
Intervention | Interventions were informed by processes of identifying evidence and crafting guidance that conforms to typical quality improvement and outcomes based research. The content of the interventions is feasible to implement across a full range of settings and the approaches to measuring outcomes are applicable to practice
Comparators | Most studies used pre-post designs.
Outcomes | Outcomes were clinically relevant and included change in PPH incidence, changes in procedures and interventions.
Setting | Studies were conducted in Europe and the United States and reflect settings typical of similar size and type (rural, academic, etc.) obstetric units in current labor and delivery environments in the United States.