# Quality/Risk of Bias Ratings

Table E-1 Quality assessment of randomized controlled trials

Outcome Author, Year | Sequence Generation | Allocation Concealment | Selective Reporting | Other Bias | Blinding of Participants/Personnel | Blinding of Outcome Assessment | Incomplete Outcome Data | Risk of Bias Rating for Outcome
Anemia
Ducloy-Bouthors 2011^1^ | Low | Low | Low | Unclear | High | High | Low | Poor/High RoB
Duration of bleeding
Ducloy-Bouthors 2011^1^ | Low | Low | Low | Unclear | High | High | Low | Poor/High RoB
Ferritin level
Froessler 2012^2^ | High | High | Low | Low | High | High | High | Poor/High RoB
Hemoglobin level
Froessler 2012^2^ | High | High | Low | Low | High | High | High | Poor/High RoB
Need to call for additional help
Ducloy-Bouthors 2011^1^ | Low | Low | Low | Unclear | High | High | Low | Poor/High RoB
Need for Transfusion/Transfusion practice
Ducloy-Bouthors 2011^1^ | Low | Low | Low | Unclear | High | High | Low | Poor/High RoB
Deneux-Tharaux 2010^3^ | Low | Low | Low | Low | High | High | Low | Fair/Moderate RoB
Physical fatigue
Prick 2014^4^ | Low | Low | Low | Unclear | High | High | Low | Poor/High RoB
Quality of life
Prick 2014^4^ | Low | Low | Low | Unclear | High | High | Low | Poor/High RoB
Rate of PPH (Overall)
Deneux-Tharaux 2010^3^ | Low | Low | Low | Low | Unclear | Unclear | Low | Fair/Moderate RoB
Rate of severe PPH
Deneux-Tharaux 2010^3^ | Low | Low | Low | Low | Unclear | Unclear | Low | Fair/Moderate RoB
Rate of sulprostone use, use of recommended interventions
Deneux-Tharaux 2010^3^ | Low | Low | Low | Low | High | High | Low | Fair/Moderate RoB

Table E-2 Quality assessment of pre-post studies

Author, Year | Objective clearly stated | Selection criteria prespecified and clearly described | Participants representative of those who would be eligible for the intervention | All eligible participants enrolled | Sample size sufficient | Intervention clearly described and delivered consistently | Outcome measures prespecified, clearly defined, valid, reliable, and assessed consistently | Outcomes assessors blinded | Loss to follow-up after baseline 20% or less and accounted for in analysis | Statistical methods examined changes in outcome measures from pre to post | Outcome measures of interest taken multiple times pre and post | For group level interventions, statistical analysis accounted for use of individual-level data | Rating
Mallaiah, 2014 5 | + | + | + | CD | - | + | + | - | + | + | - | - | Poor
Shields, 2014 6 | + | + | + | + | + | - | + | - | + | + | + | - | Fair
Lappen, 2013^7, 8^ | + | + | + | + | + | + | - | - | + | + | + | - | Fair
Laas, 2012^9^ | + | + | + | + | - | + | + | - | + | + | - | - | Fair
Markova, 2012^10^ | + | + | + | + | - | + | + | - | + | + | - | - | Fair
Shields, 2011^11^ | + | + | + | + | - | + | + | - | + | + | - | - | Fair
Dupont, 2011^12, 13^ | + | + | + | + | - | - | + | - | + | + | - | - | Poor
Auduraeu, 2009^14^ | + | + | + | + | + | + | + | - | + | + | - | - | Fair
Skupski, 2006^15^ | + | + | + | - | - | + | + | - | + | + | - | - | Poor
Rizvi, 2004^16^ | - | + | + | CD | - | - | - | - | + | - | - | - | Poor

CD-cannot determine

Table E-3 Quality assessment of cohort studies

Author, Year | Representativeness of exposed cohort | Selection of non-exposed cohort | Ascertainment of exposure | Outcome of interest not present at start of study | Comparability of cohorts | Assessment of outcome | Duration of follow-up | Adequacy of follow-up of cohorts | Quality Rating
Kim 2014^17^ | - | + | + | + | - | + | + | + | Fair
Chan 2013^18^ | + | + | + | + | - | + | + | + | Fair
Sohn 2013^19^ | - | + | + | + | + | + | - | + | Fair
Bateman 2013^20^ | + | + | + | + | + | + | + | + | Good
Ahmed 2012^21^ | + | + | + | + | - | + | + | + | Fair
Sugawara 2012^22^ | + | + | + | + | + | + | - | + | Fair
Gayat 2011^23^ | + | + | + | + | - | + | + | + | Fair
Markova 2011^10^ | + | + | + | + | - | + | + | + | Fair
Dupont 2011^12^ | + | + | + | + | - | + | + | + | Fair
Kayem 2011^24, 25^ | + | + | - | + | - | - | + | + | Fair
Alexander 2009^26^ | + | + | + | + | - | + | + | + | Fair
Feigenberg 2009^27^ | + | + | + | + | - | + | + | + | Fair
Sentilhes 2009^28^ | + | + | + | + | - | + | + | + | Fair
Zwart 2009^29^ | + | + | + | + | - | + | + | + | Fair
Baruah 2008^30^ | + | + | + | + | - | + | + | + | Fair
Chauleur 2008^31^ | + | + | + | + | - | + | + | + | Fair
Ahonen 2007^32^ | - | + | + | + | + | + | + | + | Fair
Rizvi 2004^16^ | + | + | + | + | - | + | + | + | Fair
Ledee 2001^33^ | + | + | + | + | - | + | + | + | Fair

Table E-4 Quality assessment of case-control studies

Author, Year | Case definition adequate | Representativeness of cases | Selection of controls | Definition of controls | Comparability of cases and controls | Ascertainment of exposure | Same method of ascertainment for cases and controls | Non-response rate | Quality Rating
Hardeman 2010^34^ | + | + | - | + | - | + | + | - | Poor
McMorrow 2008^35^ | + | + | - | + | - | + | + | N/A | Fair

Table E-5 Quality assessment of studies reporting harms

Author, Year | Were the harms predefined using standardized or precise definitions? | Were all pre-specified harms reported? | Did the author(s) use STANDARD scale(s) or checklist(s) for harms collection? | Were the statistical methods used to assess the main harm adequate? | Rating
Cheong 2014^36^ | - | unsure | + | + | Poor
Cowan 2014^37^ | + | + | + | + | Good
Ferrazzani 2014^38^ | - | unsure | + | + | Poor
Inoue 2014^39^ | - | unclear | + | + | Poor
Kim 2014^17^ | - | unsure | + | + | Poor
Mallaiah 2014^5^ | - | unclear | + | + | Poor
Prick 2014^4^ | + | + | + | + | Good
Teofili 2014^40^ | + | + | + | + | Good
Zatta 2014^41^ | - | unsure | + | + | Poor
An 2013^42^ | + | + | + | + | Good
Gronvall 2013^43^ | - | unsure | + | + | Poor
Kim 2013^44^ | + | + | + | + | Good
Lee 2013^45^ | + | + | + | + | Good
Yamasaki 2013^46^ | - | unsure | - | + | Poor
Bateman 2013^20^ | + | + | + | + | Good
Blanc 2012^47^ | - | unclear | + | + | Poor
Laas 2012^9^ | - | unsure | + | + | Poor
Lee 2012^48^ | - | unsure | + | + | Poor
Poujade 2012^49^ | - | unsure | + | + | Poor
Froessler 2012^2^ | - | unsure | unsure | unsure | Good
Bonnet 2012^50, 51^ | - | unsure | + | + | Poor
Ahmed 2012^21^ | - | unsure | + | + | Poor
Ducloy-Bouthors 2011^1^ | + | + | + | + | Good
Palacios-Jaraquemada 2011^52^ | - | unsure | + | + | Poor
Sentilhes 2011^53, 54,:#1378^ | - | unsure | + | + | Poor
Kayem 2011^24, 25^ | - | unsure | - | - | Poor
Ganguli 2010^55^ | - | unsure | + | + | Poor
Wright 2010^56^ | + | + | + | + | Good
Hardeman 2010^34^ | - | unsure | unsure | + | Poor
Feigenberg 2009^27^ | + | + | + | + | Good
Fiori 2009^57^ | - | unsure | + | + | Poor
Lone 2009^58^ | - | unsure | + | + | Poor
Phillips 2009^59^ | + | + | + | + | Good
Zwart 2009^29^ | - | unsure | + | + | Poor
Alexander 2009^26^ | - | unsure | + | + | Poor
Balki 2008,^60^ | - | unclear | + | + | Poor
Chauleur 2008^31^ | - | unsure | + | + | Poor
Gaia 2008^61^ | - | unsure | + | + | Poor
Glaze 2008^62^ | - | unsure | unsure | + | Poor
McMorrow 2008^35^ | - | - | unsure | - | Poor
Touboul 2008^63^ | - | unsure | - | + | Poor
Chauleur 2008^64^ | - | unsure | + | + | Poor
Alfirevic 2007^65^ | - | unsure | + | + | Poor
Sakse 2007^66^ | Unsure | unsure | + | + | Poor
Knight 2007^67^ | - | unsure | + | + | Poor
Ahonen 2007^32^ | - | unsure | + | + | Poor
Akinbiyi 2004^68^ | - | unclear | + | + | Poor
Forna 2004^69^ | + | + | + | + | Good
Hoveyda 2001^70^ | - | unsure | + | + | Poor
O'Leary 1995^71^ | - | unsure | + | + | Poor
Boyd 1995^72^ | - | unsure | + | + | Poor
Oleen 1990^73^ | - | unsure | + | + | Poor

Table E-6 Quality assessment of case series

Author, Year | Confounding and modifying variables accounted for | Concurrent intervention/unintended exposure ruled out | Study free from variations from protocol | Low rate (≤20/5) attrition | Attrition did not result in difference in groups baseline & followup | Outcome assessors blinded | Clearly stated inclusion/exclusion criteria | Measures implemented consistently | Appropriate measures for assessing interventions/exposures | Interventions implemented consistently | Clearly described measures for outcome assessment (Outcome: Blood Loss) | Clearly described measures for outcome assessment (Outcome: Transfusion) | Clearly described measures for outcome assessment (Outcome: ICU) | Clearly described measures for outcome assessment (Outcome: Cessation) | Clearly described measures for outcome assessment (Outcome: Success) | Clearly described measures for outcome assessment (Outcome: Fertility) | Clearly described measures for outcome assessment (Outcome: Hemostasis) | Clearly described measures for outcome assessment (Outcome: LOS) | Clearly described measures for outcome assessment (Outcome: Uterine Preservation) | Appropriate measures for outcome assessment (Outcome: Blood Loss) | Appropriate measure for outcome assessment (Outcome: Transfusion) | Appropriate measure for outcome assessment (Outcome: ICU) | Appropriate measure for outcome assessment (Outcome: Cessation) | Appropriate measure for outcome assessment (Outcome: Success) | Appropriate measure for outcome assessment (Outcome: Fertility) | Appropriate measure for outcome assessment (Outcome: Hemostasis) | Appropriate measure for outcome assessment (Outcome: LOS) | Appropriate measure for outcome assessment (Outcome: Uterine Preservation) | Consistent implementation of outcome assessment | Appropriate measures for confounding variables assessment | Consistent assessment of confounding variables | Secular trends and regression to the mean accounted for | Pre-specified potential outcomes | Reporting of all pre-specified outcomes
Cheong, 2014^36^ | + | NA | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | - | + | +
Ferrazzani, 2014^38^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | - | + | +
Inoue, 2014^39^ | - | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | - | - | - | + | +
Park, 2014^74^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | - | + | +
Zatta, 2014^41^ | NA | - | NR | NA | NA | NA | + | NR | + | NA | / | / | / | - | / | / | / | / | / | / | / | / | + | / | / | / | / | / | + | - | - | - | + | +
Dildy, 2013^75^ | + | - | NR | NA | NA | - | + | + | + | - | - | - | + | + | / | / | / | / | / | - | + | + | + | / | / | / | / | / | + | - | NR | NA | + | +
Gronvall, 2013^43^ | - | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | - | - | - | + | +
Lee, 2013^45^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | - | + | +
Kim, 2013^44^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | - | + | +
Yamasaki, 2013^46^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | - | + | +
Blanc, 2012^47^ | + | - | NR | + | + | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | - | + | +
Lee, 2012^48^ | + | - | NR | - | NR | - | + | + | + | NA | / | + | / | / | + | - | / | / | / | / | + | / | / | + | + | / | / | / | - | + | + | - | + | +
Poujade, 2012^49^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | NA | + | +
Ganguli, 2011^55^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | - | + | +
Palacios-Jaraquemada, 2011^52^ | - | - | NR | + | NA | - | - | NR | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | - | - | - | + | +
Wright, 2010^56^ | + | - | NR | + | + | - | + | + | + | NA | / | + | + | / | / | / | / | + | / | / | + | + | / | / | / | / | + | / | + | + | + | - | + | +
Lone, 2010^58^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | / | / | / | / | / | / | / | / | / | / | / | / | / | / | + | + | + | + | + | +
Phillips, 2009^59^ | - | - | NR | NA | NA | - | + | + | + | NA | / | + | / | + | / | / | / | / | / | / | + | / | + | / | / | / | / | / | + | - | NR | - | + | +
Gaia, 2009^61^ | - | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | + | / | / | / | / | / | / | / | + | + | / | / | / | + | - | - | - | + | +
Fiori, 2009^57^ | - | - | NR | - | NR | - | + | + | + | NA | / | / | / | / | + | + | / | / | / | / | / | / | / | + | + | / | / | / | + | + | + | - | + | +
Glaze, 2008^62^ | - | - | NR | NA | NA | - | + | + | + | NA | / | + | + | / | + | / | / | / | / | / | + | + | / | + | / | / | / | / | + | - | NA | - | + | +
Knight, 2008^67^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | NA | + | +
Touboul, 2008^63^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | + | + | + | - | + | +
Chauleur, 2008^64^ | + | - | NR | + | NA | - | + | + | + | NA | / | + | + | / | / | / | / | / | - | / | + | + | / | / | / | / | / | + | + | - | - | - | + | +
Alfirevic, 2007^65^ | - | - | NR | NA | NA | - | + | + | + | NA | - | + | + | + | / | / | / | / | / | NR | + | + | + | / | / | / | / | / | - | + | + | - | + | +
Sakse, 2007^66^ | - | - | NR | + | + | - | + | + | + | NA | - | - | / | / | / | / | / | / | / | NR | NR | / | / | / | / | / | / | / | NR | - | - | - | + | +
Forna, 2004^69^ | + | NA | NR | + | NA | - | + | + | + | + | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | + | + | - | + | +
Hoveyda, 2001^70^ | + | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | / | / | / | / | / | / | / | / | / | / | / | / | / | / | + | + | + | NA | + | +
Boyd, 1995^72^ | - | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | - | - | - | + | +
O'Leary, 1995^71^ | - | - | NR | + | NA | - | + | + | + | NA | / | / | / | / | + | / | / | / | / | / | / | / | / | + | / | / | / | / | + | - | - | + | + | +
Oleen, 1990^73^ | + | - | NR | + | NA | - | + | + | + | NA | - | + | / | / | / | / | / | / | / | + | + | / | / | / | / | / | / | / | + | + | + | NA | + | +

NA=not applicable, NR=not reported, / =outcome not rated for this study

## Quality References

1 Ducloy-Bouthors AS, Jude B, Duhamel A, et al. High-dose tranexamic acid reduces blood loss in postpartum haemorrhage. Crit Care. 2011;15:R117. [pmid: 21496253].
2 Froessler B, Cocchiaro C, Saadat-Gilani K, et al. Intravenous iron sucrose versus oral iron ferrous sulfate for antenatal and postpartum iron deficiency anemia: a randomized trial. J Matern Fetal Neonatal Med. May. 2012;26:654-9. [pmid: 23130909].
3 Deneux-Tharaux C, Dupont C, Colin C, et al. Multifaceted intervention to decrease the rate of severe postpartum haemorrhage: the PITHAGORE6 cluster-randomised controlled trial. BJOG. Sep. 2010;117:1278-87. [pmid: 20573150].
4 Prick B, Jansen A, Steegers E, et al. Transfusion policy after severe postpartum haemorrhage: a randomised non-inferiority trial. BJOG. 2014. Jan. 10. [pmid: 24405687].
5 Mallaiah S, Barclay P, Harrod I, et al. Introduction of an algorithm for ROTEM-guided fibrinogen concentrate administration in major obstetric haemorrhage. Anaesthesia. 2014. Oct. 7. [pmid: 25289791].
6 Shields LE, Wiesner S, Fulton J, et al. Comprehensive maternal hemorrhage protocols reduce the use of blood products and improve patient safety. Am J Obstet Gynecol. 2014. Jul. 12. [pmid: 25025944].
7 Lappen JR, Seidman D, Burke C, et al. Changes in care associated with the introduction of a postpartum hemorrhage patient safety program. Am J Perinatol. Nov. 2013;30:833-8. [pmid: 23359234].
8 Einerson BD, Miller ES, Grobman WA. Does a postpartum hemorrhage patient safety program result in sustained changes in management and outcomes?. Am J Obstet Gynecol. 2014. Jul. 11. [pmid: 25019484].
9 Laas E, Bui C, Popowski T, et al. Trends in the rate of invasive procedures after the addition of the intrauterine tamponade test to a protocol for management of severe postpartum hemorrhage. Am J Obstet Gynecol. Oct. 2012;207:281 e1-7. [pmid: 23021688].
10 Markova V, Sorensen JL, Holm C, et al. Evaluation of multi-professional obstetric skills training for postpartum hemorrhage. Acta Obstet Gynecol Scand. Mar. 2011;91:346-52. [pmid: 22171606].
11 Shields LE, Smalarz K, Reffigee L, et al. Comprehensive maternal hemorrhage protocols improve patient safety and reduce utilization of blood products. Am J Obstet Gynecol. Oct. 2011;205:368 e1-8. [pmid: 22083059].
12 Dupont C, Deneux-Tharaux C, Touzet S, et al. Clinical audit: a useful tool for reducing severe postpartum haemorrhages?. Int J Qual Health Care. Oct. 2011;23:583-9. [pmid: 21733978].
13 Dupont C, Occelli P, Deneux-Tharaux C, et al. Severe postpartum haemorrhage after vaginal delivery: a statistical process control chart to report seven years of continuous quality improvement. Eur J Obstet Gynecol Reprod Biol. Jul. 2014;178:169-75. [pmid: 24813084].
14 Audureau E, Deneux-Tharaux C, Lefevre P, et al. Practices for prevention, diagnosis and management of postpartum haemorrhage: impact of a regional multifaceted intervention. BJOG. Sep. 2009;116:1325-33. [pmid: 19538416].
15 Skupski DW, Lowenwirt IP, Weinbaum FI, et al. Improving hospital systems for the care of women with major obstetric hemorrhage. Obstet Gynecol. May. 2006;107:977-83. [pmid: 16648399].
16 Rizvi F, Mackey R, Barrett T, et al. Successful reduction of massive postpartum haemorrhage by use of guidelines and staff education. BJOG. May. 2004;111:495-8. [pmid: 15104617].
17 Kim TH, Lee HH, Kim JM, et al. Uterine artery embolization for primary postpartum hemorrhage. Iran J Reprod Med. Jun. 2014;11:511-8. [pmid: 24639786].
18 Chan LL, Lo TK, Lau WL, et al. Use of second-line therapies for management of massive primary postpartum hemorrhage. Int J Gynaecol Obstet. Sep. 2013;122:238-43. [pmid: 23806248].
19 Sohn CH, Kim WY, Kim SR, et al. An increase in initial shock index is associated with the requirement for massive transfusion in emergency department patients with primary postpartum hemorrhage. Shock. Aug. 2013;40:101-5. [pmid: 23707978].
20 Bateman BT, Huybrechts KF, Hernandez-Diaz S, et al. Methylergonovine maleate and the risk of myocardial ischemia and infarction. Am J Obstet Gynecol. Nov. 2013;209:459.e1-e13. [pmid: 23850529].
21 Ahmed S, Harrity C, Johnson S, et al. The efficacy of fibrinogen concentrate compared with cryoprecipitate in major obstetric haemorrhage--an observational study. Transfus Med. Oct. 2012;22:344-9. [pmid: 22994449].
22 Sugawara J, Suenaga K, Hoshiai T, et al. Efficacy of recombinant human soluble thrombomodulin in severe postpartum hemorrhage with disseminated intravascular coagulation. Clin Appl Thromb Hemost. Sep. 2012;19:557-61. [pmid: 22496090].
23 Gayat E, Resche-Rigon M, Morel O, et al. Predictive factors of advanced interventional procedures in a multicentre severe postpartum haemorrhage study. Intensive Care Med. Nov. 2011;37:1816-25. [pmid: 21805157].
24 Kayem G, Kurinczuk JJ, Alfirevic Z, et al. Specific second-line therapies for postpartum haemorrhage: a national cohort study. BJOG. Jun. 2011;118:856-64. [pmid: 21392247].
25 Kayem G, Kurinczuk JJ, Alfirevic Z, et al. Uterine compression sutures for the management of severe postpartum hemorrhage. Obstet Gynecol. Jan. 2011;117:14-20. [pmid: 21213474].
26 Alexander JM, Sarode R, McIntire DD, et al. Whole blood in the management of hypovolemia due to obstetric hemorrhage. Obstet Gynecol. Jun. 2009;113:1320-6. [pmid: 19461429].
27 Feigenberg T, Eitan Y, Sela HY, et al. Surgical versus medical treatment for secondary post-partum hemorrhage. Acta Obstet Gynecol Scand. 2009;88:909-13. [pmid: 19565365].
28 Sentilhes L, Gromez A, Clavier E, et al. Fertility and pregnancy following pelvic arterial embolisation for postpartum haemorrhage. BJOG. Jan. 2009;117:84-93. [pmid: 19832826].
29 Zwart JJ, Dijk PD, van Roosmalen J. Peripartum hysterectomy and arterial embolization for major obstetric hemorrhage: a 2-year nationwide cohort study in the Netherlands. Am J Obstet Gynecol. Feb. 2009;202:150 e1-7. [pmid: 19922900].
30 Baruah M, Cohn GM. Efficacy of rectal misoprostol as second-line therapy for the treatment of primary postpartum hemorrhage. J Reprod Med. Mar. 2008;53:203-6. [pmid: 18441726].
31 Chauleur C, Fanget C, Tourne G, et al. Serious primary post-partum hemorrhage, arterial embolization and future fertility: a retrospective study of 46 cases. Hum Reprod. Jul. 2008;23:1553-9. [pmid: 18460450].
32 Ahonen J, Jokela R, Korttila K. An open non-randomized study of recombinant activated factor VII in major postpartum haemorrhage. Acta Anaesthesiol Scand. Aug. 2007;51:929-36. [pmid: 17488316].
33 Ledee N, Ville Y, Musset D, et al. Management in intractable obstetric haemorrhage: an audit study on 61 cases. Eur J Obstet Gynecol Reprod Biol. Feb. 2001;94:189-96. [pmid: 11165724].
34 Hardeman S, Decroisette E, Marin B, et al. Fertility after embolization of the uterine arteries to treat obstetrical hemorrhage: a review of 53 cases. Fertil Steril. Dec. 2010;94:2574-9. [pmid: 20381035].
35 McMorrow RC, Ryan SM, Blunnie WP, et al. Use of recombinant factor VIIa in massive post-partum haemorrhage. Eur J Anaesthesiol. Apr. 2008;25:293-8. [pmid: 18177539].
36 Cheong JY, Kong TW, Son JH, et al. Outcome of pelvic arterial embolization for postpartum hemorrhage: A retrospective review of 117 cases. Obstet Gynecol Sci. Jan. 2014;57(1):17-27. [pmid: 24596814].
37 Cowan AD, Miller ES, Grobman WA. Subsequent pregnancy outcome after B-lynch suture placement. Obstet Gynecol. Sep. 2014;124(3):558-61. [pmid: 25162256].
38 Ferrazzani S, Iadarola R, Perrelli A, et al. Use of an intrauterine inflated catheter balloon in massive post-partum hemorrhage: a series of 52 cases. J Obstet Gynaecol Res. Jun. 2014;40:1603-10. [pmid: 24888923].
39 Inoue S, Masuyama H, Hiramatsu Y. Efficacy of transarterial embolisation in the management of post-partum haemorrhage and its impact on subsequent pregnancies. Aust N Z J Obstet Gynaecol. 2014. Oct. 28. [pmid: 25350565].
40 Teofili L, Bianchi M, Zanfini BA, et al. Acute Lung Injury Complicating Blood Transfusion in Post-Partum Hemorrhage: Incidence and Risk Factors. Mediterr J Hematol Infect Dis. 2014;6(1):e2014069. [pmid: 25408855].
41 Zatta A, McQuilten Z, Kandane-Rathnayake R, et al. The Australian and New Zealand Haemostasis Registry: ten years of data on off-licence use of recombinant activated factor VII. Blood Transfus. Jun. 2014;5:1-14. [pmid: 24960661].
42 An GH, Ryu HM, Kim MY, et al. Outcomes of subsequent pregnancies after uterine compression sutures for postpartum hemorrhage. Obstet Gynecol. Sep. 2013;122:565-70. [pmid: 23921861].
43 Gronvall M, Tikkanen M, Tallberg E, et al. Use of Bakri balloon tamponade in the treatment of postpartum hemorrhage: a series of 50 cases from a tertiary teaching hospital. Acta Obstet Gynecol Scand. Apr. 2012;92:433-8. [pmid: 22913383].
44 Kim YJ, Yoon CJ, Seong NJ, et al. Failed pelvic arterial embolization for postpartum hemorrhage: clinical outcomes and predictive factors. J Vasc Interv Radiol. May. 2013;24:703-9. [pmid: 23622042].
45 Lee HJ, Jeon GS, Kim MD, et al. Usefulness of pelvic artery embolization in cesarean section compared with vaginal delivery in 176 patients. J Vasc Interv Radiol. Jan. 2013;24:103-9. [pmid: 23273701].
46 Yamasaki Y, Morita H, Miyahara Y, et al. The factors associated with the failure of transcatheter pelvic arterial embolization for intractable postpartum hemorrhage. J Perinat Med. Dec. 2013;5:1-4. [pmid: 24310770].
47 Blanc J, Courbiere B, Desbriere R, et al. Uterine-sparing surgical management of postpartum hemorrhage: is it always effective?. Arch Gynecol Obstet. Apr. 2011;285:925-30. [pmid: 21932086].
48 Lee HY, Shin JH, Kim J, et al. Primary postpartum hemorrhage: outcome of pelvic arterial embolization in 251 patients at a single institution. Radiology. Sep. 2012;264:903-9. [pmid: 22829685].
49 Poujade O, Zappa M, Letendre I, et al. Predictive factors for failure of pelvic arterial embolization for postpartum hemorrhage. Int J Gynaecol Obstet. May. 2012;117:119-23. [pmid: 22361480].
50 Bonnet MP, Deneux-Tharaux C, Dupont C, et al. Transfusion practices in postpartum hemorrhage: a population-based study. Acta Obstet Gynecol Scand. Apr. 2012;92:404-13. [pmid: 23215892].
51 Schmitz T, Tararbit K, Dupont C, et al. Prostaglandin E2 analogue sulprostone for treatment of atonic postpartum hemorrhage. Obstet Gynecol. Aug. 2011;118:257-65. [pmid: 21775840].
52 Palacios-Jaraquemada JM. Efficacy of surgical techniques to control obstetric hemorrhage: analysis of 539 cases. Acta Obstet Gynecol Scand. Sep. 2011;90:1036-42. [pmid: 21564024].
53 Sentilhes L, Gromez A, Clavier E, et al. Long-term psychological impact of severe postpartum hemorrhage. Acta Obstet Gynecol Scand. Jun. 2011;90:615-20. [pmid: 21370999].
54 Sentilhes L, Gromez A, Clavier E, et al. Predictors of failed pelvic arterial embolization for severe postpartum hemorrhage. Obstet Gynecol. May. 2009;113:992-9. [pmid: 19384113].
55 Ganguli S, Stecker MS, Pyne D, et al. Uterine artery embolization in the treatment of postpartum uterine hemorrhage. J Vasc Interv Radiol. Feb. 2010;22:169-76. [pmid: 21183360].
56 Wright JD, Herzog TJ, Shah M, et al. Regionalization of care for obstetric hemorrhage and its effect on maternal mortality. Obstet Gynecol. Jun. 2010;115:1194-200. [pmid: 20502290].
57 Fiori O, Deux JF, Kambale JC, et al. Impact of pelvic arterial embolization for intractable postpartum hemorrhage on fertility. Am J Obstet Gynecol. Apr. 2009;200:384 e1-4. [pmid: 19217597].
58 Lone F, Sultan AH, Thakar R, et al. Risk factors and management patterns for emergency obstetric hysterectomy over 2 decades. Int J Gynaecol Obstet. Apr. 2009;109:12-5. [pmid: 19951818].
59 Phillips LE, McLintock C, Pollock W, et al. Recombinant activated factor VII in obstetric hemorrhage: experiences from the Australian and New Zealand Haemostasis Registry. Anesth Analg. Dec. 2009;109:1908-15. [pmid: 19923520].
60 Balki M, Dhumne S, Kasodekar S, et al. Blood transfusion for primary postpartum hemorrhage: a tertiary care hospital review. J Obstet Gynaecol Can. Nov. 2009;30:1002-7. [pmid: 19126281].
61 Gaia G, Chabrot P, Cassagnes L, et al. Menses recovery and fertility after artery embolization for PPH: a single-center retrospective observational study. Eur Radiol. Feb. 2008;19:481-7. [pmid: 18766350].
62 Glaze S, Ekwalanga P, Roberts G, et al. Peripartum hysterectomy: 1999 to 2006. Obstet Gynecol. Mar. 2008;111:732-8. [pmid: 18310378].
63 Touboul C, Badiou W, Saada J, et al. Efficacy of selective arterial embolisation for the treatment of life-threatening post-partum haemorrhage in a large population. PLoS One. 2008;3:e3819. [pmid: 19043573].
64 Chauleur C, Cochery-Nouvellon E, Mercier E, et al. Analysis of the venous thromboembolic risk associated with severe postpartum haemorrhage in the NOHA First cohort. Thromb Haemost. Nov. 2008;100:773-9. [pmid: 18989520].
65 Alfirevic Z, Elbourne D, Pavord S, et al. Use of recombinant activated factor VII in primary postpartum hemorrhage: the Northern European registry 2000-2004. Obstet Gynecol. Dec. 2007;110:1270-8. [pmid: 18055720].
66 Sakse A, Weber T, Nickelsen C, et al. Peripartum hysterectomy in Denmark 1995-2004. Acta Obstet Gynecol Scand. 2007;86:1472-5. [pmid: 18027114].
67 Knight M. Peripartum hysterectomy in the UK: management and outcomes of the associated haemorrhage. BJOG. Nov. 2007;114:1380-7. [pmid: 17877772].
68 Akinbiyi AA, Olatunbosun OA. Emergency obstetric hysterectomies (how many are potentially preventable?): A 28-year experience in Saskatoon. Journal of Gynecologic Surgery. Fall. 2004;20:81-7.
69 Forna F, Miles AM, Jamieson DJ. Emergency peripartum hysterectomy: a comparison of cesarean and postpartum hysterectomy. Am J Obstet Gynecol. May. 2004;190:1440-4. [pmid: 15167863].
70 Hoveyda F, MacKenzie IZ. Secondary postpartum haemorrhage: incidence, morbidity and current management. BJOG. Sep. 2001;108:927-30. [pmid: 11563461].
71 O'Leary JA. Uterine artery ligation in the control of postcesarean hemorrhage. J Reprod Med. Mar. 1995;40:189-93. [pmid: 7776302].
72 Boyd BK, Katz VL, Hansen WF. Delayed postpartum hemorrhage: a retrospective analysis. Journal of Maternal-Fetal Medicine. 1995. Jan-Feb. 1995;4:19-23.
73 Oleen MA, Mariano JP. Controlling refractory atonic postpartum hemorrhage with Hemabate sterile solution. Am J Obstet Gynecol. Jan. 1990;162:205-8. [pmid: 2405676].
74 Park HS, Shin JH, Yoon HK, et al. Transcatheter Arterial Embolization for Secondary Postpartum Hemorrhage: Outcome in 52 Patients at a Single Tertiary Referral Center. J Vasc Interv Radiol. 2014. Jun. 27. [pmid: 24985718].
75 Dildy GA, Belfort MA, Adair CD, et al. Initial experience with a dual-balloon catheter for the management of postpartum hemorrhage. Am J Obstet Gynecol. 2013. Sep. 18. [pmid: 24055586].