# Evidence Tables

Table D-1 Evidence table for studies addressing management of PPH (Cheong 2014)

Table D-2 Evidence table for studies addressing management of PPH (Cowan 2014)

Table D-3 Evidence table for studies addressing management of PPH (Dupont 2014)

Table D-4 Evidence table for studies addressing management of PPH (Einerson 2014)

Table D-5 Evidence table for studies addressing management of PPH (Ferrazzani 2014)

Table D-6 Evidence table for studies addressing management of PPH (Inoue 2014)

Table D-7 Evidence table for studies addressing management of PPH (Mallaiah 2014)

Table D-8 Evidence table for studies addressing management of PPH (Park 2014)

Table D-9 Evidence table for studies addressing management of PPH (Prick 2014)

Table D-10 Evidence table for studies addressing management of PPH (Shields 2014)

Table D-11 Evidence table for studies addressing management of PPH (Teofili 2014)

Table D-12 Evidence table for studies addressing management of PPH (Zatta 2014)

Table D-13 Evidence table for studies addressing management of PPH (An 2013)

Table D-14 Evidence table for studies addressing management of PPH (Bateman 2013)

Table D-15 Evidence table for studies addressing management of PPH (Bonnet 2013)

Table D-16 Evidence table for studies addressing management of PPH (Chan 2013)

Table D-17 Evidence table for studies addressing management of PPH (Dildy 2013)

Table D-18 Evidence table for studies addressing management of PPH (Froessler 2013)

Table D-19 Evidence table for studies addressing management of PPH (Lee 2013)

Table D-20 Evidence table for studies addressing management of PPH (Kim 2013a)

Table D-21 Evidence table for studies addressing management of PPH (Kim 2013b)

Table D-22 Evidence table for studies addressing management of PPH (Lappen 2013)

Table D-23 Evidence table for studies addressing management of PPH (Sohn 2013)

Table D-24 Evidence table for studies addressing management of PPH (Sugawara 2013)

Table D-25 Evidence table for studies addressing management of PPH (Yamasaki 2013)

Table D-26 Evidence table for studies addressing management of PPH (Blanc 2012)

Table D-27 Evidence table for studies addressing management of PPH (Laas 2012)

Table D-28 Evidence table for studies addressing management of PPH (Lee 2012)

Table D-29 Evidence table for studies addressing management of PPH (Ahmed 2012)

Table D-30 Evidence table for studies addressing management of PPH (Gronvall 2012)

Table D-31 Evidence table for studies addressing management of PPH (Markova 2012)

Table D-32 Evidence table for studies addressing management of PPH (Poujade 2012)

Table D-33 Evidence table for studies addressing management of PPH (Ducloy-Borthers 2011)

Table D-34 Evidence table for studies addressing management of PPH (Dupont 2011)

Table D-35 Evidence table for studies addressing management of PPH (Gayat 2011)

Table D-36 Evidence table for studies addressing management of PPH (Kayem 2011a)

Table D-37 Evidence table for studies addressing management of PPH (Kayem 2011b)

Table D-38 Evidence table for studies addressing management of PPH (Palacios-Jaraquemada 2011)

Table D-39 Evidence table for studies addressing management of PPH (Schmitz 2011)

Table D-40 Evidence table for studies addressing management of PPH (Shields 2011)

Table D-41 Evidence table for studies addressing management of PPH (Sentilhes 2011a)

Table D-42 Evidence table for studies addressing management of PPH (Sentilhes 2011b)

Table D-43 Evidence table for studies addressing management of PPH (Sentilhes 2011c)

Table D-44 Evidence table for studies addressing management of PPH (Deneux-Tharaux 2010)

Table D-45 Evidence table for studies addressing management of PPH (Ganguli 2008)

Table D-46 Evidence table for studies addressing management of PPH (Lone 2010)

Table D-47 Evidence table for studies addressing management of PPH (Wright 2010)

Table D-48 Evidence table for studies addressing management of PPH (Zwart 2010)

Table D-49 Evidence table for studies addressing management of PPH (Hardeman 2010)

Table D-50 Evidence table for studies addressing management of PPH (Alexander 2009)

Table D-51 Evidence table for studies addressing management of PPH (Audureau 2009)

Table D-52 Evidence table for studies addressing management of PPH (Feigenberg 2009)

Table D-53 Evidence table for studies addressing management of PPH (Fiori 2009)

Table D-54 Evidence table for studies addressing management of PPH (Gaia 2009)

Table D-55 Evidence table for studies addressing management of PPH (Phillips 2009)

Table D-56 Evidence table for studies addressing management of PPH (Balki 2008)

Table D-57 Evidence table for studies addressing management of PPH (Knight 2007)

Table D-58 Evidence table for studies addressing management of PPH (Baruah 2008)

Table D-59 Evidence table for studies addressing management of PPH (Chauleur 2008a)

Table D-60 Evidence table for studies addressing management of PPH (Chauleur 2008b)

Table D-61 Evidence table for studies addressing management of PPH (Glaze 2008)

Table D-62 Evidence table for studies addressing management of PPH (McMorrow 2008)

Table D-63 Evidence table for studies addressing management of PPH (Touboul 2008)

Table D-64 Evidence table for studies addressing management of PPH (Sakse 2007)

Table D-65 Evidence table for studies addressing management of PPH (Ahonen 2007)

Table D-66 Evidence table for studies addressing management of PPH (Alfirevic 2007)

Table D-67 Evidence table for studies addressing management of PPH (Skupski 2006)

Table D-68 Evidence table for studies addressing management of PPH (Akinbiyi 2004)

Table D-69 Evidence table for studies addressing management of PPH (Forna 2004)

Table D-70 Evidence table for studies addressing management of PPH (Rizvi 2004)

Table D-71 Evidence table for studies addressing management of PPH (Hoveyda 2001)

Table D-72 Evidence table for studies addressing management of PPH (Ledee 2001)

Table D-73 Evidence table for studies addressing management of PPH (Boyd 1995)

Table D-74 Evidence table for studies addressing management of PPH (O'Leary 1995)

Table D-75 Evidence table for studies addressing management of PPH (Oleen 1990)

## Evidence Table References

1 Cheong JY, Kong TW, Son JH, et al. Outcome of pelvic arterial embolization for postpartum hemorrhage: A retrospective review of 117 cases. Obstet Gynecol Sci. Jan. 2014;57(1):17-27. [pmid: 24596814].
2 Cowan AD, Miller ES, Grobman WA. Subsequent pregnancy outcome after B-lynch suture placement. Obstet Gynecol. Sep. 2014;124(3):558-61. [pmid: 25162256].
3 Dupont C, Occelli P, Deneux-Tharaux C, et al. Severe postpartum haemorrhage after vaginal delivery: a statistical process control chart to report seven years of continuous quality improvement. Eur J Obstet Gynecol Reprod Biol. Jul. 2014;178:169-75. [pmid: 24813084].
4 Dupont C, Deneux-Tharaux C, Touzet S, et al. Clinical audit: a useful tool for reducing severe postpartum haemorrhages?. Int J Qual Health Care. Oct. 2011;23:583-9. [pmid: 21733978].
5 Einerson BD, Miller ES, Grobman WA. Does a postpartum hemorrhage patient safety program result in sustained changes in management and outcomes?. Am J Obstet Gynecol. 2014. Jul. 11. [pmid: 25019484].
6 Ferrazzani S, Iadarola R, Perrelli A, et al. Use of an intrauterine inflated catheter balloon in massive post-partum hemorrhage: a series of 52 cases. J Obstet Gynaecol Res. Jun. 2014;40:1603-10. [pmid: 24888923].
7 Inoue S, Masuyama H, Hiramatsu Y. Efficacy of transarterial embolisation in the management of post-partum haemorrhage and its impact on subsequent pregnancies. Aust N Z J Obstet Gynaecol. 2014. Oct. 28. [pmid: 25350565].
8 Mallaiah S, Barclay P, Harrod I, et al. Introduction of an algorithm for ROTEM-guided fibrinogen concentrate administration in major obstetric haemorrhage. Anaesthesia. 2014. Oct. 7. [pmid: 25289791].
9 Park HS, Shin JH, Yoon HK, et al. Transcatheter Arterial Embolization for Secondary Postpartum Hemorrhage: Outcome in 52 Patients at a Single Tertiary Referral Center. J Vasc Interv Radiol. 2014. Jun. 27. [pmid: 24985718].
10 Prick B, Jansen A, Steegers E, et al. Transfusion policy after severe postpartum haemorrhage: a randomised non-inferiority trial. BJOG. 2014. Jan. 10. [pmid: 24405687].
11 Prick BW, Duvekot JJ, van der Moer PE, et al. Cost-effectiveness of red blood cell transfusion vs. non-intervention in women with acute anaemia after postpartum haemorrhage. Vox Sang. 2014. Jul. 31. [pmid: 25130704].
12 Shields LE, Wiesner S, Fulton J, et al. Comprehensive maternal hemorrhage protocols reduce the use of blood products and improve patient safety. Am J Obstet Gynecol. 2014. Jul. 12. [pmid: 25025944].
13 Shields LE, Smalarz K, Reffigee L, et al. Comprehensive maternal hemorrhage protocols improve patient safety and reduce utilization of blood products. Am J Obstet Gynecol. Oct. 2011;205:368 e1-8. [pmid: 22083059].
14 Teofili L, Bianchi M, Zanfini BA, et al. Acute Lung Injury Complicating Blood Transfusion in Post-Partum Hemorrhage: Incidence and Risk Factors. Mediterr J Hematol Infect Dis. 2014;6(1):e2014069. [pmid: 25408855].
15 Zatta A, McQuilten Z, Kandane-Rathnayake R, et al. The Australian and New Zealand Haemostasis Registry: ten years of data on off-licence use of recombinant activated factor VII. Blood Transfus. Jun. 2014;5:1-14. [pmid: 24960661].
16 An GH, Ryu HM, Kim MY, et al. Outcomes of subsequent pregnancies after uterine compression sutures for postpartum hemorrhage. Obstet Gynecol. Sep. 2013;122:565-70. [pmid: 23921861].
17 Bateman BT, Huybrechts KF, Hernandez-Diaz S, et al. Methylergonovine maleate and the risk of myocardial ischemia and infarction. Am J Obstet Gynecol. Nov. 2013;209:459.e1-.e13. [pmid: 23850529].
18 Bonnet MP, Deneux-Tharaux C, Dupont C, et al. Transfusion practices in postpartum hemorrhage: a population-based study. Acta Obstet Gynecol Scand. Apr. 2012;92:404-13. [pmid: 23215892].
19 Deneux-Tharaux C, Dupont C, Colin C, et al. Multifaceted intervention to decrease the rate of severe postpartum haemorrhage: the PITHAGORE6 cluster-randomised controlled trial. BJOG. Sep. 2010;117:1278-87. [pmid: 20573150].
20 Schmitz T, Tararbit K, Dupont C, et al. Prostaglandin E2 analogue sulprostone for treatment of atonic postpartum hemorrhage. Obstet Gynecol. Aug. 2011;118:257-65. [pmid: 21775840].
21 Chan LL, Lo TK, Lau WL, et al. Use of second-line therapies for management of massive primary postpartum hemorrhage. Int J Gynaecol Obstet. Sep. 2013;122:238-43. [pmid: 23806248].
22 Dildy GA, Belfort MA, Adair CD, et al. Initial experience with a dual-balloon catheter for the management of postpartum hemorrhage. Am J Obstet Gynecol. 2013. Sep. 18. [pmid: 24055586].
23 Froessler B, Cocchiaro C, Saadat-Gilani K, et al. Intravenous iron sucrose versus oral iron ferrous sulfate for antenatal and postpartum iron deficiency anemia: a randomized trial. J Matern Fetal Neonatal Med. May. 2012;26:654-9. [pmid: 23130909].
24 Lee HJ, Jeon GS, Kim MD, et al. Usefulness of pelvic artery embolization in cesarean section compared with vaginal delivery in 176 patients. J Vasc Interv Radiol. Jan. 2013;24:103-9. [pmid: 23273701].
25 Kim TH, Lee HH, Kim JM, et al. Uterine artery embolization for primary postpartum hemorrhage. Iran J Reprod Med. Jun. 2014;11:511-8. [pmid: 24639786].
26 Kim YJ, Yoon CJ, Seong NJ, et al. Failed pelvic arterial embolization for postpartum hemorrhage: clinical outcomes and predictive factors. J Vasc Interv Radiol. May. 2013;24:703-9. [pmid: 23622042].
27 Lappen JR, Seidman D, Burke C, et al. Changes in care associated with the introduction of a postpartum hemorrhage patient safety program. Am J Perinatol. Nov. 2013;30:833-8. [pmid: 23359234].
28 Sohn CH, Kim WY, Kim SR, et al. An increase in initial shock index is associated with the requirement for massive transfusion in emergency department patients with primary postpartum hemorrhage. Shock. Aug. 2013;40:101-5. [pmid: 23707978].
29 Sugawara J, Suenaga K, Hoshiai T, et al. Efficacy of recombinant human soluble thrombomodulin in severe postpartum hemorrhage with disseminated intravascular coagulation. Clin Appl Thromb Hemost. Sep. 2012;19:557-61. [pmid: 22496090].
30 Yamasaki Y, Morita H, Miyahara Y, et al. The factors associated with the failure of transcatheter pelvic arterial embolization for intractable postpartum hemorrhage. J Perinat Med. Dec. 2013;5:1-4. [pmid: 24310770].
31 Blanc J, Courbiere B, Desbriere R, et al. Uterine-sparing surgical management of postpartum hemorrhage: is it always effective?. Arch Gynecol Obstet. Apr. 2011;285:925-30. [pmid: 21932086].
32 Laas E, Bui C, Popowski T, et al. Trends in the rate of invasive procedures after the addition of the intrauterine tamponade test to a protocol for management of severe postpartum hemorrhage. Am J Obstet Gynecol. Oct. 2012;207:281 e1-7. [pmid: 23021688].
33 Lee HY, Shin JH, Kim J, et al. Primary postpartum hemorrhage: outcome of pelvic arterial embolization in 251 patients at a single institution. Radiology. Sep. 2012;264:903-9. [pmid: 22829685].
34 Ahmed S, Harrity C, Johnson S, et al. The efficacy of fibrinogen concentrate compared with cryoprecipitate in major obstetric haemorrhage--an observational study. Transfus Med. Oct. 2012;22:344-9. [pmid: 22994449].
35 Gronvall M, Tikkanen M, Tallberg E, et al. Use of Bakri balloon tamponade in the treatment of postpartum hemorrhage: a series of 50 cases from a tertiary teaching hospital. Acta Obstet Gynecol Scand. Apr. 2012;92:433-8. [pmid: 22913383].
36 Markova V, Sorensen JL, Holm C, et al. Evaluation of multi-professional obstetric skills training for postpartum hemorrhage. Acta Obstet Gynecol Scand. Mar. 2011;91:346-52. [pmid: 22171606].
37 Poujade O, Zappa M, Letendre I, et al. Predictive factors for failure of pelvic arterial embolization for postpartum hemorrhage. Int J Gynaecol Obstet. May. 2012;117:119-23. [pmid: 22361480].
38 Ducloy-Bouthors AS, Jude B, Duhamel A, et al. High-dose tranexamic acid reduces blood loss in postpartum haemorrhage. Crit Care. 2011;15:R117. [pmid: 21496253].
39 Gayat E, Resche-Rigon M, Morel O, et al. Predictive factors of advanced interventional procedures in a multicentre severe postpartum haemorrhage study. Intensive Care Med. Nov. 2011;37:1816-25. [pmid: 21805157].
40 Kayem G, Kurinczuk JJ, Alfirevic Z, et al. Specific second-line therapies for postpartum haemorrhage: a national cohort study. BJOG. Jun. 2011;118:856-64. [pmid: 21392247].
41 Kayem G, Kurinczuk JJ, Alfirevic Z, et al. Uterine compression sutures for the management of severe postpartum hemorrhage. Obstet Gynecol. Jan. 2011;117:14-20. [pmid: 21213474].
42 Palacios-Jaraquemada JM. Efficacy of surgical techniques to control obstetric hemorrhage: analysis of 539 cases. Acta Obstet Gynecol Scand. Sep. 2011;90:1036-42. [pmid: 21564024].
43 Sentilhes L, Gromez A, Clavier E, et al. Long-term psychological impact of severe postpartum hemorrhage. Acta Obstet Gynecol Scand. Jun. 2011;90:615-20. [pmid: 21370999].
44 Sentilhes L, Gromez A, Clavier E, et al. Predictors of failed pelvic arterial embolization for severe postpartum hemorrhage. Obstet Gynecol. May. 2009;113:992-9. [pmid: 19384113].
45 Sentilhes L, Gromez A, Clavier E, et al. Fertility and pregnancy following pelvic arterial embolisation for postpartum haemorrhage. BJOG. Jan. 2009;117:84-93. [pmid: 19832826].
46 Ganguli S, Stecker MS, Pyne D, et al. Uterine artery embolization in the treatment of postpartum uterine hemorrhage. J Vasc Interv Radiol. Feb. 2010;22:169-76. [pmid: 21183360].
47 Lone F, Sultan AH, Thakar R, et al. Risk factors and management patterns for emergency obstetric hysterectomy over 2 decades. Int J Gynaecol Obstet. Apr. 2009;109:12-5. [pmid: 19951818].
48 Wright JD, Herzog TJ, Shah M, et al. Regionalization of care for obstetric hemorrhage and its effect on maternal mortality. Obstet Gynecol. Jun. 2010;115:1194-200. [pmid: 20502290].
49 Zwart JJ, Dijk PD, van Roosmalen J. Peripartum hysterectomy and arterial embolization for major obstetric hemorrhage: a 2-year nationwide cohort study in the Netherlands. Am J Obstet Gynecol. Feb. 2009;202:150 e1-7. [pmid: 19922900].
50 Hardeman S, Decroisette E, Marin B, et al. Fertility after embolization of the uterine arteries to treat obstetrical hemorrhage: a review of 53 cases. Fertil Steril. Dec. 2010;94:2574-9. [pmid: 20381035].
51 Alexander JM, Sarode R, McIntire DD, et al. Whole blood in the management of hypovolemia due to obstetric hemorrhage. Obstet Gynecol. Jun. 2009;113:1320-6. [pmid: 19461429].
52 Audureau E, Deneux-Tharaux C, Lefevre P, et al. Practices for prevention, diagnosis and management of postpartum haemorrhage: impact of a regional multifaceted intervention. BJOG. Sep. 2009;116:1325-33. [pmid: 19538416].
53 Feigenberg T, Eitan Y, Sela HY, et al. Surgical versus medical treatment for secondary post-partum hemorrhage. Acta Obstet Gynecol Scand. 2009;88:909-13. [pmid: 19565365].
54 Fiori O, Deux JF, Kambale JC, et al. Impact of pelvic arterial embolization for intractable postpartum hemorrhage on fertility. Am J Obstet Gynecol. Apr. 2009;200:384 e1-4. [pmid: 19217597].
55 Gaia G, Chabrot P, Cassagnes L, et al. Menses recovery and fertility after artery embolization for PPH: a single-center retrospective observational study. Eur Radiol. Feb. 2008;19:481-7. [pmid: 18766350].
56 Phillips LE, McLintock C, Pollock W, et al. Recombinant activated factor VII in obstetric hemorrhage: experiences from the Australian and New Zealand Haemostasis Registry. Anesth Analg. Dec. 2009;109:1908-15. [pmid: 19923520].
57 Balki M, Dhumne S, Kasodekar S, et al. Blood transfusion for primary postpartum hemorrhage: a tertiary care hospital review. J Obstet Gynaecol Can. Nov. 2009;30:1002-7. [pmid: 19126281].
58 Knight M. Peripartum hysterectomy in the UK: management and outcomes of the associated haemorrhage. BJOG. Nov. 2007;114:1380-7. [pmid: 17877772].
59 Baruah M, Cohn GM. Efficacy of rectal misoprostol as second-line therapy for the treatment of primary postpartum hemorrhage. J Reprod Med. Mar. 2008;53:203-6. [pmid: 18441726].
60 Chauleur C, Cochery-Nouvellon E, Mercier E, et al. Analysis of the venous thromboembolic risk associated with severe postpartum haemorrhage in the NOHA First cohort. Thromb Haemost. Nov. 2008;100:773-9. [pmid: 18989520].
61 Chauleur C, Fanget C, Tourne G, et al. Serious primary post-partum hemorrhage, arterial embolization and future fertility: a retrospective study of 46 cases. Hum Reprod. Jul. 2008;23:1553-9. [pmid: 18460450].
62 Glaze S, Ekwalanga P, Roberts G, et al. Peripartum hysterectomy: 1999 to 2006. Obstet Gynecol. Mar. 2008;111:732-8. [pmid: 18310378].
63 McMorrow RC, Ryan SM, Blunnie WP, et al. Use of recombinant factor VIIa in massive post-partum haemorrhage. Eur J Anaesthesiol. Apr. 2008;25:293-8. [pmid: 18177539].
64 Touboul C, Badiou W, Saada J, et al. Efficacy of selective arterial embolisation for the treatment of life-threatening post-partum haemorrhage in a large population. PLoS One. 2008;3:e3819. [pmid: 19043573].
65 Sakse A, Weber T, Nickelsen C, et al. Peripartum hysterectomy in Denmark 1995-2004. Acta Obstet Gynecol Scand. 2007;86:1472-5. [pmid: 18027114].
66 Ahonen J, Jokela R, Korttila K. An open non-randomized study of recombinant activated factor VII in major postpartum haemorrhage. Acta Anaesthesiol Scand. Aug. 2007;51:929-36. [pmid: 17488316].
67 Alfirevic Z, Elbourne D, Pavord S, et al. Use of recombinant activated factor VII in primary postpartum hemorrhage: the Northern European registry 2000-2004. Obstet Gynecol. Dec. 2007;110:1270-8. [pmid: 18055720].
68 Skupski DW, Lowenwirt IP, Weinbaum FI, et al. Improving hospital systems for the care of women with major obstetric hemorrhage. Obstet Gynecol. May. 2006;107:977-83. [pmid: 16648399].
69 Akinbiyi AA, Olatunbosun OA. Emergency obstetric hysterectomies (how many are potentially preventable?): A 28-year experience in Saskatoon. Journal of Gynecologic Surgery. Fall. 2004;20:81-7.
70 Forna F, Miles AM, Jamieson DJ. Emergency peripartum hysterectomy: a comparison of cesarean and postpartum hysterectomy. Am J Obstet Gynecol. May. 2004;190:1440-4. [pmid: 15167863].
71 Rizvi F, Mackey R, Barrett T, et al. Successful reduction of massive postpartum haemorrhage by use of guidelines and staff education. BJOG. May. 2004;111:495-8. [pmid: 15104617].
72 Hoveyda F, MacKenzie IZ. Secondary postpartum haemorrhage: incidence, morbidity and current management. BJOG. Sep. 2001;108:927-30. [pmid: 11563461].
73 Ledee N, Ville Y, Musset D, et al. Management in intractable obstetric haemorrhage: an audit study on 61 cases. Eur J Obstet Gynecol Reprod Biol. Feb. 2001;94:189-96. [pmid: 11165724].
74 Boyd BK, Katz VL, Hansen WF. Delayed postpartum hemorrhage: a retrospective analysis. Journal of Maternal-Fetal Medicine. 1995. Jan-Feb. 1995;4:19-23.
75 O'Leary JA. Uterine artery ligation in the control of postcesarean hemorrhage. J Reprod Med. Mar. 1995;40:189-93. [pmid: 7776302].
76 Oleen MA, Mariano JP. Controlling refractory atonic postpartum hemorrhage with Hemabate sterile solution. Am J Obstet Gynecol. Jan. 1990;162:205-8. [pmid: 2405676].

## Evidence Table Abbreviations

μg: Micrograms
μg/kg: Micrograms per Kilogram
μg/L: Micrograms per Liter
ACS: Acute Coronary Syndrome
AIP: Advanced Interventional Procedure
AMI: Acute Myocardial Infarction
ARDS: Acute Respiratory Distress Syndrome
AUC: Area Under Curve
BMI: Body Mass Index
BP: Blood Pressure
CH: Complete Hysterectomy
CI: Confidence Interval
DBP: Diastolic Blood Pressure
DIC: Disseminated Intravascular Coagulation
DVT: Deep Vein Thrombosis
DX: Diagnosis
EBL: Estimated Blood Loss
FFP: Fresh Frozen Plasma
FGF: Fibroblast Growth Factor
g/dl: Grams per Deciliter
GAB: Gabexate mesilate
Hb: Hemoglobin
HDU: High-Dependency Unit
HELLP: Hemolysis, Elevated Liver enzymes, Low Platelet count
HR: Heart Rate
ICU: Intensive Care Unit
IQR: Interquartile Range
IU: International Units
kg/m^2^: Kilograms per Square Liter
L: Liters
mg: Milligrams
mL: Milliliters
mmHg: Millimeters of Mercury
mmol/L: Millimoles per Liter
mo: Months
NA: Not Applicable
NR: Not Reported
PAE: Pelvic arterial embolization
PC: Post cibum (after a meal)
PPH: Post-Partum Hemorrhage
pRBC: Packed Red Blood Cells
RBC: Red Blood Cells
RCC: Red Cell Concentrate
rTM: Recombinant human soluable Thrombomodulin
SAE: Selective Arterial Embolization
SBP: Systolic Blood Pressure
SD: Standard Deviation
SE: Standard Error
SES: Socioeconomic Status
SI: Shock Index
TAE: Transcatheter pelvic Arterial Embolization
UKOSS: UK Obstetric Surveillance System
VTE: Venous Thromboembolism