# Excluded Studies

Reasons for Exclusion

X-1 | Not original research
X-2 | Ineligible country
X-3 | Ineligible population
X-4 | Does not address outcomes or population of interest
X-5 | Ineligible study design
X-6 | Article not obtainable

1 Aggregate analysis of oxytocin incidents. X-1.
2 Abdel-Aleem H, Aboelnasr MF, Jayousi TM, et al. Indwelling bladder catheterisation as part of intraoperative and postoperative care for caesarean section. X-3, X-4.
3 Abdel-Aleem H, Alhusaini TK, Abdel-Aleem MA, et al. Effectiveness of tranexamic acid on blood loss in patients undergoing elective cesarean section: randomized clinical trial. X-2, X-4.
4 Abdul Sultan A, Grainge MJ, West J, et al. Impact of risk factors on the timing of first postpartum venous thromboembolism: a population-based cohort study from England. X-4.
5 Abdul Sultan A, Tata LJ, Fleming KM, et al. Pregnancy Complications and Adverse Birth Outcomes Among Women With Celiac Disease: A Population-Based Study From England. X-3, X-4.
6 Abramovici A, Szychowski JM, Biggio JR, et al. Epidural Use and Clinical Chorioamnionitis among Women Who Delivered Vaginally. X-4.
7 Adeniran AS, Fawole AA, Fakeye OO, et al. Grandmultiparity: evaluating obstetric and neonatal outcomes after eliminating confounders. X-4.
8 Aditya V. LMN Facial Palsy in Pregnancy: An Opportunity to Predict Preeclampsia-Report and Review. X-3, X-4.
9 Aggarwal RS, Mishra VV, Jasani AF, et al. Acute renal failure in pregnancy: our experience. X-2, X-4.
10 Ahmadzia HK, Thomas SM, Heine RP, et al. Survey of peripartum hysterectomy experiences: anticipated, unplanned, or averted. X-4, X-5.
11 Alfirevic Z, Aflaifel N, Weeks A. Oral misoprostol for induction of labour. X-1, X-4.
12 Allam IS, Gomaa IA, Fathi HM, et al. Incidence of emergency peripartum hysterectomy in Ain-shams University Maternity Hospital, Egypt: aretrospective study. X-2, X-4.
13 Almansa C, Camano I, Villar O, et al. Puerperal curettage after cesarean section delivery. X-4, X-5.
14 Almeida LM, Santos CC, Caldas JP, et al. Obstetric care in a migrant population with free access to health care. X-4.
15 Amsalem H, Aldrich CJ, Oskamp M, et al. Postpartum uterine response to oxytocin and carbetocin. X-4, X-5.
16 Arrowsmith S, Wray S. Oxytocin: its mechanism of action and receptor signalling in the myometrium. X-1, X-4.
17 Fareh OI, Rizk DE, Thomas L, et al. PMM.21 Antenatal Haemoglobin Levels and Blood Transfusion. X-3, X-4.
18 Zimmermann R, Breymann C, Richter C, et al. PMM.74 Are We Forgetting The Folates?. X-1.
19 Recent ACOG bulletin covers management of postpartum hemorrhage. Am Fam Physician. Oct. 1990;42:1117-9. X-1, X-2, X-4, X-5. [pmid: 2220516].
20 Alabi EM. Cultural practices in Nigeria. Newsl Inter Afr Comm Tradit Pract Affect Health Women Child. May. 1990:6-7. X-2. [pmid: 12157983].
21 Andres RL, Piacquadio KM, Resnik R. A reappraisal of the need for autologous blood donation in the obstetric patient. Am J Obstet Gynecol. Nov. 1990;163:1551-3. X-4. [pmid: 2240105].
22 Begley CM. The effect of ergometrine on breast feeding. Midwifery. Jun. 1990;6:60-72. X-3. [pmid: 2195299].
23 Begley CM. A comparison of ‘active’ and ‘physiological’ management of the third stage of labour. Midwifery. Mar. 1990;6:3-17. X-4. [pmid: 2182978].
24 Chattopadhyay SK, Deb Roy B, Edrees YB. Surgical control of obstetric hemorrhage: hypogastric artery ligation or hysterectomy?. Int J Gynaecol Obstet. Aug. 1990;32:345-51. X-2, X-4, X-5. [pmid: 1977629].
25 Evaldson GR. The grand multipara in modern obstetrics. Gynecol Obstet Invest. 1990;30:217-23. X-2, X-4. [pmid: 2289702].
26 Healey JM. The Jehovah's Witness parent's right to refuse treatment. Conn Med. Jun. 1990;54:357. X-1, X-5. [pmid: 2373012].
27 Hood DD, Holubec DM. Elective repeat cesarean section. Effect of anesthesia type on blood loss. J Reprod Med. Apr. 1990;35:368-72. X-4, X-5. [pmid: 2352227].
28 Imberti R, Preseglio I, Trotta V, et al. Blood transfusion during cesarean section. A 12 years' retrospective analysis. Acta Anaesthesiol Belg. 1990;41:139-44. X-1, X-4. [pmid: 2371803].
29 Lao TT, Huengsburg M. Labour and delivery in mothers with asthma. Eur J Obstet Gynecol Reprod Biol. May-Jun. 1990;35:183-90. X-4. [pmid: 2335253].
30 Levy DB, Peppers MP, Miller K. A last resort for postpartum hemorrhage. Emergency. 1990;22:16-7. X-1.
31 P OP, Suthutvoravut S, Chaturachinda K. Hydrops fetalis due to Bart hemoglobinopathy at Ramathibodi Hospital (1978-1987): a 10-year review. J Med Assoc Thai. Feb. Suppl 1. 1990;73:65-8. X-1, X-3, X-4. [pmid: 2351917].
32 Peyser MR, Kupferminc MJ. Management of severe postpartum hemorrhage by intrauterine irrigation with prostaglandin E2. Am J Obstet Gynecol. Mar. 1990;162:694-6. X-2, X-4, X-5. [pmid: 2316571].
33 Sofat R. Post-partum Copper-T insertion -- a trial. Indian J Matern Child Health. Jan-Mar. 1990;1:23-4. X-1, X-4. [pmid: 12319239].
34 Sonneveld SW, Correy JF. Outcome of pregnancies complicated by epilepsy in Tasmania 1981-1988. Aust N Z J Obstet Gynaecol. Nov. 1990;30:286-9. X-2, X-3, X-4. [pmid: 2082881].
35 St George L, Crandon AJ. Immediate postpartum complications. Aust N Z J Obstet Gynaecol. Feb. 1990;30:52-6. X-4. [pmid: 2346452].
36 Sweeney G, Holbrook AM, Levine M, et al. Pharmacokinetics of carbetocin, a long-acting oxytocin analogue, in nonpregnant women. Current Therapeutic Research - Clinical and Experimental. 1990;47:528-40. X-1, X-3, X-4.
37 Thomas IL, Jeffers TM, Brazier JM, et al. Does cord drainage of placental blood facilitate delivery of the placenta?. Aust N Z J Obstet Gynaecol. Nov. 1990;30:314-8. X-4. [pmid: 2082886].
38 Thorp JM Jr., Fowler WC, Donehoo R, et al. Antepartum and intrapartum events in women exposed in utero to diethylstilbestrol. Obstet Gynecol. Nov. 1990;76:828-32. X-4. [pmid: 2216234].
39 Woodcock HC, Read AW, Moore DJ, et al. Planned homebirths in Western Australia 1981-1987: a descriptive study. Med J Aust. Dec. 3-17. 1990;153:672-8. X-4. [pmid: 2246990].
40 Recently introduced products. Drug Ther Bull. Mar. 4. 1991;29:17-9. X-1, X-4. [pmid: 1935601].
41 When is manual placental extraction necessary?. Emergency Medicine (00136654). 1991;23:90-1. X-1, X-4, X-5.
42 Abdel-razik MS. Postpartum haemorrhage as a public health problem. J Egypt Soc Obstet Gynecol. Jan. 1991;17:51-61. X-1, X-4. [pmid: 12317331].
43 Bigrigg A, Chissell S, Read MD. Use of intra myometrial 15-methyl prostaglandin F2 alpha to control atonic postpartum haemorrhage following vaginal delivery and failure of conventional therapy. Br J Obstet Gynaecol. Jul. 1991;98:734-6. X-1, X-2, X-4, X-5. [pmid: 1883806].
44 Choudhury PA. The perils of motherhood. MARHIA. Apr-Jun. 1991;4(1):6-8. X-1, X-4. [pmid: 12285838].
45 Combs CA, Laros RK Jr. Prolonged third stage of labor: morbidity and risk factors. Obstet Gynecol. Jun. 1991;77:863-7. X-4, X-5. [pmid: 2030858].
46 Combs CA, Murphy EL, Laros RK Jr. Factors associated with hemorrhage in cesarean deliveries. Obstet Gynecol. Jan. 1991;77:77-82. X-4. [pmid: 1984231].
47 Combs CA, Murphy EL, Laros RK Jr. Factors associated with postpartum hemorrhage with vaginal birth. Obstet Gynecol. Jan. 1991;77:69-76. X-4. [pmid: 1984230].
48 Coyaji BJ. Maternal mortality and morbidity in the developing countries like India. Indian J Matern Child Health. 1991;2:3-9. X-2, X-4. [pmid: 12288706].
49 Crosby ET. Obstetrical anaesthesia for patients with the syndrome of haemolysis, elevated liver enzymes and low platelets. Can J Anaesth. Mar. 1991;38:227-33. X-1, X-4. [pmid: 2021995].
50 Donner C, McGinnis JA, Simon P, et al. Multifetal pregnancy reduction: a Belgian experience. Eur J Obstet Gynecol Reprod Biol. Feb. 25. 1991;38:183-7. X-1, X-4. [pmid: 2007443].
51 Duthie SJ, Ven D, Yung GL, et al. Discrepancy between laboratory determination and visual estimation of blood loss during normal delivery. Eur J Obstet Gynecol Reprod Biol. Jan. 30. 1991;38:119-24. X-3, X-4. [pmid: 1995380].
52 Endeshaw Y. Malaria in pregnancy: clinical features and outcome of treatment. Ethiop Med J. Jul. 1991;29:103-8. X-2, X-3. [pmid: 1915317].
53 Fauveau V, Stewart K, Khan SA, et al. Effect on mortality of community-based maternity-care programme in rural Bangladesh. Lancet. Nov. 9. 1991;338:1183-6. X-4. [pmid: 1682600].
54 Gachiri JR, Rogo KO. Foetal and maternal outcome of vacuum extraction. East Afr Med J. Jul. 1991;68:539-46. X-2, X-4. [pmid: 1756706].
55 Goldman M, Blajchman MA, Ali MA. Overestimation of fetomaternal haemorrhage by the acid-elution technique in mothers with beta-thalassaemia minor. Transfus Med. Jun. 1991;1:129-32. X-3, X-4. [pmid: 9259839].
56 Greer IA, Lowe GD, Walker JJ, et al. Haemorrhagic problems in obstetrics and gynaecology in patients with congenital coagulopathies. Br J Obstet Gynaecol. Sep. 1991;98:909-18. X-4, X-5. [pmid: 1911610].
57 Long P. Bleeding and the third stage of labor. NAACOGS Clin Issu Perinat Womens Health Nurs. 1991;2:385-95. X-1. [pmid: 1931386].
58 Ozumba BC, Mbagwu SC. Emergency obstetric hysterectomy in eastern Nigeria. Int Surg. Apr-Jun. 1991;76:109-11. X-2. [pmid: 1869383].
59 Ozumba BC, Uchegbu H. Incidence and management of obstructed labour in eastern Nigeria. Aust N Z J Obstet Gynaecol. Aug. 1991;31:213-6. X-2, X-4. [pmid: 1804080].
60 Penney DS. Autologous blood use in obstetrics. NAACOGS Clin Issu Perinat Womens Health Nurs. 1991;2:344-8. X-1. [pmid: 1931380].
61 Penney DS. Hemorrhage and culture: management in the developing world and cultural implications for nursing care. NAACOGS Clin Issu Perinat Womens Health Nurs. 1991;2:339-43. X-1. [pmid: 1931379].
62 Perlis DW. Bleeding in women. NAACOG's Clinical Issues in Perinatal & Women's Health Nursing. 1991;2:xi-420. X-1, X-4.
63 Poeschmann RP, Doesburg WH, Eskes TK. A randomized comparison of oxytocin, sulprostone and placebo in the management of the third stage of labour. Br J Obstet Gynaecol. Jun. 1991;98:528-30. X-4. [pmid: 1873241].
64 Porter KB, O'Brien WF, Collins MK, et al. A randomized comparison of umbilical vein and intravenous oxytocin during the puerperium. Obstet Gynecol. Aug. 1991;78:254-6. X-4, X-5. [pmid: 2067772].
65 Roopnarinesingh S, Ramoutar P, Bassaw B. Maternal mortality at Mount Hope Women's Hospital, Trinidad. West Indian Med J. Sep. 1991;40:139-41. X-2, X-4. [pmid: 1957523].
66 Sapire KE. A study of bleeding patterns with two injectable contraceptives given postpartum and the effect of two non-hormonal treatments. Adv Contracept. Dec. 1991;7:379-87. X-3, X-4. [pmid: 1837974].
67 Schuitemaker NW, Gravenhorst JB, Van Geijn HP, et al. Maternal mortality and its prevention. Eur J Obstet Gynecol Reprod Biol. Dec. Suppl. 1991;42:S31-5. X-1. [pmid: 1809606].
68 Smith LF. GP trainees' views on hospital obstetric vocational training. BMJ. Dec. 7. 1991;303:1447-50. X-3, X-4. [pmid: 1773153].
69 Smith VG, Leman AD, Seaman WJ, et al. Pig weaning weight and changes in hematology and blood chemistry of sows injected with recombinant porcine somatotropin during lactation. J Anim Sci. Sep. 1991;69:3501-10. X-1, X-3, X-4. [pmid: 1938637].
70 Toppozada M. The use of prostaglandins in post-partum haemorrhage. J Egypt Soc Obstet Gynecol. Jan. 1991;17:9-18. X-6. [pmid: 12317332].
71 Waldenstrom U, Gottvall K. A randomized trial of birthing stool or conventional semirecumbent position for second-stage labor. Birth. Mar. 1991;18:5-10. X-4. [pmid: 2006963].
72 Wells SR, Thorp JM Jr., Bowes WA Jr. Management of the nonvertex second twin. Surg Gynecol Obstet. May. 1991;172:383-5. X-4. [pmid: 2028373].
73 Yamashita Y, Takahashi M, Ito M, et al. Transcatheter arterial embolization in the management of postpartum hemorrhage due to genital tract injury. Obstet Gynecol. Jan. 1991;77:160-3. X-5. [pmid: 1984217].
74 Zulkifli SN, Paine LL, Greener DL, et al. Trends in selected obstetric complications from University Hospital, Kuala Lumpur, Malaysia. Int J Gynaecol Obstet. May. 1991;35:29-36. X-2, X-4. [pmid: 1680072].
75 What is needed to ensure the health and survival of mother and baby?. Safe Mother. Jul-Oct. 1992:4-5. X-1, X-4. [pmid: 12345881].
76 Bangladesh: village midwives save lives. Safe Mother. Mar-Jul. 1992:8. X-2. [pmid: 12285232].
77 Family planning needed for all women. Fam Plann Today. May. 1992;3:1. X-1. [pmid: 12343826].
78 Adetoro OO. Primary post-partum haemorrhage at a university hospital in Nigeria. West Afr J Med. Jul-Sep. 1992;11:172-8. X-2, X-4. [pmid: 1476960].
79 Alvarez M, Lockwood CJ, Ghidini A, et al. Prophylactic and emergent arterial catheterization for selective embolization in obstetric hemorrhage. Am J Perinatol. Sep-Nov. 1992;9:441-4. X-4, X-5. [pmid: 1418152].
80 Bakri YN, Linjawi T. Angiographic embolization for control of pelvic genital tract hemorrhage. Report of 14 cases. Acta Obstet Gynecol Scand. Jan. 1992;71:17-21. X-2, X-5. [pmid: 1315091].
81 Buckshee K, Kriplani A, Kapil A, et al. Hypothyroidism complicating pregnancy. Aust N Z J Obstet Gynaecol. Aug. 1992;32:240-2. X-2, X-4. [pmid: 1445136].
82 Combs CA, Murphy EL, Laros RK Jr. Cost-benefit analysis of autologous blood donation in obstetrics. Obstet Gynecol. Oct. 1992;80:621-5. X-4. [pmid: 1407883].
83 Copplestone JA. Asymptomatic thrombocytopenia developing during pregnancy (gestational thrombocytopenia)--a clinical study. Q J Med. Aug. 1992;84:593-601. X-3, X-4. [pmid: 1484938].
84 Doan-Wiggins L. Oxytocin use in prehospital care. Emergency Medical Services. 1992;21:26-31. X-1, X-4, X-5.
85 Gilbert WM, Moore TR, Resnik R, et al. Angiographic embolization in the management of hemorrhagic complications of pregnancy. Am J Obstet Gynecol. Feb. 1992;166:493-7. X-2, X-5. [pmid: 1536217].
86 Hadley AG, Poole GD, Amphlett NW, et al. The use of interferon-gamma-treated U937 cells in chemiluminescence assays to detect red cell, platelet and granulocyte antibodies of potential clinical significance. Clin Lab Haematol. 1992;14:315-26. X-3, X-4. [pmid: 1478011].
87 Heymann SJ, Brewer TF. The problem of transfusion-associated acquired immunodeficiency syndrome in Africa: a quantitative approach. Am J Infect Control. Oct. 1992;20:256-62. X-2, X-3, X-4. [pmid: 1443758].
88 Kane TT, el-Kady AA, Saleh S, et al. Maternal mortality in Giza, Egypt: magnitude, causes, and prevention. Stud Fam Plann. Jan-Feb. 1992;23:45-57. X-1, X-2, X-4. [pmid: 1557794].
89 Kavoo L, Rogo KO. Factors influencing early perinatal mortality in a rural district hospital. East Afr Med J. Apr. 1992;69:181-7. X-2, X-4. [pmid: 1644026].
90 McCarthy TG, Ratnam SS. Intrauterine devices. Contemp Rev Obstet Gynaecol. Oct. 1992;4:215-22. X-1, X-4. [pmid: 12345158].
91 Nelson SH, Suresh MS. Lack of reactivity of uterine arteries from patients with obstetric hemorrhage. Am J Obstet Gynecol. May. 1992;166:1436-43. X-2, X-4, X-5. [pmid: 1317676].
92 O'Hanley K, Huber DH. Postpartum IUDS: keys for success. Contraception. Apr. 1992;45:351-61. X-1, X-4. [pmid: 1516367].
93 Pierre F, Mesnard L, Body G. For a systematic policy of i.v. oxytocin inducted placenta deliveries in a unit where a fairly active management of third stage of labour is yet applied: results of a controlled trial. Eur J Obstet Gynecol Reprod Biol. Jan. 31. 1992;43:131-5. X-4. [pmid: 1563560].
94 Rosenfield A. Maternal mortality: community-based interventions. Int J Gynaecol Obstet. Jun. Suppl. 1992;38:S17-22. X-1. [pmid: 1354177].
95 Sarin AR, Singla P, Kaur H. Maternal mortality -- aetiological factors: analytic study from a teaching hospital of Punjab. Indian J Matern Child Health. Jul-Sep. 1992;3:69-73. X-2. [pmid: 12288813].
96 Saunders NS, Paterson CM, Wadsworth J. Neonatal and maternal morbidity in relation to the length of the second stage of labour. Br J Obstet Gynaecol. May. 1992;99:381-5. X-4, X-5. [pmid: 1622909].
97 Sherman SJ, Greenspoon JS, Nelson JM, et al. Identifying the obstetric patient at high risk of multiple-unit blood transfusions. J Reprod Med. Jul. 1992;37:649-52. X-4, X-5. [pmid: 1522573].
98 Stern C, Permezel M, Petterson C, et al. The Royal Women's Hospital Family Birth Centre: the first 10 years reviewed. Aust N Z J Obstet Gynaecol. Nov. 1992;32:291-6. X-4. [pmid: 1290421].
99 Viegas OA, Wiknsosastro G, Sahagun GH, et al. Safe childbirth needs more than medical services. World Health Forum. 1992;13:59-65. X-1. [pmid: 1637477].
100 Zerbe M, Bashore RG. Critical hemorrhage during pregnancy. Crit Care Nurs Clin North Am. Dec. 1992;4:729-36. X-1. [pmid: 1288597].
101 China: training village doctors. Safe Mother. Feb. 1993:9. X-2. [pmid: 12344831].
102 Midwifery modules. Safe Mother. Feb. 1993:6. X-1, X-4. [pmid: 12344826].
103 Developing skills for delivery and maternity care. Safe Mother. Feb. 1993:1. X-1. [pmid: 12344821].
104 New study could help women at risk after childbirth. Essent Drugs Monit. 1993;8. X-1, X-3, X-4. [pmid: 12286992].
105 Abdel-Aleem H, Abol-Oyoun EM, Moustafa SA, et al. Carboprost trometamol in the management of the third stage of labor. Int J Gynaecol Obstet. Sep. 1993;42:247-50. X-2, X-4, X-5. [pmid: 7901080].
106 Abouzahr C. Maternity care for all. ORGYN. 1993:12-6. X-1, X-4. [pmid: 12318474].
107 Achiron R, Goldenberg M, Lipitz S, et al. Transvaginal duplex Doppler ultrasonography in bleeding patients suspected of having residual trophoblastic tissue. Obstet Gynecol. Apr. 1993;81:507-11. X-4. [pmid: 8459957].
108 Allahbadia G, Ambiye V, Vaidya P. Unconventional use of oxytocin. J Indian Med Assoc. Feb. 1993;91:40-1. X-2, X-3, X-4. [pmid: 8501312].
109 Bolaji II, Meehan FP. Caesarean section survey in Galway--1973 through 1987. Eur J Obstet Gynecol Reprod Biol. Jan. 1993;48:1-8. X-4, X-5. [pmid: 8449255].
110 Bolaji I, Meehan FP. Caesarean section survey in Galway--1973 through 1987. Eur J Obstet Gynecol Reprod Biol. Jan. 1993;48(1):1-8. X-4. [pmid: 8449255].
111 Chua S, Arulkumaran S, Adaikan G, et al. The effect of oxytocics stored at high temperatures on postpartum uterine activity. Br J Obstet Gynaecol. Sep. 1993;100:874-5. X-2, X-4, X-5. [pmid: 8218018].
112 Dahlman TC. Osteoporotic fractures and the recurrence of thromboembolism during pregnancy and the puerperium in 184 women undergoing thromboprophylaxis with heparin. Am J Obstet Gynecol. Apr. 1993;168:1265-70. X-3, X-4. [pmid: 8475973].
113 Dickie MB, Arbeiter K. Diagnosis and therapy of the subinvolution of placental sites in the bitch. J Reprod Fertil Suppl. 1993;47:471-5. X-3, X-4. [pmid: 8229965].
114 Fenelon VS, Poulain DA, Theodosis DT. Oxytocin neuron activation and Fos expression: a quantitative immunocytochemical analysis of the effect of lactation, parturition, osmotic and cardiovascular stimulation. Neuroscience. Mar. 1993;53:77-89. X-3, X-4. [pmid: 8469314].
115 Hauser I, Gisslinger H, Locker G, et al. Postpartum factor VIII inhibitors. Report of two cases with special reference to the efficacy of various treatments. Wien Klin Wochenschr. 1993;105:355-8. X-4. [pmid: 8333206].
116 Hibbard B, Milner D. Reports on confidential enquiries into maternal deaths: an audit of previous recommendations. Health Trends. 1993;26:26-8. X-1, X-4. [pmid: 10136286].
117 Hwa HL, Chen RJ, Chen YC, et al. Maternal and fetal outcome of pregnant women with idiopathic thrombocytopenic purpura: retrospective analysis of 25 pregnancies. J Formos Med Assoc. Nov. 1993;92:957-61. X-4. [pmid: 7910066].
118 Iyasu S, Saftlas AK, Rowley DL, et al. The epidemiology of placenta previa in the United States, 1979 through 1987. Am J Obstet Gynecol. May. 1993;168:1424-9. X-4. [pmid: 8498422].
119 Khong TY, Khong TK. Delayed postpartum hemorrhage: a morphologic study of causes and their relation to other pregnancy disorders. Obstet Gynecol. Jul. 1993;82:17-22. X-4, X-5. [pmid: 8515920].
120 Konkle BA, Josephson NC, Nakaya Fletcher S, Hemophilia B. Pagon RA, Adam MP, Ardinger HH, Bird TD, Dolan CR, Fong CT, et al., editors. GeneReviews(R). Seattle (WA). University of Washington, Seattle University of Washington, Seattle. All rights reserved. 1993.
121 Leung AS, Millar LK, Koonings PP, et al. Perinatal outcome in hypothyroid pregnancies. Obstet Gynecol. Mar. 1993;81:349-53. X-4. [pmid: 8437784].
122 Levine RU, Berkowitz KM. Conservative management and pregnancy outcome in diethylstilbestrol-exposed women with and without gross genital tract abnormalities. Am J Obstet Gynecol. Nov. 1993;169:1125-9. X-4. [pmid: 8238171].
123 Mahomed K, Grant D, James DK. Amniotic fluid zinc and pregnancy outcome. Eur J Obstet Gynecol Reprod Biol. Dec. 30. 1993;52:157-61. X-3, X-4. [pmid: 8163029].
124 Martey JO, Djan JO, Twum S, et al. Maternal mortality due to hemorrhage in Ghana. Int J Gynaecol Obstet. Sep. 1993;42:237-41. X-2, X-4. [pmid: 7901078].
125 Mate-Kole MO, Yeboah ED, Affram RK, et al. Anuric acute renal failure due to bilateral accidental ureteric ligation during abdominal hysterectomy. Int J Gynaecol Obstet. Apr. 1993;41:67-73. X-2, X-3, X-4. [pmid: 8098298].
126 McDonald SJ, Prendiville WJ, Blair E. Randomised controlled trial of oxytocin alone versus oxytocin and ergometrine in active management of third stage of labour. BMJ. Nov. 6. 1993;307:1167-71. X-4. [pmid: 8251842].
127 Mitty HA, Sterling KM, Alvarez M, et al. Obstetric hemorrhage: prophylactic and emergency arterial catheterization and embolotherapy. Radiology. Jul. 1993;188:183-7. X-4, X-5. [pmid: 8511294].
128 Mordel N, Ezra Y, Benshushan A, et al. Transverse versus longitudinal uterine incision in cesarean delivery of triplets. J Reprod Med. Sep. 1993;38:695-6. X-1, X-4. [pmid: 8254591].
129 Murta EF, Carneiro JG, De Freitas MM. Total hysterectomy versus subtotal hysterectomy: which procedure should be performed during the pregnant-puerperal period?. Rev Paul Med. Mar-Apr. 1993;111:354-8. X-2, X-3, X-4. [pmid: 8284578].
130 Orhue AA. A randomized trial of 30-min and 15-min oxytocin infusion regimen for induction of labor at term in women of low parity. Int J Gynaecol Obstet. Mar. 1993;40:219-25. X-3, X-4. [pmid: 8096473].
131 Orhue AA. A randomised trial of 45 minutes and 15 minutes incremental oxytocin infusion regimes for the induction of labour in women of high parity. Br J Obstet Gynaecol. Feb. 1993;100:126-9. X-2, X-4. [pmid: 8476802].
132 Petrulis AS, Dierker LJ Jr. Renal artery aneurysm rupture: an unusual cause of postpartum hemorrhage. Journal of Maternal-Fetal Medicine. 1993;2:121-3. X-2, X-4, X-5.
133 Phuapradit W, Saropala N, Rangsipragarn R. Treatment of atonic postpartum hemorrhage with a prostaglandin E2 analogue. J Med Assoc Thai. Jun. 1993;76:303-7. X-2, X-5. [pmid: 8083621].
134 Pinchun P, Chullapram T. A 10-year review of maternal mortality in Chon Buri Hospital, Thailand. J Med Assoc Thai. Jun. 1993;76:308-13. X-2, X-4. [pmid: 8083622].
135 Sherman SJ, Greenspoon JS, Nelson JM, et al. Obstetric hemorrhage and blood utilization. J Reprod Med. Dec. 1993;38:929-34. X-4, X-5. [pmid: 8120849].
136 Sibai BM, Caritis SN, Thom E, et al. Prevention of preeclampsia with low-dose aspirin in healthy, nulliparous pregnant women. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. N Engl J Med. Oct. 21. 1993;329:1213-8. X-3, X-4. [pmid: 8413387].
137 Stones RW, Paterson CM, Saunders NJ. Risk factors for major obstetric haemorrhage. Eur J Obstet Gynecol Reprod Biol. Jan. 1993;48:15-8. X-4. [pmid: 8449256].
138 Thilaganathan B, Cutner A, Latimer J, et al. Management of the third stage of labour in women at low risk of postpartum haemorrhage. Eur J Obstet Gynecol Reprod Biol. Jan. 1993;48:19-22. X-4. [pmid: 8449257].
139 Postpartum care is crucial for health and survival. Safe Mother. Feb. 1994:4-5. X-1, X-4. [pmid: 12345457].
140 Clinical update. Injectable contraception an important option post-partum. Nursing RSA Verpleging. 1994;9:43. X-1, X-4.
141 AbdRabbo SA. Stepwise uterine devascularization: a novel technique for management of uncontrolled postpartum hemorrhage with preservation of the uterus. Am J Obstet Gynecol. Sep. 1994;171:694-700. X-2, X-4. [pmid: 8092217].
142 Akins S. Postpartum hemorrhage. A 90s approach to an age-old problem. J Nurse Midwifery. Mar-Apr. 1994;39:123s-34s. X-1. [pmid: 8035242].
143 Allahbadia G. Hypogastric artery ligation: a new perspective. J Gynecol Surg. Spring. 1994;9:35-42. X-2, X-3. [pmid: 10148525].
144 de Groot AN, Vree TB, Hekster YA, et al. Pharmacokinetics and bioavailability of oral ergometrine in male volunteers. Biopharm Drug Dispos. Jan. 1994;15:65-73. X-3, X-4. [pmid: 8161717].
145 Dua JA. Postpartum eclampsia associated with ergometrine maleate administration. Br J Obstet Gynaecol. Jan. 1994;101:72-3. X-4, X-5. [pmid: 8297875].
146 Duvekot E, Wijnen M. A comparison between health centre deliveries and deliveries born before arrival in the Aitape district. P N G Med J. Sep. 1994;37:173-7. X-2, X-4. [pmid: 7668055].
147 Fenelon VS, Theodosis DT, Poulain DA. Fos synthesis in identified magnocellular neurons varies with phenotype, stimulus, location in the hypothalamus and reproductive state. Brain Res. Oct. 31. 1994;662:165-77. X-3, X-4. [pmid: 7859070].
148 Garner P, Lai D, Baea M. Childbirth in rural areas: maternal deaths, village deliveries and obstetric service use. P N G Med J. Sep. 1994;37:166-72. X-2, X-4. [pmid: 7668054].
149 Gupta U, Chitra R. Destructive operations still have a place in developing countries. Int J Gynaecol Obstet. Jan. 1994;44:15-9. X-2, X-4. [pmid: 7907053].
150 Gupta U, Ganesh K. Emergency hysterectomy in obstetrics: review of 15 years. Asia Oceania J Obstet Gynaecol. Mar. 1994;20:1-5. X-2, X-4. [pmid: 8172519].
151 Irons DW, Sriskandabalan P, Bullough CH. A simple alternative to parenteral oxytocics for the third stage of labor. Int J Gynaecol Obstet. Jul. 1994;46:15-8. X-2, X-4, X-5. [pmid: 7805977].
152 Katesmark M, Brown R, Raju KS. Successful use of a Sengstaken-Blakemore tube to control massive postpartum haemorrhage. Br J Obstet Gynaecol. Mar. 1994;101:259-60. X-4, X-5. [pmid: 8193105].
153 Lee CN, Wu CC, Lin PY, et al. Pregnancy following cardiac prosthetic valve replacement. Obstet Gynecol. Mar. 1994;83:353-6. X-4. [pmid: 8127524].
154 Louisy C, Fraser R. Post partum haemorrhage. Care of the Critically Ill. 1994. Jan-Feb. 1994;10:31-4. X-1.
155 Lunt CC, Satin AJ, Barth WH Jr., et al. The effect of indomethacin tocolysis on maternal coagulation status. Obstet Gynecol. Nov. 1994;84:820-2. X-3, X-4. [pmid: 7936519].
156 MacLennan AH, Chan FY, Eckert K. The safety of vaginal prostaglandin F2 alpha for the stimulation of labour. Aust N Z J Obstet Gynaecol. May. 1994;34:154-8. X-4. [pmid: 7980303].
157 Mahon TR, Chazotte C, Cohen WR. Short labor: characteristics and outcome. Obstet Gynecol. Jul. 1994;84:47-51. X-4. [pmid: 8008321].
158 Makhseed M, el-Tomi N, Moussa M. A retrospective analysis of pathological placental implantation--site and penetration. Int J Gynaecol Obstet. Nov. 1994;47:127-34. X-2, X-4. [pmid: 7843481].
159 Malhotra AD. Safe motherhood: with whom the responsibility rests?. Nurs J India. Aug. 1994;85:193-5. X-1, X-4. [pmid: 7838776].
160 Martey JO, Djan JO, Twum S, et al. Maternal mortality and related factors in Ejisu District, Ghana. East Afr Med J. Oct. 1994;71:656-60. X-2, X-4. [pmid: 7821246].
161 Naef RW 3rd, Chauhan SP, Chevalier SP, et al. Prediction of hemorrhage at cesarean delivery. Obstet Gynecol. Jun. 1994;83:923-6. X-4. [pmid: 8190432].
162 Orhue AA. Incremental increases in oxytocin infusion regimens for induction of labor at term in primigravidas: a randomized controlled trial. Obstet Gynecol. Feb. 1994;83:229-33. X-4. [pmid: 8290185].
163 Phillips CA, Kinch RA. Management of the third stage of labor: a survey of practice among Texas obstetricians. Tex Med. Dec. 1994;90:44-7. X-3, X-4. [pmid: 7817327].
164 Qian YM, Jones RL, Chan KM, et al. Potent contractile actions of prostanoid EP3-receptor agonists on human isolated pulmonary artery. Br J Pharmacol. Oct. 1994;113:369-74. X-3, X-4. [pmid: 7834185].
165 Riley DP, Burgess RW. External abdominal aortic compression: a study of a resuscitation manoeuvre for postpartum haemorrhage. Anaesth Intensive Care. Oct. 1994;22:571-5. X-3. [pmid: 7818062].
166 Roberts CL, Algert CS, March LM. Delayed childbearing--are there any risks?. Med J Aust. May. 2. 1994;160:539-44. X-4. [pmid: 8164551].
167 Roberts WE, Perry KG Jr., Woods JB, et al. The intrapartum platelet count in patients with HELLP (hemolysis, elevated liver enzymes, and low platelets) syndrome: is it predictive of later hemorrhagic complications?. Am J Obstet Gynecol. Sep. 1994;171:799-804. X-4. [pmid: 8092232].
168 Schoenfeld A, Hod M, Merlob P, et al. Safety of maternal long-term indomethacin tocolysis. Int J Risk Saf Med. 1994;4:215-22. X-3, X-4. [pmid: 23511259].
169 Spence RK, Norcross ED, Costabile J, et al. Perfluorocarbons as blood substitutes: The early years. Experience with fluosol DA-20% in the 1980s. 1994;22:955-63. X-1, X-4.
170 Tayal SC, Bansal SK, Chadha DK. Hypopituitarism: a difficult diagnosis in elderly people but worth a search. Age Ageing. Jul. 1994;23:320-2. X-1, X-4. [pmid: 7976781].
171 Tsu VD. Antenatal screening: its use in assessing obstetric risk factors in Zimbabwe. J Epidemiol Community Health. Jun. 1994;48:297-305. X-2, X-4. [pmid: 8051531].
172 Vergani P, Ghidini A, Strobelt N, et al. Do uterine leiomyomas influence pregnancy outcome?. Am J Perinatol. Sep. 1994;11:356-8. X-4. [pmid: 7993518].
173 Voisin DL, Chapman C, Poulain DA, et al. Extracellular GABA concentrations in rat supraoptic nucleus during lactation and following haemodynamic changes: an in vivo microdialysis study. Neuroscience. Nov. 1994;63:547-58. X-3, X-4. [pmid: 7891864].
174 Walraven GE, Mkanje RJ, van Roosmalen J, et al. Assessment of maternal mortality in Tanzania. Br J Obstet Gynaecol. May. 1994;101:414-7. X-2, X-4. [pmid: 8018613].
175 Wardell DW. Commentary on OB emergencies: postpartum hemorrhage. [original article by Dildy G et al appears in CONTEMP OB GYN 1993;38(08): 21-9]. AWHONN's Women's Health Nursing Scan. 1994. Jan-Feb. 1994;8:10. X-1.
176 Woodcock HC, Read AW, Bower C, et al. A matched cohort study of planned home and hospital births in Western Australia 1981-1987. Midwifery. Sep. 1994;10:125-35. X-4. [pmid: 7639843].
177 Yamashita Y, Harada M, Yamamoto H, et al. Transcatheter arterial embolization of obstetric and gynaecological bleeding: efficacy and clinical outcome. Br J Radiol. Jun. 1994;67:530-4. X-5. [pmid: 8032805].
178 Midwives to receive safe motherhood training. Safe Mother. Mar-Jun. 1995:1-2. X-1, X-4. [pmid: 12346354].
179 Failure to lactate -- two cases explained. Breastfeeding Review. 1995;3:92-4. X-1, X-4.
180 Berenson AB, Wilkinson GS, Lopez LA. Substance use during pregnancy and peripartum complications in a triethnic population. Int J Addict. Jan. 1995;30:135-45. X-4. [pmid: 7759168].
181 Bobrowski RA, Jones TB. A thrombogenic uterine pack for postpartum hemorrhage. Obstet Gynecol. May. 1995;85:836-7. X-5. [pmid: 7724130].
182 Chandramohan D, Cutts F, Millard P. The effect of stay in a maternity waiting home on perinatal mortality in rural Zimbabwe. J Trop Med Hyg. Aug. 1995;98:261-7. X-2, X-4. [pmid: 7636923].
183 Chen LH, Tan KH, Yeo GS. A ten-year review of uterine rupture in modern obstetric practice. Ann Acad Med Singapore. Nov. 1995;24:830-5. X-2, X-4, X-5. [pmid: 8838990].
184 Chua S, Chew SL, Yeoh CL, et al. A randomized controlled study of prostaglandin 15-methyl F2 alpha compared with syntometrine for prophylactic use in the third stage of labour. Aust N Z J Obstet Gynaecol. Nov. 1995;35:413-6. X-4. [pmid: 8717567].
185 Cryns YL. Postpartum hemorrhage: prevention and treatment. Midwifery Today Childbirth Educ. Summer. 1995:37-9. 52. [pmid: 7787905]. X-1, X-4.
186 Dasgupta S. Reproductive morbidity. J Indian Med Assoc. Feb. 1995;93:55-7. X-1, X-4. [pmid: 7658038].
187 Davis RB, Vinal D. When things go wrong at home: obstetrical emergencies outside the hospital. JEMS: Journal of Emergency Medical Services. 1995;20:30. X-1, X-4.
188 de Groot AN, Hekster YA, Vree TB, et al. Oxytocin and desamino-oxytocin tablets are not stable under simulated tropical conditions. J Clin Pharm Ther. Apr. 1995;20:115-9. X-3, X-4. [pmid: 7650072].
189 de Groot AN, Hekster YA, Vree TB, et al. Ergometrine and methylergometrine tablets are not stable under simulated tropical conditions. J Clin Pharm Ther. Apr. 1995;20:109-13. X-1, X-3, X-4. [pmid: 7650071].
190 De Groot AN, Vree TB, Hekster YA, et al. Bioavailability and pharmacokinetics of sublingual oxytocin in male volunteers. J Pharm Pharmacol. Jul. 1995;47:571-5. X-3, X-4. [pmid: 8568623].
191 de Koning YW, Plaisier PW, Tan IL, et al. Critical limb ischemia after accidental subcutaneous infusion of sulprostone. Eur J Obstet Gynecol Reprod Biol. Aug. 1995;61:171-3. X-5. [pmid: 7556841].
192 Dehne KL, Wacker J, Cowley J. Training birth attendants in the Sahel. World Health Forum. 1995;16:415-9. X-1, X-2, X-4. [pmid: 8534351].
193 Donnelly JA, Smith EA, Runcie CJ. Transfer of the critically ill obstetric patient: experience of a specialist team and guidelines for the non-specialist. Int J Obstet Anesth. Jul. 1995;4:145-9. X-5. [pmid: 15636997].
194 Eltabbakh GH, Watson JD. Postpartum hysterectomy. Int J Gynaecol Obstet. Sep. 1995;50:257-62. X-2, X-4, X-5. [pmid: 8543108].
195 Fauveau VA. The Lao People's Democratic Republic: maternal mortality and female mortality: determining causes of deaths. World Health Stat Q. 1995;48:44-6. X-2, X-3, X-4. [pmid: 7571711].
196 Foster PA. The reproductive health of women with von Willebrand Disease unresponsive to DDAVP: results of an international survey. On behalf of the Subcommittee on von Willebrand Factor of the Scientific and Standardization Committee of the ISTH. Thromb Haemost. Aug. 1995;74:784-90. X-4, X-5. [pmid: 8585022].
197 Goodburn EA, Gazi R, Chowdhury M. Beliefs and practices regarding delivery and postpartum maternal morbidity in rural Bangladesh. Stud Fam Plann. Jan-Feb. 1995;26:22-32. X-1, X-2, X-4. [pmid: 7785065].
198 Granovsky-Grisaru S, Aboulafia Y, Diamant YZ, et al. Gynecologic and obstetric aspects of Gaucher's disease: a survey of 53 patients. Am J Obstet Gynecol. Apr. 1995;172:1284-90. X-4. [pmid: 7726271].
199 Haththotuwa R, Arulkumaran S, Chua S, et al. Postpartum haemorrhage: suggestions to reduce maternal mortality and morbidity. J Indian Med Assoc. Feb. 1995;93:67-70. 40. 57. X-1, X-4. [pmid: 7658042].
200 Jafarova V. Implementing the ICPD Plan of Action in Central Asian Republics and Kazakhstan (CARAK). Azerbaijan. Urgent need for family planning. Entre Nous Cph Den. May. 1995:12. X-1, X-4. [pmid: 12222266].
201 Khan GQ, John IS, Chan T, et al. Abu Dhabi third stage trial: oxytocin versus Syntometrine in the active management of the third stage of labour. Eur J Obstet Gynecol Reprod Biol. Feb. 1995;58:147-51. X-2, X-4. [pmid: 7774741].
202 Knuppel RA, Hatangadi SB. Acute hypotension related to hemorrhage in the obstetric patient. Obstet Gynecol Clin North Am. Mar. 1995;22:111-29. X-1. [pmid: 7784033].
203 Koong DK, McKenna KM. Is the fibroid a uterus?. Aust N Z J Obstet Gynaecol. Aug. 1995;35:332-4. X-1, X-4. [pmid: 8546659].
204 Korejo R, Jafarey SN. Obstetrics hysterectomy--five years experience at Jinnah Postgraduate Medical Centre, Karachi. J Pak Med Assoc. Apr. 1995;45:86-8. X-2, X-4. [pmid: 7623403].
205 Lackmann GM, Tollner U. The predictive value of elevation in specific serum enzymes for subsequent development of hypoxic-ischemic encephalopathy or intraventricular hemorrhage in full-term and premature asphyxiated newborns. Neuropediatrics. Aug. 1995;26:192-8. X-3, X-4. [pmid: 8544957].
206 Leonard R, Parker RK, O'Grady JP. Postpartum hemorrhage: working with the anesthesiologist. Contemporary OB/GYN. 1995;40:46-8. 51. 5 passim. PMID:. X-1.
207 Magann EF, Winchester MI, Carter DP, et al. Factors adversely affecting pregnancy outcome in the military. Am J Perinatol. Nov. 1995;12:462-6. X-4. [pmid: 8579664].
208 Makhseed M, Moussa MA. The outcome of placenta accreta in Kuwait (1981-1993). Int J Gynaecol Obstet. Aug. 1995;50:139-44. X-2, X-4. [pmid: 7589748].
209 McLean MT. Tips for bimanual compression. Midwifery Today Childbirth Educ. Summer. 1995:52. [pmid: 7787908]. X-1, X-2, X-4, X-5.
210 Naef RW 3rd, Ray MA, Chauhan SP, et al. Trial of labor after cesarean delivery with a lower-segment, vertical uterine incision: is it safe?. Am J Obstet Gynecol. Jun. 1995;172:1666-73. discussion 73-4. X-3, X-4. [pmid: 7778619].
211 Oelrichs PB, Ng JC, Seawright AA, et al. Isolation and identification of a compound from avocado (Persea americana) leaves which causes necrosis of the acinar epithelium of the lactating mammary gland and the myocardium. Nat Toxins. 1995;3:344-9. X-1, X-3, X-4. [pmid: 8581318].
212 Oosterbaan MM. Guinea-Bissau: maternal mortality assessment. World Health Stat Q. 1995;48:34-8. X-1, X-2. [pmid: 7571708].
213 Phemister DA, Laurent S, Harrison FN Jr. Use of Norplant contraceptive implants in the immediate postpartum period: safety and tolerance. Am J Obstet Gynecol. Jan. 1995;172:175-9. X-1, X-3, X-4. [pmid: 7847530].
214 Ploeckinger B, Ulm MR, Chalubinski K, et al. Epidural anaesthesia in labour: influence on surgical delivery rates, intrapartum fever and blood loss. Gynecol Obstet Invest. 1995;39:24-7. X-1, X-4. [pmid: 7890248].
215 Prakash J, Tripathi K, Pandey LK, et al. Spectrum of renal cortical necrosis in acute renal failure in eastern India. Postgrad Med J. Apr. 1995;71:208-10. X-1, X-2, X-4. [pmid: 7784278].
216 Prysak M, Lorenz RP, Kisly A. Pregnancy outcome in nulliparous women 35 years and older. Obstet Gynecol. Jan. 1995;85:65-70. X-4. [pmid: 7800328].
217 Rajapaksa DS, Karunathilaka DH. Idiopathic thrombocytopaenic purpura presenting as post-partum haemorrhage. Ceylon Med J. Mar. 1995;40:39-40. X-1, X-4. [pmid: 7781093].
218 Sibai BM, Caritis SN, Thom E, et al. Low-dose aspirin in nulliparous women: safety of continuous epidural block and correlation between bleeding time and maternal-neonatal bleeding complications. National Institute of Child Health and Human Developmental Maternal-Fetal Medicine Network. Am J Obstet Gynecol. May. 1995;172:1553-7. X-3, X-4. [pmid: 7755070].
219 Stenius-Aarniala B, Riikonen S, Teramo K. Slow-release theophylline in pregnant asthmatics. Chest. Mar. 1995;107:642-7. X-2, X-4. [pmid: 7874930].
220 Stewart MK, Festin M. Validation study of women's reporting and recall of major obstetric complications treated at the Philippine General Hospital. Int J Gynaecol Obstet. Jun. Suppl. 1995;48:S53-66. X-1, X-2, X-4. [pmid: 7672175].
221 Toohey JS, Keegan KA Jr., Morgan MA, et al. The “dangerous multipara”: fact or fiction?. Am J Obstet Gynecol. Feb. 1995;172:683-6. X-4. [pmid: 7856706].
222 Tuncer RA, Erkaya S, Sipahi T, et al. Maternal mortality in a maternity hospital in Turkey. Acta Obstet Gynecol Scand. Sep. 1995;74:604-6. X-2, X-4. [pmid: 7660764].
223 Valenzuela GJ, Craig J, Bernhardt MD, et al. Placental passage of the oxytocin antagonist atosiban. Am J Obstet Gynecol. Apr. 1995;172:1304-6. X-4, X-5. [pmid: 7726274].
224 Van Selm M, Kanhai HH, Keirse MJ. Preventing the recurrence of atonic postpartum hemorrhage: a double-blind trial. Acta Obstet Gynecol Scand. Apr. 1995;74:270-4. X-3, X-4. [pmid: 7732799].
225 Varaklis K, Stubblefield PG. Evaluating the role of incidental diagnostic dilation and curettage in young women undergoing elective laparoscopic sterilization. J Reprod Med. Jun. 1995;40:415-7. X-3, X-4. [pmid: 7650651].
226 Versi E, Liu KL, Chia P, et al. Obstetric outcome of Bangladeshi women in east London. Br J Obstet Gynaecol. Aug. 1995;102:630-7. X-3, X-4. [pmid: 7654641].
227 Xu Z. China: lowering maternal mortality in Miyun County, Beijing. World Health Stat Q. 1995;48:11-4. X-2. [pmid: 7571702].
228 Yuen PM, Chan NS, Yim SF, et al. A randomised double blind comparison of Syntometrine and Syntocinon in the management of the third stage of labour. Br J Obstet Gynaecol. May. 1995;102:377-80. X-2, X-4, X-5. [pmid: 7612530].
229 Zimmermann R, Breymann C, Richter C, et al. rhEPO treatment of postpartum anemia. J Perinat Med. 1995;23:111-7. X-2, X-4, X-5. [pmid: 7658310].
230 Team saves women's life, then she sues for being left with limp from stirrups. OB-GYN Malpractice Prevention. 1996;3:85-6. X-1, X-4.
231 Tricks of the trade... midwifery. Midwifery Today & Childbirth Education. 1996:10. X-1, X-4.
232 Can maternal height and weight be used to predict pregnancy outcome?. Safe Mother. 1996:10-1. X-1. [pmid: 12292433].
233 Albrecht JL, Tomich PG. The maternal and neonatal outcome of triplet gestations. Am J Obstet Gynecol. May. 1996;174:1551-6. X-4. [pmid: 9065128].
234 As AK, Hagen P, Webb JB. Tranexamic acid in the management of postpartum haemorrhage. Br J Obstet Gynaecol. Dec. 1996;103:1250-1. X-5. [pmid: 8968245].
235 de Groot AN, van Roosmalen J, van Dongen PW, et al. A placebo-controlled trial of oral ergometrine to reduce postpartum hemorrhage. Acta Obstet Gynecol Scand. May. 1996;75:464-8. X-4. [pmid: 8677772].
236 Goldberg CC, Kallen MA, McCurdy CM, et al. Effect of intrapartum use of oxytocin on estimated blood loss and hematocrit change at vaginal delivery. Am J Perinatol. Aug. 1996;13:373-6. X-4. [pmid: 8865985].
237 Hofmeyr GJ, Kulier R. Tocolysis for preventing fetal distress in second stage of labour. Cochrane Database of Systematic Reviews. 1996. X-1.
238 Jacques SM, Qureshi F, Trent VS, et al. Placenta accreta: mild cases diagnosed by placental examination. Int J Gynecol Pathol. Jan. 1996;15:28-33. X-1, X-4, X-5. [pmid: 8852443].
239 Jegasothy R, Paranthaman S. Sublingual nifedipine compared with intravenous hydrallazine in the acute treatment of severe hypertension in pregnancy: potential for use in rural practice. J Obstet Gynaecol Res. Feb. 1996;22:21-4. X-2, X-3, X-4. [pmid: 8624887].
240 Lao TT, Lee CP, Mak WP. Postpartum anaemia is not related to maternal iron status in the third trimester. Eur J Obstet Gynecol Reprod Biol. Jan. 1996;64:7-10. X-4. [pmid: 8801154].
241 Lecuru F, Desnos M, Taurelle R. Anticoagulant therapy in pregnancy. Report of 54 cases. Acta Obstet Gynecol Scand. Mar. 1996;75:217-21. X-4. [pmid: 8607332].
242 Lee HY, Subramaniam N, Nordin MM. Vacuum delivery at The Maternity Hospital Kuala Lumpur: a comparison of metal and silicone cups. Singapore Med J. Feb. 1996;37:55-60. X-2, X-4. [pmid: 8783915].
243 Ma J, Bauman A. Obstetric profiles and pregnancy outcomes of immigrant women in New South Wales, 1990-1992. Aust N Z J Obstet Gynaecol. May. 1996;36:119-25. X-4. [pmid: 8798294].
244 Makhseed M, Musini VM. Eclampsia in Kuwait 1981-1993. Aust N Z J Obstet Gynaecol. Aug. 1996;36:258-63. X-2, X-4. [pmid: 8883746].
245 Naqvi R, Ahmed E, Akhtar F, et al. Analysis of factors causing acute renal failure. J Pak Med Assoc. Feb. 1996;46:29-30. X-2, X-4. [pmid: 8683843].
246 Naqvi R, Akhtar F, Ahmed E, et al. Acute renal failure of obstetrical origin during 1994 at one center. Ren Fail. Jul. 1996;18:681-3. X-3, X-4. [pmid: 8875696].
247 Petherbridge J. Case study: postpartum haemorrhage with associated disseminated intravascular coagulation and acute renal failure. Nursing Monograph. 1996. 8p. X-4.
248 Rutherford JM, Rubin PC. Management of epilepsy in pregnancy: therapeutic aspects. Br J Hosp Med. May 15-Jun 4. 1996;55:620-2. X-1, X-3, X-4. [pmid: 8762119].
249 Shava J, Masihleho GE, Mazibuko MD. Peripartum hysterectomy at Ga-Rankuwa Hospital: a two and a half year review. Cent Afr J Med. Jan. 1996;42:25-8. X-2, X-4. [pmid: 8868382].
250 Soriano D, Dulitzki M, Schiff E, et al. A prospective cohort study of oxytocin plus ergometrine compared with oxytocin alone for prevention of postpartum haemorrhage. Br J Obstet Gynaecol. Nov. 1996;103:1068-73. X-4, X-5. [pmid: 8916990].
251 Tammelleo AD. Court bans non-consensual transfusions. Regan Report on Hospital Law. 1996;37:1. X-1.
252 Vermunt JJ, Greenough PR. Sole haemorrhages in dairy heifers managed under different underfoot and environmental conditions. Br Vet J. Jan. 1996;152:57-73. X-3, X-4. [pmid: 8634866].
253 Wolman I, Jaffa AJ, Pauzner D, et al. Transvaginal sonohysterography: a new aid in the diagnosis of residual trophoblastic tissue. J Clin Ultrasound. Jun. 1996;24:257-61. X-4, X-5. [pmid: 8723514].
254 Postpartum care -- what's best for mother and baby. Safe Mother. 1997:4-8. X-1, X-4. [pmid: 12321360].
255 OB sued after surgery saves patient's life. OB-GYN Malpractice Prevention. 1997;4:85-6. X-1, X-4.
256 Asnis DS, Milman PJ. Massive lower gastrointestinal hemorrhage secondary to colonic tuberculosis in a postpartum patient. Infectious Diseases in Clinical Practice. November. 1997;6:548-52. X-1, X-4, X-5.
257 C BL, Coker A, Lawal AH, et al. The B-Lynch surgical technique for the control of massive postpartum haemorrhage: an alternative to hysterectomy? Five cases reported. Br J Obstet Gynaecol. Mar. 1997;104:372-5. X-1, X-5. [pmid: 9091019].
258 Chipchase J, James D. Randomised trial of expectant versus surgical management of spontaneous miscarriage. Br J Obstet Gynaecol. Jul. 1997;104:840-1. X-3. [pmid: 9236651].
259 Chiwuzie J, Okolocha C, Okojie O, et al. Sociocultural aspects of haemorrhage in pregnancy. World Health Forum. 1997;18:185-8. X-1. [pmid: 9393003].
260 Diejomaoh FM, Bukhadour N, al-Yattamah M. Severe primary postpartum hemorrhage. Int J Gynaecol Obstet. Jun. 1997;57:315-6. X-1, X-2. [pmid: 9215496].
261 Drife J. Management of primary postpartum haemorrhage. Br J Obstet Gynaecol. Mar. 1997;104:275-7. X-1, X-4, X-5. [pmid: 9091001].
262 el-Refaey H, O'Brien P, Morafa W, et al. Use of oral misoprostol in the prevention of postpartum haemorrhage. Br J Obstet Gynaecol. Mar. 1997;104:336-9. X-4. [pmid: 9091012].
263 Etuk SJ, Asuquo EE. Maternal mortality following post-partum haemorrhage in Calabar a 6-year review. West Afr J Med. Jul-Sep. 1997;16:165-9. X-2, X-4. [pmid: 9329285].
264 Fawcus S, Mbizvo M, Lindmark G, et al. A community-based investigation of maternal mortality from obstetric haemorrhage in rural Zimbabwe. Maternal Mortality Study Group. Trop Doct. Jul. 1997;27:159-63. X-2, X-4. [pmid: 9227011].
265 Gherman RB, Goodwin TM, Souter I, et al. The McRoberts' maneuver for the alleviation of shoulder dystocia: how successful is it?. Am J Obstet Gynecol. Mar. 1997;176:656-61. X-4. [pmid: 9077624].
266 Goldenberg M, Schiff E, Achiron R, et al. Managing residual trophoblastic tissue. Hysteroscopy for directing curettage. J Reprod Med. Jan. 1997;42:26-8. X-1, X-3, X-4. [pmid: 9018641].
267 Hobisch-Hagen P, Mortl M, Schobersberger W. Hemostatic disorders in pregnancy and the peripartum period. Acta Anaesthesiol Scand Suppl. 1997;111:216-7. X-1, X-2, X-4, X-5. [pmid: 9421019].
268 Hood DD. Anesthetic techniques in obstetric emergencies. Acta Anaesthesiol Scand Suppl. 1997;111:172-3. X-1, X-2, X-5. [pmid: 9421000].
269 Hsieh TT, Hung TH, Hsu JJ, et al. Prediction of adverse perinatal outcome by maternal serum screening for Down syndrome in an Asian population. Obstet Gynecol. Jun. 1997;89:937-40. X-2, X-3, X-4. [pmid: 9170469].
270 Hunt BJ, Doughty HA, Majumdar G, et al. Thromboprophylaxis with low molecular weight heparin (Fragmin) in high risk pregnancies. Thromb Haemost. Jan. 1997;77:39-43. X-3, X-4. [pmid: 9031446].
271 Itina SM. Characteristics of traditional birth attendants and their beliefs and practices in the Offot Clan, Nigeria. Bull World Health Organ. 1997;75:563-7. X-2, X-3, X-4. [pmid: 9509629].
272 Johnson N, Lilford R, Guthrie K, et al. Randomised trial comparing a policy of early with selective amniotomy in uncomplicated labour at term. Br J Obstet Gynaecol. Mar. 1997;104:340-6. X-2, X-4, X-5. [pmid: 9091013].
273 Kadir RA, Economides DL, Braithwaite J, et al. The obstetric experience of carriers of haemophilia. Br J Obstet Gynaecol. Jul. 1997;104:803-10. X-4, X-5. [pmid: 9236645].
274 Keogh J, Tsokos N. Aortic compression in massive postpartum haemorrhage--an old but lifesaving technique. Aust N Z J Obstet Gynaecol. May. 1997;37:237-8. X-1, X-2, X-5. [pmid: 9222477].
275 Khan GQ, John IS, Wani S, et al. Controlled cord traction versus minimal intervention techniques in delivery of the placenta: a randomized controlled trial. Am J Obstet Gynecol. Oct. 1997;177:770-4. X-2, X-4, X-5. [pmid: 9369817].
276 Lau WC, Fung HY, Rogers MS. Ten years experience of caesarean and postpartum hysterectomy in a teaching hospital in Hong Kong. Eur J Obstet Gynecol Reprod Biol. Aug. 1997;74:133-7. X-5. [pmid: 9306105].
277 Nelson-Piercy C, Letsky EA, de Swiet M. Low-molecular-weight heparin for obstetric thromboprophylaxis: experience of sixty-nine pregnancies in sixty-one women at high risk. Am J Obstet Gynecol. May. 1997;176:1062-8. X-4. [pmid: 9166169].
278 Nordstrom L, Fogelstam K, Fridman G, et al. Routine oxytocin in the third stage of labour: a placebo controlled randomised trial. Br J Obstet Gynaecol. Jul. 1997;104:781-6. X-4, X-5. [pmid: 9236641].
279 Ogunniyi SO, Sanusi YO, Faleyimu BL. Forceps delivery at Wesley Guild Hospital, Ilesa, Nigeria: a ten year review. West Afr J Med. Jan-Mar. 1997;16:30-5. X-2, X-4. [pmid: 9133821].
280 Persad PS, Hiscock C, Mitchell T. Midwives' own perception of competence in obstetric procedures. British Journal of Midwifery. 1997;5:706-8. X-3, X-4.
281 Roberts RG, Bell HS, Wall EM, et al. Trial of labor or repeated cesarean section. The woman's choice. Arch Fam Med. Mar-Apr. 1997;6:120-5. X-1, X-4. [pmid: 9075445].
282 Ruggeri M, Schiavotto C, Castaman G, et al. Gestational thrombocytopenia: a prospective study. Haematologica. May-Jun. 1997;82:341-2. X-4, X-5. [pmid: 9234586].
283 Selo-Ojeme DO, Okonofua FE. Risk factors for primary postpartum haemorrhage. A case control study. Arch Gynecol Obstet. 1997;259:179-87. X-2, X-4. [pmid: 9271837].
284 Simon L, Santi TM, Sacquin P, et al. Pre-anaesthetic assessment of coagulation abnormalities in obstetric patients: usefulness, timing and clinical implications. Br J Anaesth. Jun. 1997;78:678-83. X-1, X-4. [pmid: 9215019].
285 Srisomboon J, Piyamongkol W, Aiewsakul P. Comparison of intracervical and intravaginal misoprostol for cervical ripening and labour induction in patients with an unfavourable cervix. J Med Assoc Thai. Mar. 1997;80:189-94. X-2, X-4. [pmid: 9175387].
286 Srisomboon J, Tongsong T, Pongpisuttinun S. Termination of second-trimester pregnancy with intracervicovaginal misoprostol. J Med Assoc Thai. Apr. 1997;80:242-6. X-4. [pmid: 9175393].
287 Stancato-Pasik A, Mitty HA, Richard HM 3rd, et al. Obstetric embolotherapy: effect on menses and pregnancy. Radiology. Sep. 1997;204:791-3. X-5. [pmid: 9280261].
288 Vedantham S, Goodwin SC, McLucas B, et al. Uterine artery embolization: an underused method of controlling pelvic hemorrhage. Am J Obstet Gynecol. Apr. 1997;176:938-48. X-1. [pmid: 9125624].
289 Walder J. Misoprostol: preventing postpartum haemorrhage. Mod Midwife. Sep. 1997;7:23-7. X-1. [pmid: 9370621].
290 Witlin AG, Friedman SA, Sibai BM. The effect of magnesium sulfate therapy on the duration of labor in women with mild preeclampsia at term: a randomized, double-blind, placebo-controlled trial. Am J Obstet Gynecol. Mar. 1997;176:623-7. X-4. [pmid: 9077617].
291 Wolman I, Hartoov J, Pauzner D, et al. Transvaginal sonohysterography for the early diagnosis of residual trophoblastic tissue. J Ultrasound Med. Apr. 1997;16:257-61. X-4, X-5. [pmid: 9315153].
292 Zuckerman J, Levine D, McNicholas MM, et al. Imaging of pelvic postpartum complications. AJR Am J Roentgenol. Mar. 1997;168:663-8. X-1. [pmid: 9057511].
293 Abu-Heija AT, Chalabi HE. Great grand multiparity: is it a risk?. Int J Gynaecol Obstet. Dec. 1998;59:213-6. X-1, X-4. [pmid: 9486509].
294 Ahmad Z, Jaafar R, Hassan MH, et al. A halfway house for pregnant women. World Health Forum. 1998;19:133-5. X-1. [pmid: 9652210].
295 Alcazar JL. Transvaginal ultrasonography combined with color velocity imaging and pulsed Doppler to detect residual trophoblastic tissue. Ultrasound Obstet Gynecol. Jan. 1998;11:54-8. X-2, X-5. [pmid: 9511197].
296 Alexander S, Dodds L, Armson BA. Perinatal outcomes in women with asthma during pregnancy. Obstet Gynecol. Sep. 1998;92:435-40. X-4. [pmid: 9721785].
297 Andersen B, Andersen LL, Sorensen T. Methylergometrine during the early puerperium; a prospective randomized double blind study. Acta Obstet Gynecol Scand. Jan. 1998;77:54-7. X-4, X-5. [pmid: 9492719].
298 Anderson H, Brandt L, Ericson A, et al. Blood transfusion at delivery and risk of subsequent malignant lymphoma in the mother. Vox Sang. 1998;75:145-8. X-4, X-5. [pmid: 9784669].
299 Andersson K, Ryde-Blomqvist E, Lindell K, et al. Perforations with intrauterine devices. Report from a Swedish survey. Contraception. Apr. 1998;57:251-5. X-3. [pmid: 9649917].
300 Assaley J, Baron JM, Cibils LA. Effects of magnesium sulfate infusion upon clotting parameters in patients with pre-eclampsia. J Perinat Med. 1998;26:115-9. X-4. [pmid: 9650132].
301 Baker S. Parenthood. Shattered dreams: the story of Matilda. British Journal of Midwifery. 1998;6:518-21. X-1.
302 Bamigboye AA, Hofmeyr GJ, Merrell DA. Rectal misoprostol in the prevention of postpartum hemorrhage: a placebo-controlled trial. Am J Obstet Gynecol. Oct. 1998;179:1043-6. X-2, X-4, X-5. [pmid: 9790395].
303 Bamigboye AA, Merrell DA, Hofmeyr GJ, et al. Randomized comparison of rectal misoprostol with Syntometrine for management of third stage of labor. Acta Obstet Gynecol Scand. Feb. 1998;77:178-81. X-3, X-4. [pmid: 9512323].
304 Barry H. Can intraumbilical oxytocin reduce the duration of the third stage of labor, reduce the use of manual placental extraction, and prevention postpartum hemorrhage?. Evidence-Based Practice. 1998;1:8. insert 2p. PMID:. X-1, X-4.
305 Barry H. Does the active management of the third stage of labor reduce hemorrhage?. Evidence-Based Practice. 1998;1:5-6. insert 2p. PMID:. X-1, X-4.
306 Berger R, Bender S, Sefkow S, et al. Peri/intraventricular haemorrhage: a cranial ultrasound study on 5286 neonates. Eur J Obstet Gynecol Reprod Biol. Dec. 1998;75:191-203. X-3. [pmid: 9447373].
307 Boucher M, Horbay GL, Griffin P, et al. Double-blind, randomized comparison of the effect of carbetocin and oxytocin on intraoperative blood loss and uterine tone of patients undergoing cesarean section. J Perinatol. May-Jun. 1998;18:202-7. X-4, X-5. [pmid: 9659650].
308 Bruner JP, Drummond SB, Meenan AL, et al. All-fours maneuver for reducing shoulder dystocia during labor. J Reprod Med. May. 1998;43:439-43. X-4. [pmid: 9610468].
309 Chen JH, Wu SC, Shao WQ, et al. The comparative trial of TCu 380A IUD and progesterone-releasing vaginal ring used by lactating women. Contraception. Jun. 1998;57:371-9. X-1, X-3, X-4. [pmid: 9693396].
310 Chew S, Biswas A. Caesarean and postpartum hysterectomy. Singapore Med J. Jan. 1998;39:9-13. X-2, X-4. [pmid: 9557096].
311 Chez RA. The B-Lynch suture for control of massive postpartum hemorrhage. Contemporary OB/GYN. 1998;43:93. X-1, X-4, X-5.
312 Choo WL, Chua S, Chong YS, et al. Correlation of change in uterine activity to blood loss in the third stage of labour. Gynecol Obstet Invest. 1998;46:178-80. X-3, X-4. [pmid: 9736799].
313 Craig S, Dalton R, Tuck M, et al. Sublingual glyceryl trinitrate for uterine relaxation at Caeserean section--a prospective trial. Aust N Z J Obstet Gynaecol. Feb. 1998;38:34-9. X-3, X-4. [pmid: 9521387].
314 Dagli AC. Management of the third stage of labor. J Fam Pract. Jun. 1998;46:452-3. X-1, X-4, X-5. [pmid: 9638101].
315 Das BN, Biswas AK. Ligation of internal iliac arteries in pelvic haemorrhage. J Obstet Gynaecol Res. Aug. 1998;24:251-4. X-2, X-4, X-5. [pmid: 9798353].
316 Gazvani MR, Luckas MJ, Drakeley AJ, et al. Intraumbilical oxytocin for the management of retained placenta: a randomized controlled trial. Obstet Gynecol. Feb. 1998;91:203-7. X-4, X-5. [pmid: 9469276].
317 Golding J. A randomised trial of low dose aspirin for primiparae in pregnancy. The Jamaica Low Dose Aspirin Study Group. Br J Obstet Gynaecol. Mar. 1998;105:293-9. X-2, X-4. [pmid: 9532989].
318 Gregory KD, Henry OA, Ramicone E, et al. Maternal and infant complications in high and normal weight infants by method of delivery. Obstet Gynecol. Oct. 1998;92:507-13. X-4. [pmid: 9764620].
319 Hepner DL, Gutsche BB. Obstetric hemorrhage. Current Reviews for PeriAnesthesia Nurses. 1998;20:134-44. X-1, X-4.
320 Hofmeyr GJ, Nikodem VC, de Jager M, et al. A randomised placebo controlled trial of oral misoprostol in the third stage of labour. Br J Obstet Gynaecol. Sep. 1998;105:971-5. X-2, X-4, X-5. [pmid: 9763047].
321 Kadir RA, Lee CA, Sabin CA, et al. Pregnancy in women with von Willebrand's disease or factor XI deficiency. Br J Obstet Gynaecol. Mar. 1998;105:314-21. X-4. [pmid: 9532993].
322 Kovavisarach E, Rojsangruang S. Effect of umbilical vein oxytocin injection on the third stage of labor: a randomized controlled study. J Med Assoc Thai. Sep. 1998;81:693-7. X-2, X-4. [pmid: 9737127].
323 Kupferminc MJ, Gull I, Bar-Am A, et al. Intrauterine irrigation with prostaglandin F2-alpha for management of severe postpartum hemorrhage. Acta Obstet Gynecol Scand. May. 1998;77:548-50. X-2, X-5. [pmid: 9654178].
324 Lao TT, Ho LF, Liu KL. Gestational diabetes mellitus in teenage pregnancy: a case-control study. Diabet Med. Dec. 1998;15:1036-8. X-4. [pmid: 9868978].
325 Lavender T, Alfirevic Z, Walkinshaw S. Partogram action line study: a randomised trial. Br J Obstet Gynaecol. Sep. 1998;105:976-80. X-4. [pmid: 9763048].
326 Leroy V, Ladner J, Nyiraziraje M, et al. Effect of HIV-1 infection on pregnancy outcome in women in Kigali, Rwanda, 1992-1994. Pregnancy and HIV Study Group. AIDS. Apr. 16. 1998;12:643-50. X-2, X-4. [pmid: 9583605].
327 Lindqvist PG, Svensson PJ, Dahlback B, et al. Factor V Q506 mutation (activated protein C resistance) associated with reduced intrapartum blood loss--a possible evolutionary selection mechanism. Thromb Haemost. Jan. 1998;79:69-73. X-4. [pmid: 9459326].
328 MacLeod J, Rhode R. Retrospective follow-up of maternal deaths and their associated risk factors in a rural district of Tanzania. Trop Med Int Health. Feb. 1998;3:130-7. X-2, X-4. [pmid: 9537275].
329 Malone FD, Kaufman GE, Chelmow D, et al. Maternal morbidity associated with triplet pregnancy. Am J Perinatol. Jan. 1998;15:73-7. X-4. [pmid: 9475692].
330 Martindale EA, Subiris JF, Wake CR. Severe secondary postpartum haemorrhage successfully managed by vaginal myomectomy. J Obstet Gynaecol. Jul. 1998;18(4):380-1. X-4, X-5. [pmid: 15512116].
331 Mattera CJ. Emergency childbirth: part two of a two-part series: deliveries, complications and post-delivery care. JEMS: Journal of Emergency Medical Services. 1998;23:60-4. 6. 70. 2-4 passim. PMID:. X-1, X-4.
332 Mazor M, Hershkovitz R, Bashiri A, et al. Meconium stained amniotic fluid in preterm delivery is an independent risk factor for perinatal complications. Eur J Obstet Gynecol Reprod Biol. Oct. 1998;81:9-13. X-4. [pmid: 9846706].
333 Morey SS. ACOG releases report on risk factors, causes and management of postpartum hemorrhage. Am Fam Physician. Sep. 15. 1998;58:1002. 4. X-1. [pmid: 9767732].
334 Nkyekyer K. Arrival in the labour ward in second stage of labour--any prognostic significance?. East Afr Med J. May. 1998;75:282-7. X-2, X-4. [pmid: 9746999].
335 O'Brien P, El-Refaey H, Gordon A, et al. Rectally administered misoprostol for the treatment of postpartum hemorrhage unresponsive to oxytocin and ergometrine: a descriptive study. Obstet Gynecol. Aug. 1998;92:212-4. X-4, X-5. [pmid: 9699753].
336 Odent M. Don't manage the third stage of labour!... reprinted from The Practising Midwife, September 1998, vol. 1, no. 9. Midwifery Today. 1998:39-40. X-1.
337 Oei PL, Chua S, Tan L, et al. Arterial embolization for bleeding following hysterectomy for intractable postpartum hemorrhage. Int J Gynaecol Obstet. Jul. 1998;62:83-6. X-5. [pmid: 9722131].
338 Orlikowski CE, Rocke DA. The coagulopathic parturient: anesthetic management. Anesthesiology Clinics of North America. 1998;16:349-73. X-1.
339 Pelage JP, Le Dref O, Mateo J, et al. Life-threatening primary postpartum hemorrhage: treatment with emergency selective arterial embolization. Radiology. Aug. 1998;208:359-62. X-5. [pmid: 9680559].
340 Ransom SB, Fundaro G, Dombrowski MP. The cost-effectiveness of routine type and screen admission testing for expected vaginal delivery. Obstet Gynecol. Oct. 1998;92:493-5. X-4. [pmid: 9764617].
341 Ries LT, Kopelman JN, Macri CI. Evaluation of routine antepartum and postpartum blood counts. J Reprod Med. Jul. 1998;43:581-5. X-4. [pmid: 9693408].
342 Robinson J. Maternal deaths -- thrombosis the main killer... the maternal death enquiry report. AIMS Journal. 1998;10:15-6. X-1, X-4, X-5.
343 Rogers J, Wood J, McCandlish R, et al. Active versus expectant management of third stage of labour: the Hinchingbrooke randomised controlled trial. Lancet. Mar. 7. 1998;351:693-9. X-4. [pmid: 9504513].
344 Ronsmans C, Vanneste AM, Chakraborty J, et al. Decline in maternal mortality in Matlab, Bangladesh: a cautionary tale. Lancet. Dec. 20-27. 1998;350:1810-4. X-2. [pmid: 9428252].
345 Roungsipragarn R, Herabutya Y. Shoulder dystocia: fifteen years' experience in Ramathibodi Hospital. J Med Assoc Thai. Nov. 1998;81:821-3. X-2, X-4. [pmid: 9803079].
346 Singh K, Fong YF, Arulkumaran S. Anaemia in pregnancy--a cross-sectional study in Singapore. Eur J Clin Nutr. Jan. 1998;52:65-70. X-4. [pmid: 9481535].
347 Solymoss S. Postpartum acquired factor VIII inhibitors: results of a survey. Am J Hematol. Sep. 1998;59:1-4. X-2, X-4, X-5. [pmid: 9723568].
348 Tang LC, Kwok AC, Wong AY, et al. Critical care in obstetrical patients: an eight-year review. Chin Med J (Engl). Dec. 1998;110:936-41. X-2, X-4. [pmid: 9772406].
349 Templeton A. Misoprostol for all?. Br J Obstet Gynaecol. Sep. 1998;105:937-9. X-1, X-4, X-5. [pmid: 9763042].
350 Vaarst M, Hindhede J, Enevoldsen C. Sole disorders in conventionally managed and organic dairy herds using different housing systems. J Dairy Res. May. 1998;65:175-86. X-3, X-4. [pmid: 9627837].
351 van Dongen PW, Verbruggen MM, de Groot AN, et al. Ascending dose tolerance study of intramuscular carbetocin administered after normal vaginal birth. Eur J Obstet Gynecol Reprod Biol. Apr. 1998;77:181-7. X-4, X-5. [pmid: 9578276].
352 Williams-Judge S. Managing postpartum hemorrhage. Mother Baby Journal. 1998;3:5. X-1.
353 Zaki ZM, Bahar AM, Ali ME, et al. Risk factors and morbidity in patients with placenta previa accreta compared to placenta previa non-accreta. Acta Obstet Gynecol Scand. Apr. 1998;77:391-4. X-2, X-4, X-5. [pmid: 9598946].
354 Case lessons. Mother dies of postpartum hemorrhage after attending doubts junior resident: $5 million settlement. OB-GYN Malpractice Prevention. 1999;6:20. X-1, X-4.
355 Amant F, Spitz B, Timmerman D, et al. Misoprostol compared with methylergometrine for the prevention of postpartum haemorrhage: a double-blind randomised trial. Br J Obstet Gynaecol. Oct. 1999;106:1066-70. X-4, X-5. [pmid: 10519433].
356 Anderson T. Prophylactic syntometrine vs oxytocin in the third stage of labour. Pract Midwife. Oct. 1999;1:40-1. X-1, X-4. [pmid: 10026588].
357 Babinszki A, Kerenyi T, Torok O, et al. Perinatal outcome in grand and great-grand multiparity: effects of parity on obstetric risk factors. Am J Obstet Gynecol. Sep. 1999;181:669-74. X-4, X-5. [pmid: 10486482].
358 Chandramohan D, Rodrigues LC, Maude GH, et al. The validity of verbal autopsies for assessing the causes of institutional maternal death. Stud Fam Plann. Dec. 1999;29:414-22. X-1, X-2, X-4. [pmid: 9919634].
359 Chowdhury BR. Unusual presentation of non-puerperal uterine inversion: A case report. Bangladesh Journal of Obstetrics and Gynecology. 1999;14:78-80. X-2, X-3, X-4.
360 Dansereau J, Joshi AK, Helewa ME, et al. Double-blind comparison of carbetocin versus oxytocin in prevention of uterine atony after cesarean section. Am J Obstet Gynecol. Mar. 1999;180:670-6. X-3, X-4. [pmid: 10076146].
361 Davidson MRM. Outcomes of nurse midwifery care in a high-risk population. George Mason University. 1999.
362 Dobson LS, Gillespie AM, Coleman RE, et al. The presentation and management of post-partum choriocarcinoma. Br J Cancer. Mar. 1999;79:1531-3. X-4, X-5. [pmid: 10188902].
363 Featherstone IE. Clinical. Physiological third stage of labour. British Journal of Midwifery. 1999;7:216-21. X-1, X-4.
364 Hansch E, Chitkara U, McAlpine J, et al. Pelvic arterial embolization for control of obstetric hemorrhage: a five-year experience. Am J Obstet Gynecol. Jun. 1999;180:1454-60. X-5. [pmid: 10368488].
365 Hoj L, Stensballe J, Aaby P. Maternal mortality in Guinea-Bissau: the use of verbal autopsy in a multi-ethnic population. Int J Epidemiol. Feb. 1999;28:70-6. X-2, X-4. [pmid: 10195667].
366 Jain KA, Olcott EW. Magnetic resonance imaging of postpartum pelvic hematomas: early experience in diagnosis and treatment planning. Magn Reson Imaging. Sep. 1999;17:973-7. X-4, X-5. [pmid: 10463646].
367 Juul SE, Stallings SA, Christensen RD. Erythropoietin in the cerebrospinal fluid of neonates who sustained CNS injury. Pediatr Res. Nov. 1999;46:543-7. X-3, X-4. [pmid: 10541316].
368 Kovavisarach E, Varanuntakul T. Neonatal and maternal complications among pregnant women delivered by vacuum extraction or forceps extraction. J Med Assoc Thai. Apr. 1999;82:319-24. X-2, X-4. [pmid: 10410490].
369 Krivak TC, Drewes P, Horowitz GM. Kielland vs. nonrotational forceps for the second stage of labor. J Reprod Med. Jun. 1999;44:511-7. X-4. [pmid: 10394545].
370 Lee CA. Women and von Willebrand disease. Haemophilia. May. Suppl 2. 1999;5:38-45. X-1. [pmid: 23401898].
371 Lind B, Thorsen S. A novel missense mutation in the human plasmin inhibitor (alpha2-antiplasmin) gene associated with a bleeding tendency. Br J Haematol. Nov. 1999;107:317-22. X-4. [pmid: 10583218].
372 Lindqvist PG, Svensson PJ, Marsaal K, et al. Activated protein C resistance (FV:Q506) and pregnancy. Thromb Haemost. Apr. 1999;81:532-7. X-3, X-4. [pmid: 10235434].
373 Mahutte NG, Murphy-Kaulbeck L, Le Q, et al. Obstetric admissions to the intensive care unit. Obstet Gynecol. Aug. 1999;94:263-6. X-2, X-4, X-5. [pmid: 10432140].
374 Makhseed M, Musini VM, Hassan NA, et al. Post-invasion change in the trend of complications and outcome of pregnancy in Maternity Hospital Kuwait from 1981 to 1995. Med Confl Surviv. Apr-Jun. 1999;15:161-70. X-2, X-4. [pmid: 10371871].
375 Manor M, Blickstein I, Ben-Arie A, et al. Case series of labor induction in twin gestations with an Intrauterine Balloon catheter. Gynecol Obstet Invest. 1999;47:244-6. X-3, X-4. [pmid: 10352385].
376 Nishimoto K, Shiiki H, Nishino T, et al. Glomerular hypertrophy in preeclamptic patients with focal segmental glomerulosclerosis. A morphometric analysis. Clin Nephrol. Apr. 1999;51:209-19. X-3, X-4. [pmid: 10230553].
377 Palacios Jaraquemada JM. Selective vascular ligation versus embolization in obstetric hemorrhage. Radiology. Mar. 1999;210:876-8. X-1, X-2, X-4, X-5. [pmid: 10207497].
378 Pelage JP, Le Dref O, Jacob D, et al. Selective arterial embolization of the uterine arteries in the management of intractable post-partum hemorrhage. Acta Obstet Gynecol Scand. Sep. 1999;78:698-703. X-4, X-5. [pmid: 10468062].
379 Pelage JP, Soyer P, Repiquet D, et al. Secondary postpartum hemorrhage: treatment with selective arterial embolization. Radiology. Aug. 1999;212:385-9. X-5. [pmid: 10429694].
380 Pettila V, Kaaja R, Leinonen P, et al. Thromboprophylaxis with low molecular weight heparin (dalteparin) in pregnancy. Thromb Res. Nov. 15. 1999;96:275-82. X-4, X-5. [pmid: 10593430].
381 Prentice-Bjerkeseth R. Perioperative anesthetic management of trauma in pregnancy. Anesthesiology Clinics of North America. 1999;17:277-94. X-1.
382 Robinson J. Managing the third stage. AIMS Journal. 1999;11:4-6. X-1.
383 Santagostino E, Gringeri A, Mannucci PM. Home treatment with recombinant activated factor VII in patients with factor VIII inhibitors: the advantages of early intervention. Br J Haematol. Jan. 1999;104:22-6. X-3, X-4. [pmid: 10027707].
384 Schonholz DH. Blood transfusion and the pregnant Jehovah's witness patient: avoiding a dilemma. Mt Sinai J Med. Sep. 1999;66:277-9. X-1. [pmid: 10477484].
385 Sherer DM, Onyeije CI, Bernstein PS, et al. Utilization of real-time ultrasound on labor and delivery in an active academic teaching hospital. Am J Perinatol. 1999;16:303-7. X-4. [pmid: 10586984].
386 Stevenson J. Midwifery guidelines. Midwifery Matters. 1999:32-4. X-1.
387 Suleiman AB, Mathews A, Jegasothy R, et al. A strategy for reducing maternal mortality. Bull World Health Organ. 1999;77:190-3. X-2. [pmid: 10083722].
388 Surbek DV, Fehr PM, Hosli I, et al. Oral misoprostol for third stage of labor: a randomized placebo-controlled trial. Obstet Gynecol. Aug. 1999;94:255-8. X-4, X-5. [pmid: 10432138].
389 Swaim LS, Perriatt S, Andres RL, et al. Clinical utility of routine postpartum hemoglobin determinations. Am J Perinatol. 1999;16:333-7. X-4. [pmid: 10614700].
390 Szal SE, Croughan-Minihane MS, Kilpatrick SJ. Effect of magnesium prophylaxis and preeclampsia on the duration of labor. Am J Obstet Gynecol. Jun. 1999;180:1475-9. X-4. [pmid: 10368493].
391 Taylor-Adams S, Vincent C, Stanhope N. Applying human factors methods to the investigation and analysis of clinical adverse events. Safety Science. March. 1999;31:143-59. X-1.
392 Whitehead A, Bailey AJ, Elbourne D. Combining summaries of binary outcomes with those of continuous outcomes in a meta-analysis. J Biopharm Stat. Mar. 1999;9:1-16. X-1, X-5. [pmid: 10091907].
393 Wong SF, Ho LC. Labour outcome of low-risk multiparas of 40 years and older. A case-control study. Aust N Z J Obstet Gynaecol. Nov. 1999;38:388-90. X-4. [pmid: 9890215].
394 Wu YC, Ho CM, Tsou MY, et al. Successful management of malignant hyperthermia susceptibility during cesarean hysterectomy for postpartum hemorrhage. Acta Obstet Gynecol Scand. Sep. 1999;78:738-9. X-2, X-4, X-5. [pmid: 10468070].
395 Yin CS, Lee YT, Chan CC, et al. Severe delayed postpartum hemorrhage following cesarean section. Tzu Chi Medical Journal. 1999;11:93-6. X-2, X-4, X-5.
396 A review of maternal deaths in South Africa during 1998. National Committee on Confidential Enquiries into Maternal Deaths. S Afr Med J. Apr. 2000;90:367-73. X-1, X-2, X-4. [pmid: 10957921].
397 Al Sakka M, Dauleh W, Al Hassani S. Case series of uterine rupture and subsequent pregnancy outcome. Int J Fertil Womens Med. Nov-Dec. 2000;44:297-300. X-5. [pmid: 10617251].
398 Allaire AD, Moos MK, Wells SR. Complementary and alternative medicine in pregnancy: a survey of North Carolina certified nurse-midwives. Obstet Gynecol. Jan. 2000;95:19-23. X-4, X-5. [pmid: 10636495].
399 Ascher-Walsh C, Tharakan T, Baxi L. Is induction of labor with continuous release dinoprostone vaginal pessary a viable option in patients with preeclampsia?. Prim Care Update Ob Gyns. Jul. 1. 2000;5:183. X-3, X-4. [pmid: 10838342].
400 Aso S, Ehara H, Anai M, et al. Effects on growth of rat offspring born from dams treated subcutaneously with a surfactant, polyoxyethylene(10)nonylphenyl ether(NP-10), during lactational period. J Toxicol Sci. Dec. Suppl 2. 2000;24:129-40. X-3. [pmid: 10664960].
401 Atalla RK, Thompson JR, Oppenheimer CA, et al. Reactive thrombocytosis after caesarean section and vaginal delivery: implications for maternal thromboembolism and its prevention. BJOG. Mar. 2000;107:411-4. X-3, X-4. [pmid: 10740340].
402 Azeez Pasha SA, Kooheji AJ, Azeez A. Anesthetic management of peripartum hemorrhage. Seminars in Anesthesia, Perioperative Medicine & Pain. 2000;19:225-36. X-1, X-4, X-5.
403 Bangerter M, Guthner C, Beneke H, et al. Pregnancy in essential thrombocythaemia: treatment and outcome of 17 pregnancies. Eur J Haematol. Sep. 2000;65:165-9. X-3. [pmid: 11007051].
404 Bowers D, Cohen WR. Obesity and related pregnancy complications in an inner-city clinic. J Perinatol. Apr-May. 2000;19:216-9. X-4. [pmid: 10685225].
405 Calhoun BC, Jennings BM, Peniston J, et al. Focused obstetrical clinic for active duty junior enlisted service women: model for improved outcomes. Mil Med. Jan. 2000;165:45-8. X-4, X-5. [pmid: 10658428].
406 Cho JH, Jun HS, Lee CN. Hemostatic suturing technique for uterine bleeding during cesarean delivery. Obstet Gynecol. Jul. 2000;96:129-31. X-2, X-5. [pmid: 10928901].
407 Clements C. Changing practice. Critical incident analysis of the third stage of labour. British Journal of Midwifery. 2000;8:500-4. X-1.
408 Conde-Agudelo A, Belizan JM. Maternal morbidity and mortality associated with interpregnancy interval: cross sectional study. BMJ. Nov. 18. 2000;321:1255-9. X-2, X-4. [pmid: 11082085].
409 Conde-Agudelo A, Belizan JM, Lindmark G. Maternal morbidity and mortality associated with multiple gestations. Obstet Gynecol. Jun. 2000;95:899-904. X-2, X-4. [pmid: 10831988].
410 Cook CM, Spurrett B, Murray H. A randomized clinical trial comparing oral misoprostol with synthetic oxytocin or syntometrine in the third stage of labour. Aust N Z J Obstet Gynaecol. Nov. 2000;39:414-9. X-4. [pmid: 10687755].
411 De Reu PA, Nijhuis JG, Oosterbaan HP, et al. Perinatal audit on avoidable mortality in a Dutch rural region: a retrospective study. Eur J Obstet Gynecol Reprod Biol. Jan. 2000;88:65-9. X-3. [pmid: 10659919].
412 Dewerchin M, Liang Z, Moons L, et al. Blood coagulation factor X deficiency causes partial embryonic lethality and fatal neonatal bleeding in mice. Thromb Haemost. Feb. 2000;83:185-90. X-3, X-4. [pmid: 10739370].
413 Dweck MF, Lynch CM, Spellacy WN. Use of methergine for the prevention of postoperative endometritis in non-elective cesarean section patients. Infect Dis Obstet Gynecol. 2000;8:151-4. X-3, X-4. [pmid: 10968597].
414 Ellison J, Walker ID, Greer IA. Antenatal use of enoxaparin for prevention and treatment of thromboembolism in pregnancy. BJOG. Sep. 2000;107:1116-21. X-4. [pmid: 11002955].
415 El-Refaey H, Nooh R, O'Brien P, et al. The misoprostol third stage of labour study: a randomised controlled comparison between orally administered misoprostol and standard management. BJOG. Sep. 2000;107:1104-10. X-4. [pmid: 11002953].
416 Etuk SJ, Itam IH, Asuquo EE. Morbidity and mortality in booked women who deliver outside orthodox health facilities in Calabar, Nigeria. Acta Trop. May. 31. 2000;75:309-13. X-2, X-4. [pmid: 10838214].
417 Etuk SJ, Itam IH, Asuquo EE. Role of the spiritual churches in antenatal clinic default in Calabar, Nigeria. East Afr Med J. Nov. 2000;76:639-43. X-2, X-4. [pmid: 10734525].
418 Faisel H, Pittrof R. Vitamin A and causes of maternal mortality: association and biological plausibility. Public Health Nutr. Sep. 2000;3:321-7. X-1. [pmid: 10979152].
419 Feerasta SH, Motiei A, Motiwala S, et al. Uterine atony at a tertiary care hospital in Pakistan: a risk factor analysis. J Pak Med Assoc. Apr. 2000;50:132-6. X-2, X-3, X-4. [pmid: 10851836].
420 Font F, Alonso Gonzalez M, Nathan R, et al. Maternal mortality in a rural district of southeastern Tanzania: an application of the sisterhood method. Int J Epidemiol. Feb. 2000;29:107-12. X-2, X-4. [pmid: 10750611].
421 Giacalone PL, Vignal J, Daures JP, et al. A randomised evaluation of two techniques of management of the third stage of labour in women at low risk of postpartum haemorrhage. BJOG. Mar. 2000;107:396-400. X-4. [pmid: 10740337].
422 Huang YY, Ting MK, Hsu BR, et al. Demonstration of reserved anterior pituitary function among patients with amenorrhea after postpartum hemorrhage. Gynecol Endocrinol. Apr. 2000;14:99-104. X-2, X-5. [pmid: 10836196].
423 Jamila B, Jabeen F. Bilateral uterine artery ligation for control of obstetric haemorrhage and an alternative to hysterectomy. JK Practitioner. 2000;7:208-9. X-4.
424 Jolly M, Sebire N, Harris J, et al. The risks associated with pregnancy in women aged 35 years or older. Hum Reprod. Nov. 2000;15:2433-7. X-4, X-5. [pmid: 11056148].
425 Kabir MZ, Chowdhury MAA, Rahman MH, et al. Pregnancy related acute renal failure - Still a major problem. Bangladesh Journal of Obstetrics and Gynecology. 2000;15:52-8. X-2, X-4.
426 Lawal AN. Pregnancy outcome in grandmultiparous women in Lagos University Teaching Hospital (LUTH). West African Journal of Nursing. 2000;11:53-60. X-1, X-2, X-3, X-4.
427 Livingstone VH, Willis CE, Abdel-Wareth LO, et al. Neonatal hypernatremic dehydration associated with breast-feeding malnutrition: a retrospective survey. CMAJ. Mar. 7. 2000;162:647-52. X-2, X-4, X-5. [pmid: 10738450].
428 Lydon-Rochelle M, Holt VL, Martin DP, et al. Association between method of delivery and maternal rehospitalization. JAMA. May. 10. 2000;283:2411-6. X-4. [pmid: 10815084].
429 Maymon R, Sehmi IK, Herman A, et al. Serum inhibin A levels in pregnant women with systemic lupus erythematosus or antiphospholipid syndrome. Prenat Diagn. Jan. 2000;20:12-6. X-3, X-4. [pmid: 10701844].
430 Munim S, Rahbar MH, Rizvi M, et al. The effect of grandmultiparity on pregnancy related complications: the Aga Khan University experience. J Pak Med Assoc. Feb. 2000;50:54-8. X-2, X-4. [pmid: 10769523].
431 Nielsen PE, Thomson BA, Jackson RB, et al. Standard obstetric record charting system: evaluation of a new electronic medical record. Obstet Gynecol. Dec. 2000;96:1003-8. X-3, X-4. [pmid: 11084193].
432 Otigbah CM, Dhanjal MK, Harmsworth G, et al. A retrospective comparison of water births and conventional vaginal deliveries. Eur J Obstet Gynecol Reprod Biol. Jul. 2000;91:15-20. X-4. [pmid: 10817872].
433 Panchal S, Arria AM, Harris AP. Intensive care utilization during hospital admission for delivery: prevalence, risk factors, and outcomes in a statewide population. Anesthesiology. Jun. 2000;92:1537-44. X-4, X-5. [pmid: 10839902].
434 Quddusi H, Baloch SN. Intrarectal prostaglandin in the management of postpartum hemorrhage. Pakistan Journal of Medical Sciences. 2000;16:242-5. X-2, X-4.
435 Remijn MR, Finch JA, Gordon AC, et al. Placenta accreta leading to severe post partum haemorrhage controlled by selective iliac artery branch embolisation. Care of the Critically Ill. 2000;16:189-91. X-1, X-4, X-5.
436 Robson J. Obstetric hysterectomy -- an alarming report. AIMS Journal. 2000;12:18. X-1.
437 Sadler LC, Davison T, McCowan LM. A randomised controlled trial and meta-analysis of active management of labour. BJOG. Jul. 2000;107:909-15. X-4. [pmid: 10901564].
438 Saunders GK, Blodgett DJ, Hutchins TA, et al. Suspected citrus pulp toxicosis in dairy cattle. J Vet Diagn Invest. May. 2000;12:269-71. X-1, X-3, X-4. [pmid: 10826844].
439 Schuurmans N, MacKinnon C, Lane C, Etches D. Prevention and management of postpartum haemorrhage. J Soc Obstet Gynaecol Can. 2000;22(4):271-81. X-1.
440 Scott TD, Flora R, Deveny TC. Elective repeat cesarean delivery vs trial of labor: a comparison of morbidities in a community hospital setting. Prim Care Update Ob Gyns. Jul. 1. 2000;5:188. X-4. [pmid: 10838354].
441 Selcuk NY, Odabas AR, Cetinkaya R, et al. Outcome of pregnancies with HELLP syndrome complicated by acute renal failure (1989-1999). Ren Fail. May. 2000;22:319-27. X-2, X-4, X-5. [pmid: 10843242].
442 Sivalingam N, Looi KW. Clinical experience with management of “near-miss” cases in obstetrics. Med J Malaysia. Dec. 2000;54:496-503. X-2, X-4, X-5. [pmid: 11072469].
443 Slawson D. Is oral misoprostol effective in minimizing blood loss in the third stage of labor?. Evidence-Based Practice. 2000;3:7-8. 2p. PMID:. X-1, X-4.
444 Song SQ, Zhang GN, Wu YL, et al. A case of mammary metastasis from choriocarcinoma. Chinese Journal of Cancer Research. 2000;12:151. X-1.
445 Velling TE, Brennan FJ, Hall LD, et al. Role of the interventional radiologist in treating obstetric-gynecologic pathology. AJR Am J Roentgenol. Nov. 2000;175:1273-8. X-1, X-4, X-5. [pmid: 11044021].
446 Wagaarachchi PT, Fernando L. Fertility following ligation of internal iliac arteries for life-threatening obstetric haemorrhage: case report. Hum Reprod. Jun. 2000;15:1311-3. X-2, X-5. [pmid: 10831561].
447 Walley RL, Wilson JB, Crane JM, et al. A double-blind placebo controlled randomised trial of misoprostol and oxytocin in the management of the third stage of labour. BJOG. Sep. 2000;107:1111-5. X-2, X-4. [pmid: 11002954].
448 Witlin AG, Mattar F, Sibai BM. Postpartum stroke: a twenty-year experience. Am J Obstet Gynecol. Jul. 2000;183:83-8. X-3, X-4. [pmid: 10920313].
449 Wolman I, Gordon D, Yaron Y, et al. Transvaginal sonohysterography for the evaluation and treatment of retained products of conception. Gynecol Obstet Invest. 2000;50:73-6. X-4, X-5. [pmid: 10965186].
450 Wong WC, Kun KY, Tai CM. Emergency obstetric hysterectomies for postpartum haemorrhage. J Obstet Gynaecol Res. Dec. 2000;25:425-30. X-5. [pmid: 10680341].
451 Yaegashi N, Chiba-Sekii A, Okamura K. Emergency postpartum hysterectomy in women with placenta previa and prior cesarean section. Int J Gynaecol Obstet. Jan. 2000;68:49-52. X-2, X-4, X-5. [pmid: 10687838].
452 Ynag W, Shen Z. Acute fatty liver of pregnancy: an experience in diagnosis and management of eight cases. Prim Care Update Ob Gyns. Jul. 1. 2000;5:191. X-2, X-4, X-5. [pmid: 10838362].
453 Anna's story. Midwifery Matters. 2001:9-11. X-1, X-4.
454 $7.6 million verdict: mother hemorrhages, dies of ARDS 2 months postpartum. OB-GYN Malpractice Prevention. 2001;8:85. X-1, X-4.
455 Abdel-Aleem H, El-Nashar I, Abdel-Aleem A. Management of severe postpartum hemorrhage with misoprostol. Int J Gynaecol Obstet. Jan. 2001;72:75-6. X-1, X-2, X-4, X-5. [pmid: 11146081].
456 Acharya G, Al-Sammarai MT, Patel N, et al. A randomized, controlled trial comparing effect of oral misoprostol and intravenous syntocinon on intra-operative blood loss during cesarean section. Acta Obstet Gynecol Scand. Mar. 2001;80:245-50. X-4. [pmid: 11207490].
457 Bais JM, van der Borden DM, Pel M, et al. Vaginal birth after caesarean section in a population with a low overall caesarean section rate. Eur J Obstet Gynecol Reprod Biol. Jun. 2001;96:158-62. X-4. [pmid: 11384799].
458 Bakri YN, Amri A, Abdul Jabbar F. Tamponade-balloon for obstetrical bleeding. Int J Gynaecol Obstet. Aug. 2001;74:139-42. X-2, X-4, X-5. [pmid: 11502292].
459 Banatvala N, Griffin PM, Greene KD, et al. The United States National Prospective Hemolytic Uremic Syndrome Study: microbiologic, serologic, clinical, and epidemiologic findings. J Infect Dis. Apr. 1. 2001;183:1063-70. X-1, X-4. [pmid: 11237831].
460 Batukan C, Holzgreve W, Danzer E, et al. Large placental chorioangioma as a cause of sudden intrauterine fetal death. A case report. Fetal Diagn Ther. Nov-Dec. 2001;16:394-7. X-1. [pmid: 11694744].
461 Ben-Aroya Z, Yochai D, Silberstein T, et al. Oxytocin use in grand-multiparous patients: safety and complications. J Matern Fetal Med. Oct. 2001;10:328-31. X-4. [pmid: 11730496].
462 Bouvier-Colle MH, Ould El Joud D, Varnoux N, et al. Evaluation of the quality of care for severe obstetrical haemorrhage in three French regions. Bjog. Sep. 2001;108:898-903. X-4, X-5. [pmid: 11563457].
463 Bugalho A, Daniel A, Faundes A, et al. Misoprostol for prevention of postpartum hemorrhage. Int J Gynaecol Obstet. Apr. 2001;73:1-6. X-2, X-4, X-5. [pmid: 11336714].
464 Bukowski R, Hankins GDV. Managing postpartum hemorrhage. Contemporary OB/GYN. 2001;46:92-102. X-1, X-2, X-4, X-5.
465 Chan SM, Nelson EA, Leung SS, et al. Postnatal iron status of Hong Kong Chinese women in a longitudinal study of maternal nutrition. Eur J Clin Nutr. Jul. 2001;55:538-46. X-2, X-4. [pmid: 11464227].
466 Chen CL, Cheng Y, Wang PH, et al. Review of pre-eclampsia in Taiwan: a multi-institutional study. Zhonghua Yi Xue Za Zhi (Taipei). Dec. 2001;63:869-75. X-2, X-3, X-4. [pmid: 11195137].
467 Descargues G, Douvrin F, Degre S, et al. Abnormal placentation and selective embolization of the uterine arteries. Eur J Obstet Gynecol Reprod Biol. Nov. 2001;99:47-52. X-2, X-5. [pmid: 11604185].
468 Deux JF, Bazot M, Le Blanche AF, et al. Is selective embolization of uterine arteries a safe alternative to hysterectomy in patients with postpartum hemorrhage?. AJR Am J Roentgenol. Jul. 2001;177:145-9. X-4, X-5. [pmid: 11418416].
469 El-Sherbiny MT, El-Gharieb IH, Gewely HA. Vaginal misoprostol for induction of labor: 25 vs. 50 microg dose regimen. Int J Gynaecol Obstet. Jan. 2001;72:25-30. X-4. [pmid: 11146073].
470 Engelsen IB, Albrechtsen S, Iversen OE. Peripartum hysterectomy-incidence and maternal morbidity. Acta Obstet Gynecol Scand. May. 2001;80:409-12. X-4, X-5. [pmid: 11328216].
471 Galaal KA, Krolikowski A. A randomized controlled study of peritoneal closure at cesarean section. Saudi Med J. Aug. 2001;21:759-61. X-2, X-4. [pmid: 11423890].
472 Gardella C, Taylor M, Benedetti T, et al. The effect of sequential use of vacuum and forceps for assisted vaginal delivery on neonatal and maternal outcomes. Am J Obstet Gynecol. Oct. 2001;185:896-902. X-4. [pmid: 11641674].
473 Gerstenfeld TS, Wing DA. Rectal misoprostol versus intravenous oxytocin for the prevention of postpartum hemorrhage after vaginal delivery. Am J Obstet Gynecol. Oct. 2001;185:878-82. X-2, X-4, X-5. [pmid: 11641670].
474 Gulmezoglu AM, Villar J, Ngoc NT, et al. WHO multicentre randomised trial of misoprostol in the management of the third stage of labour. Lancet. Sep. 1. 2001;358:689-95. X-2, X-4, X-5. [pmid: 11551574].
475 Harris T. Evidence-based care. Changing the focus for the third stage of labour. British Journal of Midwifery. 2001;9:7-12. X-1.
476 Hassouna A, Allam H. Oral anticoagulation therapy during pregnancy in patients with mechanical mitral valves: a prospective study. Cardiovasc Surg. Oct. 2001;9:478-81. X-2, X-4, X-5. [pmid: 11489653].
477 Hazelgrove JF, Price C, Pappachan VJ, et al. Multicenter study of obstetric admissions to 14 intensive care units in southern England. Crit Care Med. Apr. 2001;29:770-5. X-3, X-4. [pmid: 11373467].
478 Hofmeyr GJ, Nikodem VC, de Jager M, et al. Side-effects of oral misoprostol in the third stage of labour--a randomised placebo-controlled trial. S Afr Med J. May. 2001;91:432-5. X-2, X-4. [pmid: 11455810].
479 Jackson KW Jr., Allbert JR, Schemmer GK, et al. A randomized controlled trial comparing oxytocin administration before and after placental delivery in the prevention of postpartum hemorrhage. Am J Obstet Gynecol. Oct. 2001;185:873-7. X-4, X-5. [pmid: 11641669].
480 Johanson R, Kumar M, Obhrai M, et al. Management of massive postpartum haemorrhage: use of a hydrostatic balloon catheter to avoid laparotomy. Bjog. Apr. 2001;108:420-2. X-5. [pmid: 11305551].
481 Kuller JA, D'Andrea NM, McMahon MJ. Renal biopsy and pregnancy. Am J Obstet Gynecol. May. 2001;184:1093-6. X-3, X-4. [pmid: 11349167].
482 Kundodyiwa TW, Majoko F, Rusakaniko S. Misoprostol versus oxytocin in the third stage of labor. Int J Gynaecol Obstet. Dec. 2001;75:235-41. X-2, X-4. [pmid: 11728483].
483 Lak M, Peyvandi F, Mannucci PM. Clinical manifestations and complications of childbirth and replacement therapy in 385 Iranian patients with type 3 von Willebrand disease. Br J Haematol. Dec. 2001;111:1236-9. X-2, X-4. [pmid: 11167767].
484 Lamont RF, Morgan DJ, Logue M, et al. A prospective randomised trial to compare the efficacy and safety of hemabate and syntometrine for the prevention of primary postpartum haemorrhage. Prostaglandins Other Lipid Mediat. Oct. 2001;66:203-10. X-4, X-5. [pmid: 11577783].
485 Lokugamage AU, Sullivan KR, Niculescu I, et al. A randomized study comparing rectally administered misoprostol versus Syntometrine combined with an oxytocin infusion for the cessation of primary post partum hemorrhage. Acta Obstet Gynecol Scand. Sep. 2001;80:835-9. X-2, X-5. [pmid: 11531635].
486 Lugina HI, Christensson K, Massawe S, et al. Change in maternal concerns during the 6 weeks postpartum period: a study of primaparous mothers in Dar es Salaam, Tanzania. J Midwifery Womens Health. Jul-Aug. 2001;46:248-57. X-2, X-3, X-4. [pmid: 11603640].
487 Mantel GD, Moodley J. Can a developed country's maternal mortality review be used as the ‘gold standard’ for a developing country?. Eur J Obstet Gynecol Reprod Biol. Jan. 10. 2001;100:189-95. X-1, X-2, X-4. [pmid: 11750963].
488 Munn MB, Owen J, Vincent R, et al. Comparison of two oxytocin regimens to prevent uterine atony at cesarean delivery: a randomized controlled trial. Obstet Gynecol. Sep. 2001;98:386-90. X-4. [pmid: 11530117].
489 Myles T. Vaginal birth of twins after a previous Cesarean section. J Matern Fetal Med. Jun. 2001;10:171-4. X-4. [pmid: 11444785].
490 Nagaraja D, Taly AB, Haridas VT, et al. Heparin in haemorrhagic infarction in cerebral venous sinus thrombosis. J Assoc Physicians India. Aug. 2001;46:706-7. X-1, X-4. [pmid: 11229279].
491 Nasrat HA, Youssef MH, Marzoogi A, et al. “Near miss” obstetric morbidity in an inner city hospital in Saudi Arabia. East Mediterr Health J. Jul. 2001;5:717-26. X-2, X-3, X-4. [pmid: 11338695].
492 Ng PS, Chan AS, Sin WK, et al. A multicentre randomized controlled trial of oral misoprostol and i.m. syntometrine in the management of the third stage of labour. Hum Reprod. Jan. 2001;16:31-5. X-4. [pmid: 11139532].
493 Olatunji AO, Sule-Odu AO. Maternal mortality at Sagamu, Nigeria--a ten year review (1988 - 1997). Niger Postgrad Med J. Mar. 2001;8:12-5. X-2, X-4. [pmid: 11487777].
494 Panchal S, Arria AM, Labhsetwar SA. Maternal mortality during hospital admission for delivery: a retrospective analysis using a state-maintained database. Anesth Analg. Jul. 2001;93:134-41. X-4, X-5. [pmid: 11429354].
495 Ravid D, Gidoni Y, Bruchim I, et al. Postpartum chills phenomenon: is it a feto-maternal transfusion reaction?. Acta Obstet Gynecol Scand. Feb. 2001;80:149-51. X-3, X-4. [pmid: 11167210].
496 Read JS, Tuomala R, Kpamegan E, et al. Mode of delivery and postpartum morbidity among HIV-infected women: the women and infants transmission study. J Acquir Immune Defic Syndr. Mar. 1. 2001;26:236-45. X-3, X-4. [pmid: 11242196].
497 Robson S, Chan A, Keane RJ, et al. Subsequent birth outcomes after an unexplained stillbirth: preliminary population-based retrospective cohort study. Aust N Z J Obstet Gynaecol. Feb. 2001;41:29-35. X-3, X-4. [pmid: 11284643].
498 Sebire NJ, Jolly M, Harris J, et al. Is maternal underweight really a risk factor for adverse pregnancy outcome? A population-based study in London. BJOG. Jan. 2001;108:61-6. X-4. [pmid: 11213006].
499 Sebire NJ, Jolly M, Harris JP, et al. Maternal obesity and pregnancy outcome: a study of 287,213 pregnancies in London. Int J Obes Relat Metab Disord. Aug. 2001;25:1175-82. X-4. [pmid: 11477502].
500 Sebitloane MH, Moodley J. Emergency peripartum hysterectomy. East Afr Med J. Feb. 2001;78:70-4. X-2. [pmid: 11682949].
501 Shami N, Akbar N, Asif S. An analysis of fetal and maternal morbidity and mortality in retained second twin. Medical Forum Monthly. 2001;12:18-21. X-1, X-2, X-4.
502 Singla AK, Lapinski RH, Berkowitz RL, et al. Are women who are Jehovah's Witnesses at risk of maternal death?. Am J Obstet Gynecol. Oct. 2001;185:893-5. X-4. [pmid: 11641673].
503 Stewart R, Tuazon D, Olson G, et al. Pregnancy and primary pulmonary hypertension : successful outcome with epoprostenol therapy. Chest. Mar. 2001;119:973-5. X-1, X-3, X-4. [pmid: 11243988].
504 Waterstone M, Bewley S, Wolfe C. Incidence and predictors of severe obstetric morbidity: case-control study. BMJ. May. 5. 2001;322:1089-93. discussion 93-4. X-4. [pmid: 11337436].
505 Webster AJ. Effects of housing and two forage diets on the development of claw horn lesions in dairy cows at first calving and in first lactation. Vet J. Jul. 2001;162:56-65. X-3, X-4. [pmid: 11409930].
506 Welkovic S, Costa LO, Faundes A, et al. Post-partum bleeding and infection after post-placental IUD insertion. Contraception. Mar. 2001;63:155-8. X-2, X-3, X-4. [pmid: 11368989].
507 Wen SW, Demissie K, Liu S. Adverse outcomes in pregnancies of asthmatic women: results from a Canadian population. Ann Epidemiol. Jan. 2001;11:7-12. X-4. [pmid: 11164114].
508 Wenham J, Matijevic R. Post-partum hysterectomies: revisited. J Perinat Med. 2001;29:260-5. X-4, X-5. [pmid: 11447932].
509 Yamamoto H, Sagae S, Nishikawa S, et al. Emergency postpartum hysterectomy in obstetric practice. J Obstet Gynaecol Res. Oct. 2001;26:341-5. X-4, X-5. [pmid: 11147720].
510 Yasmeen S, Wilkins EE, Field NT, et al. Pregnancy outcomes in women with systemic lupus erythematosus. J Matern Fetal Med. Apr. 2001;10:91-6. X-4. [pmid: 11392599].
511 Ziadeh S, Yahaya A. Pregnancy outcome at age 40 and older. Arch Gynecol Obstet. Mar. 2001;265:30-3. X-4. [pmid: 11327090].
512 $1 million settlement: fetus dies after preeclampsia is misdiagnosed; mother dies after refusing blood transfusion. OB-GYN Malpractice Prevention. 2002;9:84-6. X-1, X-4.
513 Blunt versus sharp expansion of the uterine incision at cesarean delivery. ACOG Clinical Review. 2002;7:4-5. X-1, X-4.
514 Misoprostol for managing the third stage of labor. ACOG Clinical Review. 2002;7:4-5. X-1, X-4.
515 Oxytocin v. misoprostol for postpartum hemorrhage. Contemporary OB/GYN. 2002;47:35. X-1.
516 Placenta accreta leads to disastrous hemorrhage. OB-GYN Malpractice Prevention. 2002;9:21-2. X-1, X-4.
517 Mothers have heavy burden in West Africa. Safe Mother. 2002;10. X-1. [pmid: 12293572].
518 Abelin Tornblom S, Ostlund E, Granstrom L, et al. Pre-term cervical ripening and labor induction. Eur J Obstet Gynecol Reprod Biol. Sep. 10. 2002;104:120-3. X-3, X-4. [pmid: 12206923].
519 Abu-Omar AA. Prevention of postpartum hemorrhage, safety and efficacy. Saudi Med J. Dec. 2002;22:1118-21. X-2, X-4. [pmid: 11802188].
520 Ahsan S, Naeem S, Ahsan A. A case notes analysis of hysterectomy performed for non-neoplastic indications at Liaquat National Hospital, Karachi. J Pak Med Assoc. Oct. 2002;51:346-9. X-2, X-3, X-4. [pmid: 11768934].
521 Alexander J, Thomas P, Sanghera J. Treatments for secondary postpartum haemorrhage. Cochrane Database Syst Rev. 2002. CD002867. X-1, X-2, X-5. [pmid: 11869640].
522 Ali AM, Abu-Heija AT. Obstetric and perinatal outcome of women para > or = 5 including one lower segment cesarean section. J Obstet Gynaecol Res. Jun. 2002;28:163-5. X-2, X-4. [pmid: 12214833].
523 Al-Nuaim LA, Mustafa MS, Abdel Gader AG. Disseminated intravascular coagulation and massive obstetric hemorrhage. Management dilemma. Saudi Med J. Jun. 2002;23:658-62. X-2. [pmid: 12070542].
524 bij de Vaate A, Coleman R, Manneh H, et al. Knowledge, attitudes and practices of trained traditional birth attendants in the Gambia in the prevention, recognition and management of postpartum haemorrhage. Midwifery. Mar. 2002;18:3-11. X-2, X-3. [pmid: 11945047].
525 Burton R, Belfort M, Anthony J. Management of the pregnant ICU patient. Clinical Pulmonary Medicine. 2002;9:87-96. X-1.
526 Caliskan E, Meydanli MM, Dilbaz B, et al. Is rectal misoprostol really effective in the treatment of third stage of labor? A randomized controlled trial. Am J Obstet Gynecol. Oct. 2002;187:1038-45. X-2, X-4, X-5. [pmid: 12389002].
527 Choy CM, Lau WC, Tam WH, et al. A randomised controlled trial of intramuscular syntometrine and intravenous oxytocin in the management of the third stage of labour. BJOG. Feb. 2002;109:173-7. X-4, X-5. [pmid: 11905429].
528 Clark S, Blum J, Blanchard K, et al. Misoprostol use in obstetrics and gynecology in Brazil, Jamaica, and the United States. Int J Gynaecol Obstet. Jan. 2002;76:65-74. X-2, X-3. [pmid: 11818096].
529 Cordonnier C, Ha-Vien DE, Depret S, et al. Foetal growth restriction in the next pregnancy after uterine artery embolisation for post-partum haemorrhage. Eur J Obstet Gynecol Reprod Biol. Jul. 10. 2002;103:183-4. X-5. [pmid: 12069745].
530 Cottier JP, Fignon A, Tranquart F, et al. Uterine necrosis after arterial embolization for postpartum hemorrhage. Obstet Gynecol. Nov. 2002;100:1074-7. X-5. [pmid: 12423810].
531 Cunha MA, de Souza Maia MR, Gomes MSR, et al. Profile of post delivery assisted at a maternity state of Rio Branco -- Acre-Brazil. Online Brazilian Journal of Nursing. 2002;1(1). 4p. Language: English. Entry Date: 20040618. Revision Date: 20091218. Publication Type: journal article. X-2, X-4.
532 Cunha MA, Gomes MSR Mr, et al. Profile of post delivery assisted at a maternity state of Rio Branco -- Acre-Brazil. Online Brazilian Journal of Nursing. 2002;1. 4p. PMID:. X-2, X-4.
533 de Boer MA, van Gemund N, Scherjon SA, et al. Low dose sulprostone for termination of second and third trimester pregnancies. Eur J Obstet Gynecol Reprod Biol. Dec. 1. 2002;99:244-8. X-4. [pmid: 11788180].
534 French L. Does oral misoprostol prevent postpartum hemorrhage as well as parenteral oxytocin?. Evidence-Based Practice. 2002;5:10-1. insert 2p. PMID:. X-1, X-4.
535 Geelhoed D, Visser L, Agordzo P, et al. Active versus expectant management of the third stage of labor in rural Ghana. Acta Obstet Gynecol Scand. Feb. 2002;81:172-3. X-2, X-4. [pmid: 11942910].
536 Goldberg J, Pereira L, Berghella V. Pregnancy after uterine artery embolization. Obstet Gynecol. Nov. 2002;100:869-72. X-2, X-5. [pmid: 12423843].
537 Goswami R, Kochupillai N, Crock PA, et al. Pituitary autoimmunity in patients with Sheehan's syndrome. J Clin Endocrinol Metab. Sep. 2002;87:4137-41. X-2, X-4. [pmid: 12213861].
538 Hayman RG, Arulkumaran S, Steer PJ. Uterine compression sutures: surgical management of postpartum hemorrhage. Obstet Gynecol. Mar. 2002;99:502-6. X-4, X-5. [pmid: 11864681].
539 Hebisch G, Huch A. Vaginal uterine artery ligation avoids high blood loss and puerperal hysterectomy in postpartum hemorrhage. Obstet Gynecol. Sep. 2002;100:574-8. X-5. [pmid: 12220781].
540 Holland R. A tale of two births. Pract Midwife. Apr. 2002;5:46. X-1. [pmid: 11987892].
541 Hundegger R, Husslein P, Berghammer P, et al. Postpartum bleeding and von Willebrand's disease. Arch Gynecol Obstet. Jul. 2002;266:160-2. X-4. [pmid: 12197557].
542 Karkanis SG, Caloia D, Salenieks ME, et al. Randomized controlled trial of rectal misoprostol versus oxytocin in third stage management. J Obstet Gynaecol Can. Feb. 2002;24:149-54. X-2, X-4, X-5. [pmid: 12196880].
543 Kastner ES, Figueroa R, Garry D, et al. Emergency peripartum hysterectomy: experience at a community teaching hospital. Obstet Gynecol. Jun. 2002;99:971-5. X-5. [pmid: 12052583].
544 Kodio B, de Bernis L, Ba M, et al. Levels and causes of maternal mortality in Senegal. Trop Med Int Health. Jun. 2002;7:499-505. X-2, X-4. [pmid: 12031071].
545 Lee WC, Cheng YF, Chen JB. Treating hyponatremia in an empty sella syndrome patient complicated with possible myelinolysis. 2002;25:838-43. X-1, X-3.
546 Levin A, Dmytraczenko T, Ssengooba F, et al. Uganda: improving maternal health care efficiency and financing. Health Reform Prior Serv. Summer-Fall. 2002:7-9. X-2. [pmid: 12222168].
547 Li YT, Yin CS, Chen FM, et al. A useful technique for the control of severe cesarean hemorrhage: report of three cases. 2002;25:548-52. X-2, X-4, X-5.
548 Lind J, Wallenburg HC. Pregnancy and the Ehlers-Danlos syndrome: a retrospective study in a Dutch population. Acta Obstet Gynecol Scand. Apr. 2002;81:293-300. 11952457. X-4. [pmid: 11952457].
549 Liu J, Han F, Bian X. Optimal management of postpartum hemorrhage. Chin Med J (Engl). Dec. 2002;114:1280-2. X-2, X-4, X-5. [pmid: 11793853].
550 Loverro G, Pansini V, Greco P, et al. Indications and outcome for intensive care unit admission during puerperium. Arch Gynecol Obstet. Nov. 2002;265:195-8. X-4, X-5. [pmid: 11789744].
551 Lubetsky A, Martinowitz U, Luboshitz J, et al. Efficacy and safety of a factor VIII-von Willebrand factor concentrate 8Y: stability, bacteriological safety, pharmacokinetic analysis and clinical experience. Haemophilia. Sep. 2002;8:622-8. X-3, X-4. [pmid: 12199669].
552 Lukoschus H, Nierhaus M, Vetter K. Misoprostol in gynaecology and obstetrics. Gynakologische Praxis. 2002;26:9-21. X-1.
553 Lumbiganon P, Villar J, Piaggio G, et al. Side effects of oral misoprostol during the first 24 hours after administration in the third stage of labour. BJOG. Nov. 2002;109:1222-6. X-2, X-3, X-4. [pmid: 12452458].
554 Magann EF, Chauhan SP, Bufkin L, et al. Intra-operative haemorrhage by blunt versus sharp expansion of the uterine incision at caesarean delivery: a randomised clinical trial. BJOG. Apr. 2002;109:448-52. X-4. [pmid: 12013167].
555 Malhotra M, Sharma JB, Batra S, et al. Maternal and perinatal outcome in varying degrees of anemia. Int J Gynaecol Obstet. Nov. 2002;79:93-100. X-2, X-4, X-5. [pmid: 12427391].
556 Manske T, Hultgren J, Bergsten C. The effect of claw trimming on the hoof health of Swedish dairy cattle. Prev Vet Med. Jun. 25. 2002;54:113-29. X-1, X-3, X-4. [pmid: 12069775].
557 Marchant S, Alexander J, Garcia J. Postnatal vaginal bleeding problems and General Practice. Midwifery. Mar. 2002;18:21-4. X-2, X-4, X-5. [pmid: 11945049].
558 Massai MR, Diaz S, Quinteros E, et al. Contraceptive efficacy and clinical performance of Nestorone implants in postpartum women. Contraception. Dec. 2002;64:369-76. X-3, X-4. [pmid: 11834236].
559 Mousa HA, Alfirevic Z. Major postpartum hemorrhage: survey of maternity units in the United Kingdom. Acta Obstet Gynecol Scand. Aug. 2002;81:727-30. X-2, X-4, X-5. [pmid: 12174156].
560 Neill AC, Nixon RM, Thornton S. A comparison of clinical assessment with ultrasound in the management of secondary postpartum haemorrhage. Eur J Obstet Gynecol Reprod Biol. Sep. 10. 2002;104:113-5. X-4. [pmid: 12206921].
561 Nkyekyer K. Twin and singleton births in Ghana--a case-control study. Twin Res. Aug. 2002;5:265-9. X-2, X-4. [pmid: 12217231].
562 Ochoa M, Allaire AD, Stitely ML. Pyometria after hemostatic square suture technique. Obstet Gynecol. Mar. 2002;99:506-9. X-2, X-5. [pmid: 11864682].
563 Palmer CM. Obstetric emergencies and anesthetic management. Current Reviews for PeriAnesthesia Nurses. 2002;24:123. X-1, X-4, X-5.
564 Petersen LA, Lindner DS, Kleiber CM, et al. Factors that predict low hematocrit levels in the postpartum patient after vaginal delivery. Am J Obstet Gynecol. Apr. 2002;186:737-44. X-3, X-4. [pmid: 11967500].
565 Sadler LC, Davison T, McCowan LM. Maternal satisfaction with active management of labor: a randomized controlled trial. Birth. Dec. 2002;28:225-35. X-4. [pmid: 11903210].
566 Salamat SM, Landy HJ, O'sullivan MJ. Labor induction after fetal death. A retrospective analysis. J Reprod Med. Jan. 2002;47:23-6. X-3, X-4. [pmid: 11838305].
567 Sami S, Baloch SN. Maternal mortality in Balochistan: A challenge for the obstetricians. Medical Forum Monthly. 01. Jul. 2002;13:15-8. X-2, X-4.
568 Sheiner E, Shoham-Vardi I, Hallak M, et al. Placenta previa: obstetric risk factors and pregnancy outcome. J Matern Fetal Med. Dec. 2002;10:414-9. X-4. [pmid: 11798453].
569 Singla AK, Berkowitz RL, Saphier CJ. Obstetric hemorrhage in Jehovah's Witnesses. Contemporary OB/GYN. 5. 2002;47:32-6. 8 passim. PMID:. X-1.
570 Sulzdorf L. Uterine arteriovenous malformation: Sonographic diagnosis in a patient presenting with heavy postpartum vaginal bleeding. Journal of Diagnostic Medical Sonography. 2002;18:25-30. X-1.
571 Treger M, Hallak M, Silberstein T, et al. Post-term pregnancy: should induction of labor be considered before 42 weeks?. J Matern Fetal Neonatal Med. Jan. 2002;11:50-3. X-4. [pmid: 12380609].
572 Tsu VD, Free MJ. Using technology to reduce maternal mortality in low-resource settings: challenges and opportunities. J Am Med Womens Assoc. Summer. 2002;57:149-53. X-1. [pmid: 12146606].
573 Villar J, Gulmezoglu AM, Hofmeyr GJ, et al. Systematic review of randomized controlled trials of misoprostol to prevent postpartum hemorrhage. Obstet Gynecol. Dec. 2002;100:1301-12. X-1, X-4. [pmid: 12468178].
574 Vitzthum VJ, Spielvogel H, Caceres E, et al. Vaginal bleeding patterns among rural highland Bolivian women: relationship to fecundity and fetal loss. Contraception. Nov. 2002;64:319-25. X-2, X-3, X-4. [pmid: 11777494].
575 Wagaarachchi PT, Fernando L. Trends in maternal mortality and assessment of substandard care in a tertiary care hospital. Eur J Obstet Gynecol Reprod Biol. Feb. 10. 2002;101:36-40. X-2, X-4, X-5. [pmid: 11803098].
576 White PM. Crossing the river: Khmer women's perceptions of pregnancy and postpartum. J Midwifery Womens Health. Jul-Aug. 2002;47:239-46. X-1, X-2, X-4. [pmid: 12138931].
577 Yang W, Shen Z, Peng G, et al. Acute fatty liver of pregnancy: diagnosis and management of 8 cases. Chin Med J (Engl). Jun. 2002;113:540-3. X-4. [pmid: 11775876].
578 Yazbak FE, Diodati CJ. Postpartum live virus vaccination: lessons from veterinary medicine. Med Hypotheses. Sep. 2002;59:280-2. X-1, X-2, X-4, X-5. [pmid: 12208153].
579 Zamora LA. A randomized controlled trial of oxytocin administered at the end of the second stage of labor versus oxytocin administered at the end of the third stage of labor in the prevention of postpartum hemorrhage. Philipp J Obstet Gynecol. Oct-Dec. 2002;23:125-33. X-4. [pmid: 12179676].
580 Management of the 3rd stage of labour to prevent post-partum haemorrhage: joint statement: International Confederation of Midwives (ICM) International Federation of Gynaecologists and Obstetricians (FIGO). International Midwifery. 2003;16:66-7. X-1.
581 Aggarwal N, Suri V, Bapuraj JR, et al. Percutanous uterine artery embolization to control severe haemorrhage from gestational trophoblastic disease. Bulletin, Postgraduate Institute of Medical Education and Research, Chandigarh. 2003;37:170-4. X-1, X-2.
582 Aimakhu CO, Olayemi O, Enabor OO, et al. Forceps delivery at the University College Hospital, Ibadan, Nigeria. West Afr J Med. Sep. 2003;22:222-4. X-2, X-4. [pmid: 14696945].
583 Akhter S, Begum MR, Kabir Z, et al. Use of a condom to control massive postpartum hemorrhage. MedGenMed. Sep. 11. 2003;5:38. X-2. [pmid: 14600674].
584 Allen VM, O'Connell CM, Liston RM, et al. Maternal morbidity associated with cesarean delivery without labor compared with spontaneous onset of labor at term. Obstet Gynecol. Sep. 2003;102:477-82. X-4. [pmid: 12962927].
585 Al-Ojaimi EH. Medical quiz. Bahrain Medical Bulletin. June. 2003;25:83+94. X-1, X-4.
586 Bai SW, Lee HJ, Cho JS, et al. Peripartum hysterectomy and associated factors. J Reprod Med. Mar. 2003;48:148-52. X-2, X-4, X-5. [pmid: 12698770].
587 Baskett TF. Emergency obstetric hysterectomy. J Obstet Gynaecol. Jul. 2003;23:353-5. X-5. [pmid: 12881069].
588 Baudo F, de Cataldo F. Acquired factor VIII inhibitors in pregnancy: data from the Italian Haemophilia Register relevant to clinical practice. BJOG. Mar. 2003;110:311-4. X-4, X-5. [pmid: 12628274].
589 Bhutta SZ, Aziz S, Korejo R. Pregnancy following cardiac surgery. J Pak Med Assoc. Sep. 2003;53:407-13. X-4. [pmid: 14620316].
590 Bodner K, Bodner-Adler B, Wierrani F, et al. Effects of water birth on maternal and neonatal outcomes. Wien Klin Wochenschr. Jun. 14. 2003;114:391-5. X-4. [pmid: 12708093].
591 Bohra U, Donnelly J, O'Connell MP, et al. Active management of labour revisited: the first 1000 primiparous labours in 2000. J Obstet Gynaecol. Mar. 2003;23:118-20. X-4. [pmid: 12745551].
592 Bouwmeester FW, Jonkhoff AR, Verheijen RH, et al. Successful treatment of life-threatening postpartum hemorrhage with recombinant activated factor VII. Obstet Gynecol. Jun. 2003;101:1174-6. X-4, X-5. [pmid: 12798521].
593 Caliskan E, Dilbaz B, Meydanli MM, et al. Oral misoprostol for the third stage of labor: a randomized controlled trial. Obstet Gynecol. May. 2003;101:921-8. X-2, X-4, X-5. [pmid: 12738151].
594 Chung JW, Jeong HJ, Joh JH, et al. Percutaneous transcatheter angiographic embolization in the management of obstetric hemorrhage. J Reprod Med. Apr. 2003;48:268-76. X-2, X-4, X-5. [pmid: 12746991].
595 Cochet L, Pattinson RC, Macdonald AP. Severe acute maternal morbidity and maternal death audit--a rapid diagnostic tool for evaluating maternal care. S Afr Med J. Sep. 2003;93:700-2. X-2, X-4. [pmid: 14635560].
596 Condous GS, Arulkumaran S, Symonds I, et al. The “tamponade test” in the management of massive postpartum hemorrhage. Obstet Gynecol. Apr. 2003;101:767-72. X-4, X-5. [pmid: 12681884].
597 Delaney T, Young DC. Spontaneous versus induced labor after a previous cesarean delivery. Obstet Gynecol. Jul. 2003;102:39-44. X-4. [pmid: 12850605].
598 Di Benedetto P, Baciarello M, Cabetti L, et al. Thrombelastography. Present and future perspectives in clinical practice. Minerva Anestesiol. Jun. 2003;69:501-9. 9. 15. X-1. [pmid: 14564249].
599 El-Jallad MF, Zayed F, Al-Rimawi HS. Emergency peripartum hysterectomy in Northern Jordan: indications and obstetric outcome (an 8-year review). Arch Gynecol Obstet. Dec. 2003;270:271-3. X-2. [pmid: 14676963].
600 Festin MR, Lumbiganon P, Tolosa JE, et al. International survey on variations in practice of the management of the third stage of labour. Bull World Health Organ. 2003;81:286-91. X-3, X-4. [pmid: 12764495].
601 Forna F, Jamieson DJ, Sanders D, et al. Pregnancy outcomes in foreign-born and US-born women. Int J Gynaecol Obstet. Dec. 2003;83:257-65. X-4. [pmid: 14643035].
602 Foy R, Penney G, Greer I. The impact of national clinical guidelines on obstetricians in Scotland. Health Bull (Edinb). Nov. 2003;59:364-72. X-2, X-4, X-5. [pmid: 12661386].
603 French L. How does rectal misoprostol compare with other methods of preventing postpartum hemorrhage?. Evidence-Based Practice. 2003;6:3-4. 2p. X-1, X-4.
604 Goldszmidt E, Davies S. Two cases of hemorrhage secondary to amniotic fluid embolus managed with uterine artery embolization. Can J Anaesth. Nov. 2003;50:917-21. X-2, X-5. [pmid: 14617589].
605 Harrigill KM, Miller HS, Haynes DE. The effect of intraabdominal irrigation at cesarean delivery on maternal morbidity: a randomized trial. Obstet Gynecol. Jan. 2003;101:80-5. X-4, X-5. [pmid: 12517650].
606 Harris T. Choice in third stage: challenging and changing practice. Midwifery Matters. 2003:12-5. X-1.
607 Heep A, Behrendt D, Nitsch P, et al. Increased serum levels of interleukin 6 are associated with severe intraventricular haemorrhage in extremely premature infants. Arch Dis Child Fetal Neonatal Ed. Nov. 2003;88:F501-4. X-3, X-4. [pmid: 14602698].
608 Hiruta Y. A survey of maternity care in practice in Japan. British Journal of Midwifery. 2003;11:38-42. X-2, X-3, X-4.
609 Hong TM, Tseng HS, Lee RC, et al. Uterine artery embolization: an effective treatment for intractable obstetric haemorrhage. Clin Radiol. Jan. 2003;59:96-101. X-2, X-4, X-5. [pmid: 14697382].
610 Hsu S, Rodgers B, Lele A, et al. Use of packing in obstetric hemorrhage of uterine origin. J Reprod Med. Feb. 2003;48:69-71. X-2, X-5. [pmid: 12621788].
611 Humphrey MD. Is grand multiparity an independent predictor of pregnancy risk? A retrospective observational study. Med J Aust. Sep. 15. 2003;179:294-6. X-4. [pmid: 12964911].
612 Ijaiya MA, Aboyeji AP, Abubakar D. Analysis of 348 consecutive cases of primary postpartum haemorrhage at a tertiary hospital in Nigeria. J Obstet Gynaecol. Jul. 2003;23:374-7. X-2, X-4. [pmid: 12881075].
613 Islam MA, Chowdhury RI, Chakraborty N, et al. A multistage model for maternal morbidity during antenatal, delivery and postpartum periods. Stat Med. Jan. 15. 2003;23:137-58. X-2, X-4. [pmid: 14695645].
614 Jolly MC, Sebire NJ, Harris JP, et al. Risk factors for macrosomia and its clinical consequences: a study of 350,311 pregnancies. Eur J Obstet Gynecol Reprod Biol. Nov. 10. 2003;111:9-14. X-4. [pmid: 14557004].
615 Karpati PC, Rossignol M, Pirot M, et al. High incidence of myocardial ischemia during postpartum hemorrhage. Anesthesiology. Jan. 2003;100:30-6. discussion 5A. X-4, X-5. [pmid: 14695721].
616 Kaye D, Mirembe F, Aziga F, et al. Maternal mortality and associated near-misses among emergency intrapartum obstetric referrals in Mulago Hospital, Kampala, Uganda. East Afr Med J. Mar. 2003;80:144-9. X-2, X-4. [pmid: 12762430].
617 Khan RU, El-Refaey H. Pharmacokinetics and adverse-effect profile of rectally administered misoprostol in the third stage of labor. Obstet Gynecol. May. 2003;101:968-74. X-4. [pmid: 12738159].
618 Kirtava A, Drews C, Lally C, et al. Medical, reproductive and psychosocial experiences of women diagnosed with von Willebrand's disease receiving care in haemophilia treatment centres: a case-control study. Haemophilia. May. 2003;9:292-7. X-4. [pmid: 12694520].
619 Langdana F, Geary M, Haw W, et al. Peripartum hysterectomy in the 1990s: any new lessons?. J Obstet Gynaecol. Mar. 2003;21:121-3. X-5. [pmid: 12521876].
620 Lim JH, Tan BC, Jammal AE, et al. Delivery of macrosomic babies: management and outcomes of 330 cases. J Obstet Gynaecol. Jul. 2003;22:370-4. X-2, X-4. [pmid: 12521456].
621 Majoko F, Nystrom L, Lindmark G. No benefit, but increased harm from high dose (100 microg) misoprostol for induction of labour: a randomised trial of high vs. low (50 microg) dose misoprostol. J Obstet Gynaecol. Nov. 2003;22:614-7. X-2, X-4. [pmid: 12554247].
622 Mathai M. Preventing infection during manual removal of the placenta. Natl Med J India. Nov-Dec. 2003;15:349-50. X-1, X-2, X-4, X-5. [pmid: 12540070].
623 Mekbib T, Kassaye E, Getachew A, et al. The FIGO Save the Mothers Initiative: the Ethiopia-Sweden collaboration. Int J Gynaecol Obstet. Apr. 2003;81:93-102. X-1, X-2. [pmid: 12676407].
624 Mesko N, Osrin D, Tamang S, et al. Care for perinatal illness in rural Nepal: a descriptive study with cross-sectional and qualitative components. BMC Int Health Hum Rights. Aug. 21. 2003;3:3. X-2, X-4. [pmid: 12932300].
625 Mesko N, Osrin D, Tamang S, et al. Care for perinatal illness in rural Nepal: A descriptive study with cross-sectional and qualitative components. United Kingdom. BioMed Central Ltd. 2003. http://www.biomedcentral.com/1472-698X/3/3http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed6&NEWS=N=AN=2004472735. Accessed on (Mesko, Osrin, Costello) International Perinatal Care Unit, Institute of Child Health, University College, London, United Kingdom 3.
626 Moodley J. Saving mothers: 1999-2001. S Afr Med J. May. 2003;93:364-6. X-1. [pmid: 12830600].
627 Morales T, Sawchenko PE. Brainstem prolactin-releasing peptide neurons are sensitive to stress and lactation. Neuroscience. 2003;121:771-8. X-1, X-3, X-4. [pmid: 14568035].
628 Mozurkewich E, Horrocks J, Daley S, et al. The MisoPROM study: a multicenter randomized comparison of oral misoprostol and oxytocin for premature rupture of membranes at term. Am J Obstet Gynecol. Oct. 2003;189:1026-30. X-4, X-5. [pmid: 14586349].
629 Myles TD. Is there an obstetric July phenomenon?. Obstet Gynecol. Nov. 2003;102:1080-4. X-4. [pmid: 14672490].
630 Myles TD, Santolaya J. Maternal and neonatal outcomes in patients with a prolonged second stage of labor. Obstet Gynecol. Jul. 2003;102:52-8. X-4. [pmid: 12850607].
631 Naqvi MM. Outcome of twin pregnancy in booked versus unbooked cases. J Coll Physicians Surg Pak. Sep. 2003;13:498-500. X-2, X-4. [pmid: 12971867].
632 Nizard J, Barrinque L, Frydman R, et al. Fertility and pregnancy outcomes following hypogastric artery ligation for severe post-partum haemorrhage. Hum Reprod. Apr. 2003;18:844-8. X-4, X-5. [pmid: 12660282].
633 Oboro VO, Tabowei TO. A randomised controlled trial of misoprostol versus oxytocin in the active management of the third stage of labour. J Obstet Gynaecol. Jan. 2003;23:13-6. X-4. [pmid: 12623474].
634 Odukogbe AA, Adewole IF, Ojengbede OA, et al. Grandmultiparity--trends and complications: a study in two hospital settings. J Obstet Gynaecol. Jul. 2003;21:361-7. X-2, X-4. [pmid: 12521827].
635 Ofir K, Sheiner E, Levy A, et al. Uterine rupture: risk factors and pregnancy outcome. Am J Obstet Gynecol. Oct. 2003;189:1042-6. X-4. [pmid: 14586352].
636 Ogueh O, Morin L, Usher RH, et al. Obstetric implications of low-lying placentas diagnosed in the second trimester. Int J Gynaecol Obstet. Oct. 2003;83:11-7. X-4. [pmid: 14511867].
637 Ohkuchi A, Onagawa T, Usui R, et al. Effect of maternal age on blood loss during parturition: a retrospective multivariate analysis of 10,053 cases. J Perinat Med. 2003;31:209-15. X-4. [pmid: 12825476].
638 Okogbenin SA, Gharoro EP, Otoide VO, et al. Obstetric hysterectomy: fifteen years' experience in a Nigerian tertiary centre. J Obstet Gynaecol. Jul. 2003;23:356-9. X-2, X-3, X-4. [pmid: 12881070].
639 Olesen AW, Westergaard JG, Olsen J. Perinatal and maternal complications related to postterm delivery: a national register-based study, 1978-1993. Am J Obstet Gynecol. Jul. 2003;189:222-7. X-4. [pmid: 12861166].
640 Onwudiegwu U, Ezechi OC. Emergency obstetric admissions: late referrals, misdiagnoses and consequences. J Obstet Gynaecol. Nov. 2003;21:570-5. X-2, X-4. [pmid: 12521770].
641 Ornan D, White R, Pollak J, et al. Pelvic embolization for intractable postpartum hemorrhage: long-term follow-up and implications for fertility. Obstet Gynecol. Nov. 2003;102:904-10. X-5. [pmid: 14672461].
642 Pal M, Biswas AK, Bhattacharya SM. B-Lynch Brace Suturing in primary post-partum hemorrhage during cesarean section. J Obstet Gynaecol Res. Oct. 2003;29:317-20. X-2, X-5. [pmid: 14641702].
643 Pattinson RC, Buchmann E, Mantel G, et al. Can enquiries into severe acute maternal morbidity act as a surrogate for maternal death enquiries?. BJOG. Oct. 2003;110:889-93. X-2, X-4. [pmid: 14550357].
644 Phillip H, Fletcher H, Reid M. The impact of induced labour on postpartum blood loss. J Obstet Gynaecol. Jan. 2003;24:12-5. X-2, X-4. [pmid: 14675973].
645 Picone O, Salomon LJ, Ville Y, et al. Fetal growth and Doppler assessment in patients with a history of bilateral internal iliac artery embolization. J Matern Fetal Neonatal Med. May. 2003;13:305-8. X-2, X-5. [pmid: 12916679].
646 Praneshwari Devi RK, Das P, Tomba Singh K. A case of morbid adhesion of placenta. JMS - Journal of Medical Society. May. 2003;17:72-3. X-1.
647 Qiu H, Zhu H, Ouyang W, et al. Clinical effects and mechanism of chanlibao in accelerating second stage of labor. J Tongji Med Univ. 2003;19:141-4. X-4. [pmid: 12840859].
648 Reyal F, Sibony O, Oury JF, et al. Criteria for transfusion in severe postpartum hemorrhage: analysis of practice and risk factors. Eur J Obstet Gynecol Reprod Biol. Jan. 15. 2003;112:61-4. X-5. [pmid: 14687741].
649 Rivlin ME, Carroll CS Sr., Morrison JC. Uterine incisional necrosis complicating cesarean section. J Reprod Med. Sep. 2003;48:687-91. X-2, X-4, X-5. [pmid: 14562632].
650 Roman AS, Rebarber A. Seven ways to control postpartum hemorrhage. Contemporary OB/GYN. 2003;48:34-6. 8. 41-2 passim. PMID:. X-1.
651 Roopnarinesingh R, Fay L, McKenna P. A 27-year review of obstetric hysterectomy. J Obstet Gynaecol. May. 2003;23:252-4. X-4, X-5. [pmid: 12850853].
652 Salomon LJ, deTayrac R, Castaigne-Meary V, et al. Fertility and pregnancy outcome following pelvic arterial embolization for severe post-partum haemorrhage. A cohort study. Hum Reprod. Apr. 2003;18:849-52. X-4, X-5. [pmid: 12660283].
653 Schiff E, Friedman SA, Zolti M, et al. A matched controlled study of Kielland's forceps for transverse arrest of the fetal vertex. J Obstet Gynaecol. Nov. 2003;21:576-9. X-4. [pmid: 12521771].
654 Segal S, Shemesh IY, Blumenthal R, et al. Treatment of obstetric hemorrhage with recombinant activated factor VII (rFVIIa). Arch Gynecol Obstet. Oct. 2003;268:266-7. X-5. [pmid: 14504866].
655 Sert M, Tetiker T, Kirim S, et al. Clinical report of 28 patients with Sheehan's syndrome. Endocr J. Jun. 2003;50:297-301. X-2, X-4, X-5. [pmid: 12940458].
656 Sheiner E, Levy A, Katz M, et al. Identifying risk factors for peripartum cesarean hysterectomy. A population-based study. J Reprod Med. Aug. 2003;48:622-6. X-2, X-4, X-5. [pmid: 12971143].
657 Singh KC, Jain P, Goel N, et al. Drotaverine hydrochloride for augmentation of labor. Int J Gynaecol Obstet. Jan. 2003;84:17-22. X-3, X-4. [pmid: 14698825].
658 Skandalakis JE, Mirilas P. Nihilism: a benign denial. World J Surg. Jun. 2003;27:748-52. X-1. [pmid: 12732992].
659 Smith KL, Baskett TF. Uterine compression sutures as an alternative to hysterectomy for severe postpartum hemorrhage. J Obstet Gynaecol Can. Mar. 2003;25:197-200. X-5. [pmid: 12610671].
660 Strand RT, da Silva F, Bergstrom S. Use of cholera beds in the delivery room: a simple and appropriate method for direct measurement of postpartum bleeding. Trop Doct. Oct. 2003;33:215-6. X-2, X-4. [pmid: 14620424].
661 Tahir S, Aleem M, Akram S. Indication and maternal outcome of emergency peripartum hysterectomy. Pakistan Journal of Medical Sciences. July/September. 2003;19:182-6. X-2, X-4.
662 Tsu VD, Sutanto A, Vaidya K, et al. Oxytocin in prefilled Uniject injection devices for managing third-stage labor in Indonesia. Int J Gynaecol Obstet. Oct. 2003;83:103-11. X-2, X-4. [pmid: 14511884].
663 Walsh D. Birthwrite. Haemorrhage and the third stage of labour. British Journal of Midwifery. 2003;11:72. X-1, X-4.
664 Weerasekera DS, Premaratne S. A randomised prospective trial of the obstetric forceps versus vacuum extraction using defined criteria. J Obstet Gynaecol. Jul. 2003;22:344-5. X-4. [pmid: 12521450].
665 Wehbe SA, Ghulmiyyah LM, Carroll KT, et al. Correlations from gadopentetate dimeglumine-enhanced magnetic resonance imaging after methotrexate chemotherapy for hemorrhagic placenta increta. Biomagn Res Technol. Nov. 14. 2003;1:3. X-2, X-4, X-5. [pmid: 14617375].
666 Westerway SC, Keogh J, Heard R, et al. Incidence of fetal macrosomia and birth complications in Chinese immigrant women. Aust N Z J Obstet Gynaecol. Feb. 2003;43:46-9. X-4. [pmid: 12755347].
667 Wright JM, Newton W. Is rectal misoprostol as effective as oxytocin in preventing postpartum hemorrhage?. J Fam Pract. Apr. 2003;52:281-2. X-1, X-2, X-4, X-5. [pmid: 12681086].
668 Yamani Zamzami TY. Indication of emergency peripartum hysterectomy: review of 17 cases. Arch Gynecol Obstet. Aug. 2003;268:131-5. X-2. [pmid: 12756583].
669 Zeeman GG, Wendel GD Jr., Cunningham FG. A blueprint for obstetric critical care. Am J Obstet Gynecol. Feb. 2003;188:532-6. X-4, X-5. [pmid: 12592267].
670 Prevention and treatment of postpartum hemorrhage: new advances for low resource settings (#2004/042). J Midwifery Womens Health. Jul-Aug. 2004;49:375-6. X-1, X-2, X-4, X-5. [pmid: 15257274].
671 Long-term follow-up of pelvic embolization. ACOG Clinical Review. 2004;9:6. X-1, X-4.
672 Postpartum hemorrhage and pelvic embolization. ACOG Clinical Review. 2004;9:4. X-1, X-4.
673 Aali BS, Ghafoorian J, Mohamad-Alizadeh S. Severe preeclampsia and eclampsia in Kerman, Iran: complications and outcomes. Med Sci Monit. Apr. 2004;10:CR163-7. X-2, X-4. [pmid: 15039647].
674 Abu-Heija AT, Chalabi HE. Great grand multiparity: is it a risk?. J Obstet Gynaecol. Mar. 2004;18:136-8. X-1, X-4. [pmid: 15512031].
675 Alfirevic Z, Edwards G, Platt MJ. The impact of delivery suite guidelines on intrapartum care in ‘standard primigravida’. Eur J Obstet Gynecol Reprod Biol. Jul. 15. 2004;115:28-31. X-4, X-5. [pmid: 15223161].
676 Almog B, Levin I, Winkler N, et al. The contribution of laminaria placement for cervical ripening in second trimester termination of pregnancy induced by intraamniotic injection of prostaglandin F(2)alpha followed by concentrated oxytocin infusion. Eur J Obstet Gynecol Reprod Biol. Jan. 10. 2004;118:32-5. X-4. [pmid: 15596269].
677 Andolina KL, Tolosa JE, Monzo JM, et al. Oral misoprostol is rapidly absorbed in postpartum women at term. J Matern Fetal Neonatal Med. Oct. 2004;14:229-32. X-3, X-4. [pmid: 14738167].
678 Anwari JS, Butt AA, Al-Dar MA. Obstetric admissions to the intensive care unit. Saudi Med J. Oct. 2004;25:1394-9. X-2. [pmid: 15494809].
679 Bagga R, Jain V, Kalra J, et al. Uterovaginal packing with rolled gauze in postpartum hemorrhage. MedGenMed : Medscape general medicine. 2004;6:50. X-1, X-2, X-5. [pmid: 15208561].
680 Bailit JL, Blanchard MH. The effect of house staff working hours on the quality of obstetric and gynecologic care. Obstet Gynecol. Apr. 2004;103:613-6. X-4. [pmid: 15051548].
681 Bais JM, Eskes M, Pel M, et al. Postpartum haemorrhage in nulliparous women: incidence and risk factors in low and high risk women. A Dutch population-based cohort study on standard (> or = 500 ml) and severe (> or = 1000 ml) postpartum haemorrhage. Eur J Obstet Gynecol Reprod Biol. Aug. 10. 2004;115:166-72. X-4. [pmid: 15262350].
682 Bang RA, Bang AT, Reddy MH, et al. Maternal morbidity during labour and the puerperium in rural homes and the need for medical attention: A prospective observational study in Gadchiroli, India. BJOG. Mar. 2004;111:231-8. X-2, X-4. [pmid: 14961884].
683 Bashiri A, Smolin A, Sheiner E, et al. Maternal rehospitalization after singleton term vaginal delivery. J Matern Fetal Neonatal Med. Nov. 2004;14:344-8. X-4. [pmid: 14986810].
684 Baskett TF. Surgical management of severe obstetric hemorrhage: experience with an obstetric hemorrhage equipment tray. J Obstet Gynaecol Can. Sep. 2004;26:805-8. X-5. [pmid: 15361276].
685 Bhullar A, Carlan SJ, Hamm J, et al. Buccal misoprostol to decrease blood loss after vaginal delivery: a randomized trial. Obstet Gynecol. Dec. 2004;104:1282-8. X-4, X-5. [pmid: 15572491].
686 Biaggi A, Paradisi G, Ferrazzani S, et al. Maternal mortality in Italy, 1980-1996. Eur J Obstet Gynecol Reprod Biol. Jun. 15. 2004;114:144-9. X-4, X-5. [pmid: 15140506].
687 Bloom AI, Verstandig A, Gielchinsky Y, et al. Arterial embolisation for persistent primary postpartum haemorrhage: before or after hysterectomy?. Bjog. Aug. 2004;111:880-4. X-5. [pmid: 15270943].
688 Bodnar LM, Siega-Riz AM, Arab L, et al. Predictors of pregnancy and postpartum haemoglobin concentrations in low-income women. Public Health Nutr. Sep. 2004;7:701-11. X-4. [pmid: 15369607].
689 Bodner-Adler B, Bodner K, Kimberger O, et al. Influence of the birth attendant on maternal and neonatal outcomes during normal vaginal delivery: a comparison between midwife and physician management. Wien Klin Wochenschr. Jun. 30. 2004;116:379-84. X-4. [pmid: 15291290].
690 Boucher M, Nimrod CA, Tawagi GF, et al. Comparison of carbetocin and oxytocin for the prevention of postpartum hemorrhage following vaginal delivery:a double-blind randomized trial. J Obstet Gynaecol Can. May. 2004;26:481-8. X-4. [pmid: 15151735].
691 Boulleret C, Chahid T, Gallot D, et al. Hypogastric arterial selective and superselective embolization for severe postpartum hemorrhage: a retrospective review of 36 cases. Cardiovasc Intervent Radiol. Jul-Aug. 2004;27:344-8. X-1, X-4, X-5. [pmid: 15129337].
692 Brace V, Penney G, Hall M. Quantifying severe maternal morbidity: a Scottish population study. BJOG. May. 2004;111:481-4. X-4. [pmid: 15104614].
693 Buckland RH, Popham PA. Lymphocytic hypophysitis complicated by post-partum haemorrhage. Int J Obstet Anesth. Oct. 2004;7:263-6. X-1, X-4, X-5. [pmid: 15321191].
694 Carvalho JC, Balki M, Kingdom J, et al. Oxytocin requirements at elective cesarean delivery: a dose-finding study. Obstet Gynecol. Nov. 2004;104:1005-10. X-3, X-4. [pmid: 15516392].
695 Catling SJ, Freites O, Krishnan S, et al. Clinical experience with cell salvage in obstetrics: 4 cases from one UK centre. Int J Obstet Anesth. Apr. 2004;11:128-34. X-5. [pmid: 15321566].
696 Chandra S, Persad V, Young D, et al. A preliminary study of cutaneous blood flow associated with postpartum use of oral misoprostol. J Obstet Gynaecol Can. Dec. 2004;26:1073-6. X-3, X-4. [pmid: 15607043].
697 Cheng YY, Hwang JI, Hung SW, et al. Angiographic embolization for emergent and prophylactic management of obstetric hemorrhage: a four-year experience. J Chin Med Assoc. Dec. 2004;66:727-34. X-2, X-5. [pmid: 15015822].
698 Cherine M, Khalil K, Hassanein N, et al. Management of the third stage of labor in an Egyptian teaching hospital. Int J Gynaecol Obstet. Oct. 2004;87:54-8. X-2, X-4. [pmid: 15464784].
699 Chou YJ, Cheng YF, Shen CC, et al. Failure of uterine arterial embolization: placenta accreta with profuse postpartum hemorrhage. Acta Obstet Gynecol Scand. Jul. 2004;83:688-90. X-2, X-4, X-5. [pmid: 15225198].
700 Dehbashi S, Honarvar M, Fardi FH. Manual removal or spontaneous placental delivery and postcesarean endometritis and bleeding. Int J Gynaecol Obstet. Jul. 2004;86:12-5. X-4. [pmid: 15207663].
701 Demirkiran O, Dikmen Y, Utku T, et al. Critically ill obstetric patients in the intensive care unit. Int J Obstet Anesth. Oct. 2004;12:266-70. X-2, X-4, X-5. [pmid: 15321455].
702 Demissie K, Rhoads GG, Smulian JC, et al. Operative vaginal delivery and neonatal and infant adverse outcomes: population based retrospective analysis. BMJ. Jul. 3. 2004;329:24-9. X-4. [pmid: 15231617].
703 Descargues G, Mauger Tinlot F, Douvrin F, et al. Menses, fertility and pregnancy after arterial embolization for the control of postpartum haemorrhage. Hum Reprod. Feb. 2004;19:339-43. X-5. [pmid: 14747177].
704 Donovan GA, Risco CA, Temple GM, et al. Influence of transition diets on occurrence of subclinical laminitis in Holstein dairy cows. J Dairy Sci. Jan. 2004;87:73-84. X-3. [pmid: 14765813].
705 Duff E. No more ‘quarrelling at the mother's bedside’: inter-professional approaches can help to stop women dying. MIDIRS Midwifery Digest. 2004;14:35-6. X-1, X-4.
706 Ezechi OC, Fasubaa OB, Dare FO. Socioeconomic barriers to safe motherhood among booked patients in rural Nigerian communities. J Obstet Gynaecol. Jan. 2004;20:32-4. X-2, X-4. [pmid: 15512461].
707 Ezechi OC, Kalu BK, Njokanma FO, et al. Vaginal misoprostol induction of labour: a Nigerian hospital experience. J Obstet Gynaecol. Apr. 2004;24:239-42. X-2, X-4. [pmid: 15203615].
708 Ezechi OC, Kalu BK, Njokanma FO, et al. Emergency peripartum hysterectomy in a Nigerian hospital: a 20-year review. J Obstet Gynaecol. Jun. 2004;24:372-3. X-2, X-4. [pmid: 15203573].
709 Gai MY, Wu LF, Su QF, et al. Clinical observation of blood loss reduced by tranexamic acid during and after caesarian section: a multi-center, randomized trial. Eur J Obstet Gynecol Reprod Biol. Feb. 10. 2004;112:154-7. X-4. [pmid: 14746950].
710 Geller SE, Patel A, Niak VA, et al. Conducting international collaborative research in developing nations. Int J Gynaecol Obstet. Dec. 2004;87:267-71. X-1. [pmid: 15548406].
711 Ghourab S, Al-Nuaim L, Al-Jabari A, et al. Abdomino-pelvic packing to control severe haemorrhage following caesarean hysterectomy. J Obstet Gynaecol. Mar. 2004;19:155-8. X-2, X-5. [pmid: 15512258].
712 Goldberg J, Pereira L, Berghella V, et al. Pregnancy outcomes after treatment for fibromyomata: uterine artery embolization versus laparoscopic myomectomy. Am J Obstet Gynecol. Jul. 2004;191:18-21. X-4. [pmid: 15295339].
713 Gould DA, Butler-Manuel SA, Turner MJ, et al. Emergency obstetric hysterectomy - an increasing incidence. J Obstet Gynaecol. Nov. 2004;19:580-3. X-2, X-5. [pmid: 15512405].
714 Hazra S, Chilaka VN, Rajendran S, et al. Massive postpartum haemorrhage as a cause of maternal morbidity in a large tertiary hospital. J Obstet Gynaecol. Aug. 2004;24:519-20. X-4. [pmid: 15369931].
715 Healey S, Buzaglo K, Seti L, et al. Ovarian function after uterine artery embolization and hysterectomy. J Am Assoc Gynecol Laparosc. Aug. 2004;11(3):348-52. X-3, X-4. [pmid: 15559347].
716 Hebisch G, Neumaier-Wagner PM, Huch R, et al. Maternal serum interleukin-1 beta, -6 and -8 levels and potential determinants in pregnancy and peripartum. J Perinat Med. 2004;32:475-80. X-3, X-4. [pmid: 15576267].
717 Heinonen S, Tyrvainen E, Saarikoski S, et al. Need for maternal critical care in obstetrics: a population-based analysis. Int J Obstet Anesth. Oct. 2004;11:260-4. X-4. [pmid: 15321532].
718 Hidar S, Jennane TM, Bouguizane S, et al. The effect of placental removal method at cesarean delivery on perioperative hemorrhage: a randomized clinical trial ISRCTN 49779257. Eur J Obstet Gynecol Reprod Biol. Dec. 1. 2004;117:179-82. X-2, X-4, X-5. [pmid: 15541854].
719 Hofmeyr GJ, Ferreira S, Nikodem VC, et al. Misoprostol for treating postpartum haemorrhage: a randomized controlled trial [ISRCTN72263357]. BMC Pregnancy Childbirth. Aug. 6. 2004;4:16. X-2. [pmid: 15298718].
720 Holtsema H, Nijland R, Huisman A, et al. The B-Lynch technique for postpartum haemorrhage: an option for every gynaecologist. Eur J Obstet Gynecol Reprod Biol. Jul. 15. 2004;115:39-42. X-2, X-5. [pmid: 15223163].
721 Hughes S, Goodyear P, Sansome A. The anaesthetic management of a woman with a 31-week abdominal pregnancy. Int J Obstet Anesth. Oct. 2004;10:321-4. X-1. [pmid: 15321592].
722 Huh WK, Chelmow D, Malone FD. A double-blinded, randomized controlled trial of oxytocin at the beginning versus the end of the third stage of labor for prevention of postpartum hemorrhage. Gynecol Obstet Invest. 2004;58:72-6. X-4. [pmid: 15103233].
723 Ioscovich A, Elstein Y, Halpern S, et al. Anesthesia for obstetric patients with Gaucher disease: survey and review. Int J Obstet Anesth. Oct. 2004;13:244-50. X-3, X-4. [pmid: 15477054].
724 Karnad DR, Lapsia V, Krishnan A, et al. Prognostic factors in obstetric patients admitted to an Indian intensive care unit. Crit Care Med. Jun. 2004;32:1294-9. X-2, X-4. [pmid: 15187509].
725 Khanal R. Caesarean delivery at Nepal Medical College Teaching Hospital, Kathmandu, Nepal. Nepal Med Coll J. Jun. 2004;6:53-5. X-2, X-4. [pmid: 15449656].
726 Kodkany BS, Derman RJ, Goudar SS, et al. Initiating a novel therapy in preventing postpartum hemorrhage in rural India: a joint collaboration between the United States and India. Int J Fertil Womens Med. Mar-Apr. 2004;49:91-6. X-1, X-2, X-4. [pmid: 15188836].
727 Koroukian SM. Relative risk of postpartum complications in the Ohio Medicaid population: vaginal versus cesarean delivery. Med Care Res Rev. Jun. 2004;61:203-24. X-4. [pmid: 15155052].
728 Kurdi AM, Mesleh RA, Al-Hakeem MM, et al. Multiple pregnancy and preterm labor. Saudi Med J. May. 2004;25:632-7. X-2, X-3, X-4. [pmid: 15138532].
729 Lam H, Tang OS, Lee CP, et al. A pilot-randomized comparison of sublingual misoprostol with syntometrine on the blood loss in third stage of labor. Acta Obstet Gynecol Scand. Jul. 2004;83:647-50. X-4. [pmid: 15225189].
730 Laven RA, Livesey CT, May SA. Relationship between acute phase proteins and hoof horn haemorrhages in postpartum first-lactation heifers. Vet Rec. Mar. 27. 2004;154:389-95. X-3, X-4. [pmid: 15083972].
731 Lazarus JV, Lalonde A. Reducing postpartum hemorrhage in Africa. Int J Gynaecol Obstet. Jan. 2004;88:89-90. X-1. [pmid: 15617720].
732 Leverment J, Turner R, Bowman M, et al. Report of the use of hyperbaric oxygen therapy (HBO2) in an unusual case of secondary infertility. Undersea Hyperb Med. Summer. 2004;31:245-50. X-3, X-4. [pmid: 15485087].
733 Mascola MA, Schellpfeffer MA, Kruse TK, et al. Pregnancy-associated deaths and pregnancy-related deaths in Wisconsin, 1998-2001. WMJ. 2004;103:61-6. X-4. [pmid: 15553567].
734 Meldrum DJ, Evans G, Popham P. Spinal anaesthesia and dysfibrinogenaemia. Int J Obstet Anesth. Jan. 2004;10:64-7. X-4, X-5. [pmid: 15321654].
735 Mesleh R, Ayoub H, Algwiser A, et al. Emergency peripartum hysterectomy. J Obstet Gynaecol. Nov. 2004;18:533-7. X-2, X-4. [pmid: 15512170].
736 Mirghani HM, Hamed M, Ezimokhai M, et al. Pregnancy-related admissions to the intensive care unit. Int J Obstet Anesth. Apr. 2004;13:82-5. X-4, X-5. [pmid: 15321409].
737 Nahar S, Begum S, Yasnur S, et al. Use of Misoprostol for induction of labour in unfavorable cervix in eclampsia. Pakistan Journal of Medical Sciences. July/September. 2004;20:181-5. X-2, X-4.
738 Nanda S, Sharma N, Dahiya K, et al. Eyes do not see what the mind does not know: Pitfalls in the diagnosis of intraligamentary pregnancy. Journal of Gynecologic Surgery. Winter. 2004;20:131-4. X-1.
739 Nizard J, Pessel M, De Keersmaecker B, et al. High-intensity focused ultrasound in the treatment of postpartum hemorrhage: an animal model. Ultrasound Obstet Gynecol. Mar. 2004;23:262-6. X-3, X-4. [pmid: 15027015].
740 Noor S, Halimi M, Faiz NR, et al. Magnesium sulphate in the prophylaxis and treatment of eclampsia. J Ayub Med Coll Abbottabad. Apr-Jun. 2004;16:50-4. X-2, X-4. [pmid: 15455618].
741 O'Donoghue K, Byrne BM. Antenatal detection of abnormal liver function tests - a marker for poor perinatal outcome. J Obstet Gynaecol. Sep. 2004;20:475-8. X-4. [pmid: 15512630].
742 Ofir K, Sheiner E, Levy A, et al. Uterine rupture: differences between a scarred and an unscarred uterus. Am J Obstet Gynecol. Aug. 2004;191:425-9. X-4. [pmid: 15343216].
743 Ozden S, Yildirim G, Basaran T, et al. Analysis of 59 cases of emergent peripartum hysterectomies during a 13-year period. Arch Gynecol Obstet. Apr. 2004;271:363-7. X-2, X-4. [pmid: 15205986].
744 Potts M, Campbell M. Three meetings and fewer funerals--misoprostol in postpartum haemorrhage. Lancet. Sep 25-Oct 1. 2004;364:1110-1. X-1, X-4, X-5. [pmid: 15451208].
745 Ramsey PS, Savage K, Lincoln T, et al. Vaginal misoprostol versus concentrated oxytocin and vaginal PGE2 for second-trimester labor induction. Obstet Gynecol. Jul. 2004;104:138-45. X-4, X-5. [pmid: 15229013].
746 Robinson J. Why are more mothers dying?. AIMS Journal. 2004;16:1. X-1.
747 Ruano R, Dumez Y, Cabrol D, et al. Second- and third-trimester therapeutic terminations of pregnancy in cases with complete placenta previa--does feticide decrease postdelivery maternal hemorrhage?. Fetal Diagn Ther. Nov-Dec. 2004;19:475-8. X-4, X-5. [pmid: 15539869].
748 Segal S, Shemesh IY, Blumental R, et al. The use of recombinant factor VIIa in severe postpartum hemorrhage. Acta Obstet Gynecol Scand. Aug. 2004;83:771-2. X-5. [pmid: 15255852].
749 Serjeant GR, Loy LL, Crowther M, et al. Outcome of pregnancy in homozygous sickle cell disease. Obstet Gynecol. Jun. 2004;103:1278-85. X-4. [pmid: 15172865].
750 Sharma JB, Pundir P, Malhotra M, et al. Evaluation of placental drainage as a method of placental delivery in vaginal deliveries. Arch Gynecol Obstet. Apr. 2004;271:343-5. X-3, X-4. [pmid: 15034720].
751 Sheiner E, Levy A, Mazor M. Precipitate labor: higher rates of maternal complications. Eur J Obstet Gynecol Reprod Biol. Sep. 10. 2004;116:43-7. X-4. [pmid: 15294366].
752 Sibley L, Buffington ST, Haileyesus D. The American College of Nurse-Midwives' home-based lifesaving skills program: a review of the Ethiopia field test. J Midwifery Womens Health. Jul-Aug. 2004;49:320-8. X-2, X-3, X-4. [pmid: 15236712].
753 Simmonds M. Hemiparesis following post-partum haemorrhage and eclampsia. Int J Obstet Anesth. Oct. 2004;8:273-8. X-1, X-4. [pmid: 15321123].
754 Sokol ER, Casele H, Haney EI. Ultrasound examination of the postpartum uterus: what is normal?. J Matern Fetal Neonatal Med. Feb. 2004;15:95-9. X-3, X-4. [pmid: 15209115].
755 Stotland NE, Caughey AB, Breed EM, et al. Risk factors and obstetric complications associated with macrosomia. Int J Gynaecol Obstet. Dec. 2004;87:220-6. X-4. [pmid: 15548393].
756 Sullivan EA, Ford JB, Chambers G, et al. Maternal mortality in Australia, 1973-1996. Aust N Z J Obstet Gynaecol. Oct. 2004;44:452-7. discussion 377. X-4. [pmid: 15387869].
757 Tanaka YO, Shigemitsu S, Ichikawa Y, et al. Postpartum MR diagnosis of retained placenta accreta. Eur Radiol. Jun. 2004;14:945-52. X-4. [pmid: 15045519].
758 Thonneau PF, Matsudai T, Alihonou E, et al. Distribution of causes of maternal mortality during delivery and post-partum: results of an African multicentre hospital-based study. Eur J Obstet Gynecol Reprod Biol. Jun. 15. 2004;114:150-4. X-2, X-4. [pmid: 15140507].
759 Tsang ML, Wong WC, Kun KY, et al. Arterial embolisation in intractable primary post-partum haemorrhage: case series. Hong Kong Med J. Oct. 2004;10:301-6. X-4, X-5. [pmid: 15479957].
760 Tsukahara T, Ezaki T, Moriguchi J, et al. No effects of hematuria and proteinuria in school days, and probably current pregnancy and current lactation also, as risk factors of cadmium-induced renal tubular dysfunction among adult women in general populations in Japan. Arch Environ Contam Toxicol. Apr. 2004;46:413-8. X-3, X-4. [pmid: 15195814].
761 Ural SH. Management of catastrophic obstetrical hemorrhages: review questions. Hospital Physician. 2004;40:35-6. X-1.
762 Valbonesi M, Giannini G. Nine years of cascade filtration for thrombotic thrombocytopenic purpura. Ther Apher Dial. Apr. 2004;8:87-92. X-2, X-4, X-5. [pmid: 15255122].
763 Vanderjagt DJ, Patel RJ, El-Nafaty AU, et al. High-density lipoprotein and homocysteine levels correlate inversely in preeclamptic women in northern Nigeria. Acta Obstet Gynecol Scand. Jun. 2004;83:536-42. X-2, X-3, X-4. [pmid: 15144334].
764 Vanek M, Sheiner E, Levy A, et al. Chronic hypertension and the risk for adverse pregnancy outcome after superimposed pre-eclampsia. Int J Gynaecol Obstet. Jul. 2004;86:7-11. X-4. [pmid: 15207662].
765 Vimala N, Mittal S, Kumar S, et al. Sublingual misoprostol versus methylergometrine for active management of the third stage of labor. Int J Gynaecol Obstet. Oct. 2004;87:1-5. X-3, X-4. [pmid: 15464767].
766 Vogel D, Burkhardt T, Rentsch K, et al. Misoprostol versus methylergometrine: pharmacokinetics in human milk. Am J Obstet Gynecol. Dec. 2004;191:2168-73. X-4, X-5. [pmid: 15592308].
767 Walker MC, Murphy KE, Pan S, et al. Adverse maternal outcomes in multifetal pregnancies. BJOG. Nov. 2004;111:1294-6. X-4. [pmid: 15521878].
768 Walraven G, Dampha Y, Bittaye B, et al. Misoprostol in the treatment of postpartum haemorrhage in addition to routine management: a placebo randomised controlled trial. BJOG. Sep. 2004;111:1014-7. X-2, X-4, X-5. [pmid: 15327620].
769 Weerasekera DS. Placenta praevia and scarred uterus - an obstetrician's dilemma. J Obstet Gynaecol. Sep. 2004;20:484-5. X-1, X-4. [pmid: 15512632].
770 Weerasekera DS. The role of forceps in modern obstetrics. J Obstet Gynaecol. Mar. 2004;19:146-9. X-2, X-4. [pmid: 15512255].
771 Yamani Zamzami TY. Vaginal birth after cesarean section in grand multiparous women. Arch Gynecol Obstet. Jul. 2004;270:21-4. X-2, X-4. [pmid: 15224215].
772 Zhou W, Gao E, Che Y, et al. Induced abortion and duration of third stage labour in a subsequent pregnancy. J Obstet Gynaecol. Jul. 2004;19:349-54. X-2, X-4. [pmid: 15512328].
773 International joint policy statement. FIGO/ICM global initiative to prevent post-partum hemorrhage. J Obstet Gynaecol Can. Dec. 2005;26:1100-2. 8. 11. X-1, X-2, X-4, X-5. [pmid: 15696639].
774 Accidental child poisoning with methylergometrine intended for the mother. Prescrire Int. Feb. 2005;14:23-4. X-1. [pmid: 15751178].
775 Nettalk. Midwifery Matters. 2005:32-6. X-1, X-4.
776 Adams V, Miller S, Craig S, et al. The challenge of cross-cultural clinical trials research: case report from the Tibetan Autonomous Region, People's Republic of China. Med Anthropol Q. Sep. 2005;19:267-89. X-2, X-3, X-4. [pmid: 16222962].
777 Adeniran JO, Abdur-Rahman L. One-stage correction of intermediate imperforate anus in males. Pediatr Surg Int. Feb. 2005;21:88-90. X-3. [pmid: 15630587].
778 Aggarwal N, Suri V, Malhotra S. Use of misoprostol for control of post-partum haemorrhage in a case of aplastic anaemia. Bulletin, Postgraduate Institute of Medical Education and Research. Chandigarh. September. 2005;39:121-2. X-2, X-4.
779 Ahonen J, Jokela R. Recombinant factor VIIa for life-threatening post-partum haemorrhage. Br J Anaesth. May. 2005;94:592-5. X-5. [pmid: 15708871].
780 Aisien AO, Oronsaye AU. Vaginal birth after one previous caesarean section in a tertiary institution in Nigeria. J Obstet Gynaecol. Nov. 2005;24:886-90. X-2, X-3, X-4. [pmid: 16147643].
781 Akhter S, Begum MR, Kabir J. Condom hydrostatic tamponade for massive postpartum hemorrhage. Int J Gynaecol Obstet. Aug. 2005;90:134-5. X-2, X-5. [pmid: 15913618].
782 Al Sakka M, Rasul KI, Dauleh W, et al. Presentation and management of post-partum choriocarcinoma in Qatar. Qatar Medical Journal. June. 2005;14:20-2. X-1, X-2.
783 Alder CM, Patterson DK. Radiological case of the month... complete uterine perforation by an intrauterine contraceptive device. Applied Radiology. 2005;34:41. X-1, X-4, X-5.
784 Ali SI, Ibraham RC, Joseph L. Transfusion related acute lung injury: A case report. Pakistan Journal of Medical Sciences. April/June. 2005;21:223-4. X-1, X-2.
785 Allam MS, C BL. The B-Lynch and other uterine compression suture techniques. Int J Gynaecol Obstet. Jun. 2005;89:236-41. X-1. [pmid: 15919388].
786 Baksu A, Kalan A, Ozkan A, et al. The effect of placental removal method and site of uterine repair on postcesarean endometritis and operative blood loss. Acta Obstet Gynecol Scand. Mar. 2005;84:266-9. X-3. [pmid: 15715535].
787 Baskett TF, O'Connell CM. Severe obstetric maternal morbidity: a 15-year population-based study. J Obstet Gynaecol. Jan. 2005;25:7-9. X-4. [pmid: 16147683].
788 Ben-Ami I, Schneider D, Maymon R, et al. Sonographic versus clinical evaluation as predictors of residual trophoblastic tissue. Hum Reprod. Apr. 2005;20:1107-11. X-3. [pmid: 15650045].
789 Berg C, Ludwig M, Sturm N, et al. Intraamniotic ethacridine lactate instillation versus vaginal PGE1 in second trimester termination of pregnancy. Eur J Obstet Gynecol Reprod Biol. Jun. 1. 2005;126:193-6. X-3, X-4. [pmid: 16188373].
790 Berg CJ, Harper MA, Atkinson SM, et al. Preventability of pregnancy-related deaths: results of a state-wide review. Obstet Gynecol. Dec. 2005;106:1228-34. X-4. [pmid: 16319245].
791 Bessos H, Seghatchian J. What's happening? The expanding role of apheresis platelet support in neonatal alloimmune thrombocytopenia: current status and future trends. Transfus Apher Sci. Oct. 2005;33:191-7. X-1. [pmid: 16140039].
792 Betts D. Post natal acupuncture. Journal of Chinese Medicine. 2005:5-16. X-1, X-4, X-5.
793 Beuker JM, Erwich JJ, Khong TY. Is endomyometrial injury during termination of pregnancy or curettage following miscarriage the precursor to placenta accreta?. J Clin Pathol. Mar. 2005;58:273-5. X-4. [pmid: 15735159].
794 Bolbos G, Sindos M. The Bolbos technique for the management of uncontrollable intra-caesarean uterine bleeding. Arch Gynecol Obstet. Jul. 2005;272:142-4. X-1, X-5. [pmid: 15770514].
795 Bondagji N. The perinatal and neonatal outcome in grand-grand multiparous women, a comparative case control study. Bahrain Medical Bulletin. December. 2005;27:180-2. X-2, X-4.
796 Carpenter TT, Walker WJ. Pregnancy following uterine artery embolisation for symptomatic fibroids: a series of 26 completed pregnancies. BJOG. Mar. 2005;112:321-5. X-3, X-4. [pmid: 15713147].
797 Chandhiok N, Dhillon BS, Datey S, et al. Oral misoprostol for prevention of postpartum hemorrhage by paramedical workers in India. Int J Gynaecol Obstet. Feb. 2005;92:170-5. X-2, X-4. [pmid: 16371228].
798 Clark V. Facilities for blood salvage (cell saver technique) must be available in every obstetric theatre. Int J Obstet Anesth. Jan. 2005;14:50-2. X-1, X-2, X-4, X-5. [pmid: 15627540].
799 Collins D. Legally speaking: risk management in obstetrics and gynecology. Contemporary OB/GYN. 2005;50:23. X-1, X-4, X-5.
800 Conde-Agudelo A, Belizan JM, Lammers C. Maternal-perinatal morbidity and mortality associated with adolescent pregnancy in Latin America: Cross-sectional study. Am J Obstet Gynecol. Feb. 2005;192:342-9. X-2, X-4. [pmid: 15695970].
801 Daramola AO, Banjo AA, Elesha SO. Maternal deaths in the Lagos University Teaching Hospital: a ten-year review (1989 - 1998). Niger Postgrad Med J. Dec. 2005;11:274-8. X-2, X-4. [pmid: 15627156].
802 Davies GA, Tessier JL, Woodman MC, et al. Maternal hemodynamics after oxytocin bolus compared with infusion in the third stage of labor: a randomized controlled trial. Obstet Gynecol. Feb. 2005;105:294-9. X-4. [pmid: 15684155].
803 Demirci F, Ozdemir I, Safak A, et al. Comparison of colour Doppler indices of pelvic arteries in women with bilateral hypogastric artery ligation and controls. J Obstet Gynaecol. Apr. 2005;25:273-4. X-2, X-5. [pmid: 16147734].
804 Denton J. Twins and more--1. Some current thinking on multiple births. J Fam Health Care. 2005;15:143-6. X-1. [pmid: 16315682].
805 Detti L, Mecacci F, Piccioli A, et al. Postpartum heparin therapy for patients with the syndrome of hemolysis, elevated liver enzymes, and low platelets (HELLP) is associated with significant hemorrhagic complications. J Perinatol. Apr. 2005;25:236-40. X-5. [pmid: 15703776].
806 El-Hamamy E, C BL. A worldwide review of the uses of the uterine compression suture techniques as alternative to hysterectomy in the management of severe post-partum haemorrhage. J Obstet Gynaecol. Feb. 2005;25:143-9. X-1. [pmid: 15814393].
807 Epiney M, Boehlen F, Boulvain M, et al. D-dimer levels during delivery and the postpartum. J Thromb Haemost. Feb. 2005;3:268-71. X-3, X-4. [pmid: 15670031].
808 Fareh OI, Rizk DE, Thomas L, et al. Obstetric impact of anaemia in pregnant women in United Arab Emirates. J Obstet Gynaecol. Jul. 2005;25:440-4. X-4. [pmid: 16183576].
809 Fenton JJ, Baumeister LM, Fogarty J. Active management of the third stage of labor among American Indian women. Fam Med. Jun. 2005;37:410-4. X-2, X-4, X-5. [pmid: 15933913].
810 Fischer A, LaCoursiere DY, Barnard P, et al. Differences between hospitals in cesarean rates for term primigravidas with cephalic presentation. Obstet Gynecol. Apr. 2005;105:816-21. X-4. [pmid: 15802411].
811 Garg P, Batra S, Gandhi G. Oral misoprostol versus injectable methylergometrine in management of the third stage of labor. Int J Gynaecol Obstet. Nov. 2005;91:160-1. X-4. [pmid: 16126208].
812 Hamm J, Russell Z, Botha T, et al. Buccal misoprostol to prevent hemorrhage at cesarean delivery: a randomized study. Am J Obstet Gynecol. May. 2005;192:1404-6. X-2, X-4, X-5. [pmid: 15902121].
813 Hamoda H, Critchley HO, Paterson K, et al. The acceptability of home medical abortion to women in UK settings. BJOG. Jun. 2005;112:781-5. X-3, X-4. [pmid: 15924537].
814 Haq G, Tayyab S. Control of postpartum and post abortal haemorrhage with uterine packing. J Pak Med Assoc. Sep. 2005;55:369-71. X-2, X-5. [pmid: 16302468].
815 Harvey P. The role of the ODP in obstetric haemorrhage. Journal of Operating Department Practice. 2005;1:16-9. X-1, X-4.
816 Henry A, Birch MR, Sullivan EA, et al. Primary postpartum haemorrhage in an Australian tertiary hospital: a case-control study. Aust N Z J Obstet Gynaecol. Jun. 2005;45:233-6. X-4. [pmid: 15904450].
817 Hoj L, Cardoso P, Nielsen BB, et al. Effect of sublingual misoprostol on severe postpartum haemorrhage in a primary health centre in Guinea-Bissau: randomised double blind clinical trial. BMJ. Oct. 1. 2005;331:723. X-2, X-4. [pmid: 16195287].
818 Hwu YM, Chen CP, Chen HS, et al. Parallel vertical compression sutures: a technique to control bleeding from placenta praevia or accreta during caesarean section. Bjog. Oct. 2005;112:1420-3. X-2, X-5. [pmid: 16167948].
819 Islam MA, Chowdhury RI, Chakraborty N, et al. Factors associated with delivery complications in rural Bangladesh. Eur J Contracept Reprod Health Care. Dec. 2005;9:203-13. X-2, X-4. [pmid: 15799179].
820 James AH, Bushnell CD, Jamison MG, et al. Incidence and risk factors for stroke in pregnancy and the puerperium. Obstet Gynecol. Sep. 2005;106:509-16. X-4, X-5. [pmid: 16135580].
821 Jerbi M, Hidar S, Zardi H, et al. Previous cesarean scar exploration following vaginal delivery and hemorrhagic morbidity. Int J Gynaecol Obstet. Feb. 2005;92:135-6. X-2, X-4, X-5. [pmid: 16378610].
822 Jyotsna A, Jopir E, Devi Kh I, et al. An observational study on the outcomes of pregnancy with myomas. JMS - Journal of Medical Society. September. 2005;19:117-20. X-2, X-4.
823 Kelestimur F, Jonsson P, Molvalilar S, et al. Sheehan's syndrome: baseline characteristics and effect of 2 years of growth hormone replacement therapy in 91 patients in KIMS - Pfizer International Metabolic Database. Eur J Endocrinol. Apr. 2005;152:581-7. X-4, X-5. [pmid: 15817914].
824 Kwee A, Bots ML, Visser GH, et al. Emergency peripartum hysterectomy: A prospective study in The Netherlands. Eur J Obstet Gynecol Reprod Biol. Feb. 1. 2005;124:187-92. X-2, X-5. [pmid: 16026917].
825 Larsen R, Titlestad K, Lillevang ST, et al. Cesarean section: is pretransfusion testing for red cell alloantibodies necessary?. Acta Obstet Gynecol Scand. May. 2005;84:448-55. X-3, X-4. [pmid: 15842209].
826 Lema VM, Changole J, Kanyighe C, et al. Maternal mortality at the Queen Elizabeth Central Teaching Hospital, Blantyre, Malawi. East Afr Med J. Jan. 2005;82:3-9. X-2, X-4. [pmid: 16122104].
827 Liu S, Heaman M, Joseph KS, et al. Risk of maternal postpartum readmission associated with mode of delivery. Obstet Gynecol. Apr. 2005;105:836-42. X-4. [pmid: 15802414].
828 Maclean AB. Ergometrine. J Obstet Gynaecol. Jan. 2005;25:1-2. X-1, X-4, X-5. [pmid: 16147681].
829 Magann EF, Evans S, Chauhan SP, et al. The length of the third stage of labor and the risk of postpartum hemorrhage. Obstet Gynecol. Feb. 2005;105:290-3. X-4. [pmid: 15684154].
830 Magann EF, Evans S, Hutchinson M, et al. Postpartum hemorrhage after vaginal birth: an analysis of risk factors. South Med J. Apr. 2005;98:419-22. X-4. [pmid: 15898516].
831 Magann EF, Evans S, Hutchinson M, et al. Postpartum hemorrhage after cesarean delivery: an analysis of risk factors. South Med J. Jul. 2005;98:681-5. X-4. [pmid: 16108235].
832 Malik AM, Shah IA, Iqbal T, et al. A study to determine the risks associated with grand multiparity. Medical Forum Monthly. February. 2005;16:17-20. X-2, X-4.
833 Maslovitz S, Many A, Landsberg JA, et al. The safety of low molecular weight heparin therapy during labor. J Matern Fetal Neonatal Med. Jan. 2005;17:39-43. X-4. [pmid: 15804785].
834 Mathew M, Machado L, Al-Ghabshi R, et al. Fetal macrosomia. Risk factor and outcome. Saudi Med J. Jan. 2005;26:96-100. X-2, X-4. [pmid: 15756361].
835 Mazouni C, Bretelle F, Collette E, et al. Maternal and neonatal morbidity after first vaginal delivery using Thierry's spatulas. Aust N Z J Obstet Gynaecol. Oct. 2005;45:405-9. X-3, X-4. [pmid: 16171477].
836 McLean MT. Marion's message. Unchanging protocols. Midwifery Today Int Midwife. Spring. 2005;9:66. [pmid: 15835835]. X-1, X-2, X-4, X-5.
837 McLintock C. Postpartum haemorrhage. Thromb Res. Feb. Suppl 1. 2005;115:65-8. X-1. [pmid: 15790159].
838 Mesogitis S, Pilalis A, Daskalakis G, et al. Management of early viable cervical pregnancy. BJOG. Apr. 2005;112:409-11. X-4, X-5. [pmid: 15777436].
839 Milan M. Independent midwifery compared with other caseload practice. MIDIRS Midwifery Digest. 2005;15:439-49. X-1, X-4.
840 Moiloa MRA. The toxic effects of the African pitocine: Leucas capensis in relation to the law of similars. Homoeopathic Links. 2005;18:209-13. X-2, X-4, X-5.
841 Nwagha UI, Okaro JM, Nwagha TU. Intraoperative uterine packing with mops: an effective, but under utilized method of controlling post partum haemorrhage-experience from South Eastern Nigeria. Niger J Med. Jul-Sep. 2005;14:279-82. X-2. [pmid: 16350697].
842 Oberbaum M, Galoyan N, Lerner-Geva L, et al. The effect of the homeopathic remedies Arnica montana and Bellis perennis on mild postpartum bleeding--a randomized, double-blind, placebo-controlled study--preliminary results. Complement Ther Med. Jun. 2005;13:87-90. X-4, X-5. [pmid: 16036165].
843 Ojala K, Perala J, Kariniemi J, et al. Arterial embolization and prophylactic catheterization for the treatment for severe obstetric hemorrhage*. Acta Obstet Gynecol Scand. Nov. 2005;84:1075-80. X-5. [pmid: 16232175].
844 Ozkaya O, Sezik M, Kaya H, et al. Placebo-controlled randomized comparison of vaginal with rectal misoprostol in the prevention of postpartum hemorrhage. J Obstet Gynaecol Res. Oct. 2005;31:389-93. X-4. [pmid: 16176505].
845 Papp Z, Toth-Pal E, Papp C, et al. Hypogastric artery ligation for intractable pelvic hemorrhage. Int J Gynaecol Obstet. Jan. 2005;92:27-31. X-5. [pmid: 16242133].
846 Pather S, Ford M, Reid R, et al. Postpartum curettage: an audit of 200 cases. Aust N Z J Obstet Gynaecol. Oct. 2005;45:368-71. X-4, X-5. [pmid: 16171469].
847 Pereira A, Nunes F, Pedroso S, et al. Compressive uterine sutures to treat postpartum bleeding secondary to uterine atony. Obstet Gynecol. Sep. 2005;106:569-72. X-5. [pmid: 16135589].
848 Prata N, Mbaruku G, Campbell M. Using the kanga to measure postpartum blood loss. Int J Gynaecol Obstet. Apr. 2005;89:49-50. X-2, X-4, X-5. [pmid: 15777900].
849 Prata N, Mbaruku G, Campbell M, et al. Controlling postpartum hemorrhage after home births in Tanzania. Int J Gynaecol Obstet. Jul. 2005;90:51-5. X-2. [pmid: 15919088].
850 Rabelo E, Rezende RL, Bertics SJ, et al. Effects of pre- and postfresh transition diets varying in dietary energy density on metabolic status of periparturient dairy cows. J Dairy Sci. Dec. 2005;88:4375-83. X-3, X-4. [pmid: 16291629].
851 Romano PS, Yasmeen S, Schembri ME, et al. Coding of perineal lacerations and other complications of obstetric care in hospital discharge data. Obstet Gynecol. Oct. 2005;106:717-25. X-3, X-4. [pmid: 16199627].
852 Rudra A, Rautji R, Behera C, et al. Fatal uterine inversion in a home delivery - A case report. International Journal of Medical Toxicology and Legal Medicine. July/December. 2005;8:15-6. X-1.
853 Salomon O, Steinberg DM, Pshithizki M, et al. The influence of prothrombotic polymorphisms and obstetrical and medical variables on the length of secondary postpartum hemorrhage. J Womens Health (Larchmt). May. 2005;14:306-10. X-4. [pmid: 15916503].
854 Salomon O, Steinberg DM, Tamarin I, et al. Plasma replacement therapy during labor is not mandatory for women with severe factor XI deficiency. Blood Coagul Fibrinolysis. Jan. 2005;16:37-41. X-4, X-5. [pmid: 15650544].
855 Samuels N, Oberbaum M. The effect of the homoeopathic remedies Arnica montana and Bellis perennis on postpartum bleeding -- a randomised, double-blind, placebo-controlled study. 12th Annual Symposium on Complementary Health Care -- Abstracts. 19th-21st September 2005. Exeter, UK. Focus on Alternative & Complementary Therapies. 2005;10:47. X-2, X-4, X-5.
856 Schaaps JP, Tsatsaris V, Goffin F, et al. Shunting the intervillous space: new concepts in human uteroplacental vascularization. Am J Obstet Gynecol. Jan. 2005;192:323-32. X-3, X-4. [pmid: 15672043].
857 Schaff EA, DiCenzo R, Fielding SL. Comparison of misoprostol plasma concentrations following buccal and sublingual administration. Contraception. Jan. 2005;71:22-5. X-3, X-4. [pmid: 15639067].
858 Selo-Ojeme DO, Bhattacharjee P, Izuwa-Njoku NF, et al. Emergency peripartum hysterectomy in a tertiary London hospital. Arch Gynecol Obstet. Feb. 2005;271:154-9. X-4, X-5. [pmid: 15690169].
859 Serjeant GR, Hambleton I, Thame M. Fecundity and pregnancy outcome in a cohort with sickle cell-haemoglobin C disease followed from birth. BJOG. Sep. 2005;112:1308-14. X-2, X-4. [pmid: 16101613].
860 Seror J, Allouche C, Elhaik S. Use of Sengstaken-Blakemore tube in massive postpartum hemorrhage: a series of 17 cases. Acta Obstet Gynecol Scand. Jul. 2005;84:660-4. X-5. [pmid: 15954876].
861 Sharma S, Tandon VR, Gupta S. Alternative obstetrics. JK Science. October/December. 2005;7:236-8. X-1.
862 Sheiner E, Sarid L, Levy A, et al. Obstetric risk factors and outcome of pregnancies complicated with early postpartum hemorrhage: a population-based study. J Matern Fetal Neonatal Med. Sep. 2005;18:149-54. X-4, X-5. [pmid: 16272036].
863 Shen JJ, Tymkow C, MacMullen N. Disparities in maternal outcomes among four ethnic populations. Ethn Dis. Summer. 2005;15:492-7. X-4. [pmid: 16108310].
864 Shoukrey MN, Fakokunde AF, Whitlow B, et al. Postpartum transcervical endometrial resection under laparoscopic control for retained degenerated products of conception. Gynecological Surgery. September. 2005;2:201-3. X-2, X-5.
865 Sieunarine K, Moxey P, Boyle DC, et al. Selective vessel ligation in the pelvis: an invaluable tool in certain surgical procedures. Int J Gynecol Cancer. Sep-Oct. 2005;15:967-73. X-3, X-4. [pmid: 16174253].
866 Simon CE, Grobman WA. When has an induction failed?. Obstet Gynecol. Apr. 2005;105:705-9. X-2, X-4, X-5. [pmid: 15802394].
867 Sinclair D, Gaither K, Mason TC. Fertility outcomes following myomectomy in an urban hospital setting. J Natl Med Assoc. Oct. 2005;97:1346-8. X-4. [pmid: 16353656].
868 Strand RT, Da Silva F, Jangsten E, et al. Postpartum hemorrhage: a prospective, comparative study in Angola using a new disposable device for oxytocin administration. Acta Obstet Gynecol Scand. Mar. 2005;84:260-5. X-2, X-4. [pmid: 15715534].
869 Tabassum S, Afridi B, Aman Z. Phloroglucinol for acceleration of labour: double blind, randomized controlled trial. J Pak Med Assoc. Jul. 2005;55:270-3. X-2, X-4. [pmid: 16108507].
870 Tata LJ, Card TR, Logan RF, et al. Fertility and pregnancy-related events in women with celiac disease: a population-based cohort study. Gastroenterology. Apr. 2005;128:849-55. X-4. [pmid: 15825068].
871 Taylor LK, Simpson JM, Roberts CL, et al. Risk of complications in a second pregnancy following caesarean section in the first pregnancy: a population-based study. Med J Aust. Nov. 21. 2005;183:515-9. X-4. [pmid: 16296964].
872 Thomas D. Facilities for blood salvage (cell saver technique) must be available in every obstetric theatre. Int J Obstet Anesth. Jan. 2005;14(1):48-50. X-1. [pmid: 15627539].
873 Usha Kiran TS, Hemmadi S, Bethel J, et al. Outcome of pregnancy in a woman with an increased body mass index. BJOG. Jun. 2005;112:768-72. X-4. [pmid: 15924535].
874 Vardhan S, Behra RC, Jose T, et al. Hydramnios associated with foetal duodenal atresia. Medical Journal Armed Forces India. October. 2005;61:387-8. X-1, X-2.
875 Vasegh FR, Bahiraie A, Mahmoudi M, et al. Comparison of active and physiologic management of third stage of labor. HAYAT. 2005. Winter. 2005;10:102. X-1.
876 Vegas G, Illescas T, Munoz M, et al. Selective pelvic arterial embolization in the management of obstetric hemorrhage. Eur J Obstet Gynecol Reprod Biol. Jul. 2005;127:68-72. X-5. [pmid: 16229935].
877 Vimala N, Mittal S, Kumar S. Sublingual misoprostol versus oxytocin infusion to reduce blood loss at cesarean section. Int J Gynaecol Obstet. Feb. 2005;92:106-10. X-3, X-4. [pmid: 16343498].
878 Walraven G, Blum J, Dampha Y, et al. Misoprostol in the management of the third stage of labour in the home delivery setting in rural Gambia: a randomised controlled trial. BJOG. Sep. 2005;112:1277-83. X-2, X-4. [pmid: 16101608].
879 Weiniger CF, Elram T, Ginosar Y, et al. Anaesthetic management of placenta accreta: use of a pre-operative high and low suspicion classification. Anaesthesia. Nov. 2005;60:1079-84. X-4, X-5. [pmid: 16229692].
880 Wen SW, Huang L, Liston R, et al. Severe maternal morbidity in Canada, 1991-2001. CMAJ. Sep. 27. 2005;173:759-64. X-4. [pmid: 16186582].
881 Wu HH, Yeh GP. Uterine cavity synechiae after hemostatic square suturing technique. Obstet Gynecol. May. 2005;105:1176-8. X-2, X-5. [pmid: 15863572].
882 Yamada T, Mori H, Ueki M. Autologous blood transfusion in patients with placenta previa. Acta Obstet Gynecol Scand. Mar. 2005;84:255-9. X-4. [pmid: 15715533].
883 Yasmeen S, Danielsen B, Moshesh M, et al. Is grandmultiparity an independent risk factor for adverse perinatal outcomes?. J Matern Fetal Neonatal Med. Apr. 2005;17:277-80. X-4. [pmid: 16147837].
884 Zachariah ES, Naidu M, Seshadri L. Oral misoprostol in the third stage of labor. Int J Gynaecol Obstet. Jan. 2005;92:23-6. X-2, X-5. [pmid: 16271721].
885 Zeteroglu S, Sahin HG, Sahin HA. Induction of labor in great grandmultipara with misoprostol. Eur J Obstet Gynecol Reprod Biol. May. 1. 2005;126:27-32. X-4. [pmid: 16129547].
886 Zeteroglu S, Ustun Y, Engin-Ustun Y, et al. Peripartum hysterectomy in a teaching hospital in the eastern region of Turkey. Eur J Obstet Gynecol Reprod Biol. May. 1. 2005;120:57-62. X-2. [pmid: 15866087].
887 ACOG Practice Bulletin: Clinical Management Guidelines for Obstetrician-Gynecologists Number 76, October 2006: postpartum hemorrhage. Obstet Gynecol. Oct. 2006;108:1039-47. X-1. [pmid: 17012482].
888 In vitro fertilization and multiple pregnancies: an evidence-based analysis. Ont Health Technol Assess Ser. 2006;6:1-63. X-1, X-3. [pmid: 23074488].
889 Abdel-Aleem H, Hofmeyr GJ, Shokry M, et al. Uterine massage and postpartum blood loss. Int J Gynaecol Obstet. Jun. 2006;93:238-9. X-2, X-4, X-5. [pmid: 16678826].
890 Abdullah LS. Hysterectomy: A clinicopathologic correlation. Bahrain Medical Bulletin. June. 2006;28:77-9. X-1, X-2, X-3, X-4.
891 Allahdin S, Aird C, Danielian P. B-Lynch sutures for major primary postpartum haemorrhage at caesarean section. J Obstet Gynaecol. Oct. 2006;26:639-42. X-2, X-5. [pmid: 17071430].
892 Allen VM, O'Connell CM, Baskett TF. Maternal morbidity associated with cesarean delivery without labor compared with induction of labor at term. Obstet Gynecol. Aug. 2006;108:286-94. X-2, X-4. [pmid: 16880297].
893 Al-Suleiman SA, Qutub HO, Rahman J, et al. Obstetric admissions to the intensive care unit: a 12-year review. Arch Gynecol Obstet. Apr. 2006;274:4-8. X-2, X-4, X-5. [pmid: 16432668].
894 Al-Taani MI. Termination of second trimester, complicated gestation. East Mediterr Health J. Jul. 2006;11:657-62. X-2, X-4, X-5. [pmid: 16700381].
895 Armbruster D. International survey of the management of the third stage of labor. Journal of Midwifery & Women's Health. 2006;51:387. X-1, X-4, X-5.
896 Ayuk PT. Hypertensive disorders of pregnancy are an evolutionary adaptation to mitigate the reproductive consequences of the human physique. Med Hypotheses. 2006;67:796-801. X-1. [pmid: 16759809].
897 Bainbridge J. Anti-shock suit to control postpartum haemorrhage could save lives. British Journal of Midwifery. 2006;14:186. X-1.
898 Banks E, Meirik O, Farley T, et al. Female genital mutilation and obstetric outcome: WHO collaborative prospective study in six African countries. Lancet. Jun. 3. 2006;367:1835-41. X-2, X-3, X-4. [pmid: 16753486].
899 Berg M. Obstetric hemorrhage. Laboratory Medicine. 2006;37:45. X-1, X-2, X-4, X-5.
900 Bista BK, Rana A. Acute hepatitis E in pregnancy--study of 16 cases. JNMA J Nepal Med Assoc. Jan-Mar. 2006;45:182-5. X-1, X-2, X-4. [pmid: 17160094].
901 Borna S, Borna H, Khazardoost S. Maternal and neonatal outcomes in pregnant women with immune thrombocytopenic purpura. Arch Iran Med. Apr. 2006;9:115-8. X-2, X-4. [pmid: 16649352].
902 Bose P, Regan F, Paterson-Brown S. Improving the accuracy of estimated blood loss at obstetric haemorrhage using clinical reconstructions. BJOG. Aug. 2006;113:919-24. X-3, X-4. [pmid: 16907938].
903 Cameron CA, Roberts CL, Olive EC, et al. Trends in postpartum haemorrhage. Aust N Z J Public Health. Apr. 2006;30:151-6. X-4. [pmid: 16681337].
904 Caughey AB, Bishop JT. Maternal complications of pregnancy increase beyond 40 weeks of gestation in low-risk women. J Perinatol. Sep. 2006;26:540-5. X-3, X-4. [pmid: 16837930].
905 Ceriani Cernadas JM, Carroli G, Pellegrini L, et al. The effect of timing of cord clamping on neonatal venous hematocrit values and clinical outcome at term: a randomized, controlled trial. Pediatrics. Apr. 2006;117:e779-86. X-3, X-4. [pmid: 16567393].
906 Charbit B, Mandelbrot L, Samain E, et al. The decrease of fibrinogen is an early predictor of the severity of postpartum hemorrhage. J Thromb Haemost. Feb. 2006;5:266-73. X-4. [pmid: 17087729].
907 Chi C, Shiltagh N, Kingman CE, et al. Identification and management of women with inherited bleeding disorders: a survey of obstetricians and gynaecologists in the United Kingdom. Haemophilia. Jul. 2006;12:405-12. X-3, X-4. [pmid: 16834742].
908 Deans R, Dietz HP. Ultrasound of the post-partum uterus. Aust N Z J Obstet Gynaecol. Aug. 2006;46:345-9. X-3, X-4. [pmid: 16866798].
909 Demers C, Derzko C, David M, et al. Gynaecological and obstetric management of women with inherited bleeding disorders. Int J Gynaecol Obstet. Oct. 2006;95:75-87. X-1. [pmid: 17106950].
910 Deneux-Tharaux C, Carmona E, Bouvier-Colle MH, et al. Postpartum maternal mortality and cesarean delivery. Obstet Gynecol. Sep. 2006;108:541-8. X-4. [pmid: 16946213].
911 Derman RJ, Kodkany BS, Goudar SS, et al. Oral misoprostol in preventing postpartum haemorrhage in resource-poor communities: a randomised controlled trial. Lancet. Oct. 7. 2006;368:1248-53. X-2, X-4. [pmid: 17027730].
912 Dildy GA, Scott JR, Saffer CS, et al. An effective pressure pack for severe pelvic hemorrhage. Obstet Gynecol. Nov. 2006;108:1222-6. X-2, X-5. [pmid: 17077246].
913 Doherty DA, Magann EF, Francis J, et al. Pre-pregnancy body mass index and pregnancy outcomes. Int J Gynaecol Obstet. Dec. 2006;95:242-7. X-4. [pmid: 17007857].
914 Eniola OA, Bewley S, Waterstone M, et al. Obstetric hysterectomy in a population of South East England. J Obstet Gynaecol. Feb. 2006;26:104-9. X-5. [pmid: 16483963].
915 Francois K. Grand rounds. Critical care in OB part 1: managing uterine atony and hemorrhagic shock. Contemporary OB/GYN. 2006;51:52-9. X-1.
916 Fujimoto M, Takeuchi K, Sugimoto M, et al. Prevention of postpartum hemorrhage by uterotonic agents: comparison of oxytocin and methylergometrine in the management of the third stage of labor. Acta Obstet Gynecol Scand. 2006;85:1310-4. X-2, X-4. [pmid: 17091409].
917 Fuller AJ, Carvalho B, Brummel C, et al. Epidural anesthesia for elective cesarean delivery with intraoperative arterial occlusion balloon catheter placement. Anesth Analg. Feb. 2006;102:585-7. X-4, X-5. [pmid: 16428566].
918 Geelhoed D, Agadzi F, Visser L, et al. Maternal and fetal outcome after severe anemia in pregnancy in rural Ghana. Acta Obstet Gynecol Scand. 2006;85:49-55. X-2, X-4. [pmid: 16521680].
919 Ghaem-Maghami S, Brockbank E, Bridges J. Survey of surgical experience during training in obstetrics and gynaecology in the UK. J Obstet Gynaecol. May. 2006;26:297-301. X-1, X-3, X-4. [pmid: 16753675].
920 Girolami A, Randi ML, Ruzzon E, et al. Pregnancy and oral contraceptives in congenital bleeding disorders of the vitamin K-dependent coagulation factors. Acta Haematol. 2006;115:58-63. X-4, X-5. [pmid: 16424651].
921 Guendelman S, Thornton D, Gould J, et al. Obstetric complications during labor and delivery: assessing ethnic differences in California. Womens Health Issues. Jul-Aug. 2006;16:189-97. X-4. [pmid: 16920523].
922 Habek D, Becarevic R. Emergency peripartum hysterectomy in a tertiary obstetric center: 8-year evaluation. Fetal Diagn Ther. 2006;22:139-42. X-5. [pmid: 17139172].
923 Habek D, Vranjes M, Bobic Vukovic M, et al. Successful term pregnancy after B-Lynch compression suture in a previous pregnancy on account of massive primary postpartum hemorrhage. Fetal Diagn Ther. 2006;21:475-6. X-5. [pmid: 16912499].
924 Hadar A, Rabinovich A, Sheiner E, et al. Obstetric characteristics and neonatal outcome of unplanned out-of-hospital term deliveries: a prospective, case-control study. J Reprod Med. Nov. 2006;50:832-6. X-4. [pmid: 16419631].
925 Haynes J, Laffan M, Plaat F. Use of recombinant activated factor VII in massive obstetric haemorrhage. Int J Obstet Anesth. Jan. 2006;16:40-9. X-5. [pmid: 17126006].
926 Henshaw A. Uterine fibroids: potential complications and impact on pregnancy. British Journal of Midwifery. 2006;14:73-5. X-1.
927 Hibbard JU, Della Torre M. When mom requests a cesarean. Contemporary OB/GYN. 2006;51:38. X-1.
928 Ifnan F, Jameel MB. Maternal morbidity and mortality associated with delivery after intrauterine fetal death. J Coll Physicians Surg Pak. Oct. 2006;16:648-51. X-2, X-4. [pmid: 17007753].
929 Jadesimi A, Okonofua FE. Tackling the unacceptable: Nigeria approves misoprostol for postpartum haemorrhage. J Fam Plann Reprod Health Care. Oct. 2006;32:213-4. X-1, X-2. [pmid: 17032506].
930 Jangsten E, Strand R, Gomez de Freitas EG, et al. Women's perceptions of pain and discomfort after childbirth in Angola. Afr J Reprod Health. Dec. 2006;9:148-58. X-2, X-4. [pmid: 16623199].
931 Kapyepye H, Klopper H, Bodkin C. Haemorrhage in pregnancy: information given to women in Chiradzulu (Malawi). Curationis. May. 2006;29:48-55. X-2, X-3, X-4. [pmid: 16910134].
932 Karagiannis V, Daniilidis A, Rousso D, et al. Experience from the use of absorbable type I collagen as haemostatic agent in obstetric and gynecological operations. Hippokratia. October/December. 2006;10:182-4. X-4, X-5. [pmid: 22087058].
933 Kaul V, Bagga R, Jain V, et al. The impact of primary postpartum hemorrhage in “near-miss” morbidity and mortality in a tertiary care hospital in North India. Indian J Med Sci. Jun. 2006;60:233-40. X-2, X-4. [pmid: 16790949].
934 Kavle JA, Khalfan SS, Stoltzfus RJ, et al. Measurement of blood loss at childbirth and postpartum. Int J Gynaecol Obstet. Oct. 2006;95:24-8. X-2, X-4. [pmid: 16919628].
935 Keizer JL, Zwart JJ, Meerman RH, et al. Obstetric intensive care admissions: a 12-year review in a tertiary care centre. Eur J Obstet Gynecol Reprod Biol. Sep-Oct. 2006;128:152-6. X-4, X-5. [pmid: 16443319].
936 Keriakos R, Mukhopadhyay A. The use of the Rusch balloon for management of severe postpartum haemorrhage. J Obstet Gynaecol. May. 2006;26:335-8. X-5. [pmid: 16753685].
937 Kim BJ, An SJ, Shim SS, et al. Pregnancy outcomes in women with mechanical heart valves. J Reprod Med. Aug. 2006;51:649-54. X-4. [pmid: 16967636].
938 Kirchner L, Helmer H, Heinze G, et al. Amnionitis with Ureaplasma urealyticum or other microbes leads to increased morbidity and prolonged hospitalization in very low birth weight infants. Eur J Obstet Gynecol Reprod Biol. Sep. 2006;134:44-50. X-3, X-4. [pmid: 17095137].
939 Kulkarni AA, Lee CA, Kadir RA. Pregnancy in women with congenital factor VII deficiency. Haemophilia. Jul. 2006;12:413-6. X-4, X-5. [pmid: 16834743].
940 Kushtagi P, Verghese LM. Evaluation of two uterotonic medications for the management of the third stage of labor. Int J Gynaecol Obstet. Jul. 2006;94:47-8. X-2, X-4, X-5. [pmid: 16762355].
941 Lalonde A, Daviss BA, Acosta A, et al. Postpartum hemorrhage today: ICM/FIGO initiative 2004-2006. Int J Gynaecol Obstet. Sep. 2006;94:243-53. X-1, X-5. [pmid: 16842791].
942 Lam KW, Wong HS, Pun TC. The practice of episiotomy in public hospitals in Hong Kong. Hong Kong Med J. Apr. 2006;12:94-8. X-4. [pmid: 16603774].
943 Lapaire O, Schneider MC, Stotz M, et al. Oral misoprostol vs. intravenous oxytocin in reducing blood loss after emergency cesarean delivery. Int J Gynaecol Obstet. Oct. 2006;95:2-7. X-4. [pmid: 16934269].
944 Leung SW, Ng PS, Wong WY, et al. A randomised trial of carbetocin versus syntometrine in the management of the third stage of labour. BJOG. Dec. 2006;113:1459-64. X-4. [pmid: 17176279].
945 Loder E, Golub J, Rizzoli P, et al. Postpartum headache: avoiding diagnostic and therapeutic pitfalls. Headache & Pain: Diagnostic Challenges, Current Therapy. 2006;17:155-65. X-1, X-3, X-4.
946 Loughney A, Collis R, Dastgir S. Birth before arrival at delivery suite: associations and consequences. British Journal of Midwifery. 2006;14:204-8. X-4.
947 Magann EF, Doherty DA, Turner K, et al. Second trimester placental location as a predictor of an adverse pregnancy outcome. J Perinatol. Jan. 2006;27:9-14. X-4. [pmid: 17080095].
948 Marchant S, Alexander J, Thomas P, et al. Risk factors for hospital admission related to excessive and/or prolonged postpartum vaginal blood loss after the first 24 h following childbirth. Paediatr Perinat Epidemiol. Sep. 2006;20:392-402. X-4. [pmid: 16911017].
949 Martinez R. Clinical challenge. Case #2: postpartum problems that last for 16 years. Clinical Advisor for Nurse Practitioners. 2006;9:102-3. X-1.
950 Matalon S, Sheiner E, Levy A, et al. Relationship of treated maternal hypothyroidism and perinatal outcome. J Reprod Med. Jan. 2006;51:59-63. X-4. [pmid: 16482779].
951 Mayberry L. Nursing implications of the 2006 NIH State of the Science Conference Statement: Cesarean Delivery on Maternal Request. MCN Am J Matern Child Nurs. Sep-Oct. 2006;31:286-9. X-1. [pmid: 17013066].
952 Mechery J, Burch D. Alternative management of placenta accreta. Gynecological Surgery. March. 2006;3:41-2. X-1.
953 Mercer SW, Sevar K, Sadutshan TD. Using clinical audit to improve the quality of obstetric care at the Tibetan Delek Hospital in North India: a longitudinal study. Reprod Health. 2006;3:4. X-2, X-4. [pmid: 16759384].
954 Miller S, Hamza S, Bray EH, et al. First aid for obstetric haemorrhage: the pilot study of the non-pneumatic anti-shock garment in Egypt. BJOG. Apr. 2006;113:424-9. X-2. [pmid: 16553654].
955 Mjahed K, Hamoudi D, Salmi S, et al. Obstetric patients in a surgical intensive care unit: prognostic factors and outcome. J Obstet Gynaecol. Jul. 2006;26:418-23. X-4. [pmid: 16846867].
956 Moodliar S, Moodley J, Esterhuizen TM. Complications associated with caesarean delivery in a setting with high HIV prevalence rates. Eur J Obstet Gynecol Reprod Biol. Apr. 2006;131:138-45. X-2, X-4. [pmid: 16806653].
957 Muir H. Dicing with death : there's a good chance that the pills your doctor prescribed will do you no good and might even harm you. New Sci. Jul 29-Aug 4. 2006;191:38-41. X-1, X-4. [pmid: 17115486].
958 Mulic-Lutvica A, Axelsson O. Ultrasound finding of an echogenic mass in women with secondary postpartum hemorrhage is associated with retained placental tissue. Ultrasound Obstet Gynecol. Sep. 2006;28:312-9. X-4, X-5. [pmid: 16888708].
959 Nama V, Karoshi M, Kakumani V. The single unit transfusion in post partum hemorrhage: A new perspective. Int J Fertil Womens Med. Mar-Apr. 2006;51:58-63. X-1. [pmid: 16881380].
960 Nellore V, Mittal S, Dadhwal V. Rectal misoprostol vs. 15-methyl prostaglandin F2alpha for the prevention of postpartum hemorrhage. Int J Gynaecol Obstet. Jul. 2006;94:45-6. X-2, X-4, X-5. [pmid: 16764879].
961 Ng PS, Lai CY, Sahota DS, et al. A double-blind randomized controlled trial of oral misoprostol and intramuscular syntometrine in the management of the third stage of labor. Gynecol Obstet Invest. 2006;63:55-60. X-2, X-4, X-5. [pmid: 16940738].
962 Nordin NM, Fen CK, Isa S, et al. Is grandmultiparity a significant risk factor in this new millennium?. Malays J Med Sci. Jul. 2006;13:52-60. X-2, X-4. [pmid: 22589605].
963 Nugent D, Hassadia A, Everard J, et al. Postpartum choriocarcinoma presentation, management and survival. J Reprod Med. Oct. 2006;51:819-24. X-4. [pmid: 17086810].
964 Okong P, Byamugisha J, Mirembe F, et al. Audit of severe maternal morbidity in Uganda--implications for quality of obstetric care. Acta Obstet Gynecol Scand. 2006;85:797-804. X-2, X-4. [pmid: 16817076].
965 Padhye SM, Lakhey B. “Brought Dead” - cases of maternal mortality. Kathmandu Univ Med J (KUMJ). Jul-Sep. 2006;1:184-6. X-1, X-2, X-4. [pmid: 16388227].
966 Pelage JP, Laissy JP. Management of life-threatening postpartum hemorrhage: indications and technique of arterial embolization. J Radiol. May. 2006;87:533-40. X-1. [pmid: 16733409].
967 Plesinac S, Plecas D, Babovic I. Influence of uterine myomas on course and outcome of pregnancy. Geburtshilfe und Frauenheilkunde. July. 2006;66:674-6. X-3, X-4.
968 Potts M, Hemmerling A. The worldwide burden of postpartum haemorrhage: Policy development where inaction is lethal. Int J Gynaecol Obstet. Nov. Suppl 2. 2006;94:S116-21. X-1. [pmid: 17161133].
969 Prata N, Hamza S, Gypson R, et al. Misoprostol and active management of the third stage of labor. Int J Gynaecol Obstet. Aug. 2006;94:149-55. X-1, X-4. [pmid: 16828767].
970 Price N, Lynch C. Uterine necrosis following B-Lynch suture for primary postpartum haemorrhage. Bjog. Nov. 2006;113:1341. author reply 2. X-1, X-4, X-5. [pmid: 17059399].
971 Qidwai GI, Caughey AB, Jacoby AF. Obstetric outcomes in women with sonographically identified uterine leiomyomata. Obstet Gynecol. Feb. 2006;107:376-82. X-4. [pmid: 16449127].
972 Rahim R, Shafqat T, Faiz NR. An analysis of direct causes of maternal mortality. Journal of Postgraduate Medical Institute. 2006;20:86-91. X-4.
973 Rajab KE, Issa AA, Mohammed AM, et al. Sickle cell disease and pregnancy in Bahrain. Int J Gynaecol Obstet. May. 2006;93:171-5. X-2, X-4. [pmid: 16563397].
974 Reyftmann L, Morau E, Dechaud H, et al. Extracorporeal membrane oxygenation therapy for circulatory arrest due to postpartum hemorrhage. Obstet Gynecol. Feb. 2006;107:511-4. X-1. [pmid: 16449168].
975 Rouse DJ, MacPherson C, Landon M, et al. Blood transfusion and cesarean delivery. Obstet Gynecol. Oct. 2006;108:891-7. X-4, X-5. [pmid: 17012451].
976 Saleem S. Efficacy of dinoprostone, intracervical foleys and misoprostol in labor induction. J Coll Physicians Surg Pak. Apr. 2006;16:276-9. X-2, X-4. [pmid: 16624192].
977 Sarwar I, Abbasi A, Islam A. Abruptio placentae and its complications at Ayub Teaching Hospital Abbottabad. J Ayub Med Coll Abbottabad. Jan-Mar. 2006;18:27-31. X-2, X-4. [pmid: 16773965].
978 Seracchioli R, Manuzzi L, Vianello F, et al. Obstetric and delivery outcome of pregnancies achieved after laparoscopic myomectomy. Fertil Steril. Jul. 2006;86:159-65. X-3, X-4. [pmid: 16764876].
979 Sheikh L, Zuberi NF, Riaz R, et al. Massive primary postpartum haemorrhage: setting up standards of care. J Pak Med Assoc. Jan. 2006;56:26-31. X-2, X-4. [pmid: 16454132].
980 Shim JY, Yoon HK, Won HS, et al. Angiographic embolization for obstetrical hemorrhage: effectiveness and follow-up outcome of fertility. Acta Obstet Gynecol Scand. 2006;85:815-20. X-5. [pmid: 16817079].
981 Sobieszczyk S, Breborowicz GH, Platicanov V, et al. Recombinant factor VIIa in the management of postpartum bleeds: an audit of clinical use. Acta Obstet Gynecol Scand. 2006;85:1239-47. X-5. [pmid: 17068684].
982 Sogstad AM, Osteras O, Fjeldaas T. Bovine claw and limb disorders related to reproductive performance and production diseases. J Dairy Sci. Jul. 2006;89:2519-28. X-1, X-3, X-4. [pmid: 16772570].
983 Tan LK, Kanagalingam D, Tan HK, et al. Obstetric outcomes in women with end-stage renal failure requiring renal dialysis. Int J Gynaecol Obstet. Jul. 2006;94:17-22. X-4. [pmid: 16756981].
984 Terry RR, Westcott J, O'shea L, et al. Postpartum outcomes in supine delivery by physicians vs nonsupine delivery by midwives. J Am Osteopath Assoc. Apr. 2006;106:199-202. X-4. [pmid: 16627774].
985 Thangaraju P, Moey CB. Perineal cold pads versus oral analgesics in the relief of postpartum perineal wound pain. Singapore General Hospital Proceedings. 2006;15:8-12. X-1, X-3, X-4.
986 Tonks A. Short cuts: what's new in the other general journals. BMJ: British Medical Journal (International Edition). 2006;333:799-800. X-1.
987 Trinder J, Brocklehurst P, Porter R, et al. Management of miscarriage: expectant, medical, or surgical? Results of randomised controlled trial (miscarriage treatment (MIST) trial). BMJ. May. 27. 2006;332:1235-40. X-3, X-4. [pmid: 16707509].
988 Tsu VD, Mai TT, Nguyen YH, et al. Reducing postpartum hemorrhage in Vietnam: assessing the effectiveness of active management of third-stage labor. J Obstet Gynaecol Res. Oct. 2006;32:489-96. X-2, X-4. [pmid: 16984516].
989 Tsukamoto H, Fukuoka H, Inoue K, et al. Restricting weight gain during pregnancy in Japan: a controversial factor in reducing perinatal complications. Eur J Obstet Gynecol Reprod Biol. Jul. 2006;133:53-9. X-3, X-4. [pmid: 16934385].
990 Tucker MJ, Berg CJ, Callaghan WM, et al. The Black-White disparity in pregnancy-related mortality from 5 conditions: differences in prevalence and case-fatality rates. Am J Public Health. Feb. 2006;97:247-51. X-4. [pmid: 17194867].
991 Tuladhar H, Dali SM, Pradhanang V. Complications of home delivery: a retrospective analysis. JNMA J Nepal Med Assoc. Jul-Sep. 2006;44:87-91. X-2, X-4. [pmid: 16554861].
992 Tuzovic L. Complete versus incomplete placenta previa and obstetric outcome. Int J Gynaecol Obstet. May. 2006;93:110-7. X-4. [pmid: 16563394].
993 Umeora OU, Onuh SO, Umeora MC. Socio-cultural barriers to voluntary blood donation for obstetric use in a rural Nigerian village. Afr J Reprod Health. Dec. 2006;9:72-6. X-2, X-3, X-4. [pmid: 16623191].
994 Verma U, Goharkhay N, Beydoun S. Conservative management of preterm premature rupture of membranes between 18 and 23 weeks of gestation--maternal and neonatal outcome. Eur J Obstet Gynecol Reprod Biol. Sep-Oct. 2006;128:119-24. X-4. [pmid: 16446024].
995 Walker WJ, McDowell SJ. Pregnancy after uterine artery embolization for leiomyomata: a series of 56 completed pregnancies. Am J Obstet Gynecol. Nov. 2006;195:1266-71. X-4. [pmid: 16796984].
996 Wang YL, Su TH. Obstetric uterine rupture of the unscarred uterus: a twenty-year clinical analysis. Gynecol Obstet Invest. 2006;62:131-5. X-2, X-4. [pmid: 16675909].
997 Wohlmuth CT, Gumbs J, Quebral-Ivie J. B-Lynch suture: a case series. Int J Fertil Womens Med. Jul-Aug. 2006;50:164-73. X-4, X-5. [pmid: 16405101].
998 Yong SP, Cheung KB. Management of primary postpartum haemorrhage with arterial embolisation in Hong Kong public hospitals. Hong Kong Med J. Dec. 2006;12:437-41. X-2, X-4, X-5. [pmid: 17148796].
999 Yoong W, Massiah N, Oluwu A. Obstetric hysterectomy: changing trends over 20 years in a multiethnic high risk population. Arch Gynecol Obstet. Apr. 2006;274:37-40. X-4, X-5. [pmid: 16491372].
1000 Yucel O, Ozdemir I, Yucel N, et al. Emergency peripartum hysterectomy: a 9-year review. Arch Gynecol Obstet. May. 2006;274:84-7. X-2, X-5. [pmid: 16463166].
1001 Zamzami TY. Maternal and perinatal outcome of massive postpartum hemorrhage: a review of 33 cases. Ann Saudi Med. May-Jul. 2006;23:135-9. X-2, X-5. [pmid: 16985301].
1002 Zeteroglu S, Sahin GH, Sahin HA. Induction of labor with misoprostol in pregnancies with advanced maternal age. Eur J Obstet Gynecol Reprod Biol. Dec. 2006;129:140-4. X-4. [pmid: 16406221].
1003 Federal update. Obstetrics & Gynecology. 2007;109:755. X-1, X-4, X-5.
1004 In the news. World health roundup. American Journal of Nursing. 2007;107:21. X-1, X-4, X-5. [pmid: 18049049].
1005 New campaign to reduce maternal deaths. Practising Midwife. 2007;10:11. X-1, X-4. [pmid: 18210958].
1006 News from ICM and partners. International Midwifery. 2007;20:30-1. X-1, X-4.
1007 ‘Shared action on a deadly but preventable condition’: new ICM/FIGO statement on prevention and treatment of PPH in low resource settings. Midwifery. 2007;23:3-4. X-1, X-2, X-4, X-5.
1008 Abdel-Hady el S, Mashaly AM, Sherief LS, et al. Why do mothers die in Dakahlia, Egypt?. J Obstet Gynaecol Res. Jun. 2007;33:283-7. X-2, X-4. [pmid: 17578356].
1009 Adams V, Miller S, Craig S, et al. Informed Consent in cross-cultural perspective: clinical research in the Tibetan Autonomous Region, PRC. Cult Med Psychiatry. Dec. 2007;31:445-72. X-1, X-2. [pmid: 17968637].
1010 Al-Assadi AF, Al-Waeely FA, Kadhim SS. The use of extraamniotic dexamethasone for ripening the unfavourable cervix. Journal of the Bahrain Medical Society. October. 2007;19:148-53. X-2, X-3, X-4.
1011 Amarin ZO, Alchalabi HA, Khader YS, et al. Variation in repeat caesarean section complication rates among 3 hospitals in northern Jordan. East Mediterr Health J. Sep. 2007;12:610-8. X-2, X-4. [pmid: 17333801].
1012 Amelink-Verburg MP, Verloove-Vanhorick SP, Hakkenberg RM, et al. Evaluation of 280,000 cases in Dutch midwifery practices: a descriptive study. BJOG. Apr. 2007;115:570-8. X-4, X-5. [pmid: 18162116].
1013 Anderson FW, Naik SI, Feresu SA, et al. Perceptions of pregnancy complications in Haiti. Int J Gynaecol Obstet. Feb. 2007;100:116-23. X-2, X-4. [pmid: 18076885].
1014 Anderson JM, Etches D. Prevention and management of postpartum hemorrhage. Am Fam Physician. Mar. 15. 2007;75:875-82. X-1. [pmid: 17390600].
1015 Arya R, Whitworth M, Johnston TA. Abnormal labour: an evidence-based approach. Obstetrics, Gynaecology and Reproductive Medicine. July. 2007;17:217-21. X-1.
1016 Aubrey-Bassler K, Newbery S, Kelly L, et al. Maternal outcomes of cesarean sections: do generalists' patients have different outcomes than specialists' patients?. Can Fam Physician. Dec. 2007;53:2132-8. X-4. [pmid: 18077752].
1017 Baskett TF. Uterine compression sutures for postpartum hemorrhage: efficacy, morbidity, and subsequent pregnancy. Obstet Gynecol. Jul. 2007;110:68-71. X-5. [pmid: 17601898].
1018 Baskett TF, Persad VL, Clough HJ, et al. Misoprostol versus oxytocin for the reduction of postpartum blood loss. Int J Gynaecol Obstet. Apr. 2007;97:2-5. X-4, X-5. [pmid: 17321529].
1019 Belizan M, Meier A, Althabe F, et al. Facilitators and barriers to adoption of evidence-based perinatal care in Latin American hospitals: a qualitative study. Health Educ Res. Dec. 2007;22:839-53. X-2, X-3. [pmid: 17395605].
1020 Bhattacharya S, Campbell DM, Liston WA. Effect of Body Mass Index on pregnancy outcomes in nulliparous women delivering singleton babies. BMC Public Health. 2007;7:168. X-4, X-5. [pmid: 17650297].
1021 Bhide A, Guven M, Prefumo F, et al. Maternal and neonatal outcome after failed ventouse delivery: comparison of forceps versus cesarean section. J Matern Fetal Neonatal Med. Jul. 2007;20:541-5. X-4, X-5. [pmid: 17674268].
1022 Birch L, Jones N, Doyle PM, et al. Obstetric skills drills: evaluation of teaching methods. Nurse Educ Today. Nov. 2007;27:915-22. X-4, X-5. [pmid: 17376563].
1023 Boriboonhirunsarn D, Talungjit P, Sunsaneevithayakul P, et al. Adverse pregnancy outcomes in gestational diabetes mellitus. J Med Assoc Thai. Oct. Suppl 4. 2007;89:S23-8. X-2, X-4. [pmid: 17725139].
1024 Bouma LS, Bolte AC, van Geijn HP. Use of recombinant activated factor VII in massive postpartum haemorrhage. Eur J Obstet Gynecol Reprod Biol. Apr. 2007;137:172-7. X-2, X-5. [pmid: 17928129].
1025 Brace V, Kernaghan D, Penney G. Learning from adverse clinical outcomes: major obstetric haemorrhage in Scotland, 2003-05. BJOG. Nov. 2007;114:1388-96. X-2, X-4, X-5. [pmid: 17949379].
1026 Bradley SE, Prata N, Young-Lin N, et al. Cost-effectiveness of misoprostol to control postpartum hemorrhage in low-resource settings. Int J Gynaecol Obstet. Apr. 2007;97:52-6. X-2, X-4, X-5. [pmid: 17316646].
1027 Bretelle F, Courbiere B, Mazouni C, et al. Management of placenta accreta: morbidity and outcome. Eur J Obstet Gynecol Reprod Biol. Jul. 2007;133(1):34-9. X-4, X-5. [pmid: 16965851].
1028 Burtelow M, Riley E, Druzin M, et al. How we treat: management of life-threatening primary postpartum hemorrhage with a standardized massive transfusion protocol. Transfusion. Sep. 2007;47:1564-72. X-5. [pmid: 17725718].
1029 Byams VR. Women with bleeding disorders. J Womens Health (Larchmt). Nov. 2007;16:1249-51. X-1. [pmid: 18001180].
1030 Cameron CA, Roberts CL, Bell J, et al. Getting an evidence-based post-partum haemorrhage policy into practice. Aust N Z J Obstet Gynaecol. Jun. 2007;47:169-75. X-2, X-4, X-5. [pmid: 17550481].
1031 Cardone A, Zarcone R, Visconti S, et al. A new uterine suture technique for postpartum hemorrhage. Minerva Ginecol. Jun. 2007;59:343-6. X-5. [pmid: 17576409].
1032 Caughey AB, Stotland NE, Washington AE, et al. Maternal and obstetric complications of pregnancy are associated with increasing gestational age at term. Am J Obstet Gynecol. Feb. 2007;196:155 e1-6. X-3, X-4. [pmid: 17306661].
1033 Chandraharan E, Arulkumaran S. Massive postpartum haemorrhage and management of coagulopathy. Obstetrics, Gynaecology and Reproductive Medicine. April. 2007;17:119-22. X-1.
1034 Cheng YW, Hopkins LM, Laros RK Jr., et al. Duration of the second stage of labor in multiparous women: maternal and neonatal outcomes. Am J Obstet Gynecol. Jun. 2007;196:585 e1-6. X-4. [pmid: 17547906].
1035 Chi C, Lee CA, Shiltagh N, et al. Pregnancy in carriers of haemophilia. Haemophilia. Jan. 2007;14:56-64. X-4. [pmid: 17941828].
1036 Chittacharoen A, Singhakun D, Ayudhya NI. Pregnancy outcome of twin pregnancy in Ramathibodi Hospital. J Med Assoc Thai. Oct. Suppl 4. 2007;89:S76-80. X-2, X-4. [pmid: 17725143].
1037 Chittacharoen A, Wetchapruekpitak S, Suthutvoravut S. Pregnancy induced hypertension in twin pregnancy. J Med Assoc Thai. Oct. Suppl 2. 2007;88:S69-74. X-2, X-4. [pmid: 17722320].
1038 Clark P, Walker ID, Govan L, et al. The GOAL study: a prospective examination of the impact of factor V Leiden and ABO(H) blood groups on haemorrhagic and thrombotic pregnancy outcomes. Br J Haematol. Jan. 2007;140:236-40. X-4. [pmid: 18028481].
1039 Cook EL. Delayed cord clamping or immediate cord clamping?: a literature review. British Journal of Midwifery. 2007;15:562. X-1.
1040 Crofts JF, Ellis D, Draycott TJ, et al. Change in knowledge of midwives and obstetricians following obstetric emergency training: a randomised controlled trial of local hospital, simulation centre and teamwork training. Bjog. Dec. 2007;114:1534-41. X-3, X-4. [pmid: 17903231].
1041 Cruz JR. Reduction of maternal mortality: the need for voluntary blood donors. Int J Gynaecol Obstet. Sep. 2007;98:291-3. X-2, X-4. [pmid: 17374536].
1042 Dabelea V, Schultze PM, McDuffie RS Jr. Intrauterine balloon tamponade in the management of postpartum hemorrhage. Am J Perinatol. Jun. 2007;24:359-64. X-5. [pmid: 17566947].
1043 Dadhwal V, Gupta B, Srivastava DN, et al. Uterine artery pseudoaneurysm with AV malformation: A rare cause of secondary post partum hemorrhage. JK Science. July/September. 2007;9:142-4. X-1, X-2, X-4, X-5.
1044 Dar S, Vardi IS, Holcberg G, et al. Do we need routine complete blood count following vaginal delivery?. Int J Fertil Womens Med. Nov-Dec. 2007;51:270-3. X-4, X-5. [pmid: 17566570].
1045 Daskalakis G, Anastasakis E, Papantoniou N, et al. Emergency obstetric hysterectomy. Acta Obstet Gynecol Scand. 2007;86:223-7. X-2, X-4, X-5. [pmid: 17364287].
1046 de Jonge A, van Diem MT, Scheepers PL, et al. Increased blood loss in upright birthing positions originates from perineal damage. BJOG. Mar. 2007;114:349-55. X-4. [pmid: 17217358].
1047 Dutra F, Quintans G, Banchero G. Lesions in the central nervous system associated with perinatal lamb mortality. Aust Vet J. Oct. 2007;85:405-13. X-3, X-4. [pmid: 17903128].
1048 El-Sayed YY, Watkins MM, Fix M, et al. Perinatal outcomes after successful and failed trials of labor after cesarean delivery. Am J Obstet Gynecol. Jun. 2007;196:583 e1-5. discussion e5. X-4. [pmid: 17547905].
1049 Enakpene CA, Morhason-Bello IO, Enakpene EO, et al. Oral misoprostol for the prevention of primary post-partum hemorrhage during third stage of labor. J Obstet Gynaecol Res. Dec. 2007;33:810-7. X-4. [pmid: 18001447].
1050 Enyindah CE, Fiebai PO, Anya SE, et al. Episiotomy and perineal trauma prevalence and obstetric risk factors in Port Harcourt, Nigeria. Niger J Med. Jul-Sep. 2007;16:242-5. X-2, X-4. [pmid: 17937162].
1051 Eriksson LG, Mulic-Lutvica A, Jangland L, et al. Massive postpartum hemorrhage treated with transcatheter arterial embolization: technical aspects and long-term effects on fertility and menstrual cycle. Acta Radiol. Jul. 2007;48:635-42. X-5. [pmid: 17611871].
1052 Ford AA, Bateman BT, Simpson LL, et al. Nationwide data confirms absence of ‘July phenomenon’ in obstetrics: it's safe to deliver in July. J Perinatol. Feb. 2007;27:73-6. X-4. [pmid: 17262037].
1053 Ford JB, Roberts CL, Bell JC, et al. Postpartum haemorrhage occurrence and recurrence: a population-based study. Med J Aust. Oct. 1. 2007;187:391-3. X-4. [pmid: 17908001].
1054 Ford JB, Roberts CL, Simpson JM, et al. Increased postpartum hemorrhage rates in Australia. Int J Gynaecol Obstet. Sep. 2007;98:237-43. X-4. [pmid: 17482190].
1055 Fry J. Physiological third stage of labour: support it or lose it. British Journal of Midwifery. 2007;15:693-5. X-1.
1056 Fullerton JT, Frick KD, Fogarty LA, et al. Active management of third stage of labour saves facility costs in Guatemala and Zambia. J Health Popul Nutr. Dec. 2007;24:540-51. X-2, X-4, X-5. [pmid: 17591351].
1057 Gebhardt S, Arends E. Standardised maternal guideline on the management of postpartum haemorrhage. South African Journal of Obstetrics and Gynaecology. October. 2007;13:110-7. X-1.
1058 Gessessew A. Twin deliveries in a zonal hospital: ten years retrospective study. Ethiop Med J. Jan. 2007;45:55-9. X-2, X-4. [pmid: 17642158].
1059 Gessessew A. Maternal complications--in a zonal hospital. Ethiop Med J. Jan. 2007;45:47-54. X-2, X-4. [pmid: 17642157].
1060 Ghezzi F, Cromi A, Uccella S, et al. The Hayman technique: a simple method to treat postpartum haemorrhage. BJOG. Mar. 2007;114:362-5. X-2, X-5. [pmid: 17217361].
1061 Guilliland K. The current global effort to prevent postpartum haemorrhage: how likely is it to be effective?. New Zealand College of Midwives Journal. 2007;36:28-31. X-1.
1062 Hackethal A, Brueggmann D, Oehmke F, et al. Uterine compression U-sutures in primary postpartum hemorrhage after Cesarean section: fertility preservation with a simple and effective technique. Hum Reprod. Jan. 2007;23:74-9. X-5. [pmid: 18024985].
1063 Hicks K. Survivor: a nursing challenge from the Northern Territory. ACORN: The Journal of Perioperative Nursing in Australia. 2007;20:32-3. X-1.
1064 Hossain N, Shansi T, Haider S, et al. Use of recombinant activated factor VII for massive postpartum hemorrhage. Acta Obstet Gynecol Scand. Oct. 2007;86:1200-6. X-2. [pmid: 17851797].
1065 Htay TT. Making pregnancy safer in Myanmar: introducing misoprostol to prevent post-partum haemorrhage as part of active management of the third stage of labour. Reprod Health Matters. Nov. 2007;15:214-5. X-2, X-4. [pmid: 17938087].
1066 Iftikhar R. Intrapartum complications of macrosomic fetus. Journal of the Liaquat University of Medical and Health Sciences. May/August. 2007;6:52-5. X-2, X-4.
1067 Jago AA, Ezechi OC, Achinge GI, et al. Effect of oxytocics on the blood pressure of normotensive Nigerian parturients. J Matern Fetal Neonatal Med. Sep. 2007;20:703-5. X-2, X-4. [pmid: 17701671].
1068 James AH. Prevention and management of venous thromboembolism in pregnancy. Am J Med. Oct. 2007;120:S26-34. X-1. [pmid: 17916457].
1069 James AH, Jamison MG. Bleeding events and other complications during pregnancy and childbirth in women with von Willebrand disease. J Thromb Haemost. Jun. 2007;5:1165-9. X-4, X-5. [pmid: 17403089].
1070 Javed I, Bhutta S, Shoaib T. Role of partogram in preventing prolonged labour. J Pak Med Assoc. Aug. 2007;57:408-11. X-4. [pmid: 17902525].
1071 Jeffery P, Das A, Dasgupta J, et al. Unmonitored intrapartum oxytocin use in home deliveries: evidence from Uttar Pradesh, India. Reprod Health Matters. Nov. 2007;15:172-8. X-1. [pmid: 17938082].
1072 Jerbi M, Hidar S, Elmoueddeb S, et al. Oxytocin in the third stage of labor. Int J Gynaecol Obstet. Mar. 2007;96:198-9. X-2, X-4, X-5. [pmid: 17289048].
1073 Joseph KS, Rouleau J, Kramer MS, et al. Investigation of an increase in postpartum haemorrhage in Canada. BJOG. Jun. 2007;114:751-9. X-4. [pmid: 17516968].
1074 Joshi VM, Otiv SR, Majumder R, et al. Internal iliac artery ligation for arresting postpartum haemorrhage. BJOG. Mar. 2007;114:356-61. X-2. [pmid: 17261120].
1075 Joyce D, Clark J, Miller S. The promise of the non-pneumatic anti-shock garment: a new tool to use against PPH. International Midwifery. 2007;20:12-3. X-1, X-4, X-5.
1076 Kominiarek MA, Angelopoulos SM, Shapiro NL, et al. Low-molecular-weight heparin in pregnancy: peripartum bleeding complications. J Perinatol. Jun. 2007;27:329-34. X-4, X-5. [pmid: 17443203].
1077 Kroencke TJ, Kluner C, Hamm B, et al. Use of the 4F Rosch inferior mesenteric catheter in embolization procedures in the pelvis: a review of 300 cases. Cardiovasc Intervent Radiol. Mar-Apr. 2007;30:268-72. X-2, X-4, X-5. [pmid: 17200899].
1078 Kugler E, Shoham-Vardi I, Burstien E, et al. The safety of a trial of labor after cesarean section in a grandmultiparous population. Arch Gynecol Obstet. Apr. 2007;277:339-44. X-4. [pmid: 17957377].
1079 La Folie T, Vidal V, Mehanna M, et al. Results of endovascular treatment in cases of abnormal placentation with post-partum hemorrhage. J Obstet Gynaecol Res. Oct. 2007;33:624-30. X-5. [pmid: 17845319].
1080 Larsson C, Saltvedt S, Wiklund I, et al. Estimation of blood loss after cesarean section and vaginal delivery has low validity with a tendency to exaggeration. Acta Obstet Gynecol Scand. 2007;85:1448-52. X-4. [pmid: 17260220].
1081 Liabsuetrakul T, Choobun T, Peeyananjarassri K, et al. Prophylactic use of ergot alkaloids in the third stage of labour. Cochrane Database Syst Rev. 2007. CD005456. X-1, X-4. [pmid: 17443592].
1082 Liabsuetrakul T, Peeyananjarassri K, Tassee S, et al. Emergency obstetric care in the southernmost provinces of Thailand. Int J Qual Health Care. Aug. 2007;19:250-6. X-2, X-4. [pmid: 17575277].
1083 Lohmann-Bigelow J, Longo SA, Jiang X, et al. Does dilation and curettage affect future pregnancy outcomes?. Ochsner J. Winter. 2007;7:173-6. X-4. [pmid: 21603540].
1084 Lourens R, Paterson-Brown S. Ergometrine given during caesarean section and incidence of delayed postpartum haemorrhage due to uterine atony. J Obstet Gynaecol. Nov. 2007;27:795-7. X-2, X-4, X-5. [pmid: 18097896].
1085 Lungu K, Ratsma Y. Does the upgrading of the radio communications network in health facilities reduce the delay in the referral of obstetric emergencies in Southern Malawi?. Malawi Med J. Mar. 2007;19:1-8. X-2, X-4. [pmid: 23878623].
1086 Mallory J, Dresang L. Topics in maternity care. Misoprostol for prevention and treatment of postpartum hemorrhage. Evidence-Based Practice. 2007;10:8. 2p. PMID:. X-1, X-4, X-5.
1087 Malvasi A, Tinelli A, Serio G, et al. Comparison between the use of the Joel-Cohen incision and its modification during Stark's cesarean section. J Matern Fetal Neonatal Med. Oct. 2007;20:757-61. X-3, X-4. [pmid: 17763278].
1088 Marconi AM, Bozzetti P, Morabito A, et al. Comparing two dinoprostone agents for cervical ripening and induction of labor: a randomized trial. Eur J Obstet Gynecol Reprod Biol. Jun. 2007;138:135-40. X-4. [pmid: 17889983].
1089 Maslovitz S, Barkai G, Lessing JB, et al. Recurrent obstetric management mistakes identified by simulation. Obstet Gynecol. Jun. 2007;109:1295-300. X-4, X-5. [pmid: 17540800].
1090 Massiah N, Athimulam S, Loo C, et al. Obstetric care of Jehovah's Witnesses: a 14-year observational study. Arch Gynecol Obstet. Oct. 2007;276:339-43. X-4. [pmid: 17522882].
1091 Master FJ. Some random notes on Crocus sativus. Homoeopathic Heritage. 2007;32:2. X-1.
1092 Mathai M, Gulmezoglu AM, Hill S. Saving womens lives: evidence-based recommendations for the prevention of postpartum haemorrhage. Bull World Health Organ. Apr. 2007;85:322-3. X-1, X-2, X-4, X-5. [pmid: 17546315].
1093 Mathe ML, Morau E, Vernhet-Kovacsik H, et al. Impact of the new French clinical practice recommendations in embolization in postpartum and post-abortion hemorrhage: study of 48 cases. J Perinat Med. 2007;35:532-7. X-2, X-4, X-5. [pmid: 18052838].
1094 Melhado L. Digests. International Family Planning Perspectives. 2007;33:38-43. X-1.
1095 Memon A, Sikandar R. Misoprostol for induction of labour: The Hyderabad experience. Journal of the Liaquat University of Medical and Health Sciences. May/August. 2007;6:56-9. X-2, X-4.
1096 Miller S, Butrick E, Turan JM, et al. The anti-shock garment for post-partum and post-abortion hemorrhage in Nigeria... Conference proceedings: abstracts from Research Forums presented at the ACNM 52nd Annual Meeting 2007. Journal of Midwifery & Women's Health. 2007;52:534. X-2.
1097 Miller S, Tudor C, Nyima, et al. Maternal and neonatal outcomes of hospital vaginal deliveries in Tibet. Int J Gynaecol Obstet. Sep. 2007;98:217-21. X-2, X-4. [pmid: 17481630].
1098 Miller S, Turan JM, Dau K, et al. Use of the non-pneumatic anti-shock garment (NASG) to reduce blood loss and time to recovery from shock for women with obstetric haemorrhage in Egypt. Glob Public Health. 2007;2:110-24. X-1, X-2. [pmid: 19280394].
1099 Moore ML. Misoprostol-is more research needed?. J Perinat Educ. Summer. 2007;11:43-7. X-1. [pmid: 17273309].
1100 Mousa HA, Alfirevic Z. Treatment for primary postpartum haemorrhage. Cochrane Database Syst Rev. 2007. CD003249. X-1, X-2, X-5. [pmid: 17253486].
1101 Mulic-Lutvica A, Axelsson O. Postpartum ultrasound in women with postpartum endometritis, after cesarean section and after manual evacuation of the placenta. Acta Obstet Gynecol Scand. 2007;86:210-7. X-3, X-4. [pmid: 17364285].
1102 Mutihir JT. Triplet pregnancy as seen in the Jos University Teaching Hospital. Niger Postgrad Med J. Dec. 2007;14:281-4. X-2, X-4. [pmid: 18163134].
1103 Myers B, Pavord S, Kean L, et al. Pregnancy outcome in Factor XI deficiency: incidence of miscarriage, antenatal and postnatal haemorrhage in 33 women with Factor XI deficiency. BJOG. May. 2007;114:643-6. X-4. [pmid: 17439571].
1104 Naydich M, Friedman A, Aaron G, et al. Arterial embolization of vaginal arterial branches for severe postpartum hemorrhage despite hysterectomy. J Vasc Interv Radiol. Aug. 2007;18:1047-50. X-5. [pmid: 17675626].
1105 Nelson WL, O'Brien JM. The uterine sandwich for persistent uterine atony: combining the B-Lynch compression suture and an intrauterine Bakri balloon. Am J Obstet Gynecol. May. 2007;196:e9-10. X-4, X-5. [pmid: 17466689].
1106 Ngan L, Keong W, Martins R. Carbetocin versus a combination of oxytocin and ergometrine in control of postpartum blood loss. Int J Gynaecol Obstet. May. 2007;97:152-3. X-2, X-4, X-5. [pmid: 17379220].
1107 Nielsen PE, Goldman MB, Mann S, et al. Effects of teamwork training on adverse outcomes and process of care in labor and delivery: a randomized controlled trial. Obstet Gynecol. Jan. 2007;109:48-55. X-4, X-5. [pmid: 17197587].
1108 Oladapo OT, Ariba AJ, Odusoga OL. Changing patterns of emergency obstetric care at a Nigerian University hospital. Int J Gynaecol Obstet. Sep. 2007;98:278-84. X-2, X-4. [pmid: 17612545].
1109 Ophir E, Strulov A, Solt I, et al. Delivery mode and maternal rehospitalization. Arch Gynecol Obstet. May. 2007;277:401-4. X-4, X-5. [pmid: 17922286].
1110 Orji EO, Fatusi AA, Makinde NO, et al. Impact of training on the use of partograph on maternal and perinatal outcome in peripheral health centers. Journal of the Turkish German Gynecology Association. June. 2007;8:148-52. X-1, X-4.
1111 Ouahba J, Piketty M, Huel C, et al. Uterine compression sutures for postpartum bleeding with uterine atony. BJOG. May. 2007;114:619-22. X-5. [pmid: 17355361].
1112 Paidas MJ, Rosenman S, Hossain N. Using activated factor VII in ob/gyn practice. Contemporary OB/GYN. 2007;52:46. X-1.
1113 Panpaprai P, Boriboonhirunsarn D. Risk factors of retained placenta in Siriraj Hospital. J Med Assoc Thai. Jul. 2007;90:1293-7. X-2, X-4. [pmid: 17710967].
1114 Prakash J, Vohra R, Wani IA, et al. Decreasing incidence of renal cortical necrosis in patients with acute renal failure in developing countries: a single-centre experience of 22 years from Eastern India. Nephrol Dial Transplant. Apr. 2007;22:1213-7. X-1, X-2, X-4. [pmid: 17267539].
1115 Rahmanpoor H, Hosseini SN, Mousavinasab SN, et al. Comparison of Diclofenac with pethidine on the pain after Cesarean section. International Journal of Pharmacology. March. 2007;3:201-3. X-1, X-4.
1116 Rajab KE, Essa A, Masaudi E. A hospital-based epidemiologic study of hypertensive disease in pregnancy. Journal of the Bahrain Medical Society. April. 2007;19:63-8. X-2, X-4.
1117 Roberts LM, Homer CS, Davis GK, et al. Misoprostol to induce labour: a review of its use in a NSW hospital. Aust N Z J Obstet Gynaecol. Aug. 2007;47:291-6. X-4, X-5. [pmid: 17627683].
1118 Romero-Gutierrez G, Espitia-Vera A, Ponce-Ponce de Leon AL, et al. Risk factors of maternal death in Mexico. Birth. Mar. 2007;34:21-5. X-2, X-4. [pmid: 17324174].
1119 Saaqib S, Riaz L. Labor management in a patient with von Willebrand disease. J Coll Physicians Surg Pak. Oct. 2007;17:632-4. X-3, X-4. [pmid: 17999859].
1120 Sabbour SM. Epidemiological correlates of hysterectomy, a hospital based study 1995 -1996 at Ain Shams Maternity Hospital. J Egypt Public Health Assoc. 2007;76:71-87. X-2. [pmid: 17216982].
1121 Saito K, Haruki A, Ishikawa H, et al. Prospective study of intramuscular ergometrine compared with intramuscular oxytocin for prevention of postpartum hemorrhage. J Obstet Gynaecol Res. Jun. 2007;33:254-8. X-4. [pmid: 17578351].
1122 Samms V. von Willebrand disease and pregnancy. Practising Midwife. 2007;10:20-2. X-1.
1123 Samuels LA, Christie L, Roberts-Gittens B, et al. The effect of hyoscine butylbromide on the first stage of labour in term pregnancies. BJOG. Dec. 2007;114:1542-6. X-2, X-3, X-4. [pmid: 17903230].
1124 Seal SL, Kamilya G, Bhattacharyya SK, et al. Relaparotomy after cesarean delivery: experience from an Indian teaching hospital. J Obstet Gynaecol Res. Dec. 2007;33:804-9. X-2. [pmid: 18001446].
1125 Sentilhes L, Goffinet F, Talbot A, et al. Attempted vaginal versus planned cesarean delivery in 195 breech first twin pregnancies. Acta Obstet Gynecol Scand. 2007;86:55-60. X-3, X-4. [pmid: 17230290].
1126 Seyam YS, Ahmad Riad EH, Elzain S, et al. Ultrasound prediction of fetal macrosomia in diabetic women and its effect on the route of delivery and the outcome of pregnancy. Qatar Medical Journal. June. 2007;16:30-5. X-2, X-4.
1127 Shaamash AH, Ahmed AG, Abdel Latef MM, et al. Routine postpartum ultrasonography in the prediction of puerperal uterine complications. Int J Gynaecol Obstet. Aug. 2007;98:93-9. X-2, X-4, X-5. [pmid: 17583710].
1128 Shaheen B, Hassan L. Postpartum haemorrhage: a preventable cause of maternal mortality. J Coll Physicians Surg Pak. Oct. 2007;17:607-10. X-2, X-4. [pmid: 17999851].
1129 Sheikh GM, Firdous N, Taing S, et al. Comparative study of prostaglandin F2 alpha versus ergometrine in the management of post partum haemorrhage. JK Science. January/March. 2007;9:30-2. X-2.
1130 Shrestha P, Babu CS. Influence of umbilical vein oxytocin on blood loss and length of third stage of labour. Nepal Med Coll J. Sep. 2007;9:176-8. X-2, X-4. [pmid: 18092435].
1131 Shrivastava V, Nageotte M, Major C, et al. Case-control comparison of cesarean hysterectomy with and without prophylactic placement of intravascular balloon catheters for placenta accreta. Am J Obstet Gynecol. Oct. 2007;197:402 e1-5. X-2, X-4, X-5. [pmid: 17904978].
1132 Sibley LM, Blum LS, Kalim N, et al. Women's descriptions of postpartum health problems: preliminary findings from Matlab, Bangladesh. J Midwifery Womens Health. Jul-Aug. 2007;52:351-60. X-1, X-2, X-4. [pmid: 17603957].
1133 Simoes T, Aboim L, Costa A, et al. Puerperal complications following elective Cesarean sections for twin pregnancies. J Perinat Med. 2007;35:104-7. X-4. [pmid: 17302518].
1134 Smith J, Mousa HA. Peripartum hysterectomy for primary postpartum haemorrhage: incidence and maternal morbidity. J Obstet Gynaecol. Jan. 2007;27:44-7. X-2, X-4, X-5. [pmid: 17365458].
1135 Soltan MH, El-Gendi E, Imam HH, et al. Different Doses of Sublingual Misoprostol versus Methylergometrine for the Prevention of Atonic Postpartum Haemorrhage. Int J Health Sci (Qassim). Jul. 2007;1:229-36. X-2, X-4, X-5. [pmid: 21475433].
1136 Soltan MH, Mohamed A, Ibrahim E, et al. El-menia air inflated balloon in controlling atonic post partum hemorrhage. Int J Health Sci (Qassim). Jan. 2007;1:53-9. X-2. [pmid: 21475452].
1137 Soncini E, Pelicelli A, Larini P, et al. Uterine artery embolization in the treatment and prevention of postpartum hemorrhage. Int J Gynaecol Obstet. Mar. 2007;96:181-5. X-4, X-5. [pmid: 17286979].
1138 Sorensen SS. Emergency drills in obstetrics: reducing risk of perinatal death or permanent injury. JONAS Healthc Law Ethics Regul. Jan-Mar. 2007;9:9-16. quiz 7-8. X-1. [pmid: 17413483].
1139 Stella CL, Jodicke CD, How HY, et al. Postpartum headache: is your work-up complete?. Am J Obstet Gynecol. Apr. 2007;196:318 e1-7. X-4, X-5. [pmid: 17403403].
1140 Su LL, Chong YS, Samuel M. Oxytocin agonists for preventing postpartum haemorrhage. Cochrane Database Syst Rev. 2007. CD005457. X-1. [pmid: 17636798].
1141 Sumigama S, Itakura A, Ota T, et al. Placenta previa increta/percreta in Japan: a retrospective study of ultrasound findings, management and clinical course. J Obstet Gynaecol Res. Oct. 2007;33:606-11. X-5. [pmid: 17845316].
1142 Sundararajan V, Reidpath DD, Allotey P. Ethnicity, discrimination and health outcomes: a secondary analysis of hospital data from Victoria, Australia. Diversity in Health & Social Care. 2007;4:21-32. X-4.
1143 Sunitha R, Mathew R, Thomas M. Conservative management of subdural hematoma in idiopathic thrombocytopenic purpura: Report of two cases and review of literature. Annals of Indian Academy of Neurology. 01. Jul. 2007;10:184-6. X-1.
1144 Suri V, Aggarwal N, Saxena S, et al. Maternal and perinatal outcome in idiopathic thrombocytopenic purpura (ITP) with pregnancy. Acta Obstet Gynecol Scand. 2007;85:1430-5. X-2, X-3, X-4. [pmid: 17260217].
1145 Suzuki S, Igarashi M. Clinical significance of pregnancies with succenturiate lobes of placenta. Arch Gynecol Obstet. Apr. 2007;277:299-301. X-4. [pmid: 17938944].
1146 Suzuki S, Kikuchi F, Ouchi N, et al. Risk factors for postpartum hemorrhage after vaginal delivery of twins. J Nippon Med Sch. Dec. 2007;74:414-7. X-4. [pmid: 18084135].
1147 Takeuchi K, Sugimoto M, Kitao K, et al. Pregnancy outcome of uterine arterial embolization followed by selective hysteroscopic removal of a placental polyp. Acta Obstet Gynecol Scand. 2007;86:22-5. X-3, X-4. [pmid: 17230284].
1148 Tattersall M, Braithwaite W. Balloon tamponade for vaginal lacerations causing severe postpartum haemorrhage. Bjog. May. 2007;114:647-8. X-5. [pmid: 17362483].
1149 Tsitlakidis C, Alalade A, Danso D, et al. Ten year follow-up of the effect of the B-Lynch uterine compression suture for massive postpartum hemorrhage. Int J Fertil Womens Med. Nov-Dec. 2007;51:262-5. X-4, X-5. [pmid: 17566568].
1150 Uddenfeldt Wort U, Hastings I, Bergstrom S, et al. Increased postpartum blood loss in pregnancies associated with placental malaria. Int J Gynaecol Obstet. Mar. 2007;96:171-5. X-2, X-4. [pmid: 17280666].
1151 Ullah NA, Ullah HA, Siddique S. Fetomaternal outcome of cases referred to Nishtar Hospital, Multan. Medical Forum Monthly. December. 2007;18:4-10. X-2, X-4.
1152 Umezurike CC, Nkwocha G. Placenta accreta in Aba, south eastern, Nigeria. Niger J Med. Jul-Sep. 2007;16:219-22. X-2. [pmid: 17937156].
1153 Uygur D, Tapisiz OL, Akkalyoncu B, et al. Transfusion-Related Acute Lung Injury (TRALI) after delivery - A case report. Gazi Medical Journal. September. 2007;18:142-4. X-1, X-2.
1154 Varughese J, Cohen AJ. Experience with epidural anaesthesia in pregnant women with von Willebrand disease. Haemophilia. Nov. 2007;13:730-3. X-5. [pmid: 17973849].
1155 Vasquez DN, Estenssoro E, Canales HS, et al. Clinical characteristics and outcomes of obstetric patients requiring ICU admission. Chest. Mar. 2007;131:718-24. X-4. [pmid: 17356085].
1156 Vedam S, Goff M, Marnin VN. Closing the theory-practice gap: intrapartum midwifery management of planned homebirths. J Midwifery Womens Health. May-Jun. 2007;52:291-300. X-1. [pmid: 17467596].
1157 Vettore MV, Leal M, Leao AT, et al. The relationship between periodontitis and preterm low birthweight. J Dent Res. Jan. 2007;87:73-8. X-3, X-4. [pmid: 18096898].
1158 Voke J, Keidan J, Pavord S, et al. The management of antenatal venous thromboembolism in the UK and Ireland: a prospective multicentre observational survey. Br J Haematol. Nov. 2007;139:545-58. X-4. [pmid: 17916101].
1159 Wedisinghe L, Macleod M, Murphy DJ. Use of oxytocin to prevent haemorrhage at caesarean section--a survey of practice in the United Kingdom. Eur J Obstet Gynecol Reprod Biol. Mar. 2007;137:27-30. X-3, X-4. [pmid: 17544563].
1160 West D. Inner balance. Yoga in times of excessive bleeding: when the going gets tough, flow your way through. Alternative Medicine Magazine. 2007:78. X-1.
1161 Williams C. Labour and birth. Arbitrary time limits for the second stage of labour -- do they disempower women from achieving normal birth? A literature review. MIDIRS Midwifery Digest. 2007;17:527-33. X-1.
1162 Winter C, Macfarlane A, Deneux-Tharaux C, et al. Variations in policies for management of the third stage of labour and the immediate management of postpartum haemorrhage in Europe. BJOG. Jul. 2007;114:845-54. X-2, X-4, X-5. [pmid: 17567419].
1163 Wuttikonsammakit P, Sukcharoen N. Pregnancy outcomes of multiple repeated cesarean sections in King Chulalongkorn Memorial Hospital. J Med Assoc Thai. Oct. Suppl 4. 2007;89:S81-6. X-2, X-4. [pmid: 17725144].
1164 Yamaguchi ET, Cardoso MM, Torres ML. Oxytocin in cesarean sections: what is the best way to use it?. Rev Bras Anestesiol. Jun. 2007;57:324-50. X-1. [pmid: 19466368].
1165 Yamani-Zamzami TY. Delivery outcomes at term after one previous cesarean section. Saudi Med J. Dec. 2007;28:1845-9. X-2, X-4. [pmid: 18060214].
1166 Yap SC, Drenthen W, Pieper PG, et al. Outcome of pregnancy in women after pulmonary autograft valve replacement for congenital aortic valve disease. J Heart Valve Dis. Jul. 2007;16:398-403. X-4. [pmid: 17702365].
1167 Yap YY, Perrin LC, Pain SR, et al. Manual removal of suspected placenta accreta at cesarean hysterectomy. Int J Gynaecol Obstet. Feb. 2007;100:186-7. X-4, X-5. [pmid: 17900586].
1168 Zainur RZ, Loh KY. Postpartum morbidity--what we can do. Med J Malaysia. Dec. 2007;61:651-6. X-1. [pmid: 17623974].
1169 Zhang J, Bricker L, Wray S, et al. Poor uterine contractility in obese women. BJOG. Mar. 2007;114:343-8. X-4. [pmid: 17261121].
1170 Zlatnik MG, Cheng YW, Norton ME, et al. Placenta previa and the risk of preterm delivery. J Matern Fetal Neonatal Med. Oct. 2007;20:719-23. X-4. [pmid: 17763272].
1171 Notice of retraction for Abu-Omar AA. Prevention of postpartum hemorrhage safety and efficacy. Saudi Med J 2001;22:1118-21. Saudi Med J. Oct. 2008;29:1523. X-1. [pmid: 19086102].
1172 Postpartum hemorrhage risk with SSRIs, other antidepressants. Brown University Psychopharmacology Update. 2008;19:4. X-1, X-4, X-5.
1173 Percutaneous vascular embolization: meeting the needs of multiple patients. Journal of Vascular Nursing. 2008;26(3):87. Language: English. Entry Date: 20081017. Publication Type: journal article. X-1.
1174 Abbasi RM, Rizwen N, Mumtaz F, et al. Feto maternal outcome among abruptio placentae cases at a University Hospital of Sindh. Journal of the Liaquat University of Medical and Health Sciences. May/August. 2008;7:106-9. X-2, X-4.
1175 Abdul MA, Ibrahim UN, Yusuf MD, et al. Efficacy and safety of misoprostol in induction of labour in a Nigerian tertiary hospital. West Afr J Med. Jul-Sep. 2008;26:213-6. X-2, X-4. [pmid: 18399337].
1176 Agwu UM, Umeora OU, Ejikeme BN, et al. Retained placenta aspect of clinical management in a tertiary health institution in Nigeria. Niger J Med. Apr-Jun. 2008;17:146-9. X-2, X-4. [pmid: 18686828].
1177 Akoury H, Sherman C. Uterine wall partial thickness necrosis following combined B-Lynch and Cho square sutures for the treatment of primary postpartum hemorrhage. J Obstet Gynaecol Can. May. 2008;30(5):421-4. X-3. [pmid: 18505666].
1178 Althabe F, Buekens P, Bergel E, et al. A behavioral intervention to improve obstetrical care. N Engl J Med. May. 1. 2008;358:1929-40. X-2, X-4, X-5. [pmid: 18450604].
1179 Al-Zirqi I, Vangen S, Forsen L, et al. Prevalence and risk factors of severe obstetric haemorrhage. BJOG. Sep. 2008;115:1265-72. X-4, X-5. [pmid: 18715412].
1180 Arabin B, van Eyck J. Delayed-interval delivery in twin and triplet pregnancies: 17 years of experience in 1 perinatal center. Am J Obstet Gynecol. Feb. 2008;200:154 e1-8. X-4. [pmid: 19110229].
1181 Arnold CE, Payne M, Thompson JA, et al. Periparturient hemorrhage in mares: 73 cases (1998-2005). J Am Vet Med Assoc. May. 1. 2008;232:1345-51. X-1, X-3. [pmid: 18447780].
1182 Baloch S, Khaskheli M, Khushk IA, et al. Frequency of second stage intervention and its outcome in relation with instrumental vaginal delivery versus caesarean section. J Ayub Med Coll Abbottabad. Jan-Mar. 2008;20:87-90. X-2, X-4. [pmid: 19024196].
1183 Barnett S, Nair N, Tripathy P, et al. A prospective key informant surveillance system to measure maternal mortality - findings from indigenous populations in Jharkhand and Orissa, India. BMC Pregnancy Childbirth. 2008;8:6. X-2, X-3, X-4. [pmid: 18307796].
1184 Bensal A, Weintraub AY, Levy A, et al. The significance of peripartum fever in women undergoing vaginal deliveries. Am J Perinatol. Oct. 2008;25:567-72. X-4, X-5. [pmid: 18756433].
1185 Bhattacharya S, Townend J, Shetty A, et al. Does miscarriage in an initial pregnancy lead to adverse obstetric and perinatal outcomes in the next continuing pregnancy?. BJOG. Dec. 2008;115:1623-9. X-4. [pmid: 18947339].
1186 Bibi S, Danish N, Fawad A, et al. An audit of primary post partum hemorrhage. J Ayub Med Coll Abbottabad. Oct-Dec. 2008;19:102-6. X-2. [pmid: 18693611].
1187 Biswas A, Bal R, Kundu MK, et al. A study of prophylactic use of 15-methyl prostalglandin F2alpha in the active management of third stage of labour. J Indian Med Assoc. Sep. 8. 2008;105:506-9. X-2, X-4. [pmid: 18338474].
1188 Bricker L, Peden H, Tomlinson AJ, et al. Titrated low-dose vaginal and/or oral misoprostol to induce labour for prelabour membrane rupture: a randomised trial. BJOG. Nov. 2008;115:1503-11. X-2, X-3, X-4. [pmid: 18752586].
1189 Capion N, Thamsborg SM, Enevoldsen C. Prevalence and severity of foot lesions in Danish Holstein heifers through first lactation. Vet J. Oct. 2008;182:50-8. X-1, X-3. [pmid: 18757216].
1190 Carroli G, Cuesta C, Abalos E, et al. Epidemiology of postpartum haemorrhage: a systematic review. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22:999-1012. X-1, X-4. [pmid: 18819848].
1191 Chandraharan E, Arulkumaran S. Surgical aspects of postpartum haemorrhage. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22:1089-102. X-1. [pmid: 18790675].
1192 Chang WH, Lin CK, Chiang YJ, et al. Puerperal hematoma combined with retroperitoneal dissection and obstructive uropathy. Journal of Medical Sciences. April. 2008;28:81-3. X-1, X-2, X-4, X-5.
1193 Chauleur C, Cochery-Nouvellon E, Mercier E, et al. Some hemostasis variables at the end of the population distributions are risk factors for severe postpartum hemorrhages. J Thromb Haemost. Dec. 2008;6:2067-74. X-4. [pmid: 18826390].
1194 Chelmow D. Postpartum haemorrhage: prevention. Clin Evid (Online). 2008;2008. X-1, X-3, X-4. [pmid: 19445784].
1195 Chhabra S, Tickoo C. Low-dose sublingual misoprostol versus methylergometrine for active management of the third stage of labor. J Obstet Gynaecol Res. Oct. 2008;34:820-3. X-3, X-4. [pmid: 18834340].
1196 Chigbu B, Onwere S, Kamanu C, et al. Lessons learned from the outcome of bloodless emergency laparotomies on Jehovah's Witness women presenting in the extremis with ruptured uterus. Arch Gynecol Obstet. Apr. 2008;279:469-72. X-3, X-4. [pmid: 18677500].
1197 Courbiere B, Jauffret C, Provansal M, et al. Failure of conservative management in postpartum haemorrhage: uterine necrosis and hysterectomy after angiographic selective embolization with gelfoam. Eur J Obstet Gynecol Reprod Biol. Oct. 2008;140:291-3. X-1, X-5. [pmid: 18541360].
1198 Crofts JF, Bartlett C, Ellis D, et al. Patient-actor perception of care: a comparison of obstetric emergency training using manikins and patient-actors. Qual Saf Health Care. Feb. 2008;17:20-4. X-3, X-4. [pmid: 18245215].
1199 Daniels K, Parness AJ. Development and use of mechanical devices for simulation of seizure and hemorrhage in obstetrical team training. Simul Healthc. Spring. 2008;3:42-6. X-3. [pmid: 19088641].
1200 Dankert T, Vleugels M. Hysteroscopic resection of retained placental tissue: A feasibility study. Gynecological Surgery. May. 2008;5:121-4. X-2, X-4, X-5.
1201 Dedes I, Ziogas V. Circular isthmic-cervical sutures can be an alternative method to control peripartum haemorrhage during caesarean section for placenta praevia accreta. Arch Gynecol Obstet. Dec. 2008;278:555-7. X-5. [pmid: 18449555].
1202 Deneux-Tharaux C, Macfarlane A, Winter C, et al. Policies for manual removal of placenta at vaginal delivery: variations in timing within Europe. BJOG. Jan. 2008;116:119-24. X-1, X-2. [pmid: 19087083].
1203 Desbriere R, Courbiere B, Mattei S, et al. Hemostatic multiple square suturing is an effective treatment for the surgical management of intractable obstetric hemorrhage. Eur J Obstet Gynecol Reprod Biol. Jun. 2008;138(2):244-6. X-5. [pmid: 17490801].
1204 Domini E, Guidi M, Guazzini S, et al. Pre-operative transvaginal clamping of uterine a. descending branches, a safe and reliable manoeuver to prevent profuse LUS bleeding during Caesarean Section for Central Placenta previa. A preliminary report. Giornale Italiano di Ostetricia e Ginecologia. May. 2008;30:179-80. X-1, X-2, X-4, X-5.
1205 Doumouchtsis SK, Papageorghiou AT, Vernier C, et al. Management of postpartum hemorrhage by uterine balloon tamponade: prospective evaluation of effectiveness. Acta Obstet Gynecol Scand. 2008;87:849-55. X-4, X-5. [pmid: 18704777].
1206 Egging DF, van Vlijmen-Willems I, Choi J, et al. Analysis of obstetric complications and uterine connective tissue in tenascin-X-deficient humans and mice. Cell Tissue Res. Jun. 2008;332:523-32. X-3, X-4. [pmid: 18335242].
1207 Eskild A, Vatten LJ. Abnormal bleeding associated with preeclampsia: a population study of 315,085 pregnancies. Acta Obstet Gynecol Scand. 2008;88:154-8. X-4. [pmid: 19093234].
1208 Farley DM, O'Hara MH, Frazier LM, et al. Urgent delivery, diabetes and shoulder dystocia: What can we learn from observational research?. Expert Review of Obstetrics and Gynecology. May. 2008;3:301-15. X-3, X-4.
1209 Fenger-Eriksen C, Lindberg-Larsen M, Christensen AQ, et al. Fibrinogen concentrate substitution therapy in patients with massive haemorrhage and low plasma fibrinogen concentrations. Br J Anaesth. Dec. 2008;101:769-73. X-5. [pmid: 18818192].
1210 Fesslova VM, Villa L, Chessa M, et al. Prospective evaluation from single centre of pregnancy in women with congenital heart disease. Int J Cardiol. Jan. 9. 2008;131:257-64. X-4. [pmid: 18191250].
1211 Figueras A, Narvaez E, Valsecia M, et al. An education and motivation intervention to change clinical management of the third stage of labor - the GIRMMAHP Initiative. Birth. Dec. 2008;35:283-90. X-2, X-4, X-5. [pmid: 19036040].
1212 Freedman RA, Bauer KA, Neuberg DS, et al. Timing of postpartum enoxaparin administration and severe postpartum hemorrhage. Blood Coagul Fibrinolysis. Jan. 2008;19:55-9. X-4, X-5. [pmid: 18180616].
1213 Garba SN, Ajayi AD, Isa A, et al. Incidence and causes of maternal mortality in Ahmadu Bello University Teaching Hospital, Zaria, Nigeria. West African Journal of Nursing. 2008;19:15-20. X-2, X-4.
1214 Geller SE, Goudar SS, Adams MG, et al. Factors associated with acute postpartum hemorrhage in low-risk women delivering in rural India. Int J Gynaecol Obstet. Apr. 2008;101:94-9. X-2, X-4. [pmid: 18291401].
1215 Ghaemmaghami F, Karimi Zarchi M. Early onset of metastatic gestational trophoblastic disease after full-term pregnancy. Int J Biomed Sci. Mar. 2008;4:74-7. X-1, X-5. [pmid: 23675070].
1216 Ghaemmaghami F, Zarchi MK. Early onset of metastatic gestational trophoblastic disease after full-term pregnancy. United States. Master Publishing Group. 2008. http://www.ijbs.org/User/ContentFullText.aspx?VolumeNO=4&StartPage=74&Type=pdfovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed8&NEWS=N&AN=2008230828. Accessed on (Ghaemmaghami) Tehran University of Medical Sciences, Tehran, Iran, Islamic Republic of 4.
1217 Gibson CS, Goldwater PN, MacLennan AH, et al. Fetal exposure to herpesviruses may be associated with pregnancy-induced hypertensive disorders and preterm birth in a Caucasian population. BJOG. Mar. 2008;115:492-500. X-3, X-4. [pmid: 18271886].
1218 Goudar SS, Chakraborty H, Edlavitch SA, et al. Variation in the postpartum hemorrhage rate in a clinical trial of oral misoprostol. J Matern Fetal Neonatal Med. Aug. 2008;21:559-64. X-4, X-5. [pmid: 18609354].
1219 Haggertay H. Should midwives delay administration of syntometrine?. Midwives. 2008;11:16. X-1.
1220 Haththotuwa HR, Attygalle D, Jayatilleka AC, et al. Maternal mortality due to cardiac disease in Sri Lanka. Int J Gynaecol Obstet. Mar. 2008;104:194-8. X-2, X-4. [pmid: 19081565].
1221 Henry DE, Cheng YW, Shaffer BL, et al. Perinatal outcomes in the setting of active phase arrest of labor. Obstet Gynecol. Nov. 2008;112:1109-15. X-4. [pmid: 18978113].
1222 Heslehurst N, Simpson H, Ells LJ, et al. The impact of maternal BMI status on pregnancy outcomes with immediate short-term obstetric resource implications: a meta-analysis. Obes Rev. Nov. 2008;9:635-83. X-1. [pmid: 18673307].
1223 Higson A. Cord clamping... Upfront by Helen Haggertay, June/July issue (p 16). Midwives. 2008;11:14-5. X-1.
1224 Hillier TA, Vesco KK, Whitlock EP, et al. U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Screening for Gestational Diabetes Mellitus. 2008. X-1. [pmid: 20722157].
1225 Hinshaw K, Simpson S, Cummings S, et al. A randomised controlled trial of early versus delayed oxytocin augmentation to treat primary dysfunctional labour in nulliparous women. BJOG. Sep. 2008;115:1289-95. discussion 95-6. X-4. [pmid: 18715415].
1226 Hodges M. Unmet expectations: when patient safety takes a back seat. Nurs Womens Health. Feb. 2008;12:88-7. X-1, X-4, X-5. [pmid: 18257893].
1227 Hofmeyr GJ, Abdel-Aleem H, Abdel-Aleem MA. Uterine massage for preventing postpartum haemorrhage. Cochrane Database Syst Rev. 2008. CD006431. X-1, X-4. [pmid: 18646154].
1228 Hoque M, Hoque E, Kader SB. Pregnancy complications of gradmultiparity at a rural setting of South Africa. Iranian Journal of Reproductive Medicine. 2008;6:25-31. X-2, X-4.
1229 Hounton SH, Sombie I, Townend J, et al. The tip of the iceberg: evidence of seasonality in institutional maternal mortality and implications for health resources management in Burkina Faso. Scand J Public Health. May. 2008;36:310-7. X-2, X-4. [pmid: 18519302].
1230 Ismail NA, Saharan WS, Zaleha MA, et al. Kiwi Omnicup versus Malmstrom metal cup in vacuum assisted delivery: a randomized comparative trial. J Obstet Gynaecol Res. Jun. 2008;34:350-3. X-2, X-4, X-5. [pmid: 18686348].
1231 Ivy R, Ahmed FU, Ara H, et al. Uterine bracing surgical suture during caesarean section to prevent post-partum haemorrage in high risk cases; a study in Maternal and Child Health Training Institute,(MCHTI), Azimpur, Dhaka. Bangladesh Journal of Obstetrics and Gynecology. 2008;23. X-2, X-4.
1232 Jahromi BN, Husseini Z. Pregnancy outcome at maternal age 40 and older. Taiwan J Obstet Gynecol. Sep. 2008;47:318-21. X-2, X-4. [pmid: 18935996].
1233 Jambor C, Kozek-Langenecker SA, Frietsch T, et al. Thrombelastography Should Be d in the Algorithm for the Management of Postpartum Hemorrhage. Transfus Med Hemother. 2008;35:391-2. X-1, X-4, X-5. [pmid: 21512628].
1234 James AH, Patel ST, Watson W, et al. An assessment of medical resource utilization and hospitalization cost associated with a diagnosis of anemia in women with obstetrical bleeding in the United States. J Womens Health (Larchmt). Oct. 2008;17:1279-84. X-4. [pmid: 18752459].
1235 Jetti A, Poovali S, Stanley KP. Prolonged pregnancy. Obstetrics, Gynaecology and Reproductive Medicine. January. 2008;18:7-11. X-1.
1236 Josephs SC. Obstetric and gynecologic emergencies: a review of indications and interventional techniques. Semin Intervent Radiol. Dec. 2008;25:337-46. X-1. [pmid: 21326575].
1237 Kahn S, Meyer A, Beste J, et al. Clinical inquiries. Prophylactic oxytocin: Before or after placental delivery?. J Fam Pract. Dec. 2008;57:817-8. X-1, X-4. [pmid: 19080766].
1238 Kashanian M, Fekrat M, Masoomi Z, et al. Comparison of active and expectant management on the duration of the third stage of labour and the amount of blood loss during the third and fourth stages of labour: a randomised controlled trial. Midwifery. Apr. 2008;26:241-5. X-2, X-4. [pmid: 18706744].
1239 Kavle JA, Stoltzfus RJ, Witter F, et al. Association between anaemia during pregnancy and blood loss at and after delivery among women with vaginal births in Pemba Island, Zanzibar, Tanzania. J Health Popul Nutr. Jun. 2008;26:232-40. X-2, X-4. [pmid: 18686556].
1240 Kayabasoglu F, Guzin K, Aydogdu S, et al. Emergency peripartum hysterectomy in a tertiary Istanbul hospital. Arch Gynecol Obstet. Sep. 2008;278:251-6. X-2, X-4. [pmid: 18193245].
1241 Kirschner R, Baker L. Percutaneous vascular embolization: meeting the needs of multiple patients. Journal of Vascular Nursing. 2008;26:87. X-1, X-4, X-5.
1242 Knight M, Kurinczuk JJ, Spark P, et al. Cesarean delivery and peripartum hysterectomy. Obstet Gynecol. Jan. 2008;111:97-105. X-4. [pmid: 18165397].
1243 Kongnyuy EJ, Mlava G, van den Broek N. Facility-based maternal death review in three districts in the central region of Malawi: an analysis of causes and characteristics of maternal deaths. Womens Health Issues. Jan-Feb. 2008;19:14-20. X-2, X-4. [pmid: 19111783].
1244 Kongnyuy EJ, Mlava G, van den Broek N. Using criteria-based audit to improve the management of postpartum haemorrhage in resource limited countries: a case study of Malawi. Matern Child Health J. Nov. 2008;13:873-8. X-2, X-4. [pmid: 18780170].
1245 Koskas M, Nizard J, Salomon LJ, et al. Abdominal and pelvic ultrasound findings within 24 hours following uneventful Cesarean section. Ultrasound Obstet Gynecol. Sep. 2008;32:520-6. X-3, X-4. [pmid: 18683208].
1246 Kovavisarach E, Nualplot P. Outcome of pregnancy among parturients complicated with heart disease in Rajavithi Hospital. J Med Assoc Thai. Nov. 2008;90:2253-9. X-2, X-4. [pmid: 18181303].
1247 Lambert JR, Austin SK, Peebles D, et al. Audit of the peri-delivery use of unfractionated heparin in women on therapeutic low-molecular weight heparin. Br J Haematol. Jul. 2008;142:453-6. X-3, X-4. [pmid: 18510687].
1248 Lefkou E, Hunt B. Haematological management of obstetric haemorrhage. Obstetrics, Gynaecology and Reproductive Medicine. October. 2008;18:265-71. X-1.
1249 Low LK, Bailey JM, Sacks E, et al. Postpartum hemorrhage prevention: a case study in northern rural Honduras. J Midwifery Womens Health. Jan-Feb. 2008;53:e1-6. X-2, X-4. [pmid: 18164426].
1250 Lynch CM, Sheridan C, Breathnach FM, et al. Near miss maternal morbidity. Ir Med J. May. 2008;101:134-6. X-5. [pmid: 18624257].
1251 Maassen MS, Lambers MD, Tutein Nolthenius RP, et al. Complications and failure of uterine artery embolisation for intractable postpartum haemorrhage. Bjog. Jan. 2008;116:55-61. X-5. [pmid: 19016685].
1252 Macdonald S, Brown K, Wyatt M, et al. Endgames. BMJ: British Medical Journal (International Edition). 2008;337:1359. X-1, X-4, X-5.
1253 Macleod M, Strachan B, Bahl R, et al. A prospective cohort study of maternal and neonatal morbidity in relation to use of episiotomy at operative vaginal delivery. BJOG. Dec. 2008;115:1688-94. X-4. [pmid: 19035943].
1254 Malkiel A, Pnina M, Aloni H, et al. Primiparity: a traditional intrapartum obstetric risk reconfirmed. Isr Med Assoc J. Jul. 2008;10:508-11. X-4. [pmid: 18751628].
1255 Maslovitz S, Barkai G, Lessing JB, et al. Improved accuracy of postpartum blood loss estimation as assessed by simulation. Acta Obstet Gynecol Scand. 2008;87:929-34. X-3, X-4. [pmid: 18720041].
1256 Mathe JK. Obstetric hysterectomy in rural Democratic Republic of the Congo: an analysis of 40 cases at Katwa Hospital. Afr J Reprod Health. Apr. 2008;12:60-6. X-2. [pmid: 20695156].
1257 Mazhar SB, Rahim F, Furukh T. Fetomaternal outcome in triplet pregnancy. J Coll Physicians Surg Pak. Apr. 2008;18:217-21. X-2, X-4. [pmid: 18474154].
1258 McFarlane MEC, Plummer JM, Remy T, et al. Jejunouterine fistula: A case report. Gynecological Surgery. May. 2008;5:173-5. X-1.
1259 Meydanli MM, Turkcuoglu I, Engin-Ustun Y, et al. Meydanli compression suture: new surgical procedure for postpartum hemorrhage due to uterine atony associated with abnormal placental adherence. J Obstet Gynaecol Res. Dec. 2008;34:964-70. X-2, X-4, X-5. [pmid: 19012694].
1260 Miller S, Tudor C, Thorsten V, et al. Comparison of maternal and newborn outcomes of Tibetan and Han Chinese delivering in Lhasa, Tibet. J Obstet Gynaecol Res. Dec. 2008;34:986-93. X-2, X-4. [pmid: 19012697].
1261 Misra R, Sharma BL, Gupta R, et al. Indian Rheumatology Association consensus statement on the management of adults with rheumatoid arthritis. Indian Journal of Rheumatology. November. 2008;3:S1-S16. X-1.
1262 Mousa HA, Cording V, Alfirevic Z. Risk factors and interventions associated with major primary postpartum hemorrhage unresponsive to first-line conventional therapy. Acta Obstet Gynecol Scand. 2008;87:652-61. X-4, X-5. [pmid: 18568465].
1263 Murphy DJ, MacGregor H, Munishankar B, et al. A randomised controlled trial of oxytocin 5IU and placebo infusion versus oxytocin 5IU and 30IU infusion for the control of blood loss at elective caesarean section--pilot study. ISRCTN 40302163. Eur J Obstet Gynecol Reprod Biol. Jan. 2008;142:30-3. X-4. [pmid: 18977579].
1264 Narin C, Reyhanoglu H, Tulek B, et al. Comparison of different dose regimens of enoxaparin in deep vein thrombosis therapy in pregnancy. Adv Ther. Jun. 2008;25:585-94. X-4. [pmid: 18568442].
1265 Neilson JP. Cochrane Update: Effect of timing of umbilical cord clamping at birth of term infants on mother and baby outcomes. Obstet Gynecol. Jul. 2008;112:177-8. X-1. [pmid: 18591323].
1266 Nohira T, Osakabe Y, Suda S, et al. Successful management by recombinant activated factor VII in a case of disseminated intravascular coagulopathy caused by obstetric hemorrhage. Journal of Obstetrics & Gynaecology Research. 2008;34:623-30. X-4, X-5. [pmid: 18840167].
1267 Nour NM. An introduction to maternal mortality. Rev Obstet Gynecol. Spring. 2008;1:77-81. X-1. [pmid: 18769668].
1268 Okonkwo CA, Ande ABA, Ovbagbedia O, et al. Iatrogenic injury to the internal iliac vein: A life threatening complication of internal iliac artery ligation. Pakistan Journal of Medical Sciences. April/June. 2008;24:325-7. X-1, X-2.
1269 Olopade FE, Lawoyin TO. Maternal mortality in a Nigerian Maternity Hospital. African Journal Biomedical Research. 2008;11:267-73. X-2, X-4.
1270 Orji E, Agwu F, Loto O, et al. A randomized comparative study of prophylactic oxytocin versus ergometrine in the third stage of labor. Int J Gynaecol Obstet. May. 2008;101:129-32. X-4. [pmid: 18164304].
1271 Owolabi AT, Dare FO, Fasubaa OB, et al. Risk factors for retained placenta in southwestern Nigeria. Singapore Med J. Jul. 2008;49:532-7. X-2, X-4. [pmid: 18695860].
1272 Palacios-Jaraquemada JM. Diagnosis and management of placenta accreta. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22:1133-48. X-1. [pmid: 18815074].
1273 Patted SS, Goudar SS, Naik VA, et al. Side effects of oral misoprostol for the prevention of postpartum hemorrhage: results of a community-based randomised controlled trial in rural India. J Matern Fetal Neonatal Med. Jan. 2008;22:24-8. X-2, X-4. [pmid: 19089777].
1274 Patterson DA, Winslow M, Matus CD. Spontaneous vaginal delivery. Am Fam Physician. Aug. 1. 2008;78:336-41. X-1. [pmid: 18711948].
1275 Perez A, Bacallao J, Alcina S, et al. Severe maternal morbidity in the intensive care unit of a havana teaching hospital, 1998 to 2004. MEDICC Rev. Jul. 2008;10:17-23. X-2, X-4. [pmid: 21487365].
1276 Phelps CL. An educational program: simulation training for common obstetrical emergencies. Communicating Nursing Research. 2008;41:354. X-1, X-3.
1277 Plaat F. Anaesthetic issues related to postpartum haemorrhage (excluding antishock garments). Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22:1043-56. X-1. [pmid: 18849197].
1278 Pliego JF, Wehbe-Janek H, Rajab MH, et al. OB/GYN boot cAMP using high-fidelity human simulators: enhancing residents' perceived competency, confidence in taking a leadership role, and stress hardiness. Simul Healthc. Summer. 2008;3:82-9. X-3, X-4. [pmid: 19088646].
1279 Quiroz LH, Chang H, Blomquist JL, et al. Scheduled cesarean delivery: maternal and neonatal risks in primiparous women in a community hospital setting. Am J Perinatol. Apr. 2008;26:271-7. X-4. [pmid: 19021093].
1280 Rahman SS, Myers JE, Gillham JC, et al. Post partum haemorrhage secondary to uterine atony, complicated by platelet storage pool disease and partial placenta diffusa: a case report. Cases J. 2008;1:393. X-2, X-5. [pmid: 19077291].
1281 Ratnam LA, Gibson M, Sandhu C, et al. Transcatheter pelvic arterial embolisation for control of obstetric and gynaecological haemorrhage. J Obstet Gynaecol. Aug. 2008;28:573-9. X-2, X-5. [pmid: 19003648].
1282 Rayamajhi R, Thapa M, Pande S. The challenge of grandmultiparity in obstetric practice. Kathmandu Univ Med J (KUMJ). Jan-Mar. 2008;4:70-4. X-2, X-4. [pmid: 18603872].
1283 Raza F, Majeed S. Intracervical PGE2 gel for cervical ripening and induction of labour. Pakistan Journal of Medical Sciences. April/June. 2008;24:241-5. X-2, X-4.
1284 Roberts CL, Lain SJ, Morris JM. Variation in adherence to recommendations for management of the third stage of labor. Int J Gynaecol Obstet. Nov. 2008;103:172-3. X-2, X-4, X-5. [pmid: 18692186].
1285 Roy A, Patra KK, Mukhopadhyay S, et al. Study of drotaverine on first stage of labour and pregnancy outcome. J Indian Med Assoc. Aug. 2008;105:450. 2. X-2, X-4. [pmid: 18236908].
1286 Salkeld E, Ferris LE, Juurlink DN. The risk of postpartum hemorrhage with selective serotonin reuptake inhibitors and other antidepressants. J Clin Psychopharmacol. Apr. 2008;28:230-4. X-4. [pmid: 18344737].
1287 Searle E, Pavord S, Alfirevic Z. Recombinant factor VIIa and other pro-haemostatic therapies in primary postpartum haemorrhage. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22:1075-88. X-1. [pmid: 18838340].
1288 Sentilhes L, Gromez A, Razzouk K, et al. B-Lynch suture for massive persistent postpartum hemorrhage following stepwise uterine devascularization. Acta Obstet Gynecol Scand. 2008;87:1020-6. X-5. [pmid: 18927949].
1289 Sentilhes L, Gromez A, Trichot C, et al. Fertility after B-Lynch suture and stepwise uterine devascularization. Fertil Steril. Mar. 2008;91:934 e5-9. X-5. [pmid: 18996514].
1290 Sentilhes L, Trichot C, Resch B, et al. Fertility and pregnancy outcomes following uterine devascularization for severe postpartum haemorrhage. Hum Reprod. May. 2008;23:1087-92. X-5. [pmid: 18321892].
1291 Shah AA, Grotegut CA, Likes CE 3rd, et al. Heterotopic cervical pregnancy treated with transvaginal ultrasound-guided aspiration resulting in cervical site varices within the myometrium. Fertil Steril. Mar. 2008;91:934 e19-22. X-1, X-3, X-4. [pmid: 19022428].
1292 Sharathkumar A, Hardesty B, Greist A, et al. Variability in bleeding phenotype in Amish carriers of haemophilia B with the 31008 C-->T mutation. Haemophilia. Jan. 2008;15:91-100. X-4. [pmid: 18721150].
1293 Siggelkow W, Boehm D, Skala C, et al. The influence of macrosomia on the duration of labor, the mode of delivery and intrapartum complications. Arch Gynecol Obstet. Dec. 2008;278:547-53. X-4. [pmid: 18379807].
1294 Silvestre FT, Bartolome JA, Kamimura S, et al. Postpartum suppression of ovarian activity with a Deslorelin implant enhanced uterine involution in lactating dairy cows. Anim Reprod Sci. Jan. 2008;110:79-95. X-1, X-3. [pmid: 18243603].
1295 Singh Y, Shankar A, Rohatgi S. Abruptio placentae leading to fetal death and adult respiratory distress syndrome. Medical Journal Armed Forces India. October. 2008;64:389-90. X-1, X-2.
1296 Soyer P, Fargeaudou Y, Morel O, et al. Severe postpartum haemorrhage from ruptured pseudoaneurysm: successful treatment with transcatheter arterial embolization. Eur Radiol. Jun. 2008;18:1181-7. X-5. [pmid: 18270711].
1297 Sriram S, Robertson MS. Critically ill obstetric patients in Australia: a retrospective audit of 8 years' experience in a tertiary intensive care unit. Crit Care Resusc. Jun. 2008;10:124. X-4, X-5. [pmid: 18522526].
1298 Stafford I, Belfort M. Placenta accreta, increta, and percreta: lifesaving strategies to stop the bleeding... part 1 of this two-part article. Contemporary OB/GYN. 2008;53:48-53. X-1.
1299 Stafford I, Belfort MA. Placenta accreta, increta, and percreta: a team-based approach starts with prevention. Contemporary OB/GYN. 2008;53:76-82. X-1.
1300 Stafford I, Dildy GA, Clark SL, et al. Visually estimated and calculated blood loss in vaginal and cesarean delivery. Am J Obstet Gynecol. Nov. 2008;199:519 e1-7. X-2, X-4, X-5. [pmid: 18639209].
1301 Steinauer JE, Diedrich JT, Wilson MW, et al. Uterine artery embolization after abortion. ACOG Clinical Review. 2008;13:11. X-1, X-3, X-4.
1302 Sutherland T, Bishai DM. Cost-effectiveness of misoprostol and prenatal iron supplementation as maternal mortality interventions in home births in rural India. Int J Gynaecol Obstet. Mar. 2008;104:189-93. X-1, X-2, X-3, X-4. [pmid: 19081564].
1303 Symon A. Nobody wins. British Journal of Midwifery. 2008;16:609-10. X-1.
1304 Tan WM, Klein MC, Saxell L, et al. How do physicians and midwives manage the third stage of labor?. Birth. Sep. 2008;35:220-9. X-3, X-4. [pmid: 18844648].
1305 Tantbirojn P, Crum CP, Parast MM. Pathophysiology of placenta creta: the role of decidua and extravillous trophoblast. Placenta. Jul. 2008;29:639-45. X-1, X-4. [pmid: 18514815].
1306 Tehseen F, Anwar A, Arfat Y. Intraumbilical veinous injection oxytocin in the active management of third stage of labour. J Coll Physicians Surg Pak. Sep. 2008;18:551-4. X-2, X-3, X-4. [pmid: 18803892].
1307 Tharakan T, Jha J. Randomized double blind prospective trial of active management of the third stage of labor. Archives of Medical Science. March. 2008;4:79-82. X-3, X-4.
1308 Thomas SV, Sindhu K, Ajaykumar B, et al. Maternal and obstetric outcome of women with epilepsy. Seizure. Apr. 2008;18:163-6. X-4. [pmid: 18805707].
1309 Tibary A, Rodriguez J, Sandoval S. Reproductive emergencies in camelids. Theriogenology. Aug. 2008;70:515-34. X-1, X-2, X-3, X-4. [pmid: 18514807].
1310 Tsu VD, Luu HT, Mai TT. Does a novel prefilled injection device make postpartum oxytocin easier to administer? Results from midwives in Vietnam. Midwifery. Aug. 2008;25:461-5. X-2, X-3, X-4. [pmid: 18281131].
1311 Uchiyama D, Koganemaru M, Abe T, et al. Arterial catheterization and embolization for management of emergent or anticipated massive obstetrical hemorrhage. Radiat Med. May. 2008;26:188-97. X-5. [pmid: 18509718].
1312 Upadhyay K, Scholefield H. Risk management and medicolegal issues related to postpartum haemorrhage. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22:1149-69. X-1. [pmid: 18819846].
1313 van den Bosch T, Daemen A, Van Schoubroeck D, et al. Occurrence and outcome of residual trophoblastic tissue: a prospective study. J Ultrasound Med. Mar. 2008;27:357-61. X-4, X-5. [pmid: 18314513].
1314 Villers MS, Jamison MG, De Castro LM, et al. Morbidity associated with sickle cell disease in pregnancy. Am J Obstet Gynecol. Aug. 2008;199:125 e1-5. X-4. [pmid: 18533123].
1315 Wakasa T, Wakasa K, Nakayama M, et al. Change in morphology and oxytocin receptor expression in the uterine blood vessels during the involution process. Gynecol Obstet Invest. 2008;67:137-44. X-3, X-4. [pmid: 19005262].
1316 Walraven G, Wanyonyi S, Stones W. Management of post-partum hemorrhage in low-income countries. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22:1013-23. X-1. [pmid: 18848808].
1317 Wandabwa J, Doyle P, Todd J, et al. Risk factors for severe post partum haemorrhage in Mulago hospital, Kampala, Uganda. East Afr Med J. Feb. 2008;85:64-71. X-2, X-4. [pmid: 18557249].
1318 Wei S, Fraser WD. Review: misoprostol and intramuscular prostaglandins do not prevent postpartum haemorrhage more than injectable uterotonics. Evid Based Med. Jun. 2008;13:82. X-1. [pmid: 18515629].
1319 Winograd RH. Uterine artery embolization for postpartum hemorrhage. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22:1119-32. X-1. [pmid: 18790676].
1320 Wolman I, Altman E, Fait G, et al. Evacuating retained products of conception in the setting of an ultrasound unit. Fertil Steril. Apr. 2008;91:1586-8. X-4, X-5. [pmid: 19064261].
1321 Wong HS, Hutton J, Zuccollo J, et al. The maternal outcome in placenta accreta: the significance of antenatal diagnosis and non-separation of placenta at delivery. N Z Med J. Jul. 4. 2008;121:30-8. X-4, X-5. [pmid: 18677328].
1322 Yadav S, Choudhary D, N KC, et al. Adverse reproductive outcomes associated with teenage pregnancy. Canada. McGill University. (3655 Promenade Sir William Osler, Montreal QUE H3G 1Y6, Canada). 2008. http://www.medicine.mcgill.ca/mjm/mjm1102.pdfhttp://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed8&NEWS=N&AN=2009145467). Accessed on (Yadav, Choudhary, K.C., Kumar, Mandal, Sharma, Chauhan, Agrawal) Department of Medicine, Department of Surgery Institute of Medicine (IOM), Maharajgunj Campus, Maharajgunj, Kathmandu, Nepal 11.
1323 Yanagisawa S, Wakai S. Professional healthcare use for life-threatening obstetric conditions. J Obstet Gynaecol. Oct. 2008;28:713-9. X-2, X-4. [pmid: 19065367].
1324 Yazdanpanahi Z, Forouhari S, Parsanezhad ME. Prepregnancy body mass index and gestational weight gain and their association with some pregnancy outcomes. Iranian Red Crescent Medical Journal. 2008;10:326-31. X-1, X-2, X-4.
1325 Yildirim G, Beji NK. Effects of pushing techniques in birth on mother and fetus: a randomized study. Birth. Mar. 2008;35:25-30. X-2, X-4. [pmid: 18307484].
1326 Yildirim Y, Gultekin E, Kocyigit A, et al. Color Doppler analysis of pelvic arteries following bilateral internal iliac artery ligation for severe postpartum hemorrhage. Int J Gynaecol Obstet. Jan. 2008;104:22-4. X-2, X-5. [pmid: 18962582].
1327 Yoong W, Memtsa M, Pun S, et al. Pregnancy outcomes of women with pruritus, normal bile salts and liver enzymes: a case control study. Acta Obstet Gynecol Scand. 2008;87:419-22. X-4. [pmid: 18382867].
1328 Yu PC, Ou HY, Tsang LL, et al. Prophylactic intraoperative uterine artery embolization to control hemorrhage in abnormal placentation during late gestation. Fertil Steril. May. 2008;91:1951-5. X-2, X-4, X-5. [pmid: 18501901].
1329 Zuberi NF, Durocher J, Sikander R, et al. Misoprostol in addition to routine treatment of postpartum hemorrhage: a hospital-based randomized-controlled trial in Karachi, Pakistan. BMC Pregnancy Childbirth. 2008;8:40. X-2. [pmid: 18718007].
1330 Zwart JJ, Richters JM, Ory F, et al. Severe maternal morbidity during pregnancy, delivery and puerperium in the Netherlands: a nationwide population-based study of 371,000 pregnancies. Bjog. Jun. 2008;115:842-50. X-4. [pmid: 18485162].
1331 Carbetocin: a synthetic oxytocin analogue with no clear advantages. Prescrire Int. Aug. 2009;17:150. X-1, X-4. [pmid: 19492484].
1332 Bulletin board. Journal of Women's Health (15409996). 2009;18:919-22. X-1, X-4, X-5.
1333 Induction with misoprostol increases postpartum blood loss. Contemporary OB/GYN. 2009;54:18. X-1, X-4.
1334 Maternity and neonatal. Nursing Times. 2009;105:6. X-1, X-4.
1335 Uterine balloon tamponade for postpartum hemorrhage. ACOG Clinical Review. 2009;14:3. X-1, X-4.
1336 Women needed for study. Australian Nursing Journal. 2009;16:43. X-1, X-4, X-5.
1337 WHO Guidelines Approved by the Guidelines Review Committee. WHO Guidelines for the Management of Postpartum Haemorrhage and Retained Placenta. 2009. X-1. [pmid: 23844453].
1338 Chapter 16: caring for the woman experiencing complications during the postpartal period. Maternal-child nursing care: optimizing outcomes for mothers, children, and families. Philadelphia, PA. F.A. Davis Company. 2009:511-40.
1339 Abbasi N, Danish N, Shakoor F, et al. Effectiveness and safety of vaginal misoprostol for induction of labour in unfavourable cervix in 3rd trimester. J Ayub Med Coll Abbottabad. Jul-Sep. 2009;20:33-5. X-2, X-4. [pmid: 19610511].
1340 Akwuruoha E, Kamanu C, Onwere S, et al. Grandmultiparity and pregnancy outcome in Aba, Nigeria: a case-control study. Arch Gynecol Obstet. Feb. 2009;283:167-72. X-2, X-4. [pmid: 19967382].
1341 Al-Harazi AH, Frass KA. Sublingual misoprostol for the prevention of postpartum hemorrhage. Saudi Med J. Jul. 2009;30:912-6. X-2, X-4. [pmid: 19618006].
1342 Al-Harbi NA, Al-Abra ES, Alabbad NS. Utero-vaginal packing. Seven years review in the management of post partum hemorrhage due to placenta previa/accreta at a maternity hospital in Central Saudi Arabia. Saudi Med J. Feb. 2009;30:243-6. X-2. [pmid: 19198714].
1343 Al-Kadri HM, Tariq S, Tamim HM. Risk factors for postpartum hemorrhage among Saudi women. Saudi Med J. Oct. 2009;30:1305-10. X-2, X-4. [pmid: 19838439].
1344 Allen R, O'Brien BM. Uses of misoprostol in obstetrics and gynecology. Rev Obstet Gynecol. Summer. 2009;2:159-68. X-1. [pmid: 19826573].
1345 Allen VM, Baskett TF, O'Connell CM, et al. Maternal and perinatal outcomes with increasing duration of the second stage of labor. Obstet Gynecol. Jun. 2009;113:1248-58. X-4. [pmid: 19461419].
1346 Althabe F, Aleman A, Tomasso G, et al. A pilot randomized controlled trial of controlled cord traction to reduce postpartum blood loss. Int J Gynaecol Obstet. Oct. 2009;107:4-7. X-2, X-4, X-5. [pmid: 19541304].
1347 Al-Zirqi I, Vangen S, Forsen L, et al. Effects of onset of labor and mode of delivery on severe postpartum hemorrhage. Am J Obstet Gynecol. Sep. 2009;201:273 e1-9. X-4. [pmid: 19733277].
1348 Andersen AS, Berthelsen JG, Bergholt T. Venous thromboembolism in pregnancy: prophylaxis and treatment with low molecular weight heparin. Acta Obstet Gynecol Scand. 2009;89:15-21. X-4. [pmid: 19916891].
1349 Andreani M, Vergani P, Ghidini A, et al. Are ultrasonographic myoma characteristics associated with blood loss at delivery?. Ultrasound Obstet Gynecol. Sep. 2009;34:322-5. X-4. [pmid: 19670350].
1350 Arduini M, Epicoco G, Clerici G, et al. B-Lynch suture, intrauterine balloon, and endouterine hemostatic suture for the management of postpartum hemorrhage due to placenta previa accreta. Int J Gynaecol Obstet. Mar. 2009;108:191-3. X-4, X-5. [pmid: 19945698].
1351 Arora S, Williams RM, Torrie P, et al. Sub-involution of placental site after first trimester miscarriage: sonographic appearances and a new approach to management. Ultrasound. 2009;17:103-5. X-4.
1352 Asch DA, Nicholson S, Srinivas S, et al. Evaluating obstetrical residency programs using patient outcomes. JAMA. Sep. 23. 2009;302:1277-83. X-3, X-4. [pmid: 19773562].
1353 Bahar A, Abusham A, Eskandar M, et al. Risk factors and pregnancy outcome in different types of placenta previa. J Obstet Gynaecol Can. Feb. 2009;31:126-31. X-3. [pmid: 19327211].
1354 Ball H. Active management of the third state of labor is rare in some developing countries. International Perspectives on Sexual & Reproductive Health. 2009;35:105-6. X-1, X-2, X-4, X-5.
1355 Barillari G, Frigo MG, Casarotto M, et al. Use of recombinant activated factor VII in severe post-partum haemorrhage: data from the Italian Registry: a multicentric observational retrospective study. Thromb Res. Dec. 2009;124:e41-7. X-2, X-4, X-5. [pmid: 19783283].
1356 Basurko C, Carles G, Youssef M, et al. Maternal and fetal consequences of dengue fever during pregnancy. Eur J Obstet Gynecol Reprod Biol. Nov. 2009;147:29-32. X-2, X-4. [pmid: 19632027].
1357 Bauer ST, Bonanno C. Abnormal placentation. Semin Perinatol. Apr. 2009;33:88-96. X-1. [pmid: 19324237].
1358 Berg CJ, Mackay AP, Qin C, et al. Overview of maternal morbidity during hospitalization for labor and delivery in the United States: 1993-1997 and 2001-2005. Obstet Gynecol. May. 2009;113:1075-81. X-4. [pmid: 19384123].
1359 Bodelon C, Bernabe-Ortiz A, Schiff MA, et al. Factors associated with peripartum hysterectomy. Obstet Gynecol. Jul. 2009;114:115-23. X-4, X-5. [pmid: 19546767].
1360 Boel ME, Lee SJ, Rijken MJ, et al. Castor oil for induction of labour: not harmful, not helpful. Aust N Z J Obstet Gynaecol. Oct. 2009;49:499-503. X-2, X-3, X-4. [pmid: 19780733].
1361 Borruto F, Treisser A, Comparetto C. Utilization of carbetocin for prevention of postpartum hemorrhage after cesarean section: a randomized clinical trial. Arch Gynecol Obstet. Nov. 2009;280:707-12. X-4, X-5. [pmid: 19229549].
1362 Borup L, Wurlitzer W, Hedegaard M, et al. Acupuncture as pain relief during delivery: a randomized controlled trial. Birth. Mar. 2009;36:5-12. X-3, X-4. [pmid: 19278378].
1363 Breathnach F, Geary M. Uterine atony: definition, prevention, nonsurgical management, and uterine tamponade. Semin Perinatol. Apr. 2009;33:82-7. X-1. [pmid: 19324236].
1364 Butwick AJ, Aleshi P, Fontaine M, et al. Retrospective analysis of transfusion outcomes in pregnant patients at a tertiary obstetric center. Int J Obstet Anesth. Oct. 2009;18:302-8. X-4, X-5. [pmid: 19628384].
1365 Cabero Roura L, Keith LG. Post-partum haemorrhage: diagnosis, prevention and management. J Matern Fetal Neonatal Med. Suppl 2. 2009;22:38-45. X-1, X-2, X-4, X-5. [pmid: 19951082].
1366 Chantrapitak W, Srijanteok K, Puangsa-art S. Lower uterine segment compression for management of early postpartum hemorrhage after vaginal delivery at Charoenkrung Pracharak Hospital. J Med Assoc Thai. May. 2009;92:600-5. X-2. [pmid: 19459518].
1367 Chi C, Kulkarni A, Lee CA, et al. The obstetric experience of women with factor XI deficiency. Acta Obstet Gynecol Scand. 2009;88:1095-100. X-4, X-5. [pmid: 19685354].
1368 Chicoine AL, Boison JO, Parker S, et al. Kinetics and residues after intraperitoneal procaine penicillin G administration in lactating dairy cows. J Vet Pharmacol Ther. Jun. 2009;32:289-95. X-3. [pmid: 19646094].
1369 Christian P, Khatry SK, LeClerq SC, et al. Effects of prenatal micronutrient supplementation on complications of labor and delivery and puerperal morbidity in rural Nepal. Int J Gynaecol Obstet. Jul. 2009;106:3-7. X-2, X-3, X-4. [pmid: 19368922].
1370 Chunilal SD, Bates SM. Venous thromboembolism in pregnancy: diagnosis, management and prevention. Thromb Haemost. Mar. 2009;101:428-38. X-1. [pmid: 19277402].
1371 Coffin CS, Shaheen AA, Burak KW, et al. Pregnancy outcomes among liver transplant recipients in the United States: a nationwide case-control analysis. Liver Transpl. Jan. 2009;16:56-63. X-4. [pmid: 20035524].
1372 Cohen MR. Medication errors. Look-alike obstetrical drugs: too close for comfort. Nursing. 2009;39:14. X-1.
1373 Contreras KR, Kominiarek MA, Zollinger TW. The impact of tobacco smoking on perinatal outcome among patients with gestational diabetes. J Perinatol. May. 2009;30:319-23. X-4. [pmid: 19907429].
1374 Darkaneh RF, Asgharnia M, Aghazadeh S. Hemoperitoneum caused by placenta percreta in the third trimester of pregnancy. Iranian Journal of Medical Sciences. June. 2009;34:145-8. X-2, X-4.
1375 de Vienne CM, Creveuil C, Dreyfus M. Does young maternal age increase the risk of adverse obstetric, fetal and neonatal outcomes: a cohort study. Eur J Obstet Gynecol Reprod Biol. Dec. 2009;147:151-6. X-4. [pmid: 19733429].
1376 Deering SH, Chinn M, Hodor J, et al. Use of a postpartum hemorrhage simulator for instruction and evaluation of residents. J Grad Med Educ. Dec. 2009;1:260-3. X-3. [pmid: 21975989].
1377 Delotte J, Novellas S, Koh C, et al. Obstetrical prognosis and pregnancy outcome following pelvic arterial embolisation for post-partum hemorrhage. Eur J Obstet Gynecol Reprod Biol. Aug. 2009;145:129-32. X-1. [pmid: 19398259].
1378 Devine PC. Obstetric hemorrhage. Semin Perinatol. Apr. 2009;33:76-81. X-1. [pmid: 19324235].
1379 Dixon L, Fletcher L, Tracy S, et al. Midwives care during the Third Stage of Labour: an analysis of the New Zealand College of Midwives Midwifery Database 2004-2008. [corrected] [published erratum appears in NZ COLL MIDWIVES J 2010 May;42:6]. New Zealand College of Midwives Journal. 2009;41:20-5. X-4.
1380 Dupont C, Touzet S, Colin C, et al. Incidence and management of postpartum haemorrhage following the dissemination of guidelines in a network of 16 maternity units in France. Int J Obstet Anesth. Oct. 2009;18:320-7. X-4, X-5. [pmid: 19733052].
1381 Eftekhari N, Doroodian M, Lashkarizadeh R. The effect of sublingual misoprostol versus intravenous oxytocin in reducing bleeding after caesarean section. J Obstet Gynaecol. Oct. 2009;29:633-6. X-2, X-4, X-5. [pmid: 19757270].
1382 El-Hamamy E, Wright A, C BL. The B-Lynch suture technique for postpartum haemorrhage: a decade of experience and outcome. J Obstet Gynaecol. May. 2009;29:278-83. X-1. [pmid: 19835492].
1383 Eller AG, Porter TF, Soisson P, et al. Optimal management strategies for placenta accreta. BJOG. Apr. 2009;116:648-54. X-2, X-5. [pmid: 19191778].
1384 Elmir R, Schmied V, Jackson D, et al. A tale of strength. Australian Nursing Journal. 2009;17:43. X-1, X-5.
1385 ElSedeek M, Awad EE, ElSebaey SM. Evaluation of postpartum blood loss after misoprostol-induced labour. BJOG. Feb. 2009;116:431-5. X-2, X-4, X-5. [pmid: 19187376].
1386 Errarhay S, Kamaoui I, Bouchikhi C, et al. Sheehan's Syndrome A Case Report and Literature Review. Libyan J Med. 2009;4:81-2. X-2, X-4. [pmid: 21483515].
1387 Fahy KM. Third stage of labour care for women at low risk of postpartum haemorrhage. J Midwifery Womens Health. Sep-Oct. 2009;54:380-6. X-1, X-3. [pmid: 19720339].
1388 Fargeaudou Y, Soyer P, Morel O, et al. Severe primary postpartum hemorrhage due to genital tract laceration after operative vaginal delivery: successful treatment with transcatheter arterial embolization. Eur Radiol. Sep. 2009;19:2197-203. X-5. [pmid: 19415291].
1389 Fernandez MM, Coeytaux F, de Leon RG, et al. Assessing the global availability of misoprostol. Int J Gynaecol Obstet. May. 2009;105:180-6. X-3, X-4. [pmid: 19286183].
1390 Ferrer P, Roberts I, Sydenham E, et al. Anti-fibrinolytic agents in post partum haemorrhage: a systematic review. BMC Pregnancy Childbirth. 2009;9:29. X-1, X-4, X-5. [pmid: 19604358].
1391 Focho DA, Nkeng EAP, Lucha CF, et al. Ethnobotanical survey of plants used to treat diseases of the reproductive system and preliminary phytochemical screening of some species of malvaceae in Ndop Central Sub-division, Cameroon. Journal of Medicinal Plants Research. 2009;3:301-14. X-1, X-3.
1392 Forster DA, McEgan K, Ford R, et al. Diabetes and antenatal milk expressing: a pilot project to inform the development of a randomised controlled trial. Midwifery. Apr. 2009;27:209-14. X-3, X-4. [pmid: 19615797].
1393 Fuchs KM, Miller RS, Berkowitz RL. Optimizing outcomes through protocols, multidisciplinary drills, and simulation. Semin Perinatol. Apr. 2009;33:104-8. X-1. [pmid: 19324239].
1394 Gadmour YB, Godid FA. Trial of vaginal delivery after previous caesarean section. Jamahiriya Medical Journal. Spring. 2009;9:36-40. X-2, X-3, X-4.
1395 Gallos G, Redai I, Smiley RM. The role of the anesthesiologist in management of obstetric hemorrhage. Semin Perinatol. Apr. 2009;33:116-23. X-1. [pmid: 19324241].
1396 Gangat N, Wolanskyj AP, Schwager S, et al. Predictors of pregnancy outcome in essential thrombocythemia: a single institution study of 63 pregnancies. Eur J Haematol. May. 2009;82:350-3. X-4. [pmid: 19243425].
1397 Gaym A. Maternal mortality studies in Ethiopia--magnitude, causes and trends. Ethiop Med J. Jan. 2009;47:95-108. X-1, X-2, X-4. [pmid: 19743789].
1398 Girija S, Manjunath AP. Comparison of two dosing regimens of vaginal misoprostol for labour induction: A randomised controlled trial. Journal of the Turkish German Gynecology Association. 2009;10:220-5. X-2, X-3, X-4.
1399 Gulmezoglu AM, Souza JP. The evolving management of the third stage of labour. BJOG. Oct. Suppl 1. 2009;116:26-8. X-1. [pmid: 19740167].
1400 Gulmezoglu AM, Widmer M, Merialdi M, et al. Active management of the third stage of labour without controlled cord traction: a randomized non-inferiority controlled trial. Reprod Health. 2009;6:2. X-4. [pmid: 19154621].
1401 Gungor T, Simsek A, Ozdemir AO, et al. Surgical treatment of intractable postpartum hemorrhage and changing trends in modern obstetric perspective. Arch Gynecol Obstet. Sep. 2009;280:351-5. X-2, X-4, X-5. [pmid: 19130066].
1402 Gungorduk K, Yildirim G, Dugan N, et al. Peripartum hysterectomy in Turkey: a case-control study. J Obstet Gynaecol. Nov. 2009;29:722-8. X-2. [pmid: 19821666].
1403 Halder A. A new uterine suture technique to control PPH in congenitally malformed uterus during caesarean section. J Obstet Gynaecol. Jul. 2009;29:402-4. X-2, X-5. [pmid: 19603317].
1404 Haque N, Bilkis L, Bari MS, et al. Comparative study between rectally administered misoprostol as a prophylaxis versus conventional intramuscular oxytocin in post partum hemorrhage. Mymensingh Med J. Jan. 2009;18:S40-4. X-2, X-4. [pmid: 19377430].
1405 Hasegawa J, Matsuoka R, Ichizuka K, et al. Predisposing factors for massive hemorrhage during Cesarean section in patients with placenta previa. Ultrasound Obstet Gynecol. Jul. 2009;34:80-4. X-4. [pmid: 19565529].
1406 Herdt-Losavio ML, Lin S, Druschel CM, et al. The risk of congenital malformations and other neonatal and maternal health outcomes among licensed cosmetologists. Am J Perinatol. Oct. 2009;26:625-31. X-3, X-4. [pmid: 19391082].
1407 Higgins CA, Martin W, Anderson L, et al. Maternal obesity and its relationship with spontaneous and oxytocin-induced contractility of human myometrium in vitro. Reprod Sci. Feb. 2009;17:177-85. X-1, X-4. [pmid: 19828431].
1408 Hofmeyr GJ, Gulmezoglu AM, Novikova N, et al. Misoprostol to prevent and treat postpartum haemorrhage: a systematic review and meta-analysis of maternal deaths and dose-related effects. Bull World Health Organ. Sep. 2009;87:666-77. X-1, X-2, X-5. [pmid: 19784446].
1409 Huissoud C, Carrabin N, Audibert F, et al. Bedside assessment of fibrinogen level in postpartum haemorrhage by thrombelastometry. BJOG. Jul. 2009;116:1097-102. X-4, X-5. [pmid: 19459866].
1410 Hunyinbo KI, Fawole AO, Sotiloye OS, et al. Evaluation of criteria-based clinical audit in improving quality of obstetric care in a developing country hospital. Afr J Reprod Health. Dec. 2009;12:59-70. X-2, X-5. [pmid: 19435013].
1411 Isma N, Svensson PJ, Lindblad B, et al. The effect of low molecular weight heparin (dalteparin) on duration and initiation of labour. J Thromb Thrombolysis. Aug. 2009;30:149-53. X-4. [pmid: 19949968].
1412 James AH. Von Willebrand disease in women: awareness and diagnosis. Thromb Res. Nov. Suppl 1. 2009;124:S7-10. X-1. [pmid: 19944259].
1413 James AH, Paglia MJ, Gernsheimer T, et al. Blood component therapy in postpartum hemorrhage. Transfusion. Nov. 2009;49:2430-3. X-4, X-5. [pmid: 19624606].
1414 James J. Using a reflective model to aid professional development: reactions and responsibilities in management of a major postpartum haemorrhage. MIDIRS Midwifery Digest. 2009;19:534-9. X-1, X-4.
1415 Janssen PA, Saxell L, Page LA, et al. Outcomes of planned home birth with registered midwife versus planned hospital birth with midwife or physician. CMAJ. Sep. 15. 2009;181:377-83. X-4. [pmid: 19720688].
1416 Jarvie E, Ramsay JE. Obstetric management of obesity in pregnancy. Semin Fetal Neonatal Med. Apr. 2009;15:83-8. X-1. [pmid: 19880362].
1417 Jeffries PR, Bambini D, Hensel D, et al. Constructing maternal-child learning experiences using clinical simulations. J Obstet Gynecol Neonatal Nurs. Sep-Oct. 2009;38:613-23. X-1, X-3, X-4. [pmid: 19883484].
1418 Jonas K, Johansson LM, Nissen E, et al. Effects of intrapartum oxytocin administration and epidural analgesia on the concentration of plasma oxytocin and prolactin, in response to suckling during the second day postpartum. Breastfeed Med. Jun. 2009;4:71-82. X-3, X-4. [pmid: 19210132].
1419 Jongkolsiri P, Manotaya S. Placental cord drainage and the effect on the duration of third stage labour, a randomized controlled trial. J Med Assoc Thai. Apr. 2009;92:457-60. X-2, X-3, X-4. [pmid: 19374293].
1420 Jordan S, Emery S, Watkins A, et al. Associations of drugs routinely given in labour with breastfeeding at 48 hours: analysis of the Cardiff Births Survey. BJOG. Nov. 2009;116:1622-9. discussion 30-2. X-2, X-4, X-5. [pmid: 19735379].
1421 Joseph KS, Fahey J. Validation of perinatal data in the Discharge Abstract Database of the Canadian Institute for Health Information. Chronic Dis Can. 2009;29:96-100. X-3, X-4. [pmid: 19527567].
1422 Kalim N, Anwar I, Khan J, et al. Postpartum haemorrhage and eclampsia: differences in knowledge and care-seeking behaviour in two districts of Bangladesh. J Health Popul Nutr. Apr. 2009;27:156-69. X-2, X-3, X-4. [pmid: 19489413].
1423 Kalinka J, Lipinska M, Serafin M, et al. The evaluation of the efficacy of carbetocin (Pabal) in the prevention of the postpartum haemorrhage among women undergoing emergency cesarean section - The preliminary report. 2009;13:47-56. X-4.
1424 Karoshi M, Keith L. Challenges in managing postpartum hemorrhage in resource-poor countries. Clin Obstet Gynecol. Jun. 2009;52:285-98. X-1. [pmid: 19407535].
1425 King M, Wrench I, Galimberti A, et al. Introduction of cell salvage to a large obstetric unit: the first six months. Int J Obstet Anesth. Apr. 2009;18:111-7. X-4, X-5. [pmid: 19144508].
1426 Kirby JM, Kachura JR, Rajan DK, et al. Arterial embolization for primary postpartum hemorrhage. J Vasc Interv Radiol. Aug. 2009;20:1036-45. X-5. [pmid: 19647182].
1427 Kjaergaard H, Olsen J, Ottesen B, et al. Incidence and outcomes of dystocia in the active phase of labor in term nulliparous women with spontaneous labor onset. Acta Obstet Gynecol Scand. 2009;88:402-7. X-4. [pmid: 19330572].
1428 Knight M, Callaghan WM, Berg C, et al. Trends in postpartum hemorrhage in high resource countries: a review and recommendations from the International Postpartum Hemorrhage Collaborative Group. BMC Pregnancy Childbirth. 2009;9:55. X-1. [pmid: 19943928].
1429 Koh E, Devendra K, Tan LK. B-Lynch suture for the treatment of uterine atony. Singapore Med J. Jul. 2009;50:693-7. X-5. [pmid: 19644624].
1430 Kongnyuy EJ, van den Broek N. Developing standards for postpartum hemorrhage in a resource-limited country. Health Care Women Int. Nov. 2009;30:989-1002. X-1, X-2. [pmid: 19809902].
1431 Koopmans CM, Bijlenga D, Groen H, et al. Induction of labour versus expectant monitoring for gestational hypertension or mild pre-eclampsia after 36 weeks' gestation (HYPITAT): a multicentre, open-label randomised controlled trial. Lancet. Sep. 19. 2009;374:979-88. X-4. [pmid: 19656558].
1432 Lak M, Sharifian RA, Karimi K, et al. Acquired hemophilia A: clinical features, surgery and treatment of 34 cases, and experience of using recombinant factor VIIa. Clin Appl Thromb Hemost. Jun. 2009;16:294-300. X-3, X-4. [pmid: 19211581].
1433 Lausman AY, Al-Yaseen E, Sam D, et al. Intrahepatic cholestasis of pregnancy in women with a multiple pregnancy: an analysis of risks and pregnancy outcomes. J Obstet Gynaecol Can. Nov. 2009;30:1008-13. X-4. [pmid: 19126282].
1434 Leduc D, Senikas V, Lalonde AB, et al. Active management of the third stage of labour: prevention and treatment of postpartum hemorrhage. J Obstet Gynaecol Can. Oct. 2009;31:980-93. X-1. [pmid: 19941729].
1435 Liang JL, Yu PC, Ou HY, et al. Intraoperative uterine artery embolization in two patients with placenta previa accreta: Comparison of two approaches to control bleeding. Chinese Journal of Radiology. September. 2009;34:227-30+31. X-2, X-5.
1436 Lombaard H, Pattinson RC. Common errors and remedies in managing postpartum haemorrhage. Best Pract Res Clin Obstet Gynaecol. Jun. 2009;23:317-26. X-1. [pmid: 19230783].
1437 Lu MC, Korst LM, Fridman M, et al. Identifying women most likely to benefit from prevention strategies for postpartum hemorrhage. J Perinatol. Jun. 2009;29:422-7. X-4. [pmid: 19177146].
1438 MacArthur A. Objectives for <<Update of obstetric anesthesia>> lecture. Revista Mexicana de Anestesiologia. April/June. 2009;32:S30-S4. X-1.
1439 MacArthur A. Objectives for <> lecture. 2009;32:S30-S4. X-1.
1440 Mahendru R, Taneja BK, Malik S. Preservation of fertility following abnormally adherent placenta treated conservatively: A case report. Cases Journal. December. 2009;2. X-1.
1441 Mamula O, Severinski NS, Mamula M, et al. Complications during pregnancy, labor and puerperium in women with increased BMI at pregnancy term. Central European Journal of Medicine. March. 2009;4:71-5. X-4.
1442 Matijevic R, Knezevic M, Grgic O, et al. Diagnostic accuracy of sonographic and clinical parameters in the prediction of retained products of conception. J Ultrasound Med. Mar. 2009;28:295-9. X-4. [pmid: 19244064].
1443 Mayi-Tsonga S, Oksana L, Ndombi I, et al. Delay in the provision of adequate care to women who died from abortion-related complications in the principal maternity hospital of Gabon. Reprod Health Matters. Nov. 2009;17:65-70. X-2, X-3, X-4. [pmid: 19962639].
1444 Memon S, Qazi RA, Pushpa, et al. Pattern of obstructed labour at a public sector university hospital of Sindh, Pakistan. Journal of the Liaquat University of Medical and Health Sciences. January/April. 2009;8:60-4. X-2, X-4.
1445 Mfinanga GS, Kimaro GD, Ngadaya E, et al. Health facility-based Active Management of the Third Stage of Labor: findings from a national survey in Tanzania. Health Res Policy Syst. 2009;7:6. X-2, X-4. [pmid: 19371418].
1446 Miesbach W, Scharrer I, Henschen A, et al. Inherited dysfibrinogenemia: clinical phenotypes associated with five different fibrinogen structure defects. Blood Coagul Fibrinolysis. Jan. 2009;21:35-40. X-3, X-4. [pmid: 19923982].
1447 Miller S, Ojengbede O, Turan JM, et al. A comparative study of the non-pneumatic anti-shock garment for the treatment of obstetric hemorrhage in Nigeria. Int J Gynaecol Obstet. Nov. 2009;107:121-5. X-2. [pmid: 19628207].
1448 Miller S, Tudor C, Thorsten V, et al. Randomized double masked trial of Zhi Byed 11, a Tibetan traditional medicine, versus misoprostol to prevent postpartum hemorrhage in Lhasa, Tibet. J Midwifery Womens Health. Mar-Apr. 2009;54:133-41 e1. X-2, X-4. [pmid: 19249659].
1449 Milliez J, Dickens B. Ethical aspects of multiple pregnancy. International Journal of Fertility and Sterility. May-June. 2009;3:41-6. X-1.
1450 Moodley J, Devjee J, Khedun SM, et al. Second-stage primary Caesarean deliveries: Are maternal complications increased?. South African Family Practice. 2009;51:328-31. X-2, X-4.
1451 Muench MV, Baschat AA, Malinow AM, et al. Analysis of disease in the obstetric intensive care unit at a university referral center: a 24-month review of prospective data. J Reprod Med. Dec. 2009;53:914-20. X-4. [pmid: 19160649].
1452 Mukherjee S, Arulkumaran S. Post-partum haemorrhage. Obstetrics, Gynaecology and Reproductive Medicine. May. 2009;19:121-6. X-1.
1453 Murphy CM, Murad K, Deane R, et al. Severe maternal morbidity for 2004-2005 in the three Dublin maternity hospitals. Eur J Obstet Gynecol Reprod Biol. Mar. 2009;143:34-7. X-4. [pmid: 19136192].
1454 Naidoo RP, Moodley J. Rising rates of Caesarean sections: An audit of Caesarean sections in a specialist private practice. South African Family Practice. 2009;51:254-8. X-2, X-4.
1455 Nasr A, Shahin AY, Elsamman AM, et al. Rectal misoprostol versus intravenous oxytocin for prevention of postpartum hemorrhage. Int J Gynaecol Obstet. Jun. 2009;105:244-7. X-4. [pmid: 19249048].
1456 Naz H, Sarwar I, Fawad A, et al. Maternal morbidity and mortality due to primary PPH--experience at Ayub Teaching Hospital Abbottabad. J Ayub Med Coll Abbottabad. Apr-Jun. 2009;20:59-65. X-2, X-4. [pmid: 19385460].
1457 Ndikom CM, Fawole AO. Evidence-based measures for reducing maternal and child mortality. African Journal of Midwifery & Women's Health. 2009;3:199-204. X-1, X-2, X-4.
1458 Nidagu S. Pregnancy in the community setting. International Journal of Nursing Education. 2009;1:8-9. X-1.
1459 Niles SD, Burkhart HM, Duffey DA, et al. Use of recombinant factor VIIa (NovoSeven) in pediatric cardiac surgery. J Extra Corpor Technol. Dec. 2009;40:241-8. X-3, X-4. [pmid: 19192753].
1460 Nirmala K, Zainuddin AA, Ghani NA, et al. Carbetocin versus syntometrine in prevention of post-partum hemorrhage following vaginal delivery. J Obstet Gynaecol Res. Feb. 2009;35:48-54. X-4. [pmid: 19215547].
1461 Nisar N, Sohoo NA. Emergency peripartum hysterectomy: frequency, indications and maternal outcome. J Ayub Med Coll Abbottabad. Jan-Mar. 2009;21:48-51. X-2, X-4, X-5. [pmid: 20364740].
1462 Okafor UV, Onwuekwe IO, Ezegwui HU. Management of pituitary adenoma with mass effect in pregnancy: A case report. Cases Journal. November. 2009;2. X-1, X-2.
1463 Oladapo OT, Akinola OI, Fawole AO, et al. Active management of third stage of labor: evidence versus practice. Acta Obstet Gynecol Scand. 2009;88:1252-60. X-2, X-4. [pmid: 19824866].
1464 Oladapo OT, Fawole AO, Loto OM, et al. Active management of third stage of labour: a survey of providers' knowledge in southwest Nigeria. Arch Gynecol Obstet. Dec. 2009;280:945-52. X-2, X-3, X-4. [pmid: 19306012].
1465 Ouyang DW, Khairy P, Fernandes SM, et al. Obstetric outcomes in pregnant women with congenital heart disease. Int J Cardiol. Oct. 8. 2009;144:195-9. X-4. [pmid: 19411123].
1466 Padmanabhan A, Schwartz J, Spitalnik SL. Transfusion therapy in postpartum hemorrhage. Semin Perinatol. Apr. 2009;33:124-7. X-1. [pmid: 19324242].
1467 Pagel C, Lewycka S, Colbourn T, et al. Estimation of potential effects of improved community-based drug provision, to augment health-facility strengthening, on maternal mortality due to post-partum haemorrhage and sepsis in sub-Saharan Africa: an equity-effectiveness model. Lancet. Oct. 24. 2009;374:1441-8. X-2, X-3, X-4. [pmid: 19783291].
1468 Parker J, Thompson J, Stanworth S. A retrospective one-year single-centre survey of obstetric red cell transfusions. Int J Obstet Anesth. Oct. 2009;18:309-13. X-4, X-5. [pmid: 19729296].
1469 Patvardhan C, Ayakannu T, Mastan M. Successful management of an unusual presentation of ruptured splenic artery aneurysm in the third trimester presenting as right sided abdominal pain. A case report. Internet Journal of Anesthesiology. 2009;19:1-7. X-1, X-3, X-4.
1470 Patwardhan SK, Sawant A, Ismail M, et al. Simultaneous bladder and vaginal reconstruction using ileum in complicated vesicovaginal fistula. Indian J Urol. Jul. 2009;24:348-51. X-2, X-3, X-4. [pmid: 19468466].
1471 Penninx JP, Pasmans HL, Oei SG. Arterial balloon occlusion of the internal iliac arteries for treatment of life-threatening massive postpartum haemorrhage: a series of 15 consecutive cases. Eur J Obstet Gynecol Reprod Biol. Feb. 2009;148:131-4. X-5. [pmid: 19962226].
1472 Prata N, Gessessew A, Abraha AK, et al. Prevention of postpartum hemorrhage: options for home births in rural Ethiopia. Afr J Reprod Health. Jun. 2009;13:87-95. X-2, X-4. [pmid: 20690252].
1473 Prata N, Graff M, Graves A, et al. Avoidable maternal deaths: three ways to help now. Glob Public Health. 2009;4:575-87. X-1. [pmid: 19326279].
1474 Prata N, Mbaruku G, Grossman AA, et al. Community-based availability of misoprostol: is it safe?. Afr J Reprod Health. Jun. 2009;13:117-28. X-2. [pmid: 20690255].
1475 Price LC, Germain S, Wyncoll D, et al. Management of the critically ill obstetric patient. Obstetrics, Gynaecology and Reproductive Medicine. December. 2009;19:350-8. X-1.
1476 Raba G, Baran P. Hemodynamic parameters following bilateral internal iliac arteries ligation as a treatment of intrapartum hemorrhage. Ginekol Pol. Mar. 2009;80:179-83. X-5. [pmid: 19382608].
1477 Rabiu KA, Akinlusi FM, Adewunmi AA, et al. Emergency peripartum hysterectomy in a tertiary hospital in Lagos, Nigeria: a five-year review. Trop Doct. Jan. 2009;40:1-4. X-2, X-4. [pmid: 19850603].
1478 Rahman J, Bhattee G, Rahman MS. Shoulder dystocia in a 16-year experience in a teaching hospital. J Reprod Med. Jun. 2009;54:378-84. X-4. [pmid: 19639928].
1479 Rajbhandari S, Hodgins S, Sanghvi H, et al. Expanding uterotonic protection following childbirth through community-based distribution of misoprostol: operations research study in Nepal. Int J Gynaecol Obstet. Mar. 2009;108:282-8. X-2, X-4. [pmid: 20034628].
1480 Rana A, Pradhan N, Manandhar B, et al. Maternal mortality over the last decade: a changing pattern of death due to alarming rise in hepatitis in the latter five-year period. J Obstet Gynaecol Res. Apr. 2009;35:243-51. X-2, X-4. [pmid: 19708172].
1481 Rashid M, Clark A, Rashid MH. A randomised controlled trial comparing the efficacy of intramuscular syntometrine and intravenous syntocinon, in preventing postpartum haemorrhage. J Obstet Gynaecol. Jul. 2009;29:396-401. X-4. [pmid: 19603316].
1482 Ratanasiri T, Komwilaisak R, Sittivech A, et al. Incidence, causes and pregnancy outcomes of hydrops fetalis at Srinagarind Hospital, 1996-2005: a 10-year review. J Med Assoc Thai. May. 2009;92:594-9. X-2, X-4. [pmid: 19459517].
1483 Reron A, Jaworowski A, Ossowski P. Peripartum hemorrhage risk and mode of delivery. [Polish, English]. Ginekologia i Poloznictwo. 2009;13:41-6. X-4.
1484 Reron A, Jaworowski A, Ossowski P. Peripartum hemorrhage risk and mode of delivery. 2009;13:41-6. X-4.
1485 Richa F, Karim N, Yazbeck P. Obstetric admissions to the intensive care unit: an eight-year review. J Med Liban. Oct-Dec. 2009;56:215-9. X-2, X-4. [pmid: 19115595].
1486 Richey KR, Williams FL, Karlnoski R, et al. Retrospective study of product requirements for blood loss in abnormal placentation... State of the Science General and Oral Poster Sessions, AANA Annual Meeting, San Diego, California. AANA Journal. 2009;77:396. X-1, X-4, X-5.
1487 Roberts CL, Ford JB, Algert CS, et al. Trends in adverse maternal outcomes during childbirth: a population-based study of severe maternal morbidity. BMC Pregnancy Childbirth. 2009;9:7. X-4. [pmid: 19243578].
1488 Roberts CL, Ford JB, Thompson JF, et al. Population rates of haemorrhage and transfusions among obstetric patients in NSW: a short communication. Aust N Z J Obstet Gynaecol. Jun. 2009;49:296-8. X-4. [pmid: 19566563].
1489 Rouf S, Sharmin S, Dewan F, et al. Relaparotomy after cesarean section: Experience from a tertiary referral and teaching hospital of Bangladesh. Bangladesh Journal of Obstetrics and Gynecology. 2009;24:3-9. X-2, X-4.
1490 Roy KK, Baruah J, Sharma JB, et al. Reproductive outcome following hysteroscopic adhesiolysis in patients with infertility due to Asherman's syndrome. Arch Gynecol Obstet. Feb. 2009;281:355-61. X-4. [pmid: 19455349].
1491 Saeed F, Khalid R, Khan A, et al. Peripartum hysterectomy: a ten-year experience at a tertiary care hospital in a developing country. Trop Doct. Jan. 2009;40:18-21. X-2. [pmid: 20008059].
1492 Salazar GM, Petrozza JC, Walker TG. Transcatheter endovascular techniques for management of obstetrical and gynecologic emergencies. Tech Vasc Interv Radiol. Jun. 2009;12:139-47. X-1. [pmid: 19853231].
1493 Saleem N, Ali HS, Irfan A, et al. Broad ligament haematoma following a vaginal delivery in primigravida. Pakistan Journal of Medical Sciences. July-September. 2009;25:683-5. X-1.
1494 Schutte JM, Steegers EA, Schuitemaker NW, et al. Rise in maternal mortality in the Netherlands. BJOG. Mar. 2009;117:399-406. X-4. [pmid: 19943828].
1495 Sekhavat L, Firuzabadi RD, Karimi Zarchi M. Effect of postpartum oxygen inhalation on vaginal blood loss. J Matern Fetal Neonatal Med. Nov. 2009;22:1072-6. X-2, X-4, X-5. [pmid: 19900047].
1496 Shah M, Wright JD. Surgical intervention in the management of postpartum hemorrhage. Semin Perinatol. Apr. 2009;33:109-15. X-1. [pmid: 19324240].
1497 Shahin AY, Farghaly TA, Mohamed SA, et al. Bilateral uterine artery ligation plus B-Lynch procedure for atonic postpartum hemorrhage with placenta accreta. Int J Gynaecol Obstet. Mar. 2009;108:187-90. X-2, X-4, X-5. [pmid: 19944417].
1498 Siboni SM, Spreafico M, Calo L, et al. Gynaecological and obstetrical problems in women with different bleeding disorders. Haemophilia. Nov. 2009;15:1291-9. X-4. [pmid: 19664014].
1499 Silvestre FT, Risco CA, Lopez M, et al. Use of increasing doses of a degradable Deslorelin implant to enhance uterine involution in postpartum lactating dairy cows. Anim Reprod Sci. Dec. 2009;116:196-212. X-1, X-3, X-4. [pmid: 19269118].
1500 Singh G, Radhakrishnan G, Guleria K. Comparison of sublingual misoprostol, intravenous oxytocin, and intravenous methylergometrine in active management of the third stage of labor. Int J Gynaecol Obstet. Nov. 2009;107:130-4. X-4. [pmid: 19628206].
1501 Singh Y, Kochar SPS, Biswas M, et al. Hepatic rupture complicating HELLP syndrome in pregnancy. Medical Journal Armed Forces India. 2009;65:89-90. X-1.
1502 Singi SR, Fernandez E, Pandya ST, et al. Recombinant factor VIIa: use in fatal post partum hemorrhage - Indian experience case series and review of literature. Indian J Hematol Blood Transfus. Mar. 2009;25:1-5. X-1, X-2. [pmid: 23100963].
1503 Sinicina I, Pankratz H, Bise K, et al. Forensic aspects of post-mortem histological detection of amniotic fluid embolism. Int J Legal Med. Jan. 2009;124:55-62. X-1, X-3, X-4. [pmid: 19449024].
1504 Snelgrove JW. Postpartum haemorrhage in the developing world a review of clinical management strategies. Mcgill J Med. 2009;12:61. X-1. [pmid: 21264044].
1505 Soltan MH, Faragallah MF, Mosabah MH, et al. External aortic compression device: the first aid for postpartum hemorrhage control. J Obstet Gynaecol Res. Jun. 2009;35:453-8. X-2. [pmid: 19527382].
1506 So-Osman C, Cicilia J, Brand A, et al. Triggers and appropriateness of red blood cell transfusions in the postpartum patient--a retrospective audit. Vox Sang. Jan. 2009;98:65-9. X-5. [pmid: 19686225].
1507 Sosa CG, Althabe F, Belizan JM, et al. Risk factors for postpartum hemorrhage in vaginal deliveries in a Latin-American population. Obstet Gynecol. Jun. 2009;113:1313-9. X-2, X-4. [pmid: 19461428].
1508 Stanton C, Armbruster D, Knight R, et al. Use of active management of the third stage of labour in seven developing countries. Bull World Health Organ. Mar. 2009;87:207-15. X-2, X-4. [pmid: 19377717].
1509 Su LL, Rauff M, Chan YH, et al. Carbetocin versus syntometrine for the third stage of labour following vaginal delivery--a double-blind randomised controlled trial. BJOG. Oct. 2009;116:1461-6. X-4. [pmid: 19538418].
1510 Suehiro K, Okutani R, Ogawa S. Anesthetic management for cesarean section patients with progressive muscular dystrophy. Anesthesia and Resuscitation. June. 2009;45:51-3. X-1.
1511 Tabcharoen C, Pinjaroen S, Suwanrath C, et al. Pregnancy outcome after age 40 and risk of low birth weight. J Obstet Gynaecol. Jul. 2009;29:378-83. X-4. [pmid: 19603312].
1512 Tan PC, Ling LP, Omar SZ. The 50-g glucose challenge test and pregnancy outcome in a multiethnic Asian population at high risk for gestational diabetes. Int J Gynaecol Obstet. Apr. 2009;105:50-5. X-3, X-4. [pmid: 19154997].
1513 Tang CH, Wu CS, Lee TH, et al. Preeclampsia-eclampsia and the risk of stroke among peripartum in Taiwan. Stroke. Apr. 2009;40:1162-8. X-2, X-4. [pmid: 19228854].
1514 Thanajiraprapa T, Phupong V. Pregnancy complications in women with heart disease. J Matern Fetal Neonatal Med. Oct. 2009;23:1200-4. X-4. [pmid: 19903109].
1515 Thornton D, Guendelman S, Hosang N. Obstetric complications in women with diagnosed mental illness: the relative success of California's county mental health system. Health Serv Res. Feb. 2009;45:246-64. X-4. [pmid: 19878345].
1516 Tikkanen M, Gissler M, Metsaranta M, et al. Maternal deaths in Finland: focus on placental abruption. Acta Obstet Gynecol Scand. 2009;88:1124-7. X-4. [pmid: 19707898].
1517 Tixier H, Boucard C, Ferdynus C, et al. Interest of using an underbuttocks drape with collection pouch for early diagnosis of postpartum hemorrhage. Arch Gynecol Obstet. Jan. 2009;283:25-9. X-4, X-5. [pmid: 19876638].
1518 Tixier H, Loffroy R, Guiu B, et al. Complications and failure of uterine artery embolisation for intractable postpartum haemorrhage. Bjog. Aug. 2009;116:1276-7. author reply 7-8. X-1, X-4, X-5. [pmid: 19624447].
1519 Tsu VD, Levin C, Tran MP, et al. Cost-effectiveness analysis of active management of third-stage labour in Vietnam. Health Policy Plan. Nov. 2009;24:438-44. X-2, X-3, X-4. [pmid: 19633018].
1520 Tucker A, Ogutu D, Yoong W, et al. The unbooked mother: a cohort study of maternal and foetal outcomes in a North London Hospital. Arch Gynecol Obstet. Apr. 2009;281:613-6. X-4. [pmid: 19551396].
1521 Vaid A, Dadhwal V, Mittal S, et al. A randomized controlled trial of prophylactic sublingual misoprostol versus intramuscular methyl-ergometrine versus intramuscular 15-methyl PGF2alpha in active management of third stage of labor. Arch Gynecol Obstet. Dec. 2009;280:893-7. X-3, X-4. [pmid: 19277690].
1522 Van Wolfswinkel ME, Zwart JJ, Schutte JM, et al. Maternal mortality and serious maternal morbidity in Jehovah's witnesses in The Netherlands. BJOG. Jul. 2009;116:1103-8. discussion 8-10. X-4. [pmid: 19515150].
1523 Vitthala S, Tsoumpou I, Anjum ZK, et al. Use of Bakri balloon in post-partum haemorrhage: a series of 15 cases. Aust N Z J Obstet Gynaecol. Apr. 2009;49:191-4. X-2, X-5. [pmid: 19432609].
1524 Wangwe P, Kidanto H, Muganyizi P, et al. Active management of third stage of labour: misoprostol or oxytocin?. African Journal of Midwifery & Women's Health. 2009;3:57-60. X-4.
1525 Ward SL, Hisley SM. Chapter 16: caring for the woman experiencing complications during the postpartal period. Maternal-child nursing care: optimizing outcomes for mothers, children, and families. Philadelphia, PA. F.A. Davis Company. 2009:511-40.
1526 Weeks AD, Alia G, Vernon G, et al. Umbilical vein oxytocin for the treatment of retained placenta (Release Study): a double-blind, randomised controlled trial. Lancet. Jan. 9. 2009;375:141-7. X-2, X-4, X-5. [pmid: 20004013].
1527 Weisbrod AB, Sheppard FR, Chernofsky MR, et al. Emergent management of postpartum hemorrhage for the general and acute care surgeon. World J Emerg Surg. 2009;4:43. X-1. [pmid: 19939251].
1528 Wissa I, Ebeid E, El-Shawarby S, et al. The role of recombinant activated Factor VII in major obstetric haemorrhage: the Farnborough experience. J Obstet Gynaecol. Jan. 2009;29:21-4. X-5. [pmid: 19280490].
1529 Yadav S, Choudhary D, Narayan KC, et al. Adverse reproductive outcomes associated with teenage pregnancy. Mcgill J Med. Jul. 2009;11:141-4. X-2, X-4. [pmid: 19148312].
1530 Ying H, Duan T, Bao YR, et al. Transverse annular compression sutures in the lower uterine segment to control postpartum hemorrhage at cesarean delivery for complete placenta previa. Int J Gynaecol Obstet. Mar. 2009;108:247-8. X-2, X-5. [pmid: 19939381].
1531 Yinon Y, Siu SC, Warshafsky C, et al. Use of low molecular weight heparin in pregnant women with mechanical heart valves. Am J Cardiol. Nov. 1. 2009;104:1259-63. X-4. [pmid: 19840573].
1532 Zakariah AY, Alexander S, van Roosmalen J, et al. Reproductive age mortality survey (RAMOS) in Accra, Ghana. Reprod Health. 2009;6:7. X-2, X-4. [pmid: 19497092].
1533 Zhu L, Qin M, Du L, et al. Comparison of maternal mortality between migrating population and permanent residents in Shanghai, China, 1996-2005. BJOG. Feb. 2009;116:401-7. X-2, X-4. [pmid: 19187372].
1534 Zubor P, Szunyogh N, Dokus K, et al. Application of uterotonics on the basis of regular ultrasonic evaluation of the uterus prevents unnecessary surgical intervention in the postpartum period. Arch Gynecol Obstet. Sep. 2009;282:261-7. X-2, X-4, X-5. [pmid: 19760186].
1535 Zwart JJ, Dupuis JR, Richters A, et al. Obstetric intensive care unit admission: a 2-year nationwide population-based cohort study. Intensive Care Med. Feb. 2009;36:256-63. X-4, X-5. [pmid: 19902177].
1536 Zwart JJ, Yazdani ST, Harvey MS, et al. Underreporting of major obstetric haemorrhage in the Netherlands. Transfus Med. Apr. 2009;20:118-22. X-4. [pmid: 19708894].
1537 Active management of the third stage of labour: prevention and treatment of postpartum hemorrhage: No. 235 October 2009 (Replaces No. 88, April 2000). Int J Gynaecol Obstet. Mar. 2010;108:258-67. X-1, X-4, X-5. [pmid: 20196196].
1538 Misoprostol for postpartum haemorrhage. Drug Ther Bull. Jun. 2010;48:66-9. X-1, X-3, X-4. [pmid: 20530028].
1539 Nosebleeds are associated with a greater risk for postpartum hemorrhage. Contemporary OB/GYN. 2010;55:24. X-1, X-4.
1540 Trade-offs in treating postpartum hemorrhage. International Perspectives on Sexual & Reproductive Health. 2010;36(1):5. Language: English. Entry Date: 20100716. Revision Date: 20100716. Publication Type: journal article. X-1.
1541 Abdel-Aleem H, Singata M, Abdel-Aleem M, et al. Uterine massage to reduce postpartum hemorrhage after vaginal delivery. Int J Gynaecol Obstet. Oct. 2010;111:32-6. X-2, X-4. [pmid: 20599196].
1542 Abdullah A, Shaikh AA, Jamro B. Maternal and perinatal outcome associated with eclampsia in a teaching hospital, Sukkur. Rawal Medical Journal. Jan-July. 2010;35:23-6. X-2, X-4.
1543 Afolabi EO, Kuti O, Orji EO, et al. Oral misoprostol versus intramuscular oxytocin in the active management of the third stage of labour. Singapore Med J. Mar. 2010;51:207-11. X-3, X-4. [pmid: 20428741].
1544 Agan T, Archibong EI, Ekabua JE, et al. Trends in maternal mortality at the University of Calabar Teaching Hospital, Nigeria, 1999-2009. New Zealand. Dove Medical Press Ltd. (Beechfield House, Winterton Way, Macclesfield SK11 0JL, United Kingdom). 2010. http://www.dovepress.com/getfile.php?fileID=7271http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed9&NEWS=N&AN=2010438142. Accessed on (Agan, Archibong, Ekabua, Ekanem, Abeshi) Department of Obstetrics and Gynecology, College of Medical Sciences, University of Calabar Teaching Hospital, Nigeria 2.
1545 Agan TU, Archibong EI, Ekabua JE, et al. Trends in maternal mortality at the University of Calabar Teaching Hospital, Nigeria, 1999-2009. Int J Womens Health. 2010;2:249-54. X-2, X-4. [pmid: 21151730].
1546 Ajenifuja KO, Adepiti CA, Ogunniyi SO. Post partum haemorrhage in a teaching hospital in Nigeria: a 5-year experience. Afr Health Sci. Mar. 2010;10:71-4. X-2, X-4. [pmid: 20811528].
1547 Akhtar Z, Qazi Q, Khan I. Prostaglandin F2 alpha: An effective alternate to surgical control of postpartum hemorrhage in uterine atony. Journal of Postgraduate Medical Institute. January-March. 2010;24:27-30. X-2.
1548 Al Kadri HM. Obstetric medical emergency teams are a step forward in maternal safety!. J Emerg Trauma Shock. Oct. 2010;3:337-41. X-1. [pmid: 21063555].
1549 Ali M, Khurshid M, Jabeen R. Evaluation of postpartum complications in patients admitted to Nishtar Hospital, Multan. Medical Forum Monthly. November. 2010;21:5-8. X-2, X-4.
1550 Almerie Y, Almerie MQ, Matar HE, et al. Obstetric near-miss and maternal mortality in maternity university hospital, Damascus, Syria: a retrospective study. BMC Pregnancy Childbirth. 2010;10:65. X-2, X-4. [pmid: 20959012].
1551 Al-Zirqi I, Stray-Pedersen B, Forsen L, et al. Uterine rupture after previous caesarean section. BJOG. Jun. 2010;117:809-20. X-4. [pmid: 20236103].
1552 Arbinder D, Nirmala A, Sonal B, et al. Prevalence of liver disease in pregnancy and its outcome with emphasis on obstetric cholestasis: An Indian scenario. Journal of Obstetrics and Gynecology of India. October. 2010;60:413-8. X-2, X-3, X-4.
1553 Armand-Ugon R, Cheong T, Matapandewu G, et al. Efficacy of intravenous iron for treating postpartum anemia in low-resource African countries: a pilot study in Malawi. J Womens Health (Larchmt). Jan. 2010;20:123-7. X-2. [pmid: 21091191].
1554 Asherkaci HM, Fortia IM, Sraiti OA, et al. Misoprostol usefulness on Post Partum Hemorrhage (PPH) among high risk mothers. Jamahiriya Medical Journal. Autumn. 2010;10:213-5. X-2, X-4.
1555 Attilakos G, Psaroudakis D, Ash J, et al. Carbetocin versus oxytocin for the prevention of postpartum haemorrhage following caesarean section: the results of a double-blind randomised trial. BJOG. Jul. 2010;117:929-36. X-4, X-5. [pmid: 20482535].
1556 Balci O, Mahmoud AS, Acar A, et al. Comparison of induction of labor with vaginal misoprostol plus oxytocin versus oxytocin alone in term primigravidae. J Matern Fetal Neonatal Med. Sep. 2010;24:1084-7. X-4. [pmid: 21087166].
1557 Balci O, Mahmoud AS, Ozdemir S, et al. Induction of labor with vaginal misoprostol plus oxytocin versus oxytocin alone. Int J Gynaecol Obstet. Jul. 2010;110:64-7. X-4. [pmid: 20347088].
1558 Barnett R, Kendrick B. HELLP syndrome -- a case study. New Zealand Journal of Medical Laboratory Science. 2010;64:14-7. X-1, X-4, X-5.
1559 Barnett R, Kendrick B. HELLP syndrome - A case study. New Zealand Journal of Medical Laboratory Science. April. 2010;64:14-7. X-1.
1560 Bas AY, Demirel N, Soysal A, et al. An unusual mimicker of a sepsis outbreak: ergot intoxication. Eur J Pediatr. May. 2010;170:633-7. X-2, X-3. [pmid: 20972685].
1561 Bateman BT, Berman MF, Riley LE, et al. The epidemiology of postpartum hemorrhage in a large, nationwide sample of deliveries. Anesth Analg. May. 1. 2010;110:1368-73. X-4. [pmid: 20237047].
1562 Bell SF, Rayment R, Collins PW, et al. The use of fibrinogen concentrate to correct hypofibrinogenaemia rapidly during obstetric haemorrhage. Int J Obstet Anesth. Apr. 2010;19:218-23. X-5. [pmid: 20194010].
1563 Berdichevsky K, Tucker C, Martinez A, et al. Acceptance of a new technology for management of obstetric hemorrhage: a qualitative study from rural Mexico. Health Care Women Int. May. 2010;31:444-57. X-2, X-3. [pmid: 20390665].
1564 Bergmann RL, Richter R, Bergmann KE, et al. Prevalence and risk factors for early postpartum anemia. Eur J Obstet Gynecol Reprod Biol. Jun. 2010;150:126-31. X-4, X-5. [pmid: 20303210].
1565 Bimbashi A, Ndoni E, Dokle A, et al. Care during the third stage of labour: obstetricians views and practice in an Albanian maternity hospital. BMC Pregnancy Childbirth. 2010;10:4. X-2, X-3, X-4. [pmid: 20102601].
1566 Biron-Andreani C. Venous thromboembolic disease and pregnancy: Prevention and treatment. Phlebolymphology. 2010;17:77-86. X-1.
1567 Bishai D, Bonnenfant YT, Darwish M, et al. Estimating the obstetric costs of female genital mutilation in six African countries. Bull World Health Organ. Apr. 2010;88:281-8. X-2, X-3, X-4. [pmid: 20431792].
1568 Blum J, Winikoff B, Raghavan S, et al. Treatment of post-partum haemorrhage with sublingual misoprostol versus oxytocin in women receiving prophylactic oxytocin: a double-blind, randomised, non-inferiority trial. Lancet. Jan. 16. 2010;375:217-23. X-2. [pmid: 20060162].
1569 Bomken C, Mathai S, Biss T, et al. Recombinant Activated Factor VII (rFVIIa) in the Management of Major Obstetric Haemorrhage: A Case Series and a Proposed Guideline for Use. Obstet Gynecol Int. 2010;2009:364843. X-5. [pmid: 20148069].
1570 Borthen I, Eide MG, Daltveit AK, et al. Delivery outcome of women with epilepsy: a population-based cohort study. BJOG. Nov. 2010;117:1537-43. X-4, X-5. [pmid: 20716254].
1571 Boyle RK, Waters BA, O'Rourke PK. Blood transfusion for caesarean delivery complicated by placenta praevia. Aust N Z J Obstet Gynaecol. Dec. 2010;49:627-30. X-3, X-4. [pmid: 20070711].
1572 Buduneli N, Becerik S, Buduneli E, et al. Gingival status, crevicular fluid tissue-type plasminogen activator, plasminogen activator inhibitor-2 levels in pregnancy versus post-partum. Aust Dent J. Sep. 2010;55:292-7. X-3, X-4. [pmid: 20887517].
1573 Burke C. Active versus expectant management of the third stage of labor and implementation of a protocol. J Perinat Neonatal Nurs. Jul-Sep. 2010;24:215-28. quiz 29-30. X-1. [pmid: 20697238].
1574 Callaghan WM, Kuklina EV, Berg CJ. Trends in postpartum hemorrhage: United States, 1994-2006. Am J Obstet Gynecol. Apr. 2010;202:353 e1-6. X-4. [pmid: 20350642].
1575 Camuzcuoglu H, Toy H, Vural M, et al. Internal iliac artery ligation for severe postpartum hemorrhage and severe hemorrhage after postpartum hysterectomy. J Obstet Gynaecol Res. Jun. 2010;36:538-43. X-2, X-4, X-5. [pmid: 20598034].
1576 Cansino C, Melgar JL, Burke A. Physicians' approaches to post-abortion care in Manila, Philippines. Int J Gynaecol Obstet. Jun. 2010;109:216-8. X-2, X-3. [pmid: 20176351].
1577 Chaudhuri P, Banerjee GB, Mandal A. Rectally administered misoprostol versus intravenous oxytocin infusion during cesarean delivery to reduce intraoperative and postoperative blood loss. Int J Gynaecol Obstet. Apr. 2010;109:25-9. X-2, X-4, X-5. [pmid: 20070961].
1578 Chen KH, Chen LR, Lee YH. Exploring the relationship between preterm placental calcification and adverse maternal and fetal outcome. Ultrasound Obstet Gynecol. Mar. 2010;37:328-34. X-4. [pmid: 20586039].
1579 Chodzaza E, Bultemeier K. National management guidelines for obstetric emergencies. African Journal of Midwifery & Women's Health. 2010;4:57-61. X-1, X-4.
1580 Cohain JS. Towards a physiological management of the third stage that prevents postpartum haemorrhage. MIDIRS Midwifery Digest. 2010;20:348-51. X-1, X-4.
1581 Cole-Ceesay R, Cherian M, Sonko A, et al. Strengthening the emergency healthcare system for mothers and children in The Gambia. Reprod Health. 2010;7:21. X-2, X-4. [pmid: 20718979].
1582 Collins I, Chichester M. Let's Reduce Peripartum Transfusion: Identification and Treatment of Anemia. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2010;39:S88-S. X-1, X-4, X-5.
1583 Cosmi E, Saccardi C, Litta P, et al. Transvaginal ultrasound and sonohysterography for assessment of postpartum residual trophoblastic tissue. Int J Gynaecol Obstet. Sep. 2010;110:262-4. X-3. [pmid: 20488441].
1584 Danish N, Fawad A, Abbasi N. Assessment of pregnancy outcome in primigravida: comparison between booked and un-booked patients. J Ayub Med Coll Abbottabad. Apr-Jun. 2010;22:23-5. X-2, X-4. [pmid: 21702258].
1585 Dasari P, Venkatesan B, Thyagarajan C, et al. Expectant and medical management of placenta increta in a primiparous woman presenting with postpartum haemorrhage: The role of Imaging. J Radiol Case Rep. 2010;4:32-40. X-1, X-2, X-5. [pmid: 22470732].
1586 Dinatale A, Ermito S, Fonti I, et al. Obesity and fetal-maternal outcomes. J Prenat Med. Jan. 2010;4:5-8. X-1, X-4. [pmid: 22439052].
1587 Dominici LS, Kuerer HM, Babiera G, et al. Wound complications from surgery in pregnancy-associated breast cancer (PABC). Breast Dis. 2010;31:1-5. X-3. [pmid: 20519803].
1588 Downey C, Bewley S. Childbirth practitioners' attitudes to third stage management. British Journal of Midwifery. 2010;18:576-82. X-1, X-4.
1589 Driessen M, Bouvier-Colle MH, Dupont C, et al. Postpartum hemorrhage resulting from uterine atony after vaginal delivery: factors associated with severity. Obstet Gynecol. Jan. 2010;117:21-31. X-4, X-5. [pmid: 21173641].
1590 Durocher J, Bynum J, Leon W, et al. High fever following postpartum administration of sublingual misoprostol. BJOG. Jun. 2010;117:845-52. X-2. [pmid: 20406228].
1591 Dyer RA, van Dyk D, Dresner A. The use of uterotonic drugs during caesarean section. Int J Obstet Anesth. Jul. 2010;19:313-9. X-1. [pmid: 20627531].
1592 Esakoff TF, Sparks TN, Kaimal AJ, et al. Diagnosis and morbidity of placenta accreta. Ultrasound Obstet Gynecol. Mar. 2010;37:324-7. X-4. [pmid: 20812377].
1593 Fabamwo AO, Akinola OI, Mojoyinola OO. The tragic consequences of unsupervised pregnancies among patients referred to a tertiary maternity unit in Lagos, South West Nigeria. Internet Journal of Tropical Medicine. 2010;7. X-2, X-4.
1594 Fahy K, Hastie C, Bisits A, et al. Holistic physiological care compared with active management of the third stage of labour for women at low risk of postpartum haemorrhage: a cohort study. Women Birth. Dec. 2010;23:146-52. X-4. [pmid: 20226752].
1595 Fargeaudou Y, Morel O, Soyer P, et al. Persistent postpartum haemorrhage after failed arterial ligation: value of pelvic embolisation. Eur Radiol. Jul. 2010;20:1777-85. X-5. [pmid: 20309561].
1596 Farrar D, Tuffnell D, Airey R, et al. Care during the third stage of labour: a postal survey of UK midwives and obstetricians. BMC Pregnancy Childbirth. 2010;10:23. X-1, X-3, X-4. [pmid: 20492659].
1597 Fawole AO, Sotiloye OS, Hunyinbo KI, et al. A double-blind, randomized, placebo-controlled trial of misoprostol and routine uterotonics for the prevention of postpartum hemorrhage. Int J Gynaecol Obstet. Feb. 2010;112:107-11. X-2, X-4, X-5. [pmid: 21130446].
1598 Feng XL, Zhu J, Zhang L, et al. Socio-economic disparities in maternal mortality in China between 1996 and 2006. BJOG. Nov. 2010;117:1527-36. X-2, X-3, X-4. [pmid: 20937073].
1599 Fong A, Leake J, Pan D, et al. Demographic, institutional and obstetrical risk factors for postpartum haemorrhage mortality. J Obstet Gynaecol. 2010;30:470-5. X-2, X-5. [pmid: 20604649].
1600 Fotopoulou C, Dudenhausen JW. Uterine compression sutures for preserving fertility in severe postpartum haemorrhage: an overview 13 years after the first description. J Obstet Gynaecol. May. 2010;30:339-49. X-1. [pmid: 20455714].
1601 Franchini M, Franchi M, Bergamini V, et al. The use of recombinant activated FVII in postpartum hemorrhage. Clin Obstet Gynecol. Mar. 2010;53:219-27. X-1. [pmid: 20142658].
1602 Fuglsang K, Petersen LK. New local hemostatic treatment for postpartum hemorrhage caused by placenta previa at cesarean section. Acta Obstet Gynecol Scand. Oct. 2010;89:1346-9. X-5. [pmid: 20521867].
1603 Gadmour YB, Godid FA. Factors affecting the success of trial of labour after previous cesarean delivery. Jamahiriya Medical Journal. Spring. 2010;10:34-9. X-2, X-3, X-4.
1604 Gahl WA, Huizing M. Hermansky-Pudlak Syndrome. 2010. X-1, X-3. [pmid: 20301464].
1605 Gao Y, Barclay L. Availability and quality of emergency obstetric care in Shanxi Province, China. Int J Gynaecol Obstet. Aug. 2010;110:181-5. X-2. [pmid: 20570261].
1606 Gei-Guardia O, Soto-Herrera E, Gei-Brealey A, et al. Sheehan syndrome in Costa Rica: clinical experience with 60 cases. Endocr Pract. May-Jun. 2010;17:337-44. X-2, X-3, X-4. [pmid: 21041170].
1607 Geller EJ, Wu JM, Jannelli ML, et al. Maternal outcomes associated with planned vaginal versus planned primary cesarean delivery. Am J Perinatol. Oct. 2010;27:675-83. X-4. [pmid: 20235001].
1608 George RB, McKeen D, Chaplin AC, et al. Up-down determination of the ED(90) of oxytocin infusions for the prevention of postpartum uterine atony in parturients undergoing Cesarean delivery. Can J Anaesth. Jun. 2010;57:578-82. X-4. [pmid: 20238255].
1609 Gokalp D, Tuzcu A, Bahceci M, et al. Assessment of bleeding disorders in Sheehan's syndrome: are bleeding disorders the underlying cause of Sheehan's syndrome?. Platelets. 2010;22:92-7. X-2, X-4. [pmid: 21133650].
1610 Goldfarb JM, Desai N. Options to prevent multiple pregnancies with ART. Current Women's Health Reviews. 2010;6:250-3. X-1.
1611 Gonsalves M, Belli A. The role of interventional radiology in obstetric hemorrhage. Cardiovasc Intervent Radiol. Oct. 2010;33(5):887-95. X-1. [pmid: 20464555].
1612 Grossman A, Graves A, Rwamushaija E, et al. Misoprostol for safe motherhood: one tablet, two life-saving indications. African Journal of Midwifery & Women's Health. 2010;4:121-5. X-1, X-4, X-5.
1613 Grotegut CA, Feng L, Mao L, et al. beta-Arrestin mediates oxytocin receptor signaling, which regulates uterine contractility and cellular migration. Am J Physiol Endocrinol Metab. Mar. 2010;300:E468-77. X-1, X-3. [pmid: 21139074].
1614 Grotegut CA, Paglia MJ, Johnson LN, et al. Oxytocin exposure during labor among women with postpartum hemorrhage secondary to uterine atony. Am J Obstet Gynecol. Jan. 2010;204:56 e1-6. X-4. [pmid: 21047614].
1615 Guazzelli CA, de Queiroz FT, Barbieri M, et al. Etonogestrel implant in postpartum adolescents: bleeding pattern, efficacy and discontinuation rate. Contraception. Sep. 2010;82:256-9. X-2, X-3, X-4. [pmid: 20705154].
1616 Gundry R, Siassakos D, Crofts JF, et al. Simulation training for obstetric procedures and emergencies. Fetal and Maternal Medicine Review. November. 2010;21:323-45. X-1, X-3, X-4.
1617 Gungorduk K, Asicioglu O, Besimoglu B, et al. Using intraumbilical vein injection of oxytocin in routine practice with active management of the third stage of labor: a randomized controlled trial. Obstet Gynecol. Sep. 2010;116:619-24. X-4. [pmid: 20733444].
1618 Gungorduk K, Asicioglu O, Celikkol O, et al. Use of additional oxytocin to reduce blood loss at elective caesarean section: A randomised control trial. Aust N Z J Obstet Gynaecol. Feb. 2010;50:36-9. X-2, X-4, X-5. [pmid: 20218995].
1619 Gungorduk K, Yildirim G, Asicioglu O, et al. Efficacy of intravenous tranexamic acid in reducing blood loss after elective cesarean section: a prospective, randomized, double-blind, placebo-controlled study. Am J Perinatol. Mar. 2010;28:233-40. X-4. [pmid: 20979013].
1620 Gupta SD, Khanna A, Gupta R, et al. Maternal mortality ratio and predictors of maternal deaths in selected desert districts in rajasthan a community-based survey and case control study. Womens Health Issues. Jan-Feb. 2010;20:80-5. X-2, X-4. [pmid: 20123178].
1621 Harriott J, Christie L, Wynter S, et al. A randomized comparison of rectal misoprostol with syntometrine on blood loss in the third stage of labour. West Indian Med J. Jun. 2010;58:201-6. X-4. [pmid: 20043525].
1622 Hauswald M, Williamson MR, Baty GM, et al. Use of an improvised pneumatic anti-shock garment and a non-pneumatic anti-shock garment to control pelvic blood flow. Int J Emerg Med. 2010;3:173-5. X-2, X-4, X-5. [pmid: 21031041].
1623 Hillier TA, Vesco KK, Whitlock EP, et al. 2010. May. X-1. [pmid: 20722157].
1624 Hofmeyr GJ, Fawole B, Mugerwa K, et al. Administration of 400 mug of misoprostol to augment routine active management of the third stage of labor. Int J Gynaecol Obstet. Feb. 2010;112:98-102. X-2, X-4. [pmid: 21130990].
1625 Homer CS, Kurinczuk JJ, Spark P, et al. A novel use of a classification system to audit severe maternal morbidity. Midwifery. Oct. 2010;26:532-6. X-4. [pmid: 20691518].
1626 Hossain N, Khan N, Sultana SS. Abruptio placenta and adverse pregnancy outcome. J Pak Med Assoc. Jun. 2010;60:443-6. X-2, X-4. [pmid: 20527640].
1627 Hunter LA. Exploring the role of uterine artery embolization in the management of postpartum hemorrhage. J Perinat Neonatal Nurs. Jul-Sep. 2010;24(3):207-14. X-1. [pmid: 20697237].
1628 Ion I, Enache T, Drambareanu D, et al. B-lynch compressive uterine suture. 2010;58:213-8. X-1, X-2.
1629 Janakiraman V, Ecker J, Kaimal AJ. Comparing the second stage in induced and spontaneous labor. Obstet Gynecol. Sep. 2010;116:606-11. X-4. [pmid: 20733442].
1630 Jangsten E, Mattsson LA, Lyckestam I, et al. A comparison of active management and expectant management of the third stage of labour: a Swedish randomised controlled trial. BJOG. Feb. 2010;118:362-9. X-4. [pmid: 21134105].
1631 Jaques AM, Amor DJ, Baker HW, et al. Adverse obstetric and perinatal outcomes in subfertile women conceiving without assisted reproductive technologies. Fertil Steril. Dec. 2010;94:2674-9. X-3, X-4. [pmid: 20381039].
1632 Javed M, Tariq R, Rashid M, et al. Effect of uterine fibroid on pregnancy outcome. 2010:4. X-2.
1633 Kamilya G, Seal SL, Mukherji J, et al. Maternal mortality and cesarean delivery: an analytical observational study. J Obstet Gynaecol Res. Apr. 2010;36:248-53. X-4. [pmid: 20492373].
1634 Kaplan AI. Legally speaking. Did misoprostol cause this postpartum hemorrhage?. Contemporary OB/GYN. 2010;55:22. X-1.
1635 Karabulut A, Caliskan A, Ozcan N, et al. Maternal mortality in Denizli region: Three years evaluation. Turkiye Klinikleri Jinekoloji Obstetrik. 2010;20:29-34. X-2, X-4.
1636 Kennare RM, Keirse MJ, Tucker GR, et al. Planned home and hospital births in South Australia, 1991-2006: differences in outcomes. Med J Aust. Jan. 18. 2010;192:76-80. X-4. [pmid: 20078406].
1637 Kerr N, Dresang LT. Does the non-pneumatic anti-shock garment (NASG) have a role in the management of postpartum hemorrhage?. Evidence-Based Practice. 2010;13:6. X-1, X-4, X-5.
1638 Khalil MA, Azhar A, Anwar N, et al. Aetiology, maternal and foetal outcome in 60 cases of obstetrical acute renal failure. J Ayub Med Coll Abbottabad. Oct-Dec. 2010;21:46-9. X-2, X-4. [pmid: 21067023].
1639 Khan SLA. Acute renal failure in pregnancy: One year observational study at Nephrology Department Sandeman Provincial Hospital Quetta. 2010;4:188-91. X-2.
1640 King KJ, Douglas MJ, Unger W, et al. Five unit bolus oxytocin at cesarean delivery in women at risk of atony: a randomized, double-blind, controlled trial. Anesth Analg. Dec. 2010;111:1460-6. X-4, X-5. [pmid: 20889945].
1641 Kirke AB. How safe is GP obstetrics? An assessment of antenatal risk factors and perinatal outcomes in one rural practice. Rural Remote Health. Jul-Sep. 2010;10:1545. X-4. [pmid: 20815656].
1642 Kolas T, Oian P, Skjeldestad FE. Risks for peroperative excessive blood loss in cesarean delivery. Acta Obstet Gynecol Scand. May. 2010;89:658-63. X-4, X-5. [pmid: 20218934].
1643 Lataifeh I, Amarin Z, Zayed F, et al. Indications and outcome for obstetric patients' admission to intensive care unit: a 7-year review. J Obstet Gynaecol. May. 2010;30:378-82. X-2. [pmid: 20455722].
1644 Lee HJ, Norwitz ER, Shaw J. Contemporary management of fibroids in pregnancy. Rev Obstet Gynecol. Winter. 2010;3:20-7. X-1, X-4. [pmid: 20508779].
1645 Lee JS, Shepherd SM. Endovascular treatment of postpartum hemorrhage. Clin Obstet Gynecol. Mar. 2010;53:209-18. X-1. [pmid: 20142657].
1646 Lee NK, Kim S, Kim CW, et al. Identification of bleeding sites in patients with postpartum hemorrhage: MDCT compared with angiography. AJR Am J Roentgenol. Feb. 2010;194:383-90. X-4. [pmid: 20093600].
1647 Li X, Zhu J, Dai L, et al. Trends in maternal mortality due to obstetric hemorrhage in urban and rural China, 1996-2005. J Perinat Med. Jan. 2010;39:35-41. X-2, X-4. [pmid: 21138400].
1648 Liang J, Zhu J, Dai L, et al. Maternal mortality in China, 1996-2005. Int J Gynaecol Obstet. Aug. 2010;110:93-6. X-2, X-4. [pmid: 20471015].
1649 Lie Fong S, van den Heuvel-Eibrink MM, Eijkemans MJ, et al. Pregnancy outcome in female childhood cancer survivors. Hum Reprod. May. 2010;25:1206-12. X-4. [pmid: 20172864].
1650 Liljestrand J, Moore J, Tholandi M. Active management of the third stage of labor and eclampsia management as critical components of skilled care during birth in Cambodia. Int J Gynaecol Obstet. Nov. 2010;111:188-9. X-2, X-4. [pmid: 20650458].
1651 Lim PS, Singh S, Lee A, et al. Umbilical vein oxytocin in the management of retained placenta: an alternative to manual removal of placenta?. Arch Gynecol Obstet. Nov. 2010;284:1073-9. X-4. [pmid: 21136267].
1652 Liu S, Joseph KS, Bartholomew S, et al. Temporal trends and regional variations in severe maternal morbidity in Canada, 2003 to 2007. J Obstet Gynaecol Can. Sep. 2010;32:847-55. X-4. [pmid: 21050517].
1653 Lousquy R, Morel O, Soyer P, et al. Routine use of abdominopelvic ultrasonography in severe postpartum hemorrhage: retrospective evaluation in 125 patients. Am J Obstet Gynecol. Mar. 2010;204:232 e1-6. X-4. [pmid: 21111397].
1654 Majeed T, Mobusher I, Ali A, et al. Comparison of side effects and complications of intravaginal misoprostol with extra-amniotic prostaglandin F2 alpha for termination of second trimester pregnancy. Medical Forum Monthly. December. 2010;21:29-32. X-1, X-2.
1655 Majumdar A, Saleh S, Davis M, et al. Use of balloon catheter tamponade for massive postpartum haemorrhage. J Obstet Gynaecol. 2010;30(6):586-93. X-5. [pmid: 20701508].
1656 Malik S, Brooks H, Singhal T. Cell saver use in obstetrics. J Obstet Gynaecol. 2010;30:826-8. X-5. [pmid: 21126122].
1657 Mansouri HA, Alsahly N. Rectal versus oral misoprostol for active management of third stage of labor: a randomized controlled trial. Arch Gynecol Obstet. May. 2010;283:935-9. X-4. [pmid: 20422423].
1658 Matar HE, Almerie MQ, Alsabbagh M, et al. Policies for care during the third stage of labour: a survey of maternity units in Syria. BMC Pregnancy Childbirth. 2010;10:32. X-2, X-3, X-4. [pmid: 20569439].
1659 Matthews G, Rebarber A. A practical perspective on cesarean hysterectomy: when, why, and how. Contemporary OB/GYN. 2010;55:30-2. 4. 6-8 passim. PMID:. X-1.
1660 McCaw-Binns A, Lewis-Bell K. Small victories, new challenges: two decades of maternal mortality surveillance in Jamaica. West Indian Med J. Dec. 2010;58:518-32. X-2, X-4. [pmid: 20583677].
1661 McDonnell NJ, Kennedy D, Long LJ, et al. The development and implementation of an obstetric cell salvage service. Anaesth Intensive Care. May. 2010;38:492-9. X-4, X-5. [pmid: 20514958].
1662 McKelvey A, Ashe R, McKenna D, et al. Caesarean section in the second stage of labour: a retrospective review of obstetric setting and morbidity. J Obstet Gynaecol. Apr. 2010;30:264-7. X-4, X-5. [pmid: 20373928].
1663 Miller S, Fathalla MM, Ojengbede OA, et al. Obstetric hemorrhage and shock management: using the low technology Non-pneumatic Anti-Shock Garment in Nigerian and Egyptian tertiary care facilities. BMC Pregnancy Childbirth. 2010;10:64. X-2. [pmid: 20955600].
1664 Miller S, Fathalla MM, Youssif MM, et al. A comparative study of the non-pneumatic anti-shock garment for the treatment of obstetric hemorrhage in Egypt. Int J Gynaecol Obstet. Apr. 2010;109:20-4. X-2. [pmid: 20096836].
1665 Mir S, Ahmad A. Shoulder dystocia. JK Science. Oct-Dec. 2010;12:165-7. X-1, X-4.
1666 Mobeen N, Durocher J, Zuberi N, et al. Administration of misoprostol by trained traditional birth attendants to prevent postpartum haemorrhage in homebirths in Pakistan: a randomised placebo-controlled trial. BJOG. Feb. 2010;118:353-61. X-2, X-4. [pmid: 21176086].
1667 Mockler JC, Murphy DJ, Wallace EM. An Australian and New Zealand survey of practice of the use of oxytocin at elective caesarean section. Aust N Z J Obstet Gynaecol. Feb. 2010;50:30-5. X-3, X-4. [pmid: 20218994].
1668 Mohammad KI, Gamble J, Creedy DK. Prevalence and factors associated with the development of antenatal and postnatal depression among Jordanian women. Midwifery. Dec. 2010;27:e238-45. X-2, X-3, X-5. [pmid: 21130548].
1669 Moore J, Chandraharan E. Management of massive postpartum haemorrhage and coagulopathy. Obstetrics, Gynaecology and Reproductive Medicine. 2010;20:174-80. X-1.
1670 Mourad-Youssif M, Ojengbede OA, Meyer CD, et al. Can the Non-pneumatic Anti-Shock Garment (NASG) reduce adverse maternal outcomes from postpartum hemorrhage? Evidence from Egypt and Nigeria. Reprod Health. 2010;7:24. X-2. [pmid: 20809942].
1671 Mustafa R, Hashmi H. Near-miss obstetrical events and maternal deaths. J Coll Physicians Surg Pak. Dec. 2010;19:781-5. X-2, X-4. [pmid: 20042157].
1672 Nahar S, Nargis SF, Khannam M. Simple technique of uterine compression sutures for prevention of primary postpartum hemorrhage during caesarian section. Pakistan Journal of Medical Sciences. April-June. 2010;26:319-23. X-2, X-4.
1673 Natukunda B, Schonewille H, Smit Sibinga CT. Assessment of the clinical transfusion practice at a regional referral hospital in Uganda. Transfus Med. Jun. 2010;20:134-9. X-2, X-3, X-4. [pmid: 20136779].
1674 Naz T, Hassan L. Primary postpartum hemorrhage; Profile at a tertiary care hospital. Journal of Medical Sciences. January. 2010;18:49-53. X-2, X-4.
1675 Neelam N, Kumar SJ. B-Lynch suture-an experience. Journal of Obstetrics and Gynecology of India. April. 2010;60:128-34. X-2.
1676 Nizam K, Haider G. Role of uterovaginal packing in postpartum hemorrhage. Journal of the Liaquat University of Medical and Health Sciences. January - April. 2010;9:27-9. X-2.
1677 Nojomi M, Haghighi L, Bijari B, et al. Delayed childbearing: Pregnancy and maternal outcomes. Iranian Journal of Reproductive Medicine. 2010;8:80-5. X-2, X-4.
1678 Noor S, Fawwad A, Sultana R, et al. Pregnancy with fibroids and its and its obstetric complication. J Ayub Med Coll Abbottabad. Oct-Dec. 2010;21:37-40. X-2, X-4. [pmid: 21067021].
1679 Novikova N, Hofmeyr GJ. Tranexamic acid for preventing postpartum haemorrhage. Cochrane Database Syst Rev. 2010. CD007872. X-1. [pmid: 20614466].
1680 Oboro V, Adewunmi A, Ande A, et al. Morbidity associated with failed vaginal birth after cesarean section. Acta Obstet Gynecol Scand. Sep. 2010;89:1229-32. X-2, X-4. [pmid: 20804350].
1681 O'Brien D, Babiker E, O'sullivan O, et al. Prediction of peripartum hysterectomy and end organ dysfunction in major obstetric haemorrhage. Eur J Obstet Gynecol Reprod Biol. Dec. 2010;153:165-9. X-4. [pmid: 20810201].
1682 Ogelle O, Okafor C, Eke AC, et al. Current trends in hysterectomies at a Nigerian tertiary center. Journal of Gynecologic Surgery. 01. Jan. 2010;26:7-13. X-2, X-3, X-4.
1683 Ojengbede OA, Morhason-Bello IO, Galadanci H, et al. Assessing the role of the non-pneumatic anti-shock garment in reducing mortality from postpartum hemorrhage in Nigeria. Gynecol Obstet Invest. 2010;71:66-72. X-2. [pmid: 21160197].
1684 Olive DL, Pritts EA. Fibroids and reproduction. Semin Reprod Med. May. 2010;28:218-27. X-1. [pmid: 20414844].
1685 Orbach A, Levy A, Wiznitzer A, et al. Peripartum cesarean hysterectomy: critical analysis of risk factors and trends over the years. J Matern Fetal Neonatal Med. Mar. 2010;24:480-4. X-4. [pmid: 20636233].
1686 Osmundson SS, Ou-Yang RJ, Grobman WA. Elective induction compared with expectant management in nulliparous women with a favorable cervix. Obstet Gynecol. Sep. 2010;116:601-5. X-4. [pmid: 20733441].
1687 Ozalp E, Tanir HM, Sener T. Dinoprostone vaginal insert versus intravenous oxytocin to reduce postpartum blood loss following vaginal or cesarean delivery. Clin Exp Obstet Gynecol. 2010;37:53-5. X-4. [pmid: 20420283].
1688 Palacios-Jaraquemada J, Fiorillo A. Conservative approach in heavy postpartum hemorrhage associated with coagulopathy. Acta Obstet Gynecol Scand. Sep. 2010;89:1222-5. X-2, X-5. [pmid: 20804349].
1689 Pallasmaa N, Ekblad U, Aitokallio-Tallberg A, et al. Cesarean delivery in Finland: maternal complications and obstetric risk factors. Acta Obstet Gynecol Scand. Jul. 2010;89:896-902. X-4. [pmid: 20583935].
1690 Panda S, Prashantha DK, Shankar SR, et al. Localized convexity subarachnoid haemorrhage--a sign of early cerebral venous sinus thrombosis. Eur J Neurol. Oct. 2010;17:1249-58. X-3, X-4. [pmid: 20402745].
1691 Park H, Han JY, Ahn HK, et al. Unintentional uterine hyperactivity and perinatal outcomes following labor induction with intravaginal administration of sustained-release dinoprostone insert. Journal of Clinical Pharmacology and Pharmacoepidemiology. 2010;1:9-14. X-4.
1692 Pattinson RC, Hulsbergen MH, Van Hoorick L. The effect of maternal HIV infection on maternal conditions and perinatal deaths in southwest Tshwane. Facts Views Vis Obgyn. 2010;2:227-31. X-2, X-4. [pmid: 25009711].
1693 Peng T, Li XT, Zhou SF, et al. Transcutaneous electrical nerve stimulation on acupoints relieves labor pain: a non-randomized controlled study. Chin J Integr Med. Jun. 2010;16:234-8. X-3, X-4. [pmid: 20694778].
1694 Perez A, Acevedo O, Tamayo Fdel C, et al. Characterization of obstetric patients with multiple organ failure in the intensive care unit of a Havana teaching hospital, 1998 to 2006. MEDICC Rev. Spring. 2010;12:27-32. X-2, X-4. [pmid: 20486411].
1695 Perez-Munuzuri A, Fernandez-Lorenzo JR, Couce-Pico ML, et al. Serum levels of IGF1 are a useful predictor of retinopathy of prematurity. Acta Paediatr. Apr. 2010;99:519-25. X-3, X-4. [pmid: 20085549].
1696 Porreco RP, Barkey R. Peripartum intensive care. J Matern Fetal Neonatal Med. Oct. 2010;23:1136-8. X-4. [pmid: 20540680].
1697 Porreco RP, Stettler RW. Surgical remedies for postpartum hemorrhage. Clin Obstet Gynecol. Mar. 2010;53:182-95. X-1. [pmid: 20142655].
1698 Prakash J, Niwas SS, Parekh A, et al. Acute kidney injury in late pregnancy in developing countries. Ren Fail. Jan. 2010;32:309-13. X-1, X-4. [pmid: 20370445].
1699 Prick BW, Steegers EA, Jansen AJ, et al. Well being of obstetric patients on minimal blood transfusions (WOMB trial). BMC Pregnancy Childbirth. 2010;10:83. X-1, X-2, X-4, X-5. [pmid: 21162725].
1700 Priya N, Ashok V, Suresh V. Maternal mortality: Ten years retrospective study. JK Science. July-Sep. 2010;12:134-6. X-1, X-4.
1701 Purohit R, Sharma J. Cervical clamping following ultrasound-guided uterocervical packing to control postpartum uterine hemorrhage. Int J Gynaecol Obstet. May. 2010;109:160-1. X-2, X-5. [pmid: 20176354].
1702 Qamarunisa, Memon H, Ali M. Frequency, maternal and fetal outcome of abruptio placenta in a rural medical college hospital, Mirpurkhas Sindh. Pakistan Journal of Medical Sciences. July - September. 2010;26:663-6. X-2, X-4.
1703 Qureshi ZP, Sekadde-Kigondu C, Mutiso SM. Rapid assessment of partograph utilisation in selected maternity units in Kenya. East Afr Med J. Jun. 2010;87:235-41. X-2, X-4. [pmid: 23057265].
1704 Raba G. Effect of internal iliac artery ligation on ovarian blood supply and ovarian reserve. Climacteric. Feb. 2010;14:54-7. X-4, X-5. [pmid: 20128664].
1705 Rahim R, Nahar K, Khan IA. Platelet count in 100 cases of pregnancy induced hypertension. Mymensingh Med J. Jan. 2010;19:5-9. X-2, X-4. [pmid: 20046164].
1706 Rajiv M, Malik S, Mittal A. Methotrexate therapy for placenta accreta- A rare case report. Current Pediatric Research. Jan-June. 2010;14:69-70. X-1.
1707 Rathat G, Do Trinh P, Mercier G, et al. Synechia after uterine compression sutures. Fertil Steril. Jan. 2010;95:405-9. X-4, X-5. [pmid: 20883989].
1708 Rather SY, Qadir A, Parveen S, et al. Use of condom to control intractable PPH. JK Science. July-Sep. 2010;12:127-9. X-2.
1709 Rizwan N, Abbasi RM, Jatoi N. Retained placenta still a continuing cause of maternal morbidity and mortality. J Pak Med Assoc. Dec. 2010;59:812-4. X-2, X-4. [pmid: 20201169].
1710 Rizwan N, Abbasi RM, Mughal R. Maternal morbidity and perinatal outcome with twin pregnancy. J Ayub Med Coll Abbottabad. Apr-Jun. 2010;22:105-7. X-2, X-4. [pmid: 21702280].
1711 Robson SJ, Leader LR, Dear KB, et al. Women's expectations of management in their next pregnancy after an unexplained stillbirth: an Internet-based empirical study. Aust N Z J Obstet Gynaecol. Dec. 2010;49:642-6. X-3, X-4. [pmid: 20070714].
1712 Roethlisberger M, Womastek I, Posch M, et al. Early postpartum hysterectomy: incidence and risk factors. Acta Obstet Gynecol Scand. Aug. 2010;89:1040-4. X-4, X-5. [pmid: 20602600].
1713 Rohilla M, Raveendran A, Dhaliwal LK, et al. Severe anaemia in pregnancy: a tertiary hospital experience from northern India. J Obstet Gynaecol. 2010;30:694-6. X-2. [pmid: 20925612].
1714 Romanyuk V, Raichel L, Sergienko R, et al. Pneumonia during pregnancy: radiological characteristics, predisposing factors and pregnancy outcomes. J Matern Fetal Neonatal Med. Jan. 2010;24:113-7. X-1, X-3, X-4. [pmid: 20476873].
1715 Rosenberg J. Trade-offs in treating postpartum hemorrhage. International Perspectives on Sexual & Reproductive Health. 2010;36:5. X-1, X-4, X-5.
1716 Rosenberg T, Pariente G, Sergienko R, et al. Critical analysis of risk factors and outcome of placenta previa. Arch Gynecol Obstet. Jul. 2010;284:47-51. X-4. [pmid: 20652281].
1717 Rossen J, Okland I, Nilsen OB, et al. Is there an increase of postpartum hemorrhage, and is severe hemorrhage associated with more frequent use of obstetric interventions?. Acta Obstet Gynecol Scand. Oct. 2010;89:1248-55. X-4, X-5. [pmid: 20809871].
1718 Rossi AC, Lee RH, Chmait RH. Emergency postpartum hysterectomy for uncontrolled postpartum bleeding: a systematic review. Obstet Gynecol. Mar. 2010;115:637-44. X-1, X-2, X-4, X-5. [pmid: 20177297].
1719 Rozen G, Ugoni AM, Sheehan PM. A new perspective on VBAC: a retrospective cohort study. Women Birth. Mar. 2010;24:3-9. X-4. [pmid: 20447886].
1720 Sanghvi H, Ansari N, Prata NJ, et al. Prevention of postpartum hemorrhage at home birth in Afghanistan. Int J Gynaecol Obstet. Mar. 2010;108:276-81. X-2, X-3, X-4. [pmid: 20053399].
1721 Schorn MN. Measurement of blood loss: review of the literature. J Midwifery Womens Health. Jan-Feb. 2010;55:20-7. X-1. [pmid: 20129226].
1722 Scott S, Deihes L. A Collaborative Approach for the Identification and Treatment of Obstetric Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2010;39:S13-S. X-1, X-5.
1723 Selo-Ojeme D, Rogers C, Mohanty A, et al. Is induced labour in the nullipara associated with more maternal and perinatal morbidity?. Arch Gynecol Obstet. Aug. 2010;284:337-41. X-2, X-4, X-5. [pmid: 20838800].
1724 Sentilhes L, Ambroselli C, Kayem G, et al. Maternal outcome after conservative treatment of placenta accreta. Obstet Gynecol. Mar. 2010;115:526-34. X-2, X-4, X-5. [pmid: 20177283].
1725 Sentilhes L, Kayem G, Ambroselli C, et al. Fertility and pregnancy outcomes following conservative treatment for placenta accreta. Hum Reprod. Nov. 2010;25:2803-10. X-4. [pmid: 20833739].
1726 Shaffer BL, Cheng YW, Vargas JE, et al. Manual rotation to reduce caesarean delivery in persistent occiput posterior or transverse position. J Matern Fetal Neonatal Med. Jan. 2010;24:65-72. X-4. [pmid: 20350240].
1727 Shah N, Rohra DK, Shams H, et al. Home deliveries: reasons and adverse outcomes in women presenting to a tertiary care hospital. J Pak Med Assoc. Jul. 2010;60:555-8. X-2, X-4. [pmid: 20578606].
1728 Shahid S, Javed N. Gestational choriocarcinoma with metastasis to breast: An unusual presentation. Journal of Postgraduate Medical Institute. April-June. 2010;24:163-4. X-1.
1729 Shaikh F, Memon RAD, Maqsood S. An audit of primary postpartum hemorrhage. Medical Forum Monthly. February. 2010;21:26-30. X-2, X-4.
1730 Shakur H, Elbourne D, Gulmezoglu M, et al. The WOMAN Trial (World Maternal Antifibrinolytic Trial): tranexamic acid for the treatment of postpartum haemorrhage: an international randomised, double blind placebo controlled trial. Trials. 2010;11:40. X-3, X-4. [pmid: 20398351].
1731 Sharma PP, Kalra A, Mukhopadhyay P, et al. Early re-operations after gynecological and obstetrical surgery -a five years. Journal of Obstetrics and Gynecology of India. December. 2010;60:507-10. X-2, X-4.
1732 Shechter Y, Levy A, Wiznitzer A, et al. Obstetric complications in grand and great grand multiparous women. J Matern Fetal Neonatal Med. Oct. 2010;23:1211-7. X-4. [pmid: 20402567].
1733 Shrim A, Levin I, Mallozzi A, et al. Does very advanced maternal age, with or without egg donation, really increase obstetric risk in a large tertiary center?. J Perinat Med. Nov. 2010;38:645-50. X-4. [pmid: 20707613].
1734 Sidhu HK, Prasad G, Jain V, et al. Pelvic artery embolization in the management of obstetric hemorrhage. Acta Obstet Gynecol Scand. Aug. 2010;89:1096-9. X-2, X-4, X-5. [pmid: 20397757].
1735 Simpson KR. Postpartum hemorrhage. MCN Am J Matern Child Nurs. Mar-Apr. 2010;35:124. X-1, X-2, X-4, X-5. [pmid: 20215958].
1736 Singh T, Ghosh SM, Agarwala R, et al. Anaesthetic implications of a parturient with antiphospholipid antibody syndrome. Southern African Journal of Anaesthesia and Analgesia. 2010;16:24-6. X-1.
1737 Singhania P, Singh S, Banerjee R, et al. Hyponatremia - A rare and emergency presentation of Sheehans syndrome. Pakistan Journal of Medical Sciences. July - September. 2010;26:713-5. X-1, X-2.
1738 Sloan NL, Durocher J, Aldrich T, et al. What measured blood loss tells us about postpartum bleeding: a systematic review. BJOG. Jun. 2010;117:788-800. X-1, X-4. [pmid: 20406227].
1739 Sobantka S, Pietrzak Z, Wieczorek A, et al. Comparison of blood loss in vaginal birth versus cesarean section. [Polish, English]. Ginekologia i Poloznictwo. 2010;16:15-20. X-4.
1740 Sobantka S, Pietrzak Z, Wieczorek A, et al. Comparison of blood loss in vaginal birth versus cesarean section. 2010;16:15-20. X-4.
1741 Soltan MH, Imam HH, Zahran KA, et al. Assessing changes in flow velocimetry and clinical outcome following use of an external aortic compression device in women with postpartum hemorrhage. Int J Gynaecol Obstet. Sep. 2010;110:257-61. X-2, X-4, X-5. [pmid: 20605150].
1742 Soltani H, Hutchon DR, Poulose TA. Timing of prophylactic uterotonics for the third stage of labour after vaginal birth. Cochrane Database of Systematic Reviews. 2010. X-1.
1743 Sosa CG, Althabe F, Belizan JM, et al. Use of oxytocin during early stages of labor and its effect on active management of third stage of labor. Am J Obstet Gynecol. Mar. 2010;204:238 e1-5. X-2, X-4. [pmid: 21145034].
1744 Souza JP, Cecatti JG, Pacagnella RC, et al. Development and validation of a questionnaire to identify severe maternal morbidity in epidemiological surveys. Reprod Health. 2010;7:16. X-2, X-4. [pmid: 20663159].
1745 Soyer P, Morel O, Fargeaudou Y, et al. Value of pelvic embolization in the management of severe postpartum hemorrhage due to placenta accreta, increta or percreta. Eur J Radiol. Dec. 2010;80:729-35. X-5. [pmid: 20708361].
1746 Stanirowski P, Prochenko E, Fischof I, et al. Pregnancy outcomes and trial of labour in case of foetal macrosomia. [Polish, English]. Ginekologia i Poloznictwo. 2010;16:28-36. X-4.
1747 Stanirowski P, Prochenko E, Fischof I, et al. Pregnancy outcomes and trial of labour in case of foetal macrosomia. 2010;16:28-36. X-4.
1748 Stanojevic D, Stanojevic M, Zamurovic M, et al. Uterine compression suture technique in the management of severe postpartum haemorrhage as an alternative to hysterectomy. Srp Arh Celok Lek. Nov-Dec. 2010;137:638-40. X-1, X-5. [pmid: 20069921].
1749 Suchocki S, Piec P, Kubiaczyk F. Peripartum hysterectomy - Increasing problem in modern obstetrics. [Polish, English]. Ginekologia i Poloznictwo. 2010;17:16-21. X-4.
1750 Suchocki S, Piec P, Kubiaczyk F. Peripartum hysterectomy - Increasing problem in modern obstetrics. 2010;17:16-21. X-1, X-4.
1751 Sultana N, Begum K, Begum A, et al. A lower dose of magnesium sulphate for control of convulsion in eclamptic women of Bangladesh. Bangladesh Journal of Obstetrics and Gynecology. September. 2010;25:71-6. X-1, X-2, X-4.
1752 Sutherland T, Meyer C, Bishai DM, et al. Community-based distribution of misoprostol for treatment or prevention of postpartum hemorrhage: cost-effectiveness, mortality, and morbidity reduction analysis. Int J Gynaecol Obstet. Mar. 2010;108:289-94. X-1, X-2, X-3. [pmid: 20079493].
1753 Thapa K, Malla B, Pandey S, et al. Intrauterine condom tamponade in management of post partum haemorrhage. J Nepal Health Res Counc. Apr. 2010;8:19-22. X-2, X-4, X-5. [pmid: 21879008].
1754 Thompson A, Brown Will SE, Treanor C. From Dazed and Confused to Empowered: A New Graduate's Solution for Managing Postpartum Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2010;39:S130-1. Language: English. Entry Date: 20110909. Revision Date: 20140704. Publication Type: journal article. X-1, X-4, X-5.
1755 Thompson A, Treanor C. From Dazed and Confused to Empowered: A New Graduate's Solution for Managing Postpartum Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2010;39:S130-1. X-1.
1756 Thompson JF, Heal LJ, Roberts CL, et al. Women's breastfeeding experiences following a significant primary postpartum haemorrhage: A multicentre cohort study. Int Breastfeed J. 2010;5:5. X-2, X-4, X-5. [pmid: 20504372].
1757 Toledo P, McCarthy RJ, Burke CA, et al. The effect of live and web-based education on the accuracy of blood-loss estimation in simulated obstetric scenarios. Am J Obstet Gynecol. Apr. 2010;202(4):400.e1-5. X-3, X-4. [pmid: 20035920].
1758 Tuladhar H, Khanal R, Kayastha S, et al. Complications of home delivery: our experience at Nepal Medical College Teaching Hospital. Nepal Med Coll J. Sep. 2010;11:164-9. X-2, X-4. [pmid: 20334062].
1759 Turan J, Ojengbede O, Fathalla M, et al. Positive effects of the non-pneumatic anti-shock garment on delays in accessing care for postpartum and postabortion hemorrhage in Egypt and Nigeria. J Womens Health (Larchmt). Jan. 2010;20:91-8. X-2. [pmid: 21190486].
1760 Turner MJ. Peripartum hysterectomy: an evolving picture. Int J Gynaecol Obstet. Apr. 2010;109:9-11. X-1. [pmid: 20172521].
1761 van Stralen G, van Stralen-Ruijten LL, Spaargaren CF, et al. Good quality of life after emergency embolisation in postpartum haemorrhage. J Psychosom Obstet Gynaecol. Dec. 2010;31:285-8. X-4, X-5. [pmid: 21067474].
1762 Varras M, Krivis C, Plis C, et al. Emergency obstetric hysterectomy at two tertiary centers: a clinical analysis of 11 years experience. Clin Exp Obstet Gynecol. 2010;37:117-9. X-4, X-5. [pmid: 21077501].
1763 Varras M, Vlachakos N, Akrivis C, et al. Malignant gastrointestinal stromal tumor presenting with hemoperitoneum in puerperium: report of a case with review of the literature. World J Surg Oncol. 2010;8:95. X-1, X-3, X-4. [pmid: 21054898].
1764 Visalyaputra S, Prechapanich J, Suwanvichai S, et al. Intravenous nitroglycerin for controlled cord traction in the management of retained placenta. Int J Gynaecol Obstet. Feb. 2010;112:103-6. X-2, X-4, X-5. [pmid: 21144515].
1765 Vivio D, Fullerton JT, Forman R, et al. Integration of the practice of active management of the third stage of labor within training and service implementation programming in Zambia. J Midwifery Womens Health. Sep-Oct. 2010;55:447-54. X-2, X-3, X-4. [pmid: 20732666].
1766 Waheed F, Majeed T, Mahmood Z, et al. Emergency obstetrical hysterectomy: Frequency indications and maternal outcome. Medical Forum Monthly. December. 2010;21:24-8. X-2, X-4.
1767 Wang BS, Zhou LF, Coulter D, et al. Effects of caesarean section on maternal health in low risk nulliparous women: a prospective matched cohort study in Shanghai, China. BMC Pregnancy Childbirth. 2010;10:78. X-2, X-4. [pmid: 21122153].
1768 Waters N, Chachan S, Morton K, et al. Laparoscopic repair of vaginal vault dehiscence after postpartum hysterectomy. Gynecological Surgery. September. 2010;7:275-7. X-1.
1769 Webster VJ, Stewart R, Stewart P. A survey of interventional radiology for the management of obstetric haemorrhage in the United Kingdom. Int J Obstet Anesth. Jul. 2010;19:278-81. X-3, X-4. [pmid: 20605435].
1770 Weiniger CF, Ivri S, Ioscovich A, et al. Obstetric anesthesia units in Israel: a national questionnaire-based survey. Int J Obstet Anesth. Oct. 2010;19:410-6. X-3, X-4. [pmid: 20708921].
1771 Wickham S. Research unwrapped. Practising Midwife. 2010;13:31-2. X-1. [pmid: 20302052].
1772 Widmer M, Blum J, Hofmeyr GJ, et al. Misoprostol as an adjunct to standard uterotonics for treatment of post-partum haemorrhage: a multicentre, double-blind randomised trial. Lancet. May. 22. 2010;375:1808-13. X-2, X-4, X-5. [pmid: 20494730].
1773 Wikland M, Hardarson T, Hillensjo T, et al. Obstetric outcomes after transfer of vitrified blastocysts. Hum Reprod. Jul. 2010;25:1699-707. X-3, X-4. [pmid: 20472913].
1774 Winikoff B, Dabash R, Durocher J, et al. Treatment of post-partum haemorrhage with sublingual misoprostol versus oxytocin in women not exposed to oxytocin during labour: a double-blind, randomised, non-inferiority trial. Lancet. Jan. 16. 2010;375:210-6. X-2, X-4, X-5. [pmid: 20060161].
1775 Woiski MD, Hermens RP, Middeldorp JM, et al. Haemorrhagia post partum; an implementation study on the evidence-based guideline of the Dutch Society of Obstetrics and Gynaecology (NVOG) and the MOET (Managing Obstetric Emergencies and Trauma-course) instructions; the Fluxim study. BMC Pregnancy Childbirth. 2010;10:5. X-4, X-5. [pmid: 20102607].
1776 Yogev Y, Melamed N, Bardin R, et al. Pregnancy outcome at extremely advanced maternal age. Am J Obstet Gynecol. Dec. 2010;203:558 e1-7. X-4. [pmid: 20965486].
1777 Yong-Hwa Chae MD, Yun-Young Kim MD, Gye-Hyeong An MD, Jang-Hwan Woo MD, Jin-Hoon Chung MD, June-Seek Choi MD, Hyun-Mee Ryu MD, Moon-Young Kim MD, Jae-Hyug Yang MD, Min-Hyoung Kim MD. Treatment outcome of uterine compression sutures for massive postpartum hemorrhage. Korean J Obstet Gynecol. 2010;53(9):769-77. X-6.
1778 Zelop CM. Postpartum hemorrhage: becoming more evidence-based. Obstet Gynecol. Jan. 2010;117:3-5. X-1, X-4, X-5. [pmid: 21173639].
1779 Zhang WH, Deneux-Tharaux C, Brocklehurst P, et al. Effect of a collector bag for measurement of postpartum blood loss after vaginal delivery: cluster randomised trial in 13 European countries. BMJ. 2010;340:c293. X-2, X-4. [pmid: 20123835].
1780 Zheng J, Xiong X, Ma Q, et al. A new uterine compression suture for postpartum haemorrhage with atony. BJOG. Feb. 2010;118:370-4. X-2, X-5. [pmid: 21176088].
1781 MIDIRS update. Essentially MIDIRS. 2011;2:5-16. X-1, X-4.
1782 Top 30 medicines to save mothers and children. Essentially MIDIRS. 2011;2:24. X-1, X-4.
1783 Abasiattai AM, Utuk NM, Udoma EJ, et al. Grandmultiparity: outcome of delivery in a tertiary hospital in southern Nigeria. Niger J Med. Jul-Sep. 2011;20:345-8. X-2, X-4. [pmid: 21970216].
1784 Abha S, Pratibha R. A comparative study of feto-maternal outcome in instrumental vaginal delivery. Journal of Obstetrics and Gynecology of India. December. 2011;61:663-6. X-2, X-4. [pmid: 23204687].
1785 Addo VN. Body Mass Index, Weight Gain during Pregnancy and Obstetric Outcomes. Ghana Med J. Jun. 2011;44:64-9. X-2, X-4. [pmid: 21327006].
1786 Ade-Conde JA, Alabi O, Higgins S, et al. Maternal post natal hospital readmission-trends and association with mode of delivery. Ir Med J. Jan. 2011;104:17-20. X-2, X-4, X-5. [pmid: 21387880].
1787 Agarwal N, Deinde O, Willmott F, et al. A case series of interventional radiology in postpartum haemorrhage. J Obstet Gynaecol. Aug. 2011;31:499-502. X-4, X-5. [pmid: 21823848].
1788 Agrawal R, Legge F, Pollard K, et al. Massive secondary postpartum haemorrhage managed with insertion of a bakri balloon catheter after surgical evacuation of the uterus. South African Journal of Obstetrics and Gynaecology. 2011;17:36-7. X-2, X-4, X-5.
1789 Al Riyami N, Hui D, Herer E, et al. Uterine compression sutures as an effective treatment for postpartum hemorrhage: case series. AJP Rep. Sep. 2011;1:47-52. X-2, X-5. [pmid: 23705085].
1790 Albayrak M, Ozdemir I, Koc O, et al. Post-partum haemorrhage from the lower uterine segment secondary to placenta praevia/accreta: successful conservative management with Foley balloon tamponade. Aust N Z J Obstet Gynaecol. Aug. 2011;51:377-80. X-2, X-4, X-5. [pmid: 21806571].
1791 Ali A, Ali MA, Ali MU, et al. Hospital outcomes of obstetrical-related acute renal failure in a tertiary care teaching hospital. Ren Fail. 2011;33:285-90. X-2, X-3. [pmid: 21401352].
1792 Alouini S, Coly S, Megier P, et al. Multiple square sutures for postpartum hemorrhage: results and hysteroscopic assessment. Am J Obstet Gynecol. Oct. 2011;205:335 e1-6. X-4, X-5. [pmid: 21722873].
1793 Althabe F, Mazzoni A, Cafferata ML, et al. Using Uniject to increase the use of prophylactic oxytocin for management of the third stage of labor in Latin America. Int J Gynaecol Obstet. Aug. 2011;114:184-9. X-2, X-4, X-5. [pmid: 21693378].
1794 Amaral E, Souza JP, Surita F, et al. A population-based surveillance study on severe acute maternal morbidity (near-miss) and adverse perinatal outcomes in Campinas, Brazil: the Vigimoma Project. BMC Pregnancy Childbirth. 2011;11:9. X-2, X-4. [pmid: 21255453].
1795 Amat L, Sabria J, Martinez E, et al. Cord blood collection for banking and the risk of maternal hemorrhage. Acta Obstet Gynecol Scand. Sep. 2011;90:1043-5. X-4. [pmid: 21564030].
1796 Andreatta P, Debpuur D, Danquah A, et al. Using cell phones to collect postpartum hemorrhage outcome data in rural Ghana. Int J Gynaecol Obstet. May. 2011;113:148-51. X-2, X-4. [pmid: 21420086].
1797 Andreatta P, Gans-Larty F, Debpuur D, et al. Evaluation of simulation-based training on the ability of birth attendants to correctly perform bimanual compression as obstetric first aid. Int J Nurs Stud. Oct. 2011;48:1275-80. X-2. [pmid: 21450290].
1798 Angulo Y. A Multidisciplinary Approach to a Hysterectomy: A Case Study. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2011;40:S125-6. X-1, X-2, X-4, X-5.
1799 Armstrong S, Fernando R, Ashpole K, et al. Assessment of coagulation in the obstetric population using ROTEM(R) thromboelastometry. Int J Obstet Anesth. Oct. 2011;20:293-8. X-4, X-5. [pmid: 21835606].
1800 Arrowsmith S, Wray S, Quenby S. Maternal obesity and labour complications following induction of labour in prolonged pregnancy. BJOG. Apr. 2011;118:578-88. X-4. [pmid: 21265999].
1801 Asghar S, Naz U, Awan F, et al. Obstetric outcome of iron deficiency anemia. 2011;5:303-6. X-2, X-4.
1802 Askar AA, Ismail MT, El-Ezz AA, et al. Carbetocin versus syntometrine in the management of third stage of labor following vaginal delivery. Arch Gynecol Obstet. Dec. 2011;284:1359-65. X-2, X-4. [pmid: 21336835].
1803 Awan N, Bennett MJ, Walters WA. Emergency peripartum hysterectomy: a 10-year review at the Royal Hospital for Women, Sydney. Aust N Z J Obstet Gynaecol. Jun. 2011;51:210-5. X-4, X-5. [pmid: 21631438].
1804 Baduni N, Sanwal MK, Jain A. Acute pulmonary edema after intramyometrial prostodin. Journal of Anaesthesiology Clinical Pharmacology. April-June. 2011;27:275-7. X-1, X-2, X-5.
1805 Barroso F, Allard S, Kahan BC, et al. Prevalence of maternal anaemia and its predictors: a multi-centre study. Eur J Obstet Gynecol Reprod Biol. Nov. 2011;159:99-105. X-3. [pmid: 21890259].
1806 Basak S, Kanungo S, Majhi C. Symphysiotomy: Is it obsolete?. J Obstet Gynaecol Res. Jul. 2011;37:770-4. X-3, X-4. [pmid: 21395902].
1807 Bates K. Emergency room. Practising Midwife. 2011;14:13-6. X-1, X-3, X-4.
1808 Begley C, Devane D, Clarke M, et al. Comparison of midwife-led and consultant-led care of healthy women at low risk of childbirth complications in the Republic of Ireland: a randomised trial. BMC Pregnancy Childbirth. 2011;11:85. X-3, X-4. [pmid: 22035427].
1809 Begley CM, Gyte GM, Devane D, et al. Active versus expectant management for women in the third stage of labour. Cochrane Database Syst Rev. 2011. CD007412. X-1, X-4. [pmid: 22071837].
1810 Belghiti J, Kayem G, Dupont C, et al. Oxytocin during labour and risk of severe postpartum haemorrhage: a population-based, cohort-nested case-control study. BMJ Open. 2011;1:e000514. X-4. [pmid: 22189353].
1811 Beltman J, VDA T, VANL L, et al. Beyond maternal mortality: obstetric hemorrhage in a Malawian district. Acta Obstet Gynecol Scand. Dec. 2011;90:1423-7. X-2, X-4. [pmid: 21682698].
1812 Bhagat M, Salhan S, Sarda N, et al. Spontaneous pregnancy in a patient with sheehan's syndrome. JK Science. Jan-Mar. 2011;13:33-4. X-1.
1813 Bian C, Wei Q, Liu X. Influence of heart-valve replacement of warfarin anticoagulant therapy on perinatal outcomes. Arch Gynecol Obstet. Feb. 2011;285:347-51. X-2, X-4, X-5. [pmid: 21766176].
1814 Blanc J, Courbiere B, Desbriere R, et al. Is uterine-sparing surgical management of persistent postpartum hemorrhage truly a fertility-sparing technique?. Fertil Steril. Jun. 30. 2011;95:2503-6. X-4, X-5. [pmid: 21315337].
1815 Blanchette H. The rising cesarean delivery rate in America: what are the consequences?. Obstet Gynecol. Sep. 2011;118:687-90. X-1. [pmid: 21860302].
1816 Blomberg M. Maternal obesity and risk of postpartum hemorrhage. Obstet Gynecol. Sep. 2011;118:561-8. X-4. [pmid: 21860284].
1817 Bombelli FM, Candotti GP, Cardani A, et al. Our first experience of a day-long simulation based team training session for managing postpartum haemorrhage. 2011;23:90-5. X-1, X-3.
1818 Bonnet MP, Deneux-Tharaux C, Bouvier-Colle MH. Critical care and transfusion management in maternal deaths from postpartum haemorrhage. Eur J Obstet Gynecol Reprod Biol. Oct. 2011;158:183-8. X-4, X-5. [pmid: 21632172].
1819 Bonney EA, Myers JE. Caesarean section: Techniques and complications. Obstetrics, Gynaecology and Reproductive Medicine. April. 2011;21:97-102. X-1.
1820 Borthen I, Eide MG, Daltveit AK, et al. Obstetric outcome in women with epilepsy: a hospital-based, retrospective study. BJOG. Jul. 2011;118:956-65. X-4, X-5. [pmid: 21557799].
1821 Boyar IH, Boynukalin FK, Boyar N, et al. B-Lynch suture technique to control postpartum hemorrhage in a patient with mullerian anomaly. J Turk Ger Gynecol Assoc. 2011;12:47-9. X-2, X-3, X-4. [pmid: 24591957].
1822 Bros S, Chabrot P, Kastler A, et al. Recurrent bleeding within 24 hours after uterine artery embolization for severe postpartum hemorrhage: are there predictive factors?. Cardiovasc Intervent Radiol. Jun. 2011;35:508-14. X-5. [pmid: 21614439].
1823 Bulle B, Gellman C, Farrell T, et al. “We need all the blood you have got”: enhancing collaboration among service providers. Women & Birth. 2011;24:S35-6. X-1, X-4, X-5.
1824 Buowari YD. Training workshop for traditional birth attendants at Aliero, Kebbi State, Nigeria; a community development service at Aliero, Kebbi State, Nigeria. Internet Journal of Tropical Medicine. 2011;7. X-1, X-2.
1825 Butwick A, Hilton G, Carvalho B. Non-invasive haemoglobin measurement in patients undergoing elective Caesarean section. Br J Anaesth. Feb. 2011;108:271-7. X-4, X-5. [pmid: 22116296].
1826 Byams VR, Kouides PA, Kulkarni R, et al. Surveillance of female patients with inherited bleeding disorders in United States Haemophilia Treatment Centres. Haemophilia. Jul. Suppl 1. 2011;17:6-13. X-1, X-4. [pmid: 21692922].
1827 Cabacungan ET, Ngui EM, McGinley EL. Racial/ethnic disparities in maternal morbidities: a statewide study of labor and delivery hospitalizations in Wisconsin. Matern Child Health J. Oct. 2011;16:1455-67. X-4. [pmid: 22105738].
1828 Cavazza S, Rainaldi MP, Adduci A, et al. Thromboprophylaxis following cesarean delivery: one site prospective pilot study to evaluate the application of a risk score model. Thromb Res. Jan. 2011;129:28-31. X-4, X-5. [pmid: 21840574].
1829 Chambers J, Tuson A. Scratching can reveal more than just an itch. Practising Midwife. 2011;14:30-3. X-1. [pmid: 22132539].
1830 Chang CC, Wang IT, Chen YH, et al. Anesthetic management as a risk factor for postpartum hemorrhage after cesarean deliveries. Am J Obstet Gynecol. Nov. 2011;205:462 e1-7. X-2, X-4. [pmid: 21939956].
1831 Chantrapitak W, Srijuntuek K, Wattanaluangarun R. The efficacy of lower uterine segment compression for prevention of early postpartum hemorrhage after vaginal delivery. J Med Assoc Thai. Jun. 2011;94:649-56. X-2, X-4. [pmid: 21696071].
1832 Chaudhuri P, Biswas J, Mandal A. Sublingual misoprostol versus intramuscular oxytocin for prevention of postpartum hemorrhage in low-risk women. Int J Gynaecol Obstet. Feb. 2011;116:138-42. X-2, X-4, X-5. [pmid: 22100204].
1833 Chelmow D. Postpartum haemorrhage: prevention. Clin Evid (Online). 2011;2011. X-1, X-3. [pmid: 21463537].
1834 Chen JS, Roberts CL, Simpson JM, et al. Use of hospitalisation history (lookback) to determine prevalence of chronic diseases: impact on modelling of risk factors for haemorrhage in pregnancy. BMC Med Res Methodol. 2011;11:68. X-4, X-5. [pmid: 21575257].
1835 Chibber R, Al-Hijji J, Fouda M, et al. A 26-year review of emergency peripartum hysterectomy in a tertiary teaching hospital in Kuwait - years 1983-2011. Med Princ Pract. 2011;21:217-22. X-2, X-5. [pmid: 22179393].
1836 Chitra TV, Seetha P. Pseudoaneurysm of uterine artery: A rare cause of secondary postpartum hemorrhage. India. Federation of Obstetric and Gynecologycal Societies of India. (Model Residency 605, Bapurao Jagtap Marg, Jacob Circle, Mahalaxmi East, Mumbai 400 011, India). 2011. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed10&NEWS=N&AN=2012385483. Accessed on (Chitra, Seetha) Department of Obstetrics and Gynecology, P.S.G. Institute of Medical Sciences and Research, Peelamedu, Coimbatore 641 004, Tamilnadu, India 61.
1837 Chowdhury S, Hussain MA. Maternal complications in twin pregnancies. Mymensingh Med J. Jan. 2011;20:83-7. X-2, X-4. [pmid: 21240168].
1838 Christopoulos P, Hassiakos D, Tsitoura A, et al. Obstetric hysterectomy: a review of cases over 16 years. J Obstet Gynaecol. 2011;31:139-41. X-5. [pmid: 21281029].
1839 Chunilal SD, Chan WS. Critical illness in obstetric patients: Venous thromboembolism in pregnancy. Current Women's Health Reviews. June. 2011;7:189-202. X-1.
1840 Coelius RL, Stenson A, Morris JL, et al. The tibetan uterotonic zhi byed 11: mechanisms of action, efficacy, and historical use for postpartum hemorrhage. Evid Based Complement Alternat Med. 2011;2012:794164. X-2, X-3. [pmid: 21822444].
1841 Cohen Y, Michaan N, Cohen A, et al. Umbilical cord blood collection carry increased maternal bleeding risk during cesarean section. J Matern Fetal Neonatal Med. Sep. 2011;25:1549-51. X-4. [pmid: 22010864].
1842 Collins D. Woman alleges postpartum hysterectomy was unnecessary. Contemporary OB/GYN. 2011;56:18. X-1, X-4, X-5.
1843 Cuckson C, Germain S. Hyperemesis, gastro-intestinal and liver disorders in pregnancy. Obstetrics, Gynaecology and Reproductive Medicine. March. 2011;21:80-5. X-1.
1844 Dasari P, Maurya DK, Mascarenhas M. Uterine artery pseudoaneurysm: a rare cause of secondary postpartum haemorrhage following caesarean section. BMJ Case Reports. 2011. X-2, X-4, X-5.
1845 Davis D, Herbison P, Baddock S, et al. Comparing active and physiological management of third stage of labour in a cohort of low risk women in the care of midwives in New Zealand. Women & Birth. 2011;24:S27-S. X-4, X-5.
1846 De Bonis M, Torricelli M, Leoni L, et al. Carbetocin versus oxytocin after caesarean section: similar efficacy but reduced pain perception in women with high risk of postpartum haemorrhage. J Matern Fetal Neonatal Med. Jun. 2011;25:732-5. X-3, X-4. [pmid: 21761999].
1847 de Lloyd L, Bovington R, Kaye A, et al. Standard haemostatic tests following major obstetric haemorrhage. Int J Obstet Anesth. Apr. 2011;20:135-41. X-4, X-5. [pmid: 21439811].
1848 de Vogel J, Heydanus R, Mulders AG, et al. Lifesaving intraosseous access in a patient with a massive obstetric hemorrhage. AJP Rep. Dec. 2011;1:119-22. X-4, X-5. [pmid: 23705100].
1849 De Wee EM, Knol HM, Mauser-Bunschoten EP, et al. Gynaecological and obstetric bleeding in moderate and severe von Willebrand disease. Thromb Haemost. Nov. 2011;106:885-92. X-4. [pmid: 21947221].
1850 Della Torre M, Kilpatrick SJ, Hibbard JU, et al. Assessing preventability for obstetric hemorrhage. Am J Perinatol. Dec. 2011;28:753-60. X-4, X-5. [pmid: 21698554].
1851 Demirci O, Tugrul AS, Yilmaz E, et al. Emergency peripartum hysterectomy in a tertiary obstetric center: nine years evaluation. J Obstet Gynaecol Res. Aug. 2011;37:1054-60. X-2. [pmid: 21481094].
1852 Diadhiou M, Dieng T, Ortiz C, et al. Introduction of misoprostol for prevention of postpartum hemorrhage at the community level in Senegal. Int J Gynaecol Obstet. Dec. 2011;115:251-5. X-2, X-3, X-4. [pmid: 21982859].
1853 Diemert A, Ortmeyer G, Hollwitz B, et al. The combination of intrauterine balloon tamponade and the B-Lynch procedure for the treatment of severe postpartum hemorrhage. Am J Obstet Gynecol. Jan. 2011;206:65 e1-4. X-5. [pmid: 22000893].
1854 Dixon L, Tracy SK, Guilliland K, et al. Outcomes of physiological and active third stage labour care amongst women in New Zealand. Midwifery. Jan. 2011;29:67-74. X-4, X-5. [pmid: 22188999].
1855 Dong Y. Effects of carboprost on prevention of hemorrhage after induced labor with scarred uterus. Journal of Shanghai Jiaotong University (Medical Science). 2011;31:1212-5. X-2.
1856 Dongol AS, Shrestha A, Chawla CD. Post partum haemorrhage: prevalence, morbidity and management pattern in Dhulikhel Hospital. Kathmandu Univ Med J (KUMJ). Apr-Jun. 2011;8:212-5. X-2. [pmid: 21209538].
1857 Duncan L, Kannon ER, Hart G, et al. TRICKS OF THE TRADE. Midwifery Today. 2011:7. X-1, X-4.
1858 Easmin S, Nahar K, Jahan MK, et al. Intra-vaginal use of misoprostol for induction of labour in intrauterine death. Mymensingh Med J. Oct. 2011;20:566-9. X-2, X-4. [pmid: 22081171].
1859 Edanaga M, Azumaguchi R, Ohsuda M, et al. A suspected case of amniotic fluid embolism rescued by ABO-incompatible blood transfusion and operation for a massive obstetric hemorrhage. Anesthesia and Resuscitation. September. 2011;47:73-5. X-4.
1860 Edwards N. Third Stage Reviewed. AIMS Journal. 2011;23:19-21. X-1, X-4.
1861 Ekabua JE, Ekabua KJ, Odusolu P, et al. Awareness of birth preparedness and complication readiness in southeastern Nigeria. ISRN Obstetrics and Gynecology. 2011. X-2, X-3, X-4.
1862 El Fekih C, Mourali M, Ouerdiane N, et al. Maternal and fetal outcomes of large fetus delivery: a comparative study. Tunis Med. Jun. 2011;89:553-6. X-2, X-4. [pmid: 21681719].
1863 Elati A, Elmahaishi MS, Elmahaishi MO, et al. The effect of misoprostol on postpartum contractions: a randomised comparison of three sublingual doses. BJOG. Mar. 2011;118:466-73. X-2, X-3, X-4. [pmid: 21199290].
1864 Elati A, Weeks A. Misoprostol for management of postpartum haemorrhage. BMJ: British Medical Journal (Overseas & Retired Doctors Edition). 2011;343:330-1. X-1, X-4, X-5.
1865 Elmir R. Reaching for the stars: Implementing a model of care to support women who experience emergency hysterectomy following severe postpartum haemorrhage. Women & Birth. 2011;24:S28-S. X-1, X-4, X-5.
1866 Elmir R, Schmied V, Jackson D, et al. Interviewing people about potentially sensitive topics. Nurse Res. 2011;19:12-6. X-1. [pmid: 22128582].
1867 Elmir R, Schmied V, Jackson D, et al. Between life and death: women's experiences of coming close to death, and surviving a severe postpartum haemorrhage and emergency hysterectomy. Midwifery. Apr. 2011;28:228-35. X-4, X-5. [pmid: 21251734].
1868 Elmir R, Schmied V, Wilkes L, et al. Separation, failure and temporary relinquishment: women's experiences of early mothering in the context of emergency hysterectomy. J Clin Nurs. Apr. 2011;21:1119-27. X-5. [pmid: 22176681].
1869 Elsedeek MS. Puerperal and menstrual bleeding patterns with different types of contraceptive device fitted during elective cesarean delivery. Int J Gynaecol Obstet. Jan. 2011;116:31-4. X-3, X-4. [pmid: 22036512].
1870 Eskild A, Vatten LJ. Placental weight and excess postpartum haemorrhage: a population study of 308,717 pregnancies. BJOG. Aug. 2011;118:1120-5. X-4. [pmid: 21585637].
1871 Faksh A, Wax JR, Lucas FL, et al. Preterm premature rupture of membranes >/= 32 weeks' gestation: impact of revised practice guidelines. Am J Obstet Gynecol. Oct. 2011;205:340 e1-5. X-3, X-4. [pmid: 21784402].
1872 Fatemeh F, Zohreh S, Abbas MG, et al. Maternal haemodynamic effects of oxytocin bolus or infusion in the third stage of labour. Pakistan Journal of Medical Sciences. April - June. 2011;27:656-9. X-2, X-3, X-4.
1873 Fathalla MM, Youssif MM, Meyer C, et al. Nonatonic obstetric haemorrhage: effectiveness of the nonpneumatic antishock garment in egypt. ISRN Obstet Gynecol. 2011;2011:179349. X-2. [pmid: 21845226].
1874 Fathalla MMF, Youssif MM, Meyer C, et al. Nonatonic obstetric haemorrhage: Effectiveness of the nonpneumatic antishock garment in Egypt. United States. Hindawi Publishing Corporation. (410 Park Avenue, 15th Floor, 287 pmb, New York NY 10022, United States). 2011. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed10&NEWS=N&AN=2012187456. Accessed on (Fathalla) Department of Obstetrics and Gynaecology, Faculty of Medicine, Assiut University, P.O. Box 30, Assiut, Egypt.
1875 Fawad A, Naz H, Islam A, et al. Maternal mortality in a tertiary care hospital. J Ayub Med Coll Abbottabad. Jan-Mar. 2011;23:92-5. X-2, X-3, X-4. [pmid: 22830157].
1876 Fayyaz S, Faiz NR, Rahim R, et al. Frequency of postpartum haemorrhage in maternal mortality in a tertiary care hospital. Journal of Postgraduate Medical Institute. 2011;25:257-62. X-2, X-4.
1877 Ford JB, Algert CS, Kok C, et al. Hospital data reporting on postpartum hemorrhage: under-estimates recurrence and over-estimates the contribution of uterine atony. Matern Child Health J. Oct. 2011;16:1542-8. X-4, X-5. [pmid: 22109815].
1878 Foroughipour A, Firuzeh F, Ghahiri A, et al. The effect of perineal control with hands-on and hand-poised methods on perineal trauma and delivery outcome. Journal of Research in Medical Sciences. 2011;16. X-2, X-3, X-4.
1879 Fox A. Challenges: perineal wound care in the community. World of Irish Nursing & Midwifery. 2011;19:48-50. X-1.
1880 Fung TY, Sahota DS, Lau TK, et al. Placental site in the second trimester of pregnancy and its association with subsequent obstetric outcome. Prenat Diagn. Jun. 2011;31:548-54. X-4. [pmid: 21413044].
1881 Ge J, Liao H, Duan L, et al. Uterine packing during cesarean section in the management of intractable hemorrhage in central placenta previa. Arch Gynecol Obstet. Feb. 2011;285:285-9. X-2, X-4. [pmid: 21647597].
1882 Gezginc K, Yazici F, Koyuncu T. Results of hysterosalpingogram in women with previous B-Lynch suture. Int J Gynaecol Obstet. Oct. 2011;115:68-9. X-2, X-4, X-5. [pmid: 21767836].
1883 Ghaffar N, Rahim M, Chishti AT, et al. Insertion of intrauterine contraceptive device (IUCD) at caesarean section after the delivery of placenta: An experience with 60 cases. Medical Forum Monthly. June. 2011;22:24-6. X-2, X-3, X-4.
1884 Ghazal-Aswad S, Badrinath P, Sidky I, et al. Confidential enquiries into maternal mortality in the United Arab Emirates: a feasibility study. J Obstet Gynaecol Res. Mar. 2011;37:209-14. X-2, X-4. [pmid: 21314803].
1885 Girija S, Manjunath AP. A randomized controlled trial comparing low dose vaginal misoprostol and dinoprostone gel for labor induction. Journal of Obstetrics and Gynecology of India. April. 2011;61:153-60. X-2, X-3, X-4.
1886 Gungorduk K, Asicioglu O, Yildirim G, et al. Is post-partum oxygen inhalation useful for reducing vaginal blood loss during the third and fourth stages of labour? A randomised controlled study. Aust N Z J Obstet Gynaecol. Oct. 2011;51:441-5. X-4. [pmid: 21806580].
1887 Gupta S, Naithani U, Doshi V, et al. Obstetric critical care: A prospective analysis of clinical characteristics, predictability, and fetomaternal outcome in a new dedicated obstetric intensive care unit. Indian J Anaesth. Mar. 2011;55:146-53. X-2, X-4, X-5. [pmid: 21712871].
1888 Harara R, Hanafy S, Zidan MS, et al. Intraumbilical injection of three different uterotonics in the management of retained placenta. J Obstet Gynaecol Res. Sep. 2011;37:1203-7. X-2, X-4. [pmid: 21518127].
1889 Hashima EN, Nahar S, Al Mamun M, et al. Oral misoprostol for preventing postpartum haemorrhage in home births in rural Bangladesh: how effective is it?. Glob Health Action. 2011;4. X-2, X-4. [pmid: 21845143].
1890 Higgins L, Mechery J, Tomlinson AJ. Does carbetocin for prevention of postpartum haemorrhage at caesarean section provide clinical or financial benefit compared with oxytocin?. J Obstet Gynaecol. Nov. 2011;31:732-9. X-1, X-4. [pmid: 22085065].
1891 Hofmeyr GJ. Oral misoprostol reduces the risk of postpartum haemorrhage in home births assisted by trained traditional birth attendants in Pakistan. Evid Based Med. Dec. 2011;16:180-1. X-1, X-2. [pmid: 21555320].
1892 Honiden S, Abdel-Razeq SS, Siegel MD. The management of the critically ill obstetric patient. J Intensive Care Med. Mar-Apr. 2011;28:93-106. X-1. [pmid: 21841145].
1893 Horng HC, Hu WM, Tseng HS, et al. Uterine arterial embolization in the management of severe post-partum hemorrhage: a successful rescue method to avoid peripartum hysterectomy. J Chin Med Assoc. Jun. 2011;74:255-8. X-2, X-4, X-5. [pmid: 21621168].
1894 Hossain N, Shah T, Khan N, et al. Transfusion of blood and blood component therapy for postpartum haemorrhage at a tertiary referral center. J Pak Med Assoc. Apr. 2011;61:343-5. X-2, X-4. [pmid: 21465969].
1895 Howarth L, Glanville T. Management of a pregnancy complicated by type III spinal muscular atrophy. BMJ Case Reports. 2011. X-1, X-4.
1896 Howarth LA, Sherliker S. Massive obstetric haemorrhage following removal of a cervical suture. BMJ Case Reports. 2011. X-1, X-2, X-4, X-5.
1897 Huber AW, Raio L, Alberio L, et al. Recombinant human factor VIIa prevents hysterectomy in severe postpartum hemorrhage: single center study. J Perinat Med. Jan. 2011;40:43-9. X-2, X-5. [pmid: 22017328].
1898 Ishii T, Sawada K, Koyama S, et al. Balloon tamponade during cesarean section is useful for severe post-partum hemorrhage due to placenta previa. J Obstet Gynaecol Res. Jan. 2011;38:102-7. X-4, X-5. [pmid: 21827577].
1899 Islam A, Ehsan A, Arif S, et al. Evaluating trial of scar in patients with a history of caesarean section. North American Journal of Medical Sciences. April. 2011;3:201-5. X-2, X-4. [pmid: 22540092].
1900 Janakiraman V, Lazar J, Joynt KE, et al. Hospital volume, provider volume, and complications after childbirth in U.S. hospitals. Obstet Gynecol. Sep. 2011;118:521-7. X-4, X-5. [pmid: 21826039].
1901 Javaid S, Yasmeen T, Rafique S, et al. Postpartum and emergency caesarean hysterectomy. 2011;5:239-42. X-2.
1902 Jeong H, Lee S, Jeong C, et al. Inverted takotsubo-like left ventricular dysfunction with pulmonary oedema developed after caesarean delivery complicated by massive haemorrhage in a severe preeclamptic parturient with a prolonged painful labour. Case Rep Anesthesiol. 2011;2011:164720. X-1. [pmid: 22606381].
1903 Johnson SN, Khalid S, Varadkar S, et al. Quality of care in the management of major obstetric haemorrhage. Ir Med J. Apr. 2011;104:119-21. X-4, X-5. [pmid: 21675096].
1904 Jung HN, Shin SW, Choi SJ, et al. Uterine artery embolization for emergent management of postpartum hemorrhage associated with placenta accreta. Acta Radiol. Jul. 1. 2011;52:638-42. X-4, X-5. [pmid: 21498276].
1905 Kaingu CK, Oduma JA, Kanui TI. Practices of traditional birth attendants in Machakos District, kenya. J Ethnopharmacol. Sep. 1. 2011;137:495-502. X-2, X-4. [pmid: 21679761].
1906 Kalina M, Tinkoff G, Fulda G. Massive postpartum hemorrhage: recombinant factor VIIa use is safe but not effective. Del Med J. Apr. 2011;83:109-13. X-4, X-5. [pmid: 21675158].
1907 Kanematsu M, Watanabe H, Kondo H, et al. Postpartum hemorrhage in coagulopathic patients: preliminary experience with uterine arterial embolization with N-butyl cyanoacrylate. J Vasc Interv Radiol. Dec. 2011;22:1773-6. X-5. [pmid: 22115582].
1908 Kaplan AI. Patient exsanguinates after high-risk delivery. Contemporary OB/GYN. 2011;56:27-31. X-1, X-4.
1909 Kenneth LA. Uterine artery pseudoaneurysm as a cause of secondary postpartum haemorrhage following a caesarean section. Obstetrics and Gynaecology Forum. October. 2011;21:31-4. X-2, X-5.
1910 Keriakos R, Chaudhuri S. Operative interventions in the management of major postpartum haemorrhage. J Obstet Gynaecol. Jan. 2011;32:14-25. X-4, X-5. [pmid: 22185528].
1911 Keriakos R, Chaudhuri SR. Managing Major Postpartum Haemorrhage following Acute Uterine Inversion with Rusch Balloon Catheter. Case Rep Crit Care. 2011;2011:541479. X-5. [pmid: 24826322].
1912 Kesmodel US, Jolving LR. Measuring and improving quality in obstetrics--the implementation of national indicators in Denmark. Acta Obstet Gynecol Scand. Apr. 2011;90:295-304. X-1, X-3, X-4. [pmid: 21306336].
1913 Khalil MI, Al-Dohami H, Aldahish MM. A method to improve the effectiveness of the Bakri balloon for management of postpartum hemorrhage at cesarean. Int J Gynaecol Obstet. Nov. 2011;115:198-200. X-2, X-4, X-5. [pmid: 21924420].
1914 Khatoon A, Hasnny SF, Ansari J. B-Lynch brace sutures for the treatment of major primary post partum haemorrhage: An experience at Abbasi Shaheed Hospital, Karachi. Medical Channel. 2011;17:36-8. X-2.
1915 Knight KM, Pressman EK, Hackney DN, et al. Perinatal outcomes in type 2 diabetic patients compared with non-diabetic patients matched by body mass index. J Matern Fetal Neonatal Med. Jun. 2011;25:611-5. X-4. [pmid: 21728737].
1916 Knol HM, Voskuilen MA, Holterman F, et al. Reproductive choices and obstetrical experience in Dutch carriers of haemophilia A and B. Haemophilia. Mar. 2011;17:233-6. X-4. [pmid: 21332882].
1917 Kobayashi T, Nakabayashi M, Yoshioka A, et al. Recombinant activated factor VII (rFVIIa/NovoSeven(R)) in the management of severe postpartum haemorrhage: initial report of a multicentre case series in Japan. Int J Hematol. Jan. 2011;95:57-63. X-4, X-5. [pmid: 22160834].
1918 Koyama S, Tomimatsu T, Kanagawa T, et al. The amnioscope strikes back as a useful device for pinhole amniotomy in the management of polyhydramnios. AJP Rep. Dec. 2011;1:99-104. X-1, X-3, X-4. [pmid: 23705096].
1919 Kramer MS, Dahhou M, Vallerand D, et al. Risk factors for postpartum hemorrhage: can we explain the recent temporal increase?. J Obstet Gynaecol Can. Aug. 2011;33:810-9. X-4. [pmid: 21846436].
1920 Krishna A, Chandraharan E. Management of massive obstetric haemorrhage. Current Women's Health Reviews. June. 2011;7:136-42. X-1.
1921 Krishna H, Chava M, Jasmine N, et al. Patients with postpartum hemorrhage admitted in intensive care unit: Patient condition, interventions, and outcome. J Anaesthesiol Clin Pharmacol. Apr. 2011;27:192-4. X-2, X-5. [pmid: 21772678].
1922 Lamba J, Gupta S. Role of emergency hysterectomy in modern obstetrics. JK Science. January-March. 2011;14:22-4. X-4.
1923 Lamxay V, de Boer HJ, Bjork L. Traditions and plant use during pregnancy, childbirth and postpartum recovery by the Kry ethnic group in Lao PDR. J Ethnobiol Ethnomed. 2011;7:14. X-2, X-3, X-4. [pmid: 21569234].
1924 Lapinsky SE. Acute respiratory failure in obstetric patients. Current Women's Health Reviews. June. 2011;7:143-50. X-1.
1925 Larsson C, Saltvedt S, Wiklund I, et al. Planned vaginal delivery versus planned caesarean section: short-term medical outcome analyzed according to intended mode of delivery. J Obstet Gynaecol Can. Aug. 2011;33:796-802. X-4, X-5. [pmid: 21846434].
1926 Laway BA, Mir SA, Dar MI, et al. Sheehan's syndrome with central diabetes insipidus. Arq Bras Endocrinol Metabol. Mar. 2011;55:171-4. X-1, X-2, X-4, X-5. [pmid: 21584435].
1927 Laway BA, Mir SA, Gojwari T, et al. Selective preservation of anterior pituitary functions in patients with Sheehan's syndrome. Indian J Endocrinol Metab. Sep. Suppl 3. 2011;15:S238-41. X-3, X-4. [pmid: 22029030].
1928 Lazarus JH. Screening for thyroid dysfunction in pregnancy: is it worthwhile?. J Thyroid Res. 2011;2011:397012. X-1. [pmid: 21765989].
1929 Le Ray C, Fraser W, Rozenberg P, et al. Duration of passive and active phases of the second stage of labour and risk of severe postpartum haemorrhage in low-risk nulliparous women. Eur J Obstet Gynecol Reprod Biol. Oct. 2011;158:167-72. X-4. [pmid: 21640464].
1930 Lester F, Stenson A, Meyer C, et al. Impact of the Non-pneumatic Antishock Garment on pelvic blood flow in healthy postpartum women. Am J Obstet Gynecol. May. 2011;204:409 e1-5. X-4, X-5. [pmid: 21439543].
1931 Lewis EA, Barr C, Thomas K. The mode of delivery in women taken to theatre at full dilatation: does consultant presence make a difference?. J Obstet Gynaecol. 2011;31:229-31. X-4. [pmid: 21417646].
1932 Li WH, Zhang HY, Ling Y, et al. Effect of prolonged second stage of labor on maternal and neonatal outcomes. Asian Pac J Trop Med. May. 2011;4:409-11. X-4. [pmid: 21771687].
1933 Li X, Zhu J, Dai L, et al. Hospitalized delivery and maternal deaths from obstetric hemorrhage in China from 1996 to 2006. Acta Obstet Gynecol Scand. Jun. 2011;90:586-92. X-2, X-4. [pmid: 21355859].
1934 Liabsuetrakul T, Peeyananjarassri K. Mechanical dilatation of the cervix at non-labour caesarean section for reducing postoperative morbidity. Cochrane Database of Systematic Reviews. 2011. X-1.
1935 Liang J, Dai L, Zhu J, et al. Preventable maternal mortality: geographic/rural-urban differences and associated factors from the population-based Maternal Mortality Surveillance System in China. BMC Public Health. 2011;11:243. X-2, X-4. [pmid: 21501529].
1936 Lilker SJ, Meyer RA, Downey KN, et al. Anesthetic considerations for placenta accreta. Int J Obstet Anesth. Oct. 2011;20:288-92. X-4, X-5. [pmid: 21840207].
1937 Liu X, Du J, Wang G, et al. Effect of pre-pregnancy body mass index on adverse pregnancy outcome in north of China. Arch Gynecol Obstet. Jan. 2011;283:65-70. X-2, X-4. [pmid: 21197595].
1938 Liu XJ, Wang S, Zhao YL, et al. A single-center study of hemorrhagic stroke caused by cerebrovascular disease during pregnancy and puerperium in China. Int J Gynaecol Obstet. Apr. 2011;113:82-3. X-2, X-4, X-5. [pmid: 21334622].
1939 Livingstone C. A case of postnatal hyponatraemia. CPD Bulletin Clinical Biochemistry. 2011;10:67-8. X-1.
1940 Lutomski JE, Byrne BM, Devane D, et al. Increasing trends in atonic postpartum haemorrhage in Ireland: an 11-year population-based cohort study. BJOG. Feb. 2011;119:306-14. X-4. [pmid: 22168794].
1941 Lutomski JE, Morrison JJ, Greene RA, et al. Maternal morbidity during hospitalization for delivery. Obstet Gynecol. Mar. 2011;117:596-602. X-4. [pmid: 21343763].
1942 Ma W, Bai W, Lin C, et al. Effects of Sanyinjiao (SP6) with electroacupuncture on labour pain in women during labour. Complement Ther Med. Jan. Suppl 1. 2011;19:S13-8. X-4. [pmid: 21195290].
1943 Machado LS. Emergency peripartum hysterectomy: Incidence, indications, risk factors and outcome. N Am J Med Sci. Aug. 2011;3(8):358-61. X-1. [pmid: 22171242].
1944 Mackenzie IZ, Xu J, Cusick C, et al. Acupuncture for pain relief during induced labour in nulliparae: a randomised controlled study. BJOG. Mar. 2011;118:440-7. X-4. [pmid: 21244615].
1945 Majeed T, Waheed F, Sattar Y, et al. Impact of uterine fibroids on the obstetric performance of the women; Complications and pregnancy outcome. 2011;5:274-7. X-2, X-4.
1946 Malabarey O, Almog B, Brown R, et al. Postpartum hemorrhage in low risk population. J Perinat Med. Sep. 2011;39:495-8. X-4. [pmid: 21714767].
1947 Manaktala U, Dubey C, Takkar A, et al. Condom catheter balloon in management of massive nontraumatic postpartum hemorrhage during cesarean section. Journal of Gynecologic Surgery. 01. Jun. 2011;27:115-7. X-2, X-5.
1948 Mandal D, Mandal S, Dattaray C, et al. Takayasu arteritis in pregnancy: an analysis from eastern India. Arch Gynecol Obstet. Mar. 2011;285:567-71. X-2, X-4. [pmid: 21786001].
1949 Marasinghe JP, Condous G, Seneviratne HR, et al. Modi fi ed anchored B-Lynch uterine compression suture for post partum bleeding with uterine atony. Acta Obstet Gynecol Scand. Mar. 2011;90:280-3. X-2. [pmid: 21306313].
1950 McLean MT. Marion's message. Placenta accreta. Midwifery Today Int Midwife. Spring. 2011;8:66. [pmid: 21523976]. X-1, X-2, X-4, X-5.
1951 McLintock C, James AH. Obstetric hemorrhage. J Thromb Haemost. Aug. 2011;9:1441-51. X-1. [pmid: 21668737].
1952 Melhado L. Elective Labor Induction Linked to Elevated Risk of Adverse Outcomes. International Perspectives on Sexual & Reproductive Health. 2011;37:219. X-1, X-2, X-4, X-5.
1953 Memon SR, Talpur NN, Korejo RK. Outcome of patients presenting with retained placenta. Rawal Medical Journal. 2011;36. X-2, X-4.
1954 Milman N. Postpartum anemia II: prevention and treatment. Ann Hematol. Feb. 2011;91:143-54. X-1. [pmid: 22160256].
1955 Miranda-Wood C. Deadly Deliveries: Working as a Team to Make a Difference in Preventing and/or Treating Obstetrical Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2011;40:S63-4. X-1.
1956 Moatti Z, Nisner T, Saini A, et al. Delayed postpartum haemorrhage secondary to a ruptured uterine artery pseudo-aneurysm, successfully treated by transarterial embolisation. BMJ Case Reports. 2011. X-2, X-5.
1957 Mobusher I. Role of uterine packing in control of PPH. 2011;5:442-4. X-2.
1958 Moertl MG, Friedrich S, Kraschl J, et al. Haemodynamic effects of carbetocin and oxytocin given as intravenous bolus on women undergoing caesarean delivery: a randomised trial. BJOG. Oct. 2011;118:1349-56. X-4. [pmid: 21668768].
1959 Mohammed AA, Elnour MH, Mohammed EE, et al. Maternal mortality in Kassala State - Eastern Sudan: community-based study using reproductive age mortality survey (RAMOS). BMC Pregnancy Childbirth. 2011;11:102. X-2, X-4. [pmid: 22171988].
1960 Moodley J, Khedun S. The hellp syndrome: A review. Current Women's Health Reviews. June. 2011;7:125-35. X-1.
1961 Moore C. A care pathway: delayed active management of the third stage of labour. Pract Midwife. May. 2011;14:26-7. 9. 30. X-1. [pmid: 21675475].
1962 Mori R, Tokumasu H, Pledge D, et al. High dose versus low dose oxytocin for augmentation of delayed labour. Cochrane Database of Systematic Reviews. 2011. X-1.
1963 Morris JL, Meyer C, Fathalla MMF, et al. Treating uterine atony with the nonpneumatic anti-shock garment in Egypt. African Journal of Midwifery & Women's Health. 2011. Jan-Mar. 2011;5:37-42. X-2.
1964 Movafegh A, Eslamian L, Dorabadi A. Effect of intravenous tranexamic acid administration on blood loss during and after cesarean delivery. Int J Gynaecol Obstet. Dec. 2011;115:224-6. X-4. [pmid: 21872857].
1965 Murphy DJ, Macleod M, Bahl R, et al. A cohort study of maternal and neonatal morbidity in relation to use of sequential instruments at operative vaginal delivery. Eur J Obstet Gynecol Reprod Biol. May. 2011;156:41-5. X-2, X-4. [pmid: 21277670].
1966 Mustafa Adelaja L, Olufemi Taiwo O. Maternal and fetal outcome of obstetric emergencies in a tertiary health institution in South-Western Nigeria. ISRN Obstet Gynecol. 2011;2011:160932. X-2, X-4. [pmid: 21776397].
1967 Mutihir JT, Utoo BT. Postpartum maternal morbidity in Jos, North-Central Nigeria. Niger J Clin Pract. Jan-Mar. 2011;14:38-42. X-2, X-4. [pmid: 21493990].
1968 Nanda S, Singhal SR. Hayman uterine compression stitch for arresting atonic postpartum hemorrhage: 5 years experience. Taiwan J Obstet Gynecol. Jun. 2011;50:179-81. X-2, X-4, X-5. [pmid: 21791304].
1969 Nanjundan P, Rohilla M, Raveendran A, et al. Pseudoaneurysm of uterine artery: a rare cause of secondary postpartum hemorrhage, managed with uterine artery embolisation. J Clin Imaging Sci. 2011;1:14. X-2, X-5. [pmid: 21977387].
1970 Nelson-Piercy C, Powrie R, Borg JY, et al. Tinzaparin use in pregnancy: an international, retrospective study of the safety and efficacy profile. Eur J Obstet Gynecol Reprod Biol. Dec. 2011;159:293-9. X-4, X-5. [pmid: 21945573].
1971 Nezvalova-Henriksen K, Spigset O, Nordeng H. Effects of codeine on pregnancy outcome: results from a large population-based cohort study. Eur J Clin Pharmacol. Dec. 2011;67:1253-61. X-4. [pmid: 21656212].
1972 Nuzzi FM, Tanini M, Hutson CF, et al. The use of recombinant factor vii (rFVIIa) for the treatment of postpartum hemorrhage: Case report. Italian Journal of Gynaecology and Obstetrics. 2011;23:116-22. X-1.
1973 Ojengbede O, Galadanci H, Morhason-Bello IO, et al. The non-pneumatic anti-shock garment for postpartum haemorrhage in Nigeria. African Journal of Midwifery & Women's Health. 2011;5:135-41. X-2.
1974 Oleszczuk J, Leszczynska-Gorzelak B, Szymula D, et al. Heavy postpartum hemorrhagae after delivery and cesarean section. Ginekologia i Poloznictwo. 2011;21:27-45. X-1.
1975 Omole-Ohonsi A, Ashimi AO. Grand multiparity: obstetric performance in Aminu Kano Teaching Hospital, Kano, Nigeria. Niger J Clin Pract. Jan-Mar. 2011;14:6-9. X-2, X-4. [pmid: 21493983].
1976 Onwere C, Gurol-Urganci I, Cromwell DA, et al. Maternal morbidity associated with placenta praevia among women who had elective caesarean section. Eur J Obstet Gynecol Reprod Biol. Nov. 2011;159:62-6. X-4. [pmid: 21835537].
1977 Ordean A, Kahan M. Comprehensive treatment program for pregnant substance users in a family medicine clinic. Can Fam Physician. Nov. 2011;57:e430-5. X-3, X-4. [pmid: 22084472].
1978 Osmundson S, Ou-Yang RJ, Grobman WA. Elective induction compared with expectant management in nulliparous women with an unfavorable cervix. Obstet Gynecol. Mar. 2011;117:583-7. X-4. [pmid: 21343761].
1979 Ossola MW, Somigliana E, Mauro M, et al. Risk factors for emergency postpartum hysterectomy: the neglected role of previous surgically induced abortions. Acta Obstet Gynecol Scand. Dec. 2011;90:1450-3. X-4. [pmid: 21692756].
1980 Overgaard C, Moller AM, Fenger-Gron M, et al. Freestanding midwifery unit versus obstetric unit: a matched cohort study of outcomes in low-risk women. BMJ Open. Jan. 1. 2011;1:e000262. X-4. [pmid: 22021892].
1981 Paglia MJ, Grotegut CA, Johnson LN, et al. Body mass index and severe postpartum hemorrhage. Gynecol Obstet Invest. 2011;73:70-4. X-4. [pmid: 21921570].
1982 Panuccio E, Volpi E, Ferrero A, et al. Laparoscopic bipolar coagulation of hypogastric artery in postpartum haemorrhage: a case report. Case Rep Obstet Gynecol. 2011;2011:250325. X-5. [pmid: 22567499].
1983 Park JK, Shin TB, Baek JC, et al. Failure of uterine artery embolization for controlling postpartum hemorrhage. J Obstet Gynaecol Res. Aug. 2011;37:971-8. X-5. [pmid: 21463422].
1984 Parkar R, Hassan M, Otieno D, et al. Laparoscopic trachelectomy for cervical stump ‘Carcinoma in situ’. India. Medknow Publications and Media Pvt. Ltd. (B9, Kanara Business Centre, off Link Road, Ghatkopar (E), Mumbai 400 075, India). 2011. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed10&NEWS=N&AN=2011549831). Accessed on (Parkar) Obstetrician and Gynecologist, Hysteroscopy and Laparoscopy, Sarit Center, P.O. Box 520, Nairobi, Kenya 2.
1985 Parkar RB, Hassan MA, Otieno D, et al. Laparoscopic Trachelectomy for Cervical Stump ‘Carcinoma in situ’. J Gynecol Endosc Surg. Jan. 2011;2:58-60. X-1, X-4. [pmid: 22442538].
1986 Patted S, Desai BR, Ruge J, et al. Unsuspected acquired hemophilia in a patient with severe postpartum hemorrhage. International Journal of Infertility and Fetal Medicine. January-April. 2011;2:41-3. X-1.
1987 Peled Y, Melamed N, Chen R, et al. The effect of time of day on outcome of unscheduled cesarean deliveries. J Matern Fetal Neonatal Med. Aug. 2011;24:1051-4. X-4. [pmid: 21231839].
1988 Perosky J, Richter R, Rybak O, et al. A low-cost simulator for learning to manage postpartum hemorrhage in rural Africa. Simul Healthc. Feb. 2011;6:42-7. X-1, X-2, X-4, X-5. [pmid: 21330849].
1989 Perveen F, Memon GU, Rabia S. Use of bilateral internal iliac artery ligation for controlling severe obstetric haemorrhage. Pakistan Journal of Medical Sciences. 2011;27:94-7. X-2.
1990 Peyvandi F, Menegatti M, Siboni SM. Post-partum hemorrhage in women with rare bleeding disorders. Thromb Res. Feb. Suppl 3. 2011;127:S116-9. X-1. [pmid: 21262429].
1991 Phadungkiatwattana P, Tongsakul N. Analyzing the impact of private service on the cesarean section rate in public hospital Thailand. Arch Gynecol Obstet. Dec. 2011;284:1375-9. X-2, X-3, X-4. [pmid: 21359844].
1992 Poujade O, Grossetti A, Mougel L, et al. Risk of synechiae following uterine compression sutures in the management of major postpartum haemorrhage. BJOG. Mar. 2011;118:433-9. X-3, X-4. [pmid: 21199289].
1993 Prata N, Hamza S, Bell S, et al. Inability to predict postpartum hemorrhage: insights from Egyptian intervention data. BMC Pregnancy Childbirth. 2011;11:97. X-2, X-4. [pmid: 22123123].
1994 Prata N, Passano P, Rowen T, et al. Where there are (few) skilled birth attendants. J Health Popul Nutr. Apr. 2011;29:81-91. X-1. [pmid: 21608417].
1995 Pun KD, Chauhan M. Outcome of adolescent pregnancy at Kathmandu University Hospital, Dhulikhel, Kavre. Kathmandu Univ Med J (KUMJ). Jan-Mar. 2011;9:50-3. X-2, X-4. [pmid: 22610810].
1996 RÃ©go P, Lyon P, Watson M. The impact of maternity crisis resource management training. British Journal of Midwifery. 2011;19:315. X-4.
1997 Rabiu KA, Adewunmi AA, Akinola OI, et al. Comparison of maternal and neonatal outcomes following caesarean section in second versus first stage of labour in a Tertiary Hospital in Nigeria. Niger Postgrad Med J. Sep. 2011;18:165-71. X-2, X-4. [pmid: 21909144].
1998 Raouf SA, Ball T, Hughes A, et al. Obstetric and neonatal outcomes for women with reversed and non-reversed type III female genital mutilation. Int J Gynaecol Obstet. May. 2011;113:141-3. X-1, X-4. [pmid: 21306710].
1999 Raposo L, Ferreira C, Fernandes M, et al. Maternal obesity and pregnancy outcomes. Arquivos de Medicina. May/June. 2011;25:115-23. X-1, X-4.
2000 Rath WH. Postpartum hemorrhage--update on problems of definitions and diagnosis. Acta Obstet Gynecol Scand. May. 2011;90:421-8. X-1. [pmid: 21332452].
2001 Reidy J, Russell R. CMACE 2006-2008. Int J Obstet Anesth. Jul. 2011;20(3):208-12. X-1, X-4. [pmid: 21641202].
2002 Reyes OA, Gonzalez GM. Carbetocin versus oxytocin for prevention of postpartum hemorrhage in patients with severe preeclampsia: a double-blind randomized controlled trial. J Obstet Gynaecol Can. Nov. 2011;33:1099-104. X-4. [pmid: 22082783].
2003 Riyami NA, Al-Harthy A, Zia F. Atypical case of acute Fatty liver of pregnancy. Sultan Qaboos Univ Med J. Nov. 2011;11(4):507-10. X-1, X-3, X-4. [pmid: 22087401].
2004 Rizwan N, Uddin SF. Obstetrical acute renal failure: a challenging medical complication. J Ayub Med Coll Abbottabad. Oct-Dec. 2011;23:66-8. X-2, X-4. [pmid: 23472417].
2005 Roberts I, Ker K. Tranexamic acid for postpartum bleeding. Int J Gynaecol Obstet. Dec. 2011;115:220-1. X-1, X-4, X-5. [pmid: 21939973].
2006 Roeters van Lennep JE, Meijer E, Klumper FJ, et al. Prophylaxis with low-dose low-molecular-weight heparin during pregnancy and postpartum: is it effective?. J Thromb Haemost. Mar. 2011;9:473-80. X-3, X-4. [pmid: 21232006].
2007 Rogers C, Villar R, Pisal P, et al. Effects of Syntocinon use in active management of third stage labour. British Journal of Midwifery. 2011;19:371-8. X-4.
2008 Ronel D, Wiznitzer A, Sergienko R, et al. Trends, risk factors and pregnancy outcome in women with uterine rupture. Arch Gynecol Obstet. Feb. 2011;285:317-21. X-4, X-5. [pmid: 21735183].
2009 Roshani S, Cohn DM, Stehouwer AC, et al. Incidence of postpartum haemorrhage in women receiving therapeutic doses of low-molecular-weight heparin: results of a retrospective cohort study. BMJ Open. 2011;1(2):e000257. X-4. [pmid: 22102641].
2010 Roychowdhury J, Bhattacharyya M, Kumar KA, et al. Successful pregnancy outcome in a patient of chronic myeloid leukemia without therapy. Journal of Obstetrics and Gynecology of India. October. 2011;61:565-6. X-1. [pmid: 23024532].
2011 Ruth D, Kennedy BB. Acute volume resuscitation following obstetric hemorrhage. J Perinat Neonatal Nurs. Jul-Sep. 2011;25:253-60. X-1. [pmid: 21825915].
2012 Saeed M, Rana T. Fetomaternal outcome in pregnancies complicated with placental abruption. 2011;5:140-3. X-2, X-4.
2013 Saeidi R, Hamedi A, Robatsangi MG, et al. Comparing effects of beractant and poractant alfa in decreasing mortality rate due to respiratory distress syndrome in premature infants. Tehran University Medical Journal. January. 2011;68:644-8. X-1, X-2, X-3, X-4.
2014 Saereeporncharenkul K. Correlation of BMI to pregnancy outcomes in Thai women delivered in Rajavithi Hospital. J Med Assoc Thai. Mar. Suppl 2. 2011;94:S52-8. X-2, X-4. [pmid: 21717879].
2015 Saha L, Chowdhury SB. Study on primary cesarean section. Mymensingh Med J. Apr. 2011;20:292-7. X-2, X-4. [pmid: 21522103].
2016 Saidu R, Bolaji BO, Olatinwo AW, et al. Repeat caesarean delivery as a risk factor for abnormal blood loss, blood transfusion and perinatal mortality. J Obstet Gynaecol. Nov. 2011;31:728-31. X-2, X-4. [pmid: 22085064].
2017 Saljoughian M. Uterotonic agents: An update. U.S. Pharmacist. 2011;36. X-1.
2018 Schantz-Dunn J, M N. The use of blood in obstetrics and gynecology in the developing world. Rev Obstet Gynecol. Summer. 2011;4:86-91. X-1. [pmid: 22102932].
2019 Schmid BC, Rezniczek GA, Rolf N, et al. Postpartum hemorrhage: use of hemostatic combat gauze. Am J Obstet Gynecol. Jan. 2011;206:e12-3. X-5. [pmid: 22011588].
2020 Schoenbeck D, Nicolle A, Newbegin K, et al. The use of a scoring system to guide thromboprophylaxis in a high-risk pregnant population. Thrombosis. 2011. X-1, X-4.
2021 Shahida SM, Islam MA, Begum S, et al. Maternal outcome of grand multipara. Mymensingh Med J. Jul. 2011;20:381-5. X-2, X-4. [pmid: 21804498].
2022 Sharma AM, Burbridge BE. Uterine artery pseudoaneurysm in the setting of delayed postpartum hemorrhage: successful treatment with emergency arterial embolization. Case Rep Radiol. 2011;2011:373482. X-2, X-5. [pmid: 22606544].
2023 Sharma R, Najam R, Misra MK. Efficacy of tranexamic acid in decreasing blood loss during and after cesarean section. Biomedical and Pharmacology Journal. June. 2011;4:231-5. X-3, X-4.
2024 Shavell VI, Thakur M, Sawant A, et al. Adverse obstetric outcomes associated with sonographically identified large uterine fibroids. Fertil Steril. Jan. 2011;97:107-10. X-4. [pmid: 22100166].
2025 Sheehan SR, Montgomery AA, Carey M, et al. Oxytocin bolus versus oxytocin bolus and infusion for control of blood loss at elective caesarean section: double blind, placebo controlled, randomised trial. BMJ. 2011;343:d4661. X-4. [pmid: 21807773].
2026 Sheikh L, Najmi N, Khalid U, et al. Evaluation of compliance and outcomes of a management protocol for massive postpartum hemorrhage at a tertiary care hospital in Pakistan. BMC Pregnancy Childbirth. 2011;11:28. X-2. [pmid: 21489279].
2027 Shirazee HH, Saha SK, Das I, et al. Postpartum haemorrhage: a cause of maternal morbidity. J Indian Med Assoc. Oct. 2011;108:663-6. X-2, X-4. [pmid: 21510550].
2028 Shivaprasad C. Sheehan's syndrome: Newer advances. Indian J Endocrinol Metab. Sep. Suppl 3. 2011;15:S203-7. X-1, X-2. [pmid: 22029025].
2029 Shrestha A, Dongol A, Chawla CD, et al. Rectal misoprostol versus intramuscular oxytocin for prevention of post partum hemorrhage. Kathmandu Univ Med J (KUMJ). Jan-Mar. 2011;9:8-12. X-2, X-4. [pmid: 22610801].
2030 Siddiqui FM, Siddiqui MMR, Hoque MA, et al. Selective extrapontine myelinolysis in osmotic demyelination syndrome in a case of previously undiagnosed sheehan's syndrome with recurrent hyponatraemia - a rare association. Journal of Medicine. 2011;12:77-80. X-1.
2031 Siddiqui SA, Tariq G, Soomro N, et al. Perinatal outcome and near-miss morbidity between placenta previa versus abruptio placentae. J Coll Physicians Surg Pak. Feb. 2011;21:79-83. X-2, X-4. [pmid: 21333237].
2032 Sillesen M, Hjortdal V, Vejlstrup N, et al. Pregnancy with prosthetic heart valves - 30 years' nationwide experience in Denmark. Eur J Cardiothorac Surg. Aug. 2011;40:448-54. X-4. [pmid: 21277217].
2033 Simchen MJ, Oz R, Shenkman B, et al. Impaired platelet function and peripartum bleeding in women with Gaucher disease. Thromb Haemost. Mar. 2011;105:509-14. X-4. [pmid: 21301776].
2034 Singh S, McGlennan A, England A, et al. A validation study of the CEMACH recommended modified early obstetric warning system (MEOWS). Anaesthesia. Jan. 2011;67:12-8. X-4. [pmid: 22066604].
2035 Skjeldestad FE, Oian P. Blood loss after cesarean delivery: a registry-based study in Norway, 1999-2008. Am J Obstet Gynecol. Jan. 2011;206:76 e1-7. X-4. [pmid: 21963102].
2036 Soltan MH, Ibrahim EM, Tawfek M, et al. Raised nitric oxide levels may cause atonic postpartum hemorrhage in women with anemia during pregnancy. Int J Gynaecol Obstet. Feb. 2011;116:143-7. X-2, X-3, X-4. [pmid: 22114785].
2037 Soltan MH, Sadek RR. Experience managing postpartum hemorrhage at Minia University Maternity Hospital, Egypt: no mortality using external aortic compression. J Obstet Gynaecol Res. Nov. 2011;37:1557-63. X-2. [pmid: 21676082].
2038 Sorbye IK, Vangen S, Oneko O, et al. Caesarean section among referred and self-referred birthing women: a cohort study from a tertiary hospital, northeastern Tanzania. BMC Pregnancy Childbirth. 2011;11:55. X-2, X-4. [pmid: 21798016].
2039 Sorensen BL, Rasch V, Massawe S, et al. Advanced life support in obstetrics (ALSO) and post-partum hemorrhage: a prospective intervention study in Tanzania. Acta Obstet Gynecol Scand. Jun. 2011;90:609-14. X-2, X-4. [pmid: 21388368].
2040 Soudani N, Bouaziz H, Sefi M, et al. Toxic effects of chromium (VI) by maternal ingestion on liver function of female rats and their suckling pups. Environ Toxicol. Jan. 2011;28:11-20. X-1, X-3, X-4. [pmid: 21374791].
2041 Starrs A, Winikoff B. Misoprostol for postpartum hemorrhage: moving from evidence to practice. Int J Gynaecol Obstet. Jan. 2011;116:1-3. X-1. [pmid: 22078140].
2042 Stitely ML, Cerbone L, Nixon A, et al. Assessment of a simulation training exercise to teach intrauterine tamponade for the treatment of postpartum hemorrhage. J Midwifery Womens Health. Sep-Oct. 2011;56:503-6. X-3, X-4. [pmid: 23181649].
2043 Stotler B, Padmanabhan A, Devine P, et al. Transfusion requirements in obstetric patients with placenta accreta. Transfusion. Dec. 2011;51:2627-33. X-4. [pmid: 21658046].
2044 Studelska JV. Velamentous Birth Story. Midwifery Today. 2011:9-11. X-1.
2045 Suknikhom W, Tannirandorn Y. Previous uterine operation and placenta previa. J Med Assoc Thai. Mar. 2011;94:272-7. X-2, X-4. [pmid: 21560833].
2046 Sullivan JV, Crouch ME, Stocken G, et al. Blood cell salvage during cesarean delivery. Int J Gynaecol Obstet. Nov. 2011;115:161-3. X-4, X-5. [pmid: 21872856].
2047 Sultana N, Mohyuddin S, Jabbar T. Management and maternal outcome in morbidly adherent placenta. J Ayub Med Coll Abbottabad. Apr-Jun. 2011;23:93-6. X-2. [pmid: 24800353].
2048 Suri V, Keepanasseril A, Aggarwal N, et al. Mechanical valve prosthesis and anticoagulation regimens in pregnancy: a tertiary centre experience. Eur J Obstet Gynecol Reprod Biol. Dec. 2011;159:320-3. X-4. [pmid: 21962462].
2049 Suzuki S, Hiraizumi Y, Satomi M, et al. Midwife-led care unit for ‘low risk’ pregnant women in a Japanese hospital. J Matern Fetal Neonatal Med. Aug. 2011;24:1046-50. X-4. [pmid: 21231841].
2050 Tasleem H, Tasleem S, Siddique MA, et al. Outcome of pregnancy in placental abruption. Rawal Medical Journal. 2011;36:57-9. X-2, X-4.
2051 Thies-Lagergren L, Kvist LJ, Christensson K, et al. No reduction in instrumental vaginal births and no increased risk for adverse perineal outcome in nulliparous women giving birth on a birth seat: results of a Swedish randomized controlled trial. BMC Pregnancy Childbirth. 2011;11:22. X-4. [pmid: 21435238].
2052 Tikkanen M, Paavonen J, Loukovaara M, et al. Antenatal diagnosis of placenta accreta leads to reduced blood loss. Acta Obstet Gynecol Scand. Oct. 2011;90:1140-6. X-4, X-5. [pmid: 21488840].
2053 Unal O, Kars B, Buyukbayrak EE, et al. The effectiveness of bilateral hypogastric artery ligation for obstetric hemorrhage in three different underlying conditions and its impact on future fertility. J Matern Fetal Neonatal Med. Oct. 2011;24:1273-6. X-2, X-5. [pmid: 21557692].
2054 Unterscheider J, McMenamin M, Cullinane F. Rising rates of caesarean deliveries at full cervical dilatation: a concerning trend. Eur J Obstet Gynecol Reprod Biol. Aug. 2011;157:141-4. X-2, X-4, X-5. [pmid: 21470764].
2055 Vadnais MA, Dodge LE, Awtrey CS, et al. Assessment of long-term knowledge retention following single-day simulation training for uncommon but critical obstetrical events. J Matern Fetal Neonatal Med. Sep. 2011;25:1640-5. X-3, X-4. [pmid: 22191668].
2056 van den Akker T, van Rhenen J, Mwagomba B, et al. Reduction of severe acute maternal morbidity and maternal mortality in Thyolo District, Malawi: the impact of obstetric audit. PLoS One. 2011;6:e20776. X-2. [pmid: 21677788].
2057 Vanes NK, Lazarus JH, Chan SY. Thyroid function in pregnancy: Maternal and fetal outcomes with hypothyroidism and subclinical thyroid dysfunction. Fetal and Maternal Medicine Review. August. 2011;22:169-87. X-1.
2058 Varatharajan L, Chandraharan E, Sutton J, et al. Outcome of the management of massive postpartum hemorrhage using the algorithm “HEMOSTASIS”. Int J Gynaecol Obstet. May. 2011;113:152-4. X-4, X-5. [pmid: 21396642].
2059 Vardo JH, Thornburg LL, Glantz JC. Maternal and neonatal morbidity among nulliparous women undergoing elective induction of labor. J Reprod Med. Jan-Feb. 2011;56:25-30. X-4. [pmid: 21366123].
2060 Vasquez DN, Estenssoro E. Critical illness in obstetric patients: Introduction and epidemiology. Current Women's Health Reviews. June. 2011;7:102-11. X-1.
2061 Wagner B, Meirowitz N, Shah J, et al. Comprehensive perinatal safety initiative to reduce adverse obstetric events. J Healthc Qual. Jan-Feb. 2011;34:6-15. X-4, X-5. [pmid: 22060764].
2062 Walker DM, Cohen SR, Estrada F, et al. PRONTO training for obstetric and neonatal emergencies in Mexico. Int J Gynaecol Obstet. Feb. 2011;116:128-33. X-2, X-3, X-4. [pmid: 22112786].
2063 Wandabwa JN, Doyle P, Longo-Mbenza B, et al. Human immunodeficiency virus and AIDS and other important predictors of maternal mortality in Mulago Hospital Complex Kampala Uganda. BMC Public Health. 2011;11:565. X-2, X-4. [pmid: 21756355].
2064 Wang S, Teng WP, Li JX, et al. Effects of maternal subclinical hypothyroidism on obstetrical outcomes during early pregnancy. J Endocrinol Invest. Mar. 2011;35:322-5. X-3, X-4. [pmid: 21642766].
2065 Watanabe T, Matsubara S, Usui R, et al. No increase in hemorrhagic complications with thromboprophylaxis using low-molecular-weight heparin soon after cesarean section. J Obstet Gynaecol Res. Sep. 2011;37:1208-11. X-2, X-4, X-5. [pmid: 21518131].
2066 Wickham S. Saving mothers' lives: reviewing maternal deaths to make motherhood safer: 2006 -- 08. Essentially MIDIRS. 2011;2:27-32. X-1.
2067 Wong TY. Emergency peripartum hysterectomy: a 10-year review in a tertiary obstetric hospital. N Z Med J. Nov. 4. 2011;124:34-9. X-4, X-5. [pmid: 22072164].
2068 Wright JD, Pri-Paz S, Herzog TJ, et al. Predictors of massive blood loss in women with placenta accreta. Am J Obstet Gynecol. Jul. 2011;205:38 e1-6. X-4. [pmid: 21419387].
2069 Yoong W, Ridout A, Memtsa M, et al. Application of uterine compression suture in association with intrauterine balloon tamponade (‘uterine sandwich’) for postpartum hemorrhage. Acta Obstet Gynecol Scand. Jan. 2011;91:147-51. X-5. [pmid: 21501126].
2070 Youngblood A. Code White Innovative Program Presentation. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2011;40:S38-S. X-1, X-2, X-4, X-5.
2071 Yun SY, Lee DH, Cho KH, et al. Delayed postpartum hemorrhage resulting from uterine artery pseudoaneurysm rupture. J Emerg Med. Jan. 2011;42:e11-4. X-4, X-5. [pmid: 21497477].
2072 Zakaria R, Coulter I, Enevoldson P, et al. Reversible cerebral vasoconstriction syndrome in a postpartum female complicated by subarachnoid haemorrhage. BMJ Case Reports. 2011. X-1, X-3, X-4.
2073 Zanconato G, Cavaliere E, Iacovella C, et al. Severe maternal morbidity in a tertiary care centre of northern Italy: a 5-year review. J Matern Fetal Neonatal Med. Jul. 2011;25:1025-8. X-2, X-5. [pmid: 21854133].
2074 $4.6 million verdict for ailure to have adequate blood supply. Hospital Laws Regan Report. 2012;53:2. X-1, X-2, X-4, X-5.
2075 Clinical digest. Women undergoing planned caesarean section less likely to require a blood transfusion. Nursing Standard. 2012;26:15. X-1, X-4, X-5.
2076 MIDIRS update. Essentially MIDIRS. 2012;3:5-16. X-1, X-4.
2077 No evidence for use of misoprostol to prevent life-threatening bleeding during labour. British Journal of Hospital Medicine (17508460). 2012;73:489. X-1, X-4.
2078 WHO Guidelines Approved by the Guidelines Review Committee. WHO Recommendations for the Prevention and Treatment of Postpartum Haemorrhage. Geneva. World Health Organization World Health Organization. 2012.
2079 Higher Risk of Maternal Complications/Preterm Deliveries for Women Undergoing Multiple Cesarean Surgeries. Inside Childbirth Education. 2012:4. X-1, X-4.
2080 Labour complications. Midwives. 2012;15:10. X-1, X-4, X-5.
2081 Public health round-up. Bulletin of the World Health Organization. 2012;90:248-9. X-1, X-4, X-5.
2082 Acharya R, Sharma A, Choudhary P, et al. Intrahepatic cholestasis of pregnancy: A serious but underestimated problem. Journal of SAFOG. 2012;4:118-9. X-1, X-2, X-4, X-5.
2083 Adanikin AI, Orji EO, Fasubaa OB, et al. The effect of post-cesarean rectal misoprostol on intestinal motility. Int J Gynaecol Obstet. Nov. 2012;119:159-62. X-2, X-4. [pmid: 22925817].
2084 Agha M, Selmi G, Ezzat M. Transcranial US of preterm neonates: High risk gestational age and birth weight for perinatal asphyxia. Egyptian Journal of Radiology and Nuclear Medicine. June. 2012;43:265-74. X-2, X-3, X-4.
2085 Aibar L, Aguilar MT, Puertas A, et al. Bakri balloon for the management of postpartum hemorrhage. Acta Obstet Gynecol Scand. Apr. 2012;92:465-7. X-5. [pmid: 22762694].
2086 Akbayir O, Corbacioglu Esmer A, Cilesiz Goksedef P, et al. Single square hemostatic suture for postpartum hemorrhage secondary to uterine atony. Arch Gynecol Obstet. Jan. 2012;287:25-9. X-2, X-5. [pmid: 22893103].
2087 Al JF. Grandmultiparity: a potential risk factor for adverse pregnancy outcomes. J Reprod Med. Jan-Feb. 2012;57:53-7. X-2, X-4. [pmid: 22324269].
2088 Al-Othebi KHA, Al-Shwirikh AH, Aslam S. Unforgettable lesson: Emergency in emergency room. Research Journal of Obstetrics and Gynecology. 2012;5:8-12. X-1.
2089 Alsammani MA, Ahmed SR. Fetal and maternal outcomes in pregnancies complicated with fetal macrosomia. N Am J Med Sci. Jun. 2012;4:283-6. X-2, X-4. [pmid: 22754881].
2090 Anand AK, Mir S. A randomized comparison between intravaginal misoprostol and intracervical dinoprostone for cervical ripening and labour induction in participants with unfavourable cervices. JK Science. July-September. 2012;14:115-9. X-3, X-4.
2091 Ande A, Olagbuji B, Ezeanochie M. An audit of maternal deaths from a referral university teaching hospital in Nigeria: the emergence of HIV/AIDS as a leading cause. Niger Postgrad Med J. Jun. 2012;19:83-7. X-2, X-4. [pmid: 22728972].
2092 Andersson O, Hellstrom-Westas L, Andersson D, et al. Effects of delayed compared with early umbilical cord clamping on maternal postpartum hemorrhage and cord blood gas sampling: a randomized trial. Acta Obstet Gynecol Scand. May. 2012;92:567-74. X-4. [pmid: 22913332].
2093 Andreatta P, Perosky J, Johnson TR. Two-provider technique for bimanual uterine compression to control postpartum hemorrhage. J Midwifery Womens Health. Jul-Aug. 2012;57:371-5. X-2, X-3. [pmid: 22758359].
2094 Andrighetti TP, Knestrick JM, Marowitz A, et al. Shoulder dystocia and postpartum hemorrhage simulations: student confidence in managing these complications. J Midwifery Womens Health. Jan-Feb. 2012;57:55-60. X-3, X-4. [pmid: 22251913].
2095 Anvaripour A, Shahryari H, Ahmadi S, et al. Comparison the effects of oxytocin and methylergonovine in elective caesarean section under spinal anesthesia. Arch Gynecol Obstet. May. 2012;287:979-83. X-3, X-4. [pmid: 23250341].
2096 Ara S, Tahir S, Rehman A. Maternal mortality in Faisalabad and millennium developmental goals. Pakistan Journal of Medical Sciences. 2012;28:371-5. X-2, X-4.
2097 Ãurleigh A. Delaying the clampers. AIMS Journal. 2012;24(4):13-4. Language: English. Entry Date: 20130118. Revision Date: 20130524. Publication Type: journal article. Journal Subset: Editorial Board Reviewed. X-1.
2098 Ayaz A, Farooq MU. Risk of adverse maternal and peri-natal outcome in subjects with placenta previa with previous cesarean section. Kurume Med J. 2012;59:1-4. X-2, X-3, X-4. [pmid: 23257632].
2099 Badejoko OO, Ijarotimi AO, Awowole IO, et al. Adjunctive rectal misoprostol versus oxytocin infusion for prevention of postpartum hemorrhage in women at risk: a randomized controlled trial. J Obstet Gynaecol Res. Nov. 2012;38:1294-301. X-2, X-4. [pmid: 22612662].
2100 Bajwa SK, Bajwa SJ. Delivering obstetrical critical care in developing nations. Int J Crit Illn Inj Sci. Jan. 2012;2(1):32-9. X-1. [pmid: 22624100].
2101 Balki M, Kanwal N, Erik-Soussi M, et al. Contractile efficacy of various prostaglandins in pregnant rat myometrium pretreated with oxytocin. Reprod Sci. Sep. 2012;19:968-75. X-3. [pmid: 22539357].
2102 Bamberg C, Fotopoulou C, Neissner P, et al. Maternal characteristics and twin gestation outcomes over 10 years: impact of conception methods. Fertil Steril. Jul. 2012;98:95-101. X-3, X-4. [pmid: 22608318].
2103 Basude S, Hein C, Curtis SL, et al. Low-molecular-weight heparin or warfarin for anticoagulation in pregnant women with mechanical heart valves: what are the risks? A retrospective observational study. BJOG. Jul. 2012;119:1008-13. discussion 12-3. X-3, X-4. [pmid: 22568528].
2104 Bedoya-Ronga A, Currie I. Which patients should be offered caesarean section?. Practitioner. Mar. 2012;256:16-8. 2. 3. X-1. [pmid: 22662515].
2105 Bellad MB, Tara D, Ganachari MS, et al. Prevention of postpartum haemorrhage with sublingual misoprostol or oxytocin: a double-blind randomised controlled trial. BJOG. Jul. 2012;119:975-82. discussion 82-6. X-2, X-4. [pmid: 22703421].
2106 Benson MD, Cheema N, Kaufman MW, et al. Uterine intravascular fetal material and coagulopathy at peripartum hysterectomy. Gynecol Obstet Invest. 2012;73:158-61. X-4. [pmid: 22261240].
2107 Bezircioglu I, Baloglu A, Cetinkaya B, et al. Do clinical and laboratory parameters effect maternal and fetal outcomes in pregnancies complicated with hemolysis, elevated liver enzymes, and low platelet count syndrome?. Journal of the Turkish German Gynecology Association. 2012;13:1-7. X-2, X-4, X-5.
2108 Bhatti S, Penna L. Maternal collapse. Obstetrics, Gynaecology and Reproductive Medicine. July. 2012;22:191-8. X-1.
2109 Bhutta ZA, Cabral S, Chan CW, et al. Reducing maternal, newborn, and infant mortality globally: an integrated action agenda. Int J Gynaecol Obstet. Oct. Suppl 1. 2012;119:S13-7. X-1. [pmid: 22883919].
2110 Bibi S, Ghaffar S, Memon S. Severe acute maternal morbidity (SAMM) in postpartum period requiring tertiary hospital care. Iranian Journal of Reproductive Medicine. March/April. 2012;10:87-92. X-2, X-4. [pmid: 25242979].
2111 Bieri RA, Adriaens L, Sporri S, et al. Gingival fluid cytokine expression and subgingival bacterial counts during pregnancy and postpartum: a case series. Clin Oral Investig. Jan. 2012;17:19-28. X-1, X-3, X-4. [pmid: 22249562].
2112 Bingham D. Applying the generic errors modeling system to obstetric hemorrhage quality improvement efforts. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2012;41:540-8. quiz 9-50. X-1, X-4, X-5. [pmid: 22548710].
2113 Bingham D, Jones R. Maternal death from obstetric hemorrhage. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2012;41:531-9. X-1. [pmid: 22548689].
2114 Blix E, Huitfeldt AS, Oian P, et al. Outcomes of planned home births and planned hospital births in low-risk women in Norway between 1990 and 2007: a retrospective cohort study. Sex Reprod Healthc. Dec. 2012;3:147-53. X-4. [pmid: 23182447].
2115 Borchert M, Goufodji S, Alihonou E, et al. Can hospital audit teams identify case management problems, analyse their causes, identify and implement improvements? A cross-sectional process evaluation of obstetric near-miss case reviews in Benin. BMC Pregnancy Childbirth. 2012;12:109. X-2, X-4. [pmid: 23057707].
2116 Bouvier A, Sentilhes L, Thouveny F, et al. Planned caesarean in the interventional radiology cath lab to enable immediate uterine artery embolization for the conservative treatment of placenta accreta. Clin Radiol. Nov. 2012;67:1089-94. X-2, X-5. [pmid: 22622352].
2117 Bouvier-Colle MH, Mohangoo AD, Gissler M, et al. What about the mothers? An analysis of maternal mortality and morbidity in perinatal health surveillance systems in Europe. BJOG. Jun. 2012;119:880-9. discussion 90. X-2, X-3, X-4. [pmid: 22571748].
2118 Bowman Z, Branch DW. Thromboprophylaxis in pregnancy. Contemporary OB/GYN. 2012;57:46-58. X-1, X-5.
2119 Boztosun A, Sumer D, Cetin M, et al. Idiopathic spontaneous hemoperitoneum during early postpartum period: Case report. Turkiye Klinikleri Journal of Medical Sciences. 2012;32:1718-20. X-1, X-2.
2120 Brearton C, Bhalla A, Mallaiah S, et al. The economic benefits of cell salvage in obstetric haemorrhage. Int J Obstet Anesth. Oct. 2012;21:329-33. X-2, X-4, X-5. [pmid: 22858041].
2121 Breen M. Temporary treatment of severe postpartum hemorrhage. Int J Gynaecol Obstet. Sep. 2012;118:253-4. X-1, X-2, X-4, X-5. [pmid: 22795757].
2122 Brown A, Jordan S. Impact of birth complications on breastfeeding duration: an internet survey. J Adv Nurs. Apr. 2012;69:828-39. X-4, X-5. [pmid: 22765355].
2123 Brown H, Small M. The role of the maternal-fetal medicine subspecialist in review and prevention of maternal deaths. Semin Perinatol. Feb. 2012;36:27-30. X-1. [pmid: 22280862].
2124 Bryant A, Mhyre JM, Leffert LR, et al. The association of maternal race and ethnicity and the risk of postpartum hemorrhage. Anesth Analg. Nov. 2012;115:1127-36. X-4. [pmid: 22886840].
2125 Burke N, Field K, Mujahid F, et al. Use and safety of Kielland's forceps in current obstetric practice. Obstet Gynecol. Oct. 2012;120:766-70. X-4. [pmid: 22996093].
2126 Burleigh A. Delaying the clampers. AIMS Journal. 2012;24:13-4. X-1, X-2, X-4, X-5.
2127 Calvert C, Thomas SL, Ronsmans C, et al. Identifying regional variation in the prevalence of postpartum haemorrhage: a systematic review and meta-analysis. PLoS One. 2012;7:e41114. X-1, X-4. [pmid: 22844432].
2128 Campbell J, Holland C, Richens D, et al. Impact of cell salvage during cardiac surgery on the thrombelastomeric coagulation profile: A pilot study. Perfusion. May. 2012;27:221-4. X-1, X-3. [pmid: 22185951].
2129 Cengiz H, Yasar L, Ekin M, et al. Management of intractable postpartum haemorrhage in a tertiary center: A 5-year experience. Niger Med J. Apr. 2012;53:85-8. X-2, X-5. [pmid: 23271852].
2130 Chandraharan E, Rao S, Belli AM, et al. The Triple-P procedure as a conservative surgical alternative to peripartum hysterectomy for placenta percreta. Int J Gynaecol Obstet. May. 2012;117:191-4. X-1, X-4, X-5. [pmid: 22326782].
2131 Chapman E, Reveiz L, Chambliss A, et al. Cochrane systematic reviews are useful to map research gaps for decreasing maternal mortality. J Clin Epidemiol. Jan. 2012;66:105-12. X-1. [pmid: 23177899].
2132 Chee YL, Townend J, Crowther M, et al. Assessment of von Willebrand disease as a risk factor for primary postpartum haemorrhage. Haemophilia. Jul. 2012;18:593-7. X-1, X-4. [pmid: 22335463].
2133 Cheerranichanunth P, Poolnoi P. Using blood loss pictogram for visual blood loss estimation in cesarean section. J Med Assoc Thai. Apr. 2012;95:550-6. X-3, X-4. [pmid: 22612010].
2134 Chen KH, Chen LR, Lee YH. The role of preterm placental calcification in high-risk pregnancy as a predictor of poor uteroplacental blood flow and adverse pregnancy outcome. Ultrasound Med Biol. Jun. 2012;38:1011-8. X-4. [pmid: 22475694].
2135 Chen Z, Liang MY, Wang JL. Etiology and clinical characteristics of pregnancy-emerged thrombocytopenia. Zhonghua Fu Chan Ke Za Zhi. Nov. 2012;46:834-9. X-2, X-4. [pmid: 22333233].
2136 Chijioke A, Makusidi AM, Rafiu MO. Factors influencing hemodialysis and outcome in severe acute renal failure from Ilorin, Nigeria. Saudi J Kidney Dis Transpl. Mar. 2012;23:391-6. X-2, X-3, X-4. [pmid: 22382247].
2137 Chitra TV, Panicker S. Pseudoaneurysm of uterine artery: a rare cause of secondary postpartum hemorrhage. J Obstet Gynaecol India. Dec. 2012;61:641-4. X-2, X-5. [pmid: 23204681].
2138 Christie A, Robertson I, Moss J. Interventional radiology emergency service provision for a large UK urban population: initial 3.5 years of experience. Clin Radiol. Aug. 2012;68:e440-6. X-4, X-5. [pmid: 22964368].
2139 Chu CS, Brhlikova P, Pollock AM. Rethinking WHO guidance: review of evidence for misoprostol use in the prevention of postpartum haemorrhage. J R Soc Med. Aug. 2012;105:336-47. X-1, X-3. [pmid: 22907551].
2140 Chweneyagae D, Delis-Jarrosay N, Farina Z, et al. The impact of HIV infection on maternal deaths in South Africa. South African Journal of Obstetrics and Gynaecology. 2012;18:70-6. X-2, X-4.
2141 Clark SL. Strategies for reducing maternal mortality. Semin Perinatol. Feb. 2012;36:42-7. X-1. [pmid: 22280865].
2142 Clark SL, Hankins GD. Preventing maternal death: 10 clinical diamonds. Obstet Gynecol. Feb. 2012;119:360-4. X-1. [pmid: 22270288].
2143 Cohain JS. A Novel Way to Prevent Postpartum Haemorrhage?. Midwifery Matters. 2012:21-2. X-1, X-4.
2144 Cook JR, Jarvis S, Knight M, et al. Multiple repeat caesarean section in the UK: incidence and consequences to mother and child. A national, prospective, cohort study. BJOG. Jan. 2012;120:85-91. X-4. [pmid: 23095012].
2145 Cordovani D, Balki M, Farine D, et al. Carbetocin at elective Cesarean delivery: a randomized controlled trial to determine the effective dose. Can J Anaesth. Aug. 2012;59:751-7. X-3, X-4. [pmid: 22717890].
2146 Cortet M, Deneux-Tharaux C, Dupont C, et al. Association between fibrinogen level and severity of postpartum haemorrhage: secondary analysis of a prospective trial. Br J Anaesth. Jun. 2012;108:984-9. X-4. [pmid: 22490316].
2147 Cromi A, Ghezzi F, Uccella S, et al. A randomized trial of preinduction cervical ripening: dinoprostone vaginal insert versus double-balloon catheter. Am J Obstet Gynecol. Aug. 2012;207:125 e1-7. X-3, X-4. [pmid: 22704766].
2148 Curry RA, Fletcher C, Gelson E, et al. Pulmonary hypertension and pregnancy--a review of 12 pregnancies in nine women. BJOG. May. 2012;119:752-61. X-4. [pmid: 22390684].
2149 Dabash R, Blum J, Raghavan S, et al. Misoprostol for the management of postpartum bleeding: a new approach. Int J Gynaecol Obstet. Dec. 2012;119:210-2. X-1. [pmid: 22980431].
2150 Dahlen HG, Dowling H, Tracy M, et al. Maternal and perinatal outcomes amongst low risk women giving birth in water compared to six birth positions on land. A descriptive cross sectional study in a birth centre over 12 years. Midwifery. Jul. 2012;29:759-64. X-4. [pmid: 22884894].
2151 Dasari P, Sagili H, Udupi G. Unusual complication of vaginal delivery: Is misoprostal the cause?. BMJ Case Reports. 2012. X-1, X-4.
2152 Deans R, Banks F, Liao LM, et al. Reproductive outcomes in women with classic bladder exstrophy: an observational cross-sectional study. Am J Obstet Gynecol. Jun. 2012;206:496 e1-6. X-4. [pmid: 22537419].
2153 Demetz J, Clouqueur E, D'Haveloose A, et al. Systematic use of carbetocin during cesarean delivery of multiple pregnancies: a before-and-after study. Arch Gynecol Obstet. May. 2012;287:875-80. X-4. [pmid: 23233289].
2154 Dennedy MC, Avalos G, O'Reilly MW, et al. The impact of maternal obesity on gestational outcomes. Ir Med J. May. 2012;105:23-5. X-4. [pmid: 22838105].
2155 Dennedy MC, Avalos G, O'Reilly MW, et al. ATLANTIC-DIP: raised maternal body mass index (BMI) adversely affects maternal and fetal outcomes in glucose-tolerant women according to International Association of Diabetes and Pregnancy Study Groups (IADPSG) criteria. J Clin Endocrinol Metab. Apr. 2012;97:E608-12. X-4. [pmid: 22319044].
2156 Divakar H. Iron-deficiency anemia in pregnant women: What preventing practitioners from using IV iron sucrose. International Journal of Infertility and Fetal Medicine. January-April. 2012;3:1-7. X-2, X-3, X-4.
2157 Donati S, Senatore S, Ronconi A. Obstetric near-miss cases among women admitted to intensive care units in Italy. Acta Obstet Gynecol Scand. Apr. 2012;91:452-7. X-4. [pmid: 22229438].
2158 D'Souza K, Monteiro FNP, Jayaprakash K, et al. Spectrum of grand multiparity. Journal of Clinical and Diagnostic Research. 2012;5:1247-50. X-2, X-4.
2159 Dudas L, Pedaline SH. Stop the Bleeding: A Postpartum Hemorrhage Protocol. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2012;41:S11-S. X-1, X-4, X-5.
2160 Duzyj CM, Paidas MJ. New thoughts on an old problem. Contemporary OB/GYN. 2012;57:32. X-1, X-4, X-5.
2161 Ehrenthal DB, Chichester ML, Cole OS, et al. Maternal risk factors for peripartum transfusion. J Womens Health (Larchmt). Jul. 2012;21:792-7. X-4. [pmid: 22500552].
2162 Ekin M, Islim F, Cengiz H, et al. Late postpartum hemorrhage due to uterine arteriovenous malformations. Gineco.ro. 2012;8:184-6. X-1, X-2, X-4.
2163 Elati A, Weeks A. Risk of fever after misoprostol for the prevention of postpartum hemorrhage: a meta-analysis. Obstet Gynecol. Nov. 2012;120:1140-8. X-1, X-3. [pmid: 23090533].
2164 Elsedeek MS. Impact of preoperative rectal misoprostol on blood loss during and after elective cesarean delivery. Int J Gynaecol Obstet. Aug. 2012;118:149-52. X-2, X-4, X-5. [pmid: 22698700].
2165 Endler M, Grunewald C, Saltvedt S. Epidemiology of retained placenta: oxytocin as an independent risk factor. Obstet Gynecol. Apr. 2012;119:801-9. X-4. [pmid: 22433344].
2166 Fasih A, Aamir F. Assessment of potential predictors of caesarean delivery wound morbidity. Medical Channel. 2012;19:64-7. X-2, X-3, X-4.
2167 Fawzy AEMA, Swelem M, Abdelrehim AI, et al. Active management of third stage of labor by intravenous ergometrine and rectal versus sublingual misoprostol (a double-center study). Alexandria Journal of Medicine. December. 2012;48:381-5. X-2, X-4.
2168 Fernando D, Halliday JL, Breheny S, et al. Outcomes of singleton births after blastocyst versus nonblastocyst transfer in assisted reproductive technology. Fertil Steril. Mar. 2012;97:579-84. X-3, X-4. [pmid: 22281036].
2169 Fodstad K, Laine K, Staff AC. Different episiotomy techniques, postpartum perineal pain, and blood loss: an observational study. Int Urogynecol J. May. 2012;24:865-72. X-4. [pmid: 23108732].
2170 Ford JB, Algert CS, Morris JM, et al. Decreasing length of maternal hospital stay is not associated with increased readmission rates. Aust N Z J Public Health. Oct. 2012;36:430-4. X-4. [pmid: 23025363].
2171 Ford JB, Shand AW, Roberts CL. Characteristics, causes and treatment of postpartum haemorrhage in first and second pregnancies. Aust N Z J Obstet Gynaecol. Feb. 2012;53:90-3. X-4, X-5. [pmid: 23206163].
2172 Fugate JE, Ameriso SF, Ortiz G, et al. Variable presentations of postpartum angiopathy. Stroke. Mar. 2012;43:670-6. X-3, X-4. [pmid: 22223244].
2173 Fugate JE, Wijdicks EF, Parisi JE, et al. Fulminant postpartum cerebral vasoconstriction syndrome. Arch Neurol. Jan. 2012;69:111-7. X-3, X-4. [pmid: 22232351].
2174 Fuglsang K, Dueholm M, Staehr-Hansen E, et al. Uterine healing after therapeutic intrauterine administration of TachoSil (hemostatic fleece) in cesarean section with postpartum hemorrhage caused by placenta previa. J Pregnancy. 2012;2012:635683. X-4, X-5. [pmid: 22619722].
2175 Fukushima K, Yumoto Y, Kondo Y, et al. A retrospective chart review of the perinatal period in 22 pregnancies of 16 women with Moyamoya disease. J Clin Neurosci. Oct. 2012;19:1358-62. X-3, X-4. [pmid: 22917762].
2176 Fyfe EM, Thompson JM, Anderson NH, et al. Maternal obesity and postpartum haemorrhage after vaginal and caesarean delivery among nulliparous women at term: a retrospective cohort study. BMC Pregnancy Childbirth. 2012;12:112. X-4. [pmid: 23078042].
2177 Gao H, Yang BJ, Jin LP, et al. Predisposing factors, diagnosis, treatment and prognosis of cerebral venous thrombosis during pregnancy and postpartum: a case-control study. Chin Med J (Engl). Dec. 2012;124:4198-204. X-3, X-4. [pmid: 22340387].
2178 Garba M, Nayama M, Alio AP, et al. Maternal mortality in Niger: a retrospective study in a high risk maternity. Afr J Med Med Sci. Dec. 2012;40:393-7. X-2, X-4. [pmid: 22783691].
2179 Garcia K, Morrison B, Kilanowski J. Focus Group with Guatemalan Traditional Midwives about Postpartum Hemorrhage. Online Journal of Cultural Competence in Nursing & Healthcare. 2012;2:1-10. X-2, X-3, X-4.
2180 Geetha P. Induction of labour with prostaglandin E2 vaginal gel in women with one previous caesarean section. Middle East Fertility Society Journal. September. 2012;17:170-5. X-2, X-4.
2181 Gezginc K, Yazici F, Koyuncu T, et al. Bilateral uterine and ovarian artery ligation in addition to B-lynch suture may be an alternative to hysterectomy for uterine atonic hemorrhage. Clin Exp Obstet Gynecol. 2012;39:168-70. X-2, X-5. [pmid: 22905456].
2182 Giannella L, Mfuta K, Pedroni D, et al. Delays in the delivery room of a primary maternity unit: a retrospective analysis of obstetric outcomes. J Matern Fetal Neonatal Med. Apr. 2012;26:593-7. X-4. [pmid: 23126633].
2183 Gohil JT, Tripathi B. A Study to Compare the Efficacy of Misoprostol, Oxytocin, Methyl-ergometrine and Ergometrine-Oxytocin in Reducing Blood Loss in Active Management of 3rd Stage of Labor. J Obstet Gynaecol India. Aug. 2012;61:408-12. X-2, X-4. [pmid: 22851822].
2184 Gong YH, Jia J, Lu DH, et al. Outcome and risk factors of early onset severe preeclampsia. Chin Med J (Engl). Jul. 2012;125:2623-7. X-2, X-3, X-4. [pmid: 22882950].
2185 Gonzales GF, Tapia V, Fort AL. Maternal and Perinatal outcomes in second hemoglobin measurement in nonanemic women at first booking: Effect of altitude of residence in Peru. ISRN Obstetrics and Gynecology. 2012. X-2, X-3, X-4.
2186 Gonzales GF, Tapia V, Gasco M, et al. Association of hemoglobin values at booking with adverse maternal outcomes among Peruvian populations living at different altitudes. Int J Gynaecol Obstet. May. 2012;117:134-9. X-2, X-3, X-4. [pmid: 22356761].
2187 Griffin D, Brown L, Feinn R, et al. Impact of an educational intervention and insurance coverage on patients' preferences to transfer multiple embryos. Reprod Biomed Online. Aug. 2012;25:204-8. X-3, X-4. [pmid: 22683149].
2188 Gulmezoglu AM, Lumbiganon P, Landoulsi S, et al. Active management of the third stage of labour with and without controlled cord traction: a randomised, controlled, non-inferiority trial. Lancet. May. 5. 2012;379:1721-7. X-2, X-4. [pmid: 22398174].
2189 Gungorduk K, Asicioglu O, Yildirim G, et al. Can intravenous injection of tranexamic acid be used in routine practice with active management of the third stage of labor in vaginal delivery? A randomized controlled study. Am J Perinatol. May. 2012;30:407-13. X-2, X-4, X-5. [pmid: 23023559].
2190 Gutierrez MC, Goodnough LT, Druzin M, et al. Postpartum hemorrhage treated with a massive transfusion protocol at a tertiary obstetric center: a retrospective study. Int J Obstet Anesth. Jul. 2012;21:230-5. X-2, X-4, X-5. [pmid: 22647592].
2191 Haas J, Barzilay E, Chayen B, et al. Safety of labor induction with prostaglandin E2 in grandmultiparous women. J Matern Fetal Neonatal Med. Jan. 2012;26:49-51. X-4. [pmid: 22928497].
2192 Haeri S, Dildy GA 3rd. Maternal mortality from hemorrhage. Semin Perinatol. Feb. 2012;36:48-55. X-1. [pmid: 22280866].
2193 Halloran DR, Marshall NE, Kunovich RM, et al. Obesity trends and perinatal outcomes in black and white teenagers. Am J Obstet Gynecol. Dec. 2012;207:492 e1-7. X-4. [pmid: 23174388].
2194 Hansen SS, Arafeh J. Implementing and sustaining in situ drills to improve multidisciplinary health care training. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2012;41:559-70. quiz 70-1. X-1. [pmid: 22548312].
2195 Hao J, Liu M, Mo Z. The Symptoms Get Worse after Pregnancy in Sheehan's Syndrome: A Case Report. Case Rep Med. 2012;2012:271345. X-1, X-3, X-4. [pmid: 23049563].
2196 Harding K. Risk management in obstetrics. Obstetrics, Gynaecology and Reproductive Medicine. January. 2012;22:1-5. X-1, X-3, X-4.
2197 Haspel R, Stanworth S, Callum J. Journal Club. Transfusion Medicine Reviews. 2012;26:190-7. X-1, X-2.
2198 Hawkins JL. The anesthesiologist's role during attempted VBAC. Clin Obstet Gynecol. Dec. 2012;55:1005-13. X-1. [pmid: 23090470].
2199 Hendriks J, Zwart JJ, Briet E, et al. The clinical benefit of blood transfusion: a hypothetical experiment based on a nationwide survey of severe maternal morbidity. Vox Sang. Apr. 2012;104:234-9. X-4, X-5. [pmid: 23061811].
2200 Hermida J, Salas B, Sloan NL. Sustainable scale-up of active management of the third stage of labor for prevention of postpartum hemorrhage in Ecuador. Int J Gynaecol Obstet. Jun. 2012;117:278-82. X-2, X-4. [pmid: 22483573].
2201 Hernandez B, Ortiz-Panozo E, Perez-Cuevas R. Facility-based care for delivery and management of complications related to pregnancy and childbirth in Mexico. Salud Publica Mex. Oct. 2012;54:496-505. X-2, X-4. [pmid: 23011501].
2202 Hernandez JS, Alexander JM, Sarode R, et al. Calculated blood loss in severe obstetric hemorrhage and its relation to body mass index. Am J Perinatol. Aug. 2012;29:557-60. X-4. [pmid: 22495893].
2203 Hernandez JS, Wendel GD Jr., Sheffield JS. Trends in emergency peripartum hysterectomy at a single institution: 1988-2009. Am J Perinatol. May. 2012;30:365-70. X-4. [pmid: 22918679].
2204 Hill JS, Devenie G, Powell M. Point-of-care testing of coagulation and fibrinolytic status during postpartum haemorrhage: developing a thrombelastography(R)-guided transfusion algorithm. Anaesth Intensive Care. Nov. 2012;40:1007-15. X-1, X-3. [pmid: 23194210].
2205 Hill S, Yang A, Bero L. Priority medicines for maternal and child health: a global survey of national essential medicines lists. PLoS One. 2012;7:e38055. X-1, X-3. [pmid: 22675435].
2206 Holm C, Langhoff-Roos J, Petersen KB, et al. Severe postpartum haemorrhage and mode of delivery: a retrospective cohort study. BJOG. Apr. 2012;119:596-604. X-2, X-4, X-5. [pmid: 22313728].
2207 Holt R, Santiago-Munoz P, Nelson DB, et al. Sonographic findings in two cases of complicated pregnancy in women previously treated with endometrial ablation. J Clin Ultrasound. Nov-Dec. 2012;41:566-9. X-1, X-4. [pmid: 22855420].
2208 Honey M, Connor K, Veltman M, et al. Teaching with Second Life<sup>®</sup>: Hemorrhage Management as an Example of a Process for Developing Simulations for Multiuser Virtual Environments. Clinical Simulation in Nursing. 2012;8:e79-85. X-1, X-3, X-4.
2209 Huang YY, Zhuang JY, Bao YR, et al. Use of early transverse annular compression sutures for complete placenta previa during cesarean delivery. Int J Gynaecol Obstet. Dec. 2012;119:221-3. X-2, X-5. [pmid: 22925820].
2210 Huissoud C, Cortet M, Dubernard G, et al. A stitch in time: Layers of circular sutures can staunch postpartum hemorrhage. Am J Obstet Gynecol. Feb. 2012;206:177 e1-2. X-4, X-5. [pmid: 22284157].
2211 Hundley VA, Avan BI, Sullivan CJ, et al. Should oral misoprostol be used to prevent postpartum haemorrhage in home-birth settings in low-resource countries? A systematic review of the evidence. BJOG. Feb. 2012;120:277-85. discussion 86-7. X-1, X-2, X-4. [pmid: 23190345].
2212 Iacobelli S, Robillard PY, Gouyon JB, et al. Obstetric and neonatal outcomes of adolescent primiparous singleton pregnancies: a cohort study in the South of Reunion Island, Indian Ocean. J Matern Fetal Neonatal Med. Dec. 2012;25:2591-6. X-2, X-4. [pmid: 22889253].
2213 Iau P, Ong V, Tan WT, et al. Use of activated recombinant factor VII in severe bleeding - Evidence for efficacy and safety in trauma, postpartum hemorrhage, cardiac surgery, and gastrointestinal bleeding. Switzerland. S. Karger AG. (Allschwilerstrasse 10, P.O. Box, Basel CH-4009, Switzerland). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed10&NEWS=N&AN=2012224489. Accessed on (Iau, Ong, Tan, Koh, Hartman) Department of Surgery, National University Hospital, NUHS Tower, 1E Kent Ridge Road, Block, 119228 Singapore, Singapore 39.
2214 Ibrahim MI, Raafat TA, Ellaithy MI, et al. Risk of postpartum uterine synechiae following uterine compression suturing during postpartum haemorrhage. Aust N Z J Obstet Gynaecol. Feb. 2012;53:37-45. X-2, X-5. [pmid: 23163583].
2215 James AH, McLintock C, Lockhart E. Postpartum hemorrhage: when uterotonics and sutures fail. Am J Hematol. May. Suppl 1. 2012;87:S16-22. X-1. [pmid: 22430921].
2216 James AH, Nazzaro A-M. Bleeding disorders: Impact on reproduction. Contemporary OB/GYN. 2012;57:32-9. X-1, X-4.
2217 Jillani K, Wagan F, Shaikh F, et al. B-Lynch suture for the management of postpartum Haemorrhage: An experience at Peoples Medical College Hospital Nawabshah. Medical Forum Monthly. January. 2012;23:23-5. X-2.
2218 Johnston RG, Brown AE. Maternal trait personality and childbirth: the role of extraversion and neuroticism. Midwifery. Nov. 2012;29:1244-50. X-3, X-4. [pmid: 23039942].
2219 Kalburgi EB, Nagathan V, Kuntoji N. Emergency bilateral internal iliac artery ligation - A hospital based, cross sectional study. 2012;6:1223-5. X-2, X-5.
2220 Kaluwa Kaingu C, Oduma JA, Kanui T. Preliminary investigation of contractile activity of Ricinus communis and Euclea divinorum extracts on isolated rabbit uterine strips. J Ethnopharmacol. Jul. 13. 2012;142:496-502. X-2, X-3, X-4. [pmid: 22652367].
2221 Kapungu CT, Mensah-Homiah J, Akosah E, et al. A community-based continuum of care model for the prevention of postpartum hemorrhage in rural Ghana. Int J Gynaecol Obstet. Feb. 2012;120:156-9. X-2, X-4. [pmid: 23199804].
2222 Karateke A, Kucukbas M, Sozen H, et al. Fertility sparing surgery on placenta invasion anomalies and placenta previa. Iranian Journal of Reproductive Medicine. May. 2012;10:271-4. X-2, X-4, X-5. [pmid: 25243004].
2223 Karlsson O, Sporrong T, Hillarp A, et al. Prospective longitudinal study of thromboelastography and standard hemostatic laboratory tests in healthy women during normal pregnancy. Anesth Analg. Oct. 2012;115:890-8. X-3, X-4. [pmid: 22822194].
2224 Kausar F, Morris JL, Fathalla M, et al. Nurses in low resource settings save mothers' lives with non-pneumatic anti-shock garment. MCN Am J Matern Child Nurs. Sep. 2012;37:308-16. X-2, X-5. [pmid: 22895203].
2225 Kawamura A, Kondoh E, Hamanishi J, et al. Cervical clamp with ring forceps to prevent prolapse of an intrauterine balloon in the management of postpartum hemorrhage. J Obstet Gynaecol Res. Mar. 2012;39:733-7. X-1, X-2, X-5. [pmid: 23106866].
2226 Kessous R, Danor D, Weintraub YA, et al. Risk factors for relaparotomy after cesarean section. J Matern Fetal Neonatal Med. Nov. 2012;25:2167-70. X-4, X-5. [pmid: 22394271].
2227 Khan SA, Boko E, Khookhar HA, et al. Acute gastric dilatation resulting in gastric emphysema following postpartum hemorrhage. Case Rep Surg. 2012;2012:230629. X-1, X-4, X-5. [pmid: 22779022].
2228 Khanal L, Dawson P, Silwal RC, et al. Exploration and innovation in addressing maternal, infant and neonatal mortality. J Nepal Health Res Counc. May. 2012;10:88-94. X-1. [pmid: 23034368].
2229 Khaskheli M, Baloch S, Baloch AS. Obstetrical trauma to the genital tract following vaginal delivery. J Coll Physicians Surg Pak. Feb. 2012;22:95-7. X-2, X-4. [pmid: 22313645].
2230 Khatun F, Rasheed S, Moran AC, et al. Causes of neonatal and maternal deaths in Dhaka slums: implications for service delivery. BMC Public Health. 2012;12:84. X-2, X-4. [pmid: 22280444].
2231 Kiesewetter B, Lehner R. Maternal outcome monitoring: induction of labor versus spontaneous onset of labor-a retrospective data analysis. Arch Gynecol Obstet. Jul. 2012;286:37-41. X-4. [pmid: 22298204].
2232 Kilpatrick SJ, Prentice P, Jones RL, et al. Reducing maternal deaths through state maternal mortality review. J Womens Health (Larchmt). Sep. 2012;21:905-9. X-1. [pmid: 22621323].
2233 King JR, Korst LM, Miller DA, et al. Increased composite maternal and neonatal morbidity associated with ultrasonographically suspected fetal macrosomia. J Matern Fetal Neonatal Med. Oct. 2012;25:1953-9. X-4. [pmid: 22439605].
2234 Kitson SJ, Macphail S, Bulmer J. Is pregnancy safe after uterine artery embolisation?. BJOG. Apr. 2012;119:519-21. X-1, X-4, X-5. [pmid: 22329577].
2235 Knight KM, Thornburg LL, Pressman EK. Pregnancy outcomes in type 2 diabetic patients as compared with type 1 diabetic patients and nondiabetic controls. J Reprod Med. Sep-Oct. 2012;57:397-404. X-4. [pmid: 23091986].
2236 Knol HM, Schultinge L, Veeger NJ, et al. The risk of postpartum hemorrhage in women using high dose of low-molecular-weight heparins during pregnancy. Thromb Res. Sep. 2012;130:334-8. X-4, X-5. [pmid: 22475315].
2237 Kocaoglu N, Gunusen I, Karaman S, et al. Management of anesthesia for cesarean section in parturients with placenta previa with/without placenta accreta: a retrospective study. Ginekol Pol. Feb. 2012;83:99-103. X-4. [pmid: 22568353].
2238 Kontoyannis M, Katsetos C, Panagopoulos P. Sexual intercourse during pregnancy. Health Science Journal. 2012. Jan-Mar. 2012;6:82-7. X-1.
2239 Kubio C, Tierney G, Quaye T, et al. Blood transfusion practice in a rural hospital in Northern Ghana, Damongo, West Gonja District. Transfusion. Oct. 2012;52:2161-6. X-2, X-3, X-4. [pmid: 22612858].
2240 Kumar R. Misoprostol and the politics of abortion in Sri Lanka. Reprod Health Matters. Dec. 2012;20:166-74. X-1. [pmid: 23245422].
2241 Labardee RM, Mitch R. Improving Care during a Postpartum Hemorrhage: A Patient Safety Initiative. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2012;41:S82-3. X-1, X-4, X-5.
2242 LaBossiere M. Operation Red Flag: Igniting a Passion and Commitment to Improving Patient Outcomes: An Interdisciplinary Approach to Prevention and Management of Postpartum Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2012;41:S27-S. X-1, X-4, X-5.
2243 Lalonde A. Prevention and treatment of postpartum hemorrhage in low-resource settings. Int J Gynaecol Obstet. May. 2012;117:108-18. X-2. [pmid: 22502595].
2244 Lankford DN, Akins S. Expecting the Unexpected: Proactive Planning for Massive Obstetric Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2012;41:S186-S. X-1.
2245 Lau P, Ong V, Tan WT, et al. Use of Activated Recombinant Factor VII in Severe Bleeding - Evidence for Efficacy and Safety in Trauma, Postpartum Hemorrhage, Cardiac Surgery, and Gastrointestinal Bleeding. Transfus Med Hemother. Apr. 2012;39:139-50. X-1. [pmid: 22670132].
2246 Le Ray C, Scherier S, Anselem O, et al. Association between oocyte donation and maternal and perinatal outcomes in women aged 43 years or older. Hum Reprod. Mar. 2012;27:896-901. X-4. [pmid: 22252087].
2247 Leon W, Durocher J, Barrera G, et al. Dose and side effects of sublingual misoprostol for treatment of postpartum hemorrhage: what difference do they make?. BMC Pregnancy Childbirth. 2012;12:65. X-2. [pmid: 22769055].
2248 Levin I, Rapaport AS, Salzer L, et al. Risk factors for relaparotomy after cesarean delivery. Int J Gynaecol Obstet. Nov. 2012;119(2):163-5. X-4. [pmid: 22921276].
2249 Levin I, Rapaport AS, Satzer L, et al. Risk factors for relaparotomy after cesarean delivery. Int J Gynaecol Obstet. Nov. 2012;119:163-5. X-4, X-5. [pmid: 22921276].
2250 Li X, Wang B, Li Y, et al. The Th1/Th2/Th17/Treg paradigm induced by stachydrine hydrochloride reduces uterine bleeding in RU486-induced abortion mice. J Ethnopharmacol. Jan. 9. 2012;145:241-53. X-3, X-4. [pmid: 23178269].
2251 Li X, Wang Z, Chen J, et al. Uterine artery embolization for the management of secondary postpartum haemorrhage associated with placenta accreta. Clin Radiol. Dec. 2012;67:e71-6. X-2. [pmid: 22974568].
2252 Liang J, Li X, Dai L, et al. The changes in maternal mortality in 1000 counties in mid-Western China by a government-initiated intervention. PLoS One. 2012;7:e37458. X-2, X-4. [pmid: 22629398].
2253 Liang-Kun M, Na N, Jian-Qiu Y, et al. Clinical analysis of placenta previa complicated with previous caesarean section. Chin Med Sci J. Sep. 2012;27:129-33. X-2, X-4. [pmid: 23062633].
2254 Liu AL, Yung WK, Yeung HN, et al. Factors influencing the mode of delivery and associated pregnancy outcomes for twins: a retrospective cohort study in a public hospital. Hong Kong Med J. Apr. 2012;18:99-107. X-4, X-5. [pmid: 22477732].
2255 Lotufo FA, Parpinelli MA, Haddad SM, et al. Applying the new concept of maternal near-miss in an intensive care unit. Clinics (Sao Paulo). 2012;67:225-30. X-2, X-4, X-5. [pmid: 22473402].
2256 Low LK, Bailey JM, Sacks E, et al. Reduced postpartum hemorrhage after implementation of active management of the third stage of labor in rural Honduras. Int J Gynaecol Obstet. Dec. 2012;119:217-20. X-2, X-4. [pmid: 22980430].
2257 Lusis EA, Scheithauer BW, Yachnis AT, et al. Meningiomas in pregnancy: a clinicopathologic study of 17 cases. Neurosurgery. Nov. 2012;71:951-61. X-3, X-4. [pmid: 22843130].
2258 Lyndon A, Lee HC, Gilbert WM, et al. Maternal morbidity during childbirth hospitalization in California. J Matern Fetal Neonatal Med. Dec. 2012;25:2529-35. X-4. [pmid: 22779781].
2259 Ma J, Shao H, Lu X, et al. Safety and efficacy of airbag midwifery in promoting normal vaginal delivery and reducing caesarean section. Iranian Journal of Reproductive Medicine. November/December. 2012;10:595-600. X-2, X-3, X-4. [pmid: 25246932].
2260 Magon N, Babu K. Recombinant Factor VIIa in Post-partum Hemorrhage: A New Weapon in Obstetrician's Armamentarium. N Am J Med Sci. Apr. 2012;4:157-62. X-2, X-5. [pmid: 22536557].
2261 Makino S, Tanaka T, Yorifuji T, et al. Double vertical compression sutures: A novel conservative approach to managing post-partum haemorrhage due to placenta praevia and atonic bleeding. Aust N Z J Obstet Gynaecol. Jun. 2012;52:290-2. X-5. [pmid: 22413844].
2262 Malhotra V, Nanda S, Chauhan MB, et al. Inner myometrial laceration: A newer entity causing postpartum hemorrhage. Journal of Gynecologic Surgery. 01. Dec. 2012;28:439-40. X-2, X-4, X-5.
2263 Mandal D, Dattaray C, Sarkar R, et al. Is pregnancy safe with extrahepatic portal vein obstruction? An analysis. Singapore Med J. Oct. 2012;53:676-80. X-2, X-4. [pmid: 23112020].
2264 Mangla D, Goel JK, Goel R. Prophylactic intramyometrial oxytocin before placenta delivery during cesarean section prevents postpartum hemorrhage: A prospective randomized study of 150 women. Journal of SAFOG. 2012;4:93-6. X-2, X-4.
2265 Manrique Munoz S, Munar Bauza F, Frances Gonzalez S, et al. Update on the use of uterotonic agents. Rev Esp Anestesiol Reanim. Feb. 2012;59:91-7. X-1, X-4. [pmid: 22480555].
2266 Mansueto G, Contro A, Carbognin G, et al. Endovascular treatment in postpartum haemorrhage. Radiol Med. Mar. 2012;118:215-28. X-5. [pmid: 22580802].
2267 Manzoor T, Baig MI, Ambreen A, et al. Morbidity associated with obesity in pregnancy. Medical Forum Monthly. July. 2012;23:23-6. X-2, X-4.
2268 Matsubara S. Available hemostatic measures for postpartum hemorrhage in rural settings. Rural & Remote Health. 2012;12:1-4. X-1, X-4, X-5. [pmid: 22624570].
2269 Matsunaga S, Seki H, Ono Y, et al. A retrospective analysis of transfusion management for obstetric hemorrhage in a Japanese obstetric center. ISRN Obstet Gynecol. 2012;2012:854064. X-4, X-5. [pmid: 22462007].
2270 Matthews LE, Rosenblatt L. Severe preeclampsia causes massive stroke. Healthcare Risk Management. 2012:2-4. X-1.
2271 Mehrabadi A, Hutcheon JA, Lee L, et al. Trends in postpartum hemorrhage from 2000 to 2009: a population-based study. BMC Pregnancy Childbirth. 2012;12:108. X-4. [pmid: 23057683].
2272 Melhado L. Traditional Birth Attendants Can Be Trained To Manage Hemorrhage. International Perspectives on Sexual & Reproductive Health. 2012;38:224-5. X-1, X-4, X-5.
2273 Meyer NP, Ward GH, Chandraharan E. Conservative approach to the management of morbidly adherent placentae. Ceylon Med J. Mar. 2012;57:36-9. X-2, X-5. [pmid: 22453709].
2274 Mir AM, Wajid A, Gull S. Helping rural women in Pakistan to prevent postpartum hemorrhage: a quasi experimental study. BMC Pregnancy Childbirth. 2012;12:120. X-2, X-4. [pmid: 23110458].
2275 Mirzayi F, Akbarzadeh M, Mirzayi M. Evaluation of maternal fetal and neonatal complications according to body mass index in women referred to Shiraz health choice centers, 2009. Iranian Journal of Obstetrics, Gynecology and Infertility. 2012;14. X-2, X-4.
2276 Moazzeni MS. Maternal mortality in the Islamic Republic of Iran: on track and in transition. Matern Child Health J. May. 2012;17:577-80. X-1, X-2. [pmid: 22618490].
2277 Monnin-Bares V, Vincens C, Micheau A, et al. Postpartum hemorrhage: Role of arterial embolization. Sang Thrombose Vaisseaux. 2012;24:125-31. X-1.
2278 Mori R, Nardin JM, Yamamoto N, et al. Umbilical vein injection for the routine management of third stage of labour. Cochrane Database of Systematic Reviews. 2012. X-1.
2279 Mostfa AA, Zaitoun MM. Safety pin suture for management of atonic postpartum hemorrhage. ISRN Obstet Gynecol. 2012;2012:405795. X-2, X-5. [pmid: 22548184].
2280 Mostfa AAM, Zaitoun MM. Safety pin suture for management of atonic postpartum hemorrhage. United States. Hindawi Publishing Corporation. (410 Park Avenue, 15th Floor, 287 pmb, New York NY 10022, United States). 2012. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed10&NEWS=N&AN=2012280137. Accessed on (Mostfa, Zaitoun) Department of Obstetrics and Gynecology, Faculty of Medicine, Zagazig Universiy, P.O. Box 44519, Sharqia, Egypt.
2281 Mulic-Lutvica A. Postpartum Ultrasound. Donald School Journal of Ultrasound in Obstetrics and Gynecology. January-March. 2012;6:76-92. X-1, X-4.
2282 Munireddy RA, Annabelle B. Cervical stenosis following a laser cone biopsy - An uncommon presentation in labour. 2012;6:1306-7. X-3, X-4.
2283 Mustafa R, Hashmi H. Obstetrical referrals by traditional birth attendants. J Ayub Med Coll Abbottabad. Jul-Dec. 2012;24:190-2. X-2, X-4. [pmid: 24669651].
2284 Navid S, Arshad S, Qurat ul A, et al. Impact of leiomyoma in pregnancy. J Ayub Med Coll Abbottabad. Jan-Mar. 2012;24:90-2. X-2, X-4. [pmid: 23855105].
2285 Nielsen BR, Schwarz P, Friis S, et al. Elevated liver enzymes, anaemia and osteopaenia in a young woman. BMJ Case Reports. 2012. X-1.
2286 Nishino K, Hayashi K, Chaya J, et al. Effective salvage of acute massive uterine bleeding using intrauterine balloon tamponade in a uterine adenomyosis patient on dienogest. J Obstet Gynaecol Res. Mar. 2012;39:738-41. X-1, X-2, X-4, X-5. [pmid: 23003209].
2287 Nove A, Berrington A, Matthews Z. Comparing the odds of postpartum haemorrhage in planned home birth against planned hospital birth: results of an observational study of over 500,000 maternities in the UK. BMC Pregnancy Childbirth. 2012;12:130. X-4. [pmid: 23157856].
2288 Obiechina NJ, Eleje GU, Ezebialu IU, et al. Emergency peripartum hysterectomy in Nnewi, Nigeria: a 10-year review. Niger J Clin Pract. Apr-Jun. 2012;15:168-71. X-2. [pmid: 22718166].
2289 Okafor UV, Efetie ER, Amucheazi A. Risk factors for maternal deaths in unplanned obstetric admissions to the intensive care unit-lessons for sub-Saharan Africa. Afr J Reprod Health. Dec. 2012;15:51-4. X-2, X-4. [pmid: 22571105].
2290 Okunola OO, Ayodele OE, Adekanle AD. Acute kidney injury requiring hemodialysis in the tropics. Saudi J Kidney Dis Transpl. Nov. 2012;23:1315-9. X-1, X-2, X-4. [pmid: 23168876].
2291 Oladapo OT. Misoprostol for preventing and treating postpartum hemorrhage in the community: a closer look at the evidence. Int J Gynaecol Obstet. Nov. 2012;119:105-10. X-1. [pmid: 22968139].
2292 Oladapo OT, Fawole B, Blum J, et al. Advance misoprostol distribution for preventing and treating postpartum haemorrhage. Cochrane Database Syst Rev. 2012;2. CD009336. X-1. [pmid: 22336866].
2293 Oladapo OT, Okusanya BO, Abalos E. Intramuscular versus intravenous prophylactic oxytocin for the third stage of labour. Cochrane Database Syst Rev. 2012;2. CD009332. X-1. [pmid: 22336865].
2294 Omole-Ohonsi A, Olayinka HT. Emergency peripartum hysterectomy in a developing country. J Obstet Gynaecol Can. Oct. 2012;34:954-60. X-2, X-4. [pmid: 23067951].
2295 Onwuemene O, Green D, Keith L. Postpartum hemorrhage management in 2012: predicting the future. Int J Gynaecol Obstet. Oct. 2012;119:3-5. X-1. [pmid: 22867727].
2296 Oprea TI, Bauman JE, Bologa CG, et al. Drug repurposing from an academic perspective. Drug Discovery Today: Therapeutic Strategies. Winter. 2012;8:61-9. X-1. [pmid: 22368688].
2297 Orsini J, Butala A, Diaz L, et al. Clinical Profile of Obstetric Patients Admitted to the Medical-Surgical Intensive Care Unit (MSICU) of an Inner-City Hospital in New York. J Clin Med Res. Oct. 2012;4:314-7. X-4. [pmid: 23024733].
2298 Pacheco LD, Saade G, Tyner J, et al. Obstetric hemorrhage New insights. Contemporary OB/GYN. 2012;57:30-8. X-1.
2299 Pacheco LD, Saade G, Tyner J, et al. Obstetric hemorrhage New insights. Contemporary OB/GYN. 2012;57(6):30-8. Language: English. Entry Date: 20120622. Revision Date: 20140704. Publication Type: journal article. X-1.
2300 Pardo MI, Trujillo MV, Campos S, et al. Successful uterine artery embolization for intractable postpartum hemorrhage using a novel embolic agent: ONYX. Journal of Gynecologic Surgery. 01. Aug. 2012;28:309-11. X-5.
2301 Pasquier P, Gayat E, Rackelboom T, et al. An observational study of the fresh frozen plasma: red blood cell ratio in postpartum hemorrhage. Anesth Analg. Jan. 2012;116:155-61. X-4, X-5. [pmid: 23223094].
2302 Pasupathy D, McCowan LM, Poston L, et al. Perinatal outcomes in large infants using customised birthweight centiles and conventional measures of high birthweight. Paediatr Perinat Epidemiol. Nov. 2012;26:543-52. X-4. [pmid: 23061690].
2303 Pellerin O, Bats AS, Di Primio M, et al. Postpartum hemorrhage treated with gelfoam slurry embolization using the superselective technique: immediate results and 1-month MRI follow-up. Cardiovasc Intervent Radiol. Feb. 2012;36:98-104. X-5. [pmid: 22327604].
2304 Penotti M, Vercellini P, Bolis G, et al. Compressive suture of the lower uterine segment for the treatment of postpartum hemorrhage due to complete placenta previa: a preliminary study. Gynecol Obstet Invest. 2012;73:314-20. X-5. [pmid: 22440887].
2305 Petrie J, Lockie C, Paolineli A, et al. Undiagnosed phaeochromocytoma masquerading as eclampsia. BMJ Case Reports. 2012. X-1.
2306 Poblacion Garcia G, Solera Ruiz I, Gredilla E, et al. Analysis of the causes for increases in the length of stay in the Recovery Unit of La Paz Maternity Hospital in 2008. Rev Esp Anestesiol Reanim. Feb. 2012;59:77-82. X-2, X-4. [pmid: 22480553].
2307 Potts M, Henderson CE. Global warming and reproductive health. Int J Gynaecol Obstet. Oct. Suppl 1. 2012;119:S64-7. X-1. [pmid: 22883918].
2308 Prata N, Ejembi C, Fraser A, et al. Community mobilization to reduce postpartum hemorrhage in home births in northern Nigeria. Soc Sci Med. Apr. 2012;74:1288-96. X-2, X-4. [pmid: 22377106].
2309 Prata N, Passano P, Bell S, et al. New hope: community-based misoprostol use to prevent postpartum haemorrhage. Health Policy Plan. Jul. 2012;28:339-46. X-1. [pmid: 22879523].
2310 Prata N, Quaiyum MA, Passano P, et al. Training traditional birth attendants to use misoprostol and an absorbent delivery mat in home births. Soc Sci Med. Dec. 2012;75:2021-7. X-2. [pmid: 22921713].
2311 Puri M, Taneja P, Gami N, et al. Effects of different doses of intraumbilical oxytocin on the third stage of labor. Int J Gynaecol Obstet. Sep. 2012;118:210-2. X-4. [pmid: 22727052].
2312 Pursche T, Diedrich K, Banz-Jansen C. Blood loss after caesarean section: depending on the management of oxytocin application?. Arch Gynecol Obstet. Sep. 2012;286:633-6. X-4. [pmid: 22569708].
2313 Quantin C, Benzenine E, Ferdynus C, et al. Advantages and limitations of using national administrative data on obstetric blood transfusions to estimate the frequency of obstetric hemorrhages. J Public Health (Oxf). Mar. 2012;35:147-56. X-4. [pmid: 22829662].
2314 Quinn KH, Mackey A, Cohen J, et al. A curriculum to teach and evaluate resident skills in the management of postpartum hemorrhage. J Perinat Med. 2012. Aug. 18. X-1, X-2, X-5. [pmid: 23095195].
2315 Radha P, Tagore S, Rahman MF, et al. Maternal and perinatal morbidity after Caesarean delivery at full cervical dilatation. Singapore Med J. Oct. 2012;53:655-8. X-4. [pmid: 23112016].
2316 Raghavan S, Abbas D, Winikoff B. Misoprostol for prevention and treatment of postpartum hemorrhage: what do we know? What is next?. Int J Gynaecol Obstet. Oct. Suppl 1. 2012;119:S35-8. X-1. [pmid: 22883912].
2317 Rath W, Hackethal A, Bohlmann MK. Second-line treatment of postpartum haemorrhage (PPH). Arch Gynecol Obstet. Sep. 2012;286:549-61. X-1. [pmid: 22552376].
2318 Rathore AM, Gupta S, Manaktala U, et al. Uterine tamponade using condom catheter balloon in the management of non-traumatic postpartum hemorrhage. J Obstet Gynaecol Res. Sep. 2012;38:1162-7. X-2, X-5. [pmid: 22540529].
2319 Rattray DD, O'Connell CM, Baskett TF. Acute disseminated intravascular coagulation in obstetrics: a tertiary centre population review (1980 to 2009). J Obstet Gynaecol Can. Apr. 2012;34:341-7. X-5. [pmid: 22472333].
2320 Riiskjaer M, Petersen OB, Uldbjerg N, et al. Feasibility and clinical effects of laparoscopic abdominal cerclage: an observational study. Acta Obstet Gynecol Scand. Nov. 2012;91:1314-8. X-4, X-5. [pmid: 22974182].
2321 Rios FG, Risso-Vazquez A, Alvarez J, et al. Clinical characteristics and outcomes of obstetric patients admitted to the intensive care unit. Int J Gynaecol Obstet. Nov. 2012;119:136-40. X-2, X-4, X-5. [pmid: 22902192].
2322 Roach MK, Abramovici A, Tita AT. Dose and duration of oxytocin to prevent postpartum hemorrhage: a review. Am J Perinatol. Aug. 2012;30:523-8. X-1, X-4, X-5. [pmid: 23208766].
2323 Robalo R, Pedroso C, Agapito A, et al. Acute Sheehan's syndrome presenting as central diabetes insipidus. BMJ Case Rep. 2012;2012. X-1, X-4. [pmid: 23131607].
2324 Robertson JE, Silversides CK, Mah ML, et al. A contemporary approach to the obstetric management of women with heart disease. J Obstet Gynaecol Can. Sep. 2012;34:812-9. X-4. [pmid: 22971448].
2325 Robinson AJ, Muller PR, Allan R, et al. Precise mid-trimester placenta localisation: does it predict adverse outcomes?. Aust N Z J Obstet Gynaecol. Apr. 2012;52:156-60. X-4. [pmid: 22369139].
2326 Rodgers C. Low-tech first aid for obstetric hemorrhage. Midwifery Today Int Midwife. Autumn. 2012:56-7. [pmid: 23061157]. X-1, X-4, X-5.
2327 Rodgers C. Life Wraps: Low-tech First Aid for Obstetric Hemorrhage. Midwifery Today. 2012:56-7. X-1, X-4, X-5.
2328 Rogers C, Harman J, Selo-Ojeme D. The management of the third stage of labour--A national survey of current practice. British Journal of Midwifery. 2012;20:850-7. X-3, X-4.
2329 Sagot P, Mourtialon P, Benzenine E, et al. Accuracy of blood transfusion in postpartum hemorrhage to assess maternal morbidity. Eur J Obstet Gynecol Reprod Biol. Jun. 2012;162:160-4. X-4, X-5. [pmid: 22429477].
2330 Saleh Gargari S, Fallahian M, Haghighi L, et al. Maternal and neonatal complications of substance abuse in Iranian pregnant women. Acta Med Iran. 2012;50:411-6. X-2, X-3, X-4. [pmid: 22837120].
2331 Sarwar I, Habib S, Bibi A, et al. Clinical audit of foetomaternal outcome in pregnancies with fibroid uterus. J Ayub Med Coll Abbottabad. Jan-Mar. 2012;24:79-82. X-2, X-3, X-4. [pmid: 23855102].
2332 Scholes J, Endacott R, Biro M, et al. Clinical decision-making: midwifery students' recognition of, and response to, post partum haemorrhage in the simulation environment. BMC Pregnancy Childbirth. 2012;12:19. X-4, X-5. [pmid: 22443712].
2333 Sengupta Dhar R, Misra R. Postpartum Uterine Wound Dehiscence Leading to Secondary PPH: Unusual Sequelae. Case Rep Obstet Gynecol. 2012;2012:154685. X-2, X-5. [pmid: 22720176].
2334 Senturk MB, Cakmak Y, Yildiz G, et al. Tranexamic acid for cesarean section: a double-blind, placebo-controlled, randomized clinical trial. Arch Gynecol Obstet. Apr. 2012;287:641-5. X-2, X-4, X-5. [pmid: 23143410].
2335 Shafaei FS, Kazemzadeh R, Heshmat R, et al. Effect of acupressure at Sanyinjiao (SP6)-hugo (LI4) points on delivery length in nulliparous women: A randomized controlled trial. Iranian Journal of Obstetrics, Gynecology and Infertility. 15. Nov. 2012;15:21-8. X-1, X-2, X-4.
2336 Shahbazi S, Moghaddam-Banaem L, Ekhtesari F, et al. Impact of inherited bleeding disorders on pregnancy and postpartum hemorrhage. Blood Coagul Fibrinolysis. Oct. 2012;23:603-7. X-4. [pmid: 22821002].
2337 Sheng C, Yu YH, Zhao KS, et al. Acute lung inflammatory response and injury after hemorrhagic shock are more severe in postpartum rabbits. Crit Care Med. May. 2012;40:1570-7. X-1, X-3, X-4. [pmid: 22430240].
2338 Sheriff FG, Howlett WP, Kilonzo KG. Post-partum pituitary insufficiency and livedo reticularis presenting a diagnostic challenge in a resource limited setting in Tanzania: A case report, clinical discussion and brief review of existing literature. BMC Endocrine Disorders. 14. May. 2012:12. X-1, X-2. [pmid: 22776317].
2339 Shoaib M, Afridi U, Huma ZE, et al. Maternal and fetal complications associated with full term breech delivery in sandeman provincial hospital, Quetta. 2012;6:620-2. X-2, X-4.
2340 Shukla M, Qureshi S. Post-placental intrauterine device insertion--a five year experience at a tertiary care centre in north India. Indian J Med Res. Sep. 2012;136:432-5. X-2, X-3, X-4. [pmid: 23041736].
2341 Shukla M, Qureshi S, Chandrawati. Post-placental intrauterine device insertion - A five year experience at a tertiary care centre in north India. Indian Journal of Medical Research, Supplement. 2012;136:432-5. X-2, X-3, X-4.
2342 Sierra A, Burrel M, Sebastia C, et al. Utility of multidetector CT in severe postpartum hemorrhage. Radiographics. Sep-Oct. 2012;32:1463-81. X-1, X-4. [pmid: 22977030].
2343 Sikirica V, Broder MS, Chang E, et al. Clinical and economic impact of adhesiolysis during repeat cesarean delivery. Acta Obstet Gynecol Scand. Jun. 2012;91:719-25. X-3, X-4. [pmid: 22404156].
2344 Simsek Y, Celen S, Danisman N, et al. Removal of uterine fibroids during cesarean section: a difficult therapeutic decision. Clin Exp Obstet Gynecol. 2012;39:76-8. X-3, X-4. [pmid: 22675961].
2345 Snowdon C, Elbourne D, Forsey M, et al. Information-hungry and disempowered: a qualitative study of women and their partners' experiences of severe postpartum haemorrhage. Midwifery. Dec. 2012;28:791-9. X-4, X-5. [pmid: 22365835].
2346 Solomon C, Collis RE, Collins PW. Haemostatic monitoring during postpartum haemorrhage and implications for management. Br J Anaesth. Dec. 2012;109:851-63. X-1. [pmid: 23075633].
2347 Somalwar SA, Joshi SA, Bhalerao AV, et al. Total uterine necrosis: A complication of b-lynch suture. Journal of SAFOG. 2012;4:61-3. X-1, X-2.
2348 Sovik E, Stokkeland P, Storm BS, et al. The use of aortic occlusion balloon catheter without fluoroscopy for life-threatening post-partum haemorrhage. Acta Anaesthesiol Scand. Mar. 2012;56:388-93. X-4, X-5. [pmid: 22260088].
2349 Soyer P, Sirol M, Fargeaudou Y, et al. Placental vascularity and resorption delay after conservative management of invasive placenta: MR imaging evaluation. Eur Radiol. Jan. 2012;23:262-71. X-4. [pmid: 22760345].
2350 Spatling L. “Quilting” sutures to prevent hysterectomy in patients with postpartum hemorrhage. Int J Gynaecol Obstet. Jun. 2012;117:291. X-5. [pmid: 22424662].
2351 Stanton C, Koski A, Cofie P, et al. Uterotonic drug quality: an assessment of the potency of injectable uterotonic drugs purchased by simulated clients in three districts in Ghana. BMJ Open. 2012;2. X-2, X-3, X-4. [pmid: 22556159].
2352 Stanton CK, Newton S, Mullany LC, et al. Impact on postpartum hemorrhage of prophylactic administration of oxytocin 10 IU via Uniject by peripheral health care providers at home births: design of a community-based cluster-randomized trial. BMC Pregnancy Childbirth. 2012;12:42. X-2, X-3, X-4. [pmid: 22676921].
2353 Stefanovic V, Paavonen J, Loukovaara M, et al. Intravenous sulprostone infusion in the treatment of retained placenta. Acta Obstet Gynecol Scand. Apr. 2012;92:426-32. X-4, X-5. [pmid: 22862433].
2354 Stock SJ, Ferguson E, Duffy A, et al. Outcomes of elective induction of labour compared with expectant management: population based study. BMJ. 2012;344:e2838. X-4. [pmid: 22577197].
2355 Stolk KH, Zwart JJ, Schutte J, et al. Severe maternal morbidity and mortality from amniotic fluid embolism in the Netherlands. Acta Obstet Gynecol Scand. Aug. 2012;91:991-5. X-4. [pmid: 22568783].
2356 Sutton L. Update on postpartum haemorrgahe. Midwives. 2012;15:52-3. X-1.
2357 Sutton L. Update on postpartum haemorrhage. Midwives. 2012;15:52-3. [pmid: 24868694]. X-1, X-4, X-5.
2358 Suzuki S, Hiraizumi Y, Miyake H. Risk factors for postpartum hemorrhage requiring transfusion in cesarean deliveries for Japanese twins: comparison with those for singletons. Arch Gynecol Obstet. Dec. 2012;286:1363-7. X-4. [pmid: 22810621].
2359 Taebi M, Kalahroudi MA, Sadat Z, et al. The duration of the third stage of labor and related factors. Iran J Nurs Midwifery Res. Feb. 2012;17(2 Suppl 1):S76-9. X-2, X-4. [pmid: 23833605].
2360 Talungchit P, Liabsuetrakul T. Clinical audit of postpartum hemorrhage at district-level and referral-level hospitals in southern Thailand. J Med Assoc Thai. Oct. 2012;95:1244-51. X-2, X-4. [pmid: 23193735].
2361 Tammello DA. Pregnancy after tubes tied; Fishie clip found floating around (Medical Law Case on Point. Medical Law's Regan Report. 2012;45. 1p. X-1.
2362 Tathem K, Harris LJ, O'Rourke P, et al. Dinoprostone vaginal pessary for induction of labour: safety of use for up to 24 h. Aust N Z J Obstet Gynaecol. Dec. 2012;52:582-7. X-4. [pmid: 23004009].
2363 Tavasoli F, Saghafi N, Ghomian N, et al. Comparison of effects of labetalol and hydralazine in treatment of hypertension in patients with severe preeclampsia. Iranian Journal of Obstetrics, Gynecology and Infertility. September. 2012;15:1-7. X-1, X-2, X-4.
2364 Thabet A, Kalva SP, Liu B, et al. Interventional radiology in pregnancy complications: indications, technique, and methods for minimizing radiation exposure. Radiographics. Jan-Feb. 2012;32:255-74. X-1. [pmid: 22236906].
2365 Thies-Lagergren L, Kvist LJ, Christensson K, et al. Striving for scientific stringency: a re-analysis of a randomised controlled trial considering first-time mothers' obstetric outcomes in relation to birth position. BMC Pregnancy Childbirth. 2012;12:135. X-4. [pmid: 23173988].
2366 Tindell K, Garfinkel R, Abu-Haydar E, et al. Uterine balloon tamponade for the treatment of postpartum haemorrhage in resource-poor settings: a systematic review. BJOG. Jan. 2012;120:5-14. X-1. [pmid: 22882240].
2367 Tita AT, Szychowski JM, Rouse DJ, et al. Higher-dose oxytocin and hemorrhage after vaginal delivery: a randomized controlled trial. Obstet Gynecol. Feb. 2012;119:293-300. X-4. [pmid: 22227638].
2368 Toledo P, Eosakul ST, Goetz K, et al. Decay in blood loss estimation skills after web-based didactic training. Simul Healthc. Feb. 2012;7:18-21. X-1, X-3, X-4. [pmid: 22228284].
2369 Tuncalp O, Hofmeyr GJ, Gulmezoglu AM. Prostaglandins for preventing postpartum haemorrhage. Cochrane Database Syst Rev. 2012;8. CD000494. X-1, X-4. [pmid: 22895917].
2370 Urundady V, Shetty V. Uterine artery embolisation for management of refractory postpartal haemmorhage. Journal of Clinical and Diagnostic Research. 15. Dec. 2012;6:1753-5. X-2, X-5. [pmid: 23373044].
2371 Uzoechina NS Jr., Abiola AO, Akodu BA, et al. Pattern and outcome of cases seen at the Adult Accident and Emergency Department of the Lagos University Teaching Hospital, Idi-Araba, Lagos. Nig Q J Hosp Med. Jul-Sep. 2012;22:209-15. X-2, X-3, X-4. [pmid: 24564099].
2372 Vahdat M, Mehdizadeh A, Sariri E, et al. Placenta percreta invading broad ligament and parametrium in a woman with two previous cesarean sections: a case report. Case Rep Obstet Gynecol. 2012;2012:251381. X-2, X-4, X-5. [pmid: 23097727].
2373 van Stralen G, Veenhof M, Holleboom C, et al. No reduction of manual removal after misoprostol for retained placenta: a double-blind, randomized trial. Acta Obstet Gynecol Scand. Apr. 2012;92:398-403. X-3, X-4. [pmid: 23231499].
2374 von Kohler C. Implementation of an Obstetric Hemorrhage Protocol Outside the Obstetric Department. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2012;41:S182-S. X-1, X-4, X-5.
2375 Vrachnis N, Iavazzo C, Salakos N, et al. Uterine tamponade balloon for the management of massive hemorrhage during cesarean section due to placenta previa/increta. Clin Exp Obstet Gynecol. 2012;39:255-7. X-4, X-5. [pmid: 22905480].
2376 Wagner V, Osepchook C, Harney E, et al. Remote Midwifery in Nunavik, Québec, Canada: Outcomes of Perinatal Care for the Inuulitsivik Health Centre, 2000-2007. Birth: Issues in Perinatal Care. 2012;39:230-7. X-4.
2377 Weissmann-Brenner A, Simchen MJ, Zilberberg E, et al. Maternal and neonatal outcomes of large for gestational age pregnancies. Acta Obstet Gynecol Scand. Jul. 2012;91:844-9. X-4. [pmid: 22471810].
2378 Wikkelsoe AJ, Afshari A, Stensballe J, et al. The FIB-PPH trial: fibrinogen concentrate as initial treatment for postpartum haemorrhage: study protocol for a randomised controlled trial. Trials. 2012;13:110. X-1, X-2, X-4, X-5. [pmid: 22805300].
2379 Winikoff B, Durocher J. Postpartum bleeding is reduced with sublingual powdered misoprostol when compared with oxytocin injection, but a new formulation of misoprostol is unlikely to revolutionise postpartum haemorrhage care. Evid Based Med. Aug. 2012;18:143-4. X-1, X-2, X-4, X-5. [pmid: 23125238].
2380 Witiw CD, Abou-Hamden A, Kulkarni AV, et al. Cerebral cavernous malformations and pregnancy: hemorrhage risk and influence on obstetrical management. Neurosurgery. Sep. 2012;71:626-30. discussion 31. X-3, X-4. [pmid: 22710379].
2381 Xu J, Gao W, Ju Y. Tranexamic acid for the prevention of postpartum hemorrhage after cesarean section: a double-blind randomization trial. Arch Gynecol Obstet. Mar. 2012;287:463-8. X-4. [pmid: 23064441].
2382 Yaeko K, Hiromi ETO, Mariko I, et al. Japan Academy of Midwifery: 2012 evidence-based guidelines for midwifery care during childbirth. Journal of Japan Academy of Midwifery. 2012;26:275-83. X-1.
2383 Yang HJ, Shen RG, Li H, et al. Study on maternal deaths in Beijing, from 1996 to 2010. Zhonghua Liu Xing Bing Xue Za Zhi. Nov. 2012;32:1131-4. X-2, X-4. [pmid: 22336550].
2384 Yassaee F, Eskandari R, Amiri Z. Pregnancy outcomes in women with idiopathic thrombocytopenic purpura. Iranian Journal of Reproductive Medicine. September. 2012;10:489-92. X-1, X-2, X-4. [pmid: 25246917].
2385 Yazdani S, Yosofniyapasha Y, Nasab BH, et al. Effect of maternal body mass index on pregnancy outcome and newborn weight. BMC Res Notes. 2012;5:34. X-4. [pmid: 22251801].
2386 Yi SW, Lee JH. Uterine pseudoaneurysm leakage may cause delayed postpartum haemorrhage: multidetector CT with angiography and transcatheter uterine arterial embolisation. J Obstet Gynaecol. Aug. 2012;32:552-5. X-2, X-5. [pmid: 22779960].
2387 You F, Huo K, Wang R, et al. Maternal mortality in Henan Province, China: changes between 1996 and 2009. PLoS One. 2012;7:e47153. X-2, X-4. [pmid: 23071740].
2388 2013. [pmid: 23844453]. X-1, X-2, X-5.
2389 2013. [pmid: 23586122]. X-1.
2390 Hemorrhage. Midwifery Today. 2013:7. X-1, X-4.
2391 Over $4.6 million award for failure to maintain adequate blood supply resulting in death of mother. Healthcare Risk Management. 2013;35:3-4. X-1, X-4.
2392 Postpartum hemorrhage in the developed world: wither misoprostol?. Essentially MIDIRS. 2013;4:10. X-1, X-4, X-5.
2393 Should we be using misoprostol to prevent postpartum haemorrhage?... PIC. Practising Midwife. 2013;16:9. X-1, X-4, X-5.
2394 Postpartum hemorrhage shows higher incidence in antidepressant users. Brown University Psychopharmacology Update. 2013;24:4. X-1, X-4.
2395 Study finds that postpartum haemorrhage during a first pregnancy does not affect future pregnancies. MIDIRS Midwifery Digest. 2013;23(2):265. Language: English. Entry Date: 20140214. Revision Date: 20140926. Publication Type: journal article. X-1.
2396 Abasiattai AM, Umoiyoho AJ, Utuk NM, et al. Emergency peripartum hysterectomy in a tertiary hospital in southern Nigeria. Pan Afr Med J. 2013;15:60. X-2. [pmid: 24147186].
2397 Abbasi N, Balayla J, Laporta DP, et al. Trends, risk factors and mortality among women with venous thromboembolism during labour and delivery: a population-based study of 8 million births. Arch Gynecol Obstet. Feb. 2013;289:275-84. X-4. [pmid: 23864199].
2398 Adu-Bonsaffoh K, Oppong SA, Binlinla G, et al. Maternal deaths attributable to hypertensive disorders in a tertiary hospital in Ghana. Int J Gynaecol Obstet. Nov. 2013;123(2):110-3. X-2, X-4. [pmid: 23969337].
2399 Adu-Bonsaffoh K, Samuel OA, Binlinla G. Maternal deaths attributable to hypertensive disorders in a tertiary hospital in Ghana. Int J Gynaecol Obstet. Nov. 2013;123:110-3. X-2, X-4. [pmid: 23969337].
2400 Aengst J. Silences and Moral Narratives: Infanticide as Reproductive Disruption. Med Anthropol. 2013. Dec. 9. X-1. [pmid: 24321033].
2401 Afshari P, Medforth J, Aarabi M, et al. Management of third stage labour following vaginal birth in Iran: A survey of current policies. Midwifery. Jan. 2013;30:65-71. X-2, X-4. [pmid: 23522664].
2402 Aj J. Overview of postpartum hemorrhage. UpToDate. 2013. X-1, X-4, X-5.
2403 Ajayi OA, Sant M, Ikhena S, et al. Uterine rupture complicating sequential curettage and Bakri balloon tamponade to control secondary PPH. BMJ Case Reports. 2013. X-4.
2404 Al-Azemi N, Diejomaoh MF, Angelaki E, et al. Clinical presentation and management of diabetes mellitus in pregnancy. International Journal of Women's Health. 2013;6. X-2, X-3, X-4.
2405 Al-Farsi SH, Al-Riyami NM, Al-Khabori MK, et al. Maternal complications and the association with baseline variables in pregnant women with sickle cell disease. Hemoglobin. 2013;37:219-26. X-4. [pmid: 23590330].
2406 Alfirevic Z, Milan SJ, Livio S. Caesarean section versus vaginal delivery for preterm birth in singletons. Cochrane Database Syst Rev. 2013;9. CD000078. X-1. [pmid: 24030708].
2407 Ali MK, Badee AY, Abbas AM, et al. A novel technique for modified B-Lynch suture for the control of atonic postpartum haemorrhage. Aust N Z J Obstet Gynaecol. Feb. 2013;53:94-7. X-2, X-4, X-5. [pmid: 23405999].
2408 Ali MK, Badee AYA, Abbas AM, et al. A novel technique for modified B- Lynch suture for the control of atonic postpartum haemorrhage. Australian & New Zealand Journal of Obstetrics & Gynaecology. 2013;53(1):94-7. Language: English. Entry Date: 20130301. Revision Date: 20140214. Publication Type: journal article. X-2, X-5. [pmid: 23405999].
2409 Al-Sawaf A, El-Mazny A, Shohayeb A. A randomised controlled trial of sublingual misoprostol and intramuscular oxytocin for prevention of postpartum haemorrhage. J Obstet Gynaecol. Apr. 2013;33:277-9. X-2, X-4, X-5. [pmid: 23550857].
2410 Anandakrishnan S, Balki M, Farine D, et al. Carbetocin at elective Cesarean delivery: a randomized controlled trial to determine the effective dose, part 2. Can J Anaesth. Nov. 2013;60:1054-60. X-4. [pmid: 24158878].
2411 Anjum S, Sarfraz N, Masood MS. Pharmacological management of postpartum hemorrhage by giving P/R misoprostol after failure of syntocinon. 2013;7:948-50. X-2.
2412 Antony KM, Dildy GA 3rd. Postpartum hemorrhage: the role of the Maternal-Fetal Medicine specialist in enhancing quality and patient safety. Semin Perinatol. Aug. 2013;37:246-56. X-1. [pmid: 23916023].
2413 Antony KM, Dildy GA. Postpartum hemorrhage: The role of the Maternal–Fetal Medicine specialist in enhancing quality and patient safety. Seminars in Perinatology. 2013;37:246-56. X-1. [pmid: 23916023].
2414 Artymuk N, Surina M, Marochko T. Active management of the third stage of labor with and without controlled cord traction. Int J Gynaecol Obstet. Jan. 2013;124:84-5. X-4. [pmid: 24156986].
2415 Arumugham S, Mathew M, Deoskar S, et al. Uterine torsion mimicking supine hypotension syndrome after regional anaesthesia. BMJ Case Reports. 2013;31. X-1, X-3, X-4.
2416 Austin DM, Sadler L, McLintok C, et al. Early detection of severe maternal morbidity: A retrospective assessment of the role of an Early Warning Score System. Aust N Z J Obstet Gynaecol. 2013. Dec. 23. X-2, X-4. [pmid: 24359235].
2417 Aviram A, Raban O, Melamed N, et al. The association between young maternal age and pregnancy outcome. J Matern Fetal Neonatal Med. Oct. 2013;26:1554-8. X-1, X-4. [pmid: 23570233].
2418 Ayaz H, Black M, Madhuvrata P, et al. Maternal and neonatal outcomes following additional doses of vaginal prostaglandin E2 for induction of labour: a retrospective cohort study. Eur J Obstet Gynecol Reprod Biol. Oct. 2013;170:364-7. X-4. [pmid: 23932182].
2419 Aziz S, Soomro N. Twin births and their complications in women of low socioeconomic profile. J Pak Med Assoc. Nov. 2013;62:1204-8. X-2, X-4. [pmid: 23866412].
2420 Baghirzada L, Downey KN, Macarthur AJ. Assessment of quality of life indicators in the postpartum period. Int J Obstet Anesth. Jul. 2013;22:209-16. X-4, X-5. [pmid: 23707037].
2421 Bahl R, Van de Venne M, Macleod M, et al. Maternal and neonatal morbidity in relation to the instrument used for mid-cavity rotational operative vaginal delivery: a prospective cohort study. BJOG. Nov. 2013;120:1526-32. X-4. [pmid: 23924292].
2422 Bai J, Sun Q, Zhai H. A comparison of oxytocin and carboprost tromethamine in the prevention of postpartum hemorrhage in high-risk patients undergoing cesarean delivery. Exp Ther Med. Jan. 2013;7:46-50. X-4. [pmid: 24348762].
2423 Bailit JL, Grobman WA, Rice MM, et al. Risk-adjusted models for adverse obstetric outcomes and variation in risk-adjusted outcomes across hospitals. Am J Obstet Gynecol. Nov. 2013;209:446 e1-e30. X-4. [pmid: 23891630].
2424 Bangal Vidyadhar B, Giri Purushottam A, Gavhane Satyajit P, et al. Grim face of maternal mortality at tertiary care hospital of rural India: A 16 years study. 2013;4:197-201. X-1, X-2, X-4.
2425 Baser E, Seckin KD, Erkilinc S, et al. The impact of parity on perinatal outcomes in pregnancies complicated by advanced maternal age. Journal of the Turkish German Gynecology Association. December. 2013;14:205-9. X-2, X-4, X-5.
2426 Bateman B, Hernandez-Diaz S, Huybrechts K, et al. Outpatient calcium-channel blockers and the risk of postpartum haemorrhage: a cohort study. BJOG. 2013. Sep. 11. X-4. [pmid: 24020971].
2427 Bateman BT, Hernandez-Diaz S, Huybrechts KF, et al. Outpatient calcium-channel blockers and the risk of postpartum haemorrhage: a cohort study. BJOG. Dec. 2013;120(13):1668-76. dicussion 76-7. X-4. [pmid: 24020971].
2428 Baud D, Rouiller S, Hohlfeld P, et al. Adverse obstetrical and neonatal outcomes in elective and medically indicated inductions of labor at term. J Matern Fetal Neonatal Med. Nov. 2013;26:1595-601. X-4. [pmid: 23581489].
2429 Baumann Kreuziger LM, Morton CT, Reding MT. Is prophylaxis required for delivery in women with factor VII deficiency?. Haemophilia. Nov. 2013;19:827-32. X-1. [pmid: 23607277].
2430 Bazant E, Rakotovao JP, Rasolofomanana JR, et al. Quality of care to prevent and treat postpartum hemorrhage and pre-eclampsia/eclampsia : an observational assessment in Madagascar's hospitals. Med Sante Trop. May. 1. 2013;23:168-75. X-2, X-4. [pmid: 23694783].
2431 Beltman JJ, van den Akker T, Bwirire D, et al. Local health workers' perceptions of substandard care in the management of obstetric hemorrhage in rural Malawi. BMC Pregnancy Childbirth. 2013;13:39. X-2, X-3. [pmid: 23414077].
2432 Berg RC, Underland V. The obstetric consequences of female genital mutilation/cutting: a systematic review and meta-analysis. Obstet Gynecol Int. 2013;2013:496564. X-1, X-4. [pmid: 23878544].
2433 Berlit S, Nickol J, Weiss C, et al. Cervical dilatation and curettage in elective caesarean section. A retrospective analysis. In Vivo. Sep-Oct. 2013;27:661-5. X-4. [pmid: 23988903].
2434 Bernitz S, Oian P, Rolland R, et al. Oxytocin and dystocia as risk factors for adverse birth outcomes: A cohort of low-risk nulliparous women. Midwifery. 2013. May. 16. X-4. [pmid: 23684697].
2435 Bhandari S, Raja EA, Shetty A, et al. Maternal and perinatal consequences of antepartum haemorrhage of unknown origin. BJOG. Jan. 2013;121:44-50. discussion -2. X-4, X-5. [pmid: 24125550].
2436 Bharti A, Puri S, Mohan B, et al. Maternal heart disease and pregnancy outcomes. JK Science. January- March. 2013;15:7-10. X-2, X-4.
2437 Bhatti K, Lashari AA, Shaikh F, et al. Eclapsia: Still a major cause for adverse maternal and perinatal outcome. Medical Forum Monthly. March. 2013;24:15-7. X-2, X-4.
2438 Bildircin FD, Kurtoglu E, Kokcu A, et al. Comparison of perinatal outcome between adolescent and adult pregnancies. J Matern Fetal Neonatal Med. 2013. Sep. 5. X-2, X-3, X-4. [pmid: 23899128].
2439 Bohlmann MK, Rath W. Medical prevention and treatment of postpartum hemorrhage: a comparison of different guidelines. Arch Gynecol Obstet. Mar. 2013;289:555-67. X-1. [pmid: 24006033].
2440 Boisrame T, Sananes N, Fritz G, et al. Abruptio placentae. Diagnosis, management and maternal-fetal prognosis: A retrospective study of 100 cases. Gynecol Obstet Fertil. 2013. Dec. 2. X-4. [pmid: 24309032].
2441 Bonnet MP, Basso O, Bouvier-Colle MH, et al. Postpartum haemorrhage in Canada and France: a population-based comparison. PLoS One. 2013;8:e66882. X-4, X-5. [pmid: 23826165].
2442 Bouaziz M, Chaari A, Turki O, et al. Acute renal failure and pregnancy: a seventeen-year experience of a Tunisian intensive care unit. Ren Fail. Oct. 2013;35:1210-5. X-2, X-4. [pmid: 24021030].
2443 Boulet SL, Okoroh EM, Azonobi I, et al. Sickle cell disease in pregnancy: maternal complications in a Medicaid-enrolled population. Matern Child Health J. Feb. 2013;17:200-7. X-4. [pmid: 23315242].
2444 Boynukalin FK, Boyar H, Gormus H, et al. Bilateral hypogastric artery ligation in emergency setting for intractable postpartum hemorrhage: a secondary care center experience. Clin Exp Obstet Gynecol. 2013;40:85-8. X-2, X-4, X-5. [pmid: 23724515].
2445 Breborowicz GH, Markwitz W, Gaca M, et al. Conservative management of placenta previa complicated by abnormal placentation. J Matern Fetal Neonatal Med. Jul. 2013;26:1012-5. X-1, X-4. [pmid: 23350544].
2446 Brookfield KF, Goodnough LT, Lyell DJ, et al. Perioperative and transfusion outcomes in women undergoing cesarean hysterectomy for abnormal placentation. Transfusion. 2013. Nov. 4. X-2, X-4, X-5. [pmid: 24188691].
2447 Broughton EI, Ikram AN, Sahak I. How accurate are medical record data in Afghanistan's maternal health facilities? An observational validity study. BMJ Open. 2013;3. X-2, X-4.
2448 Brown G, Allen L, Torkelson A. Direct patient interventions that can reduce maternal mortality in developing countries: a systematic review. Fam Med. Sep. 2013;45:550-7. X-1, X-3. [pmid: 24129867].
2449 Burke C, Grobman W, Miller D. Interdisciplinary collaboration to maintain a culture of safety in a labor and delivery setting. J Perinat Neonatal Nurs. Apr-Jun. 2013;27:113-23. quiz 24-5. X-1, X-2, X-4, X-5. [pmid: 23618932].
2450 Butcher C, Plyman C, Hughes M, et al. Clubbing, cyanosis and a new diagnosis of atrial septal defect in a parturient: a straightforward diagnosis of Eisenmenger syndrome?. BMJ Case Reports. 2013. X-1, X-3, X-4.
2451 Caliskan E, Cakiroglu Y, Aynioglu O, et al. Menstrual pattern and intrauterine adhesions after transuterine suture for postpartum hemorrhage. J Reprod Med. May-Jun. 2013;58:212-8. X-2. [pmid: 23763005].
2452 Calvert C, Ronsmans C. HIV and the risk of direct obstetric complications: a systematic review and meta-analysis. PLoS One. 2013;8:e74848. X-2, X-4. [pmid: 24124458].
2453 Calvert KL, McGurgan PM, Debenham EM, et al. Emergency obstetric simulation training: How do we know where we are going, if we don't know where we have been?. Aust N Z J Obstet Gynaecol. Dec. 2013;53:509-16. X-1. [pmid: 24033002].
2454 Canonico S, Arduini M, Epicoco G, et al. Placenta Previa Percreta: A Case Report of Successful Management via Conservative Surgery. Case Rep Obstet Gynecol. 2013;2013:702067. X-2, X-5. [pmid: 23401816].
2455 Carbone JF, Tuuli MG, Fogertey PJ, et al. Combination of Foley bulb and vaginal misoprostol compared with vaginal misoprostol alone for cervical ripening and labor induction: a randomized controlled trial. Obstet Gynecol. Feb. 2013;121:247-52. X-3, X-4. [pmid: 23303106].
2456 Catling-Paull C, Coddington RL, Foureur MJ, et al. Publicly funded homebirth in Australia: a review of maternal and neonatal outcomes over 6 years. Med J Aust. Jun. 17. 2013;198:616-20. X-4. [pmid: 23919710].
2457 Cenksoy PO, Ficicioglu C, Yesiladali M, et al. The Diagnosis and Management of Asherman's Syndrome Developed after Cesarean Section and Reproductive Outcome. Case Rep Obstet Gynecol. 2013;2013:450658. X-1, X-3. [pmid: 23840987].
2458 Chaabane K, Trigui K, Kebaili S, et al. Antepartum detection of macrosomic fetus: the effect of misdiagnosis. Tunis Med. Apr. 2013;91:240-2. X-4. [pmid: 23673701].
2459 Chai VY, To WW. Uterine compression sutures for management of severe postpartum haemorrhage: a 5-year audit. Hong Kong Med J. 2013. Oct. 21. X-2, X-5. [pmid: 24141858].
2460 Chamilos C, Sgouros S. Intrauterine grade IV intraventricular hemorrhage in a full-term infant leading to hydrocephalus. Childs Nerv Syst. May. 2013;29:861-5. X-1. [pmid: 23319105].
2461 Chantraine F, Braun T, Gonser M, et al. Prenatal diagnosis of abnormally invasive placenta reduces maternal peripartum hemorrhage and morbidity. Acta Obstet Gynecol Scand. Apr. 2013;92:439-44. X-4, X-5. [pmid: 23331024].
2462 Chen JS, Ford JB, Roberts CL, et al. Pregnancy outcomes in women with juvenile idiopathic arthritis: a population-based study. Rheumatology (Oxford). Jun. 2013;52:1119-25. X-4. [pmid: 23382363].
2463 Chen M, Chang Q, Duan T, et al. Uterine massage to reduce blood loss after vaginal delivery: a randomized controlled trial. Obstet Gynecol. Aug. 2013;122:290-5. X-2, X-4. [pmid: 23969797].
2464 Cheng N, Xiang T, Wu X, et al. Acute fatty liver of pregnancy: a retrospective study of 32 cases in South China. J Matern Fetal Neonatal Med. 2013. Dec. 4. X-2, X-4. [pmid: 24304174].
2465 Chibber R, Fouda M, Shishtawy W, et al. Maternal and neonatal outcome in triplet, quadruplet and quintuplet gestations following ART: a 11-year study. Arch Gynecol Obstet. Oct. 2013;288:759-67. X-4. [pmid: 23543239].
2466 Choulagai B, Onta S, Subedi N, et al. Barriers to using skilled birth attendants' services in mid- and far-western Nepal: a cross-sectional study. BMC Int Health Hum Rights. 2013;13:49. X-2, X-3, X-4. [pmid: 24365039].
2467 Chung MY, Cheng YK, Yu SC, et al. Nonremoval of an abnormally invasive placenta at cesarean section with postoperative uterine artery embolization. Acta Obstet Gynecol Scand. Nov. 2013;92:1250-5. X-4, X-5. [pmid: 23937444].
2468 Cilingir IU, Atalay V, Karahasanoglu A, et al. A life-threatening uterine inversion and massive post partum hemorrhage caused by uterine atony in a Primigravida uterine inversion. Haseki Tip Bulteni. 2013;51:139-40. X-1, X-2, X-4, X-5.
2469 Coombe JE, Pyman MF, Mansell PD, et al. The effects on claw health of supplement feeding grazing dairy cows on feed pads. Vet J. Dec. 2013;198:672-7. X-1, X-3, X-4. [pmid: 24206633].
2470 Costley PL, East CE. Oxytocin augmentation of labour in women with epidural analgesia for reducing operative deliveries. Cochrane Database Syst Rev. 2013;7. CD009241. X-1. [pmid: 23846738].
2471 Cox KJ, Schlegel R, Payne P, et al. Outcomes of planned home births attended by certified nurse-midwives in southeastern Pennsylvania, 1983-2008. J Midwifery Womens Health. Mar-Apr. 2013;58:145-9. X-4. [pmid: 23437812].
2472 Crane JM, Murphy P, Burrage L, et al. Maternal and perinatal outcomes of extreme obesity in pregnancy. J Obstet Gynaecol Can. Jul. 2013;35:606-11. X-4. [pmid: 23876637].
2473 Dagraca J, Malladi V, Nunes K, et al. Outcomes after institution of a new oxytocin infusion protocol during the third stage of labor and immediate postpartum period. Int J Obstet Anesth. Jul. 2013;22:194-9. X-4, X-5. [pmid: 23692707].
2474 Dars S, Sultana F, Akhter N. Abruptio placentae: Risk factors and maternal outcomes at a tertiary care hospital. 2013;12:198-202. X-2.
2475 Dave A, Maru L, Daksha S, et al. Weight does matter! A study of effect of obesity on pregnancy and its outcome. 2013;5:107-10. X-2, X-4.
2476 Davis D, Baddock S, Pairman S, et al. Risk of severe postpartum hemorrhage in low-risk childbearing women in new zealand: exploring the effect of place of birth and comparing third stage management of labor. Birth. Jun. 2013;39:98-105. X-4. [pmid: 23281857].
2477 de Castro Parreira MV, Gomes NC. Preventing postpartum haemorrhage: active management of the third stage of labour. J Clin Nurs. 2013. Jul. 22. X-1. [pmid: 23875752].
2478 de Jonge A, Mesman JA, Mannien J, et al. Severe adverse maternal outcomes among low risk women with planned home versus hospital births in the Netherlands: nationwide cohort study. BMJ. 2013;346:f3263. X-4. [pmid: 23766482].
2479 de la Cruz CZ, Coulter ML, O'Rourke K, et al. Women's experiences, emotional responses, and perceptions of care after emergency peripartum hysterectomy: a qualitative survey of women from 6 months to 3 years postpartum. Birth. Dec. 2013;40:256-63. X-2, X-4, X-5. [pmid: 24344706].
2480 de Souza Mde L, Laurenti R, Knobel R, et al. Maternal mortality due to hemorrhage in Brazil. Rev Lat Am Enfermagem. May-Jun. 2013;21:711-8. X-2, X-4. [pmid: 23918016].
2481 Deepak NN, Mirzabagi E, Koski A, et al. Knowledge, attitudes, and practices related to uterotonic drugs during childbirth in Karnataka, India: a qualitative research study. PLoS One. 2013;8:e62801. X-2, X-4. [pmid: 23638148].
2482 Dempsey A. Massive Transfusion Protocol: Saving Our Patients Lives. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2013;42:S97-S. X-1, X-4, X-5.
2483 Deneux-Tharaux C, Sentilhers L, Maillard F, et al. Effect of routine controlled cord traction as part of the active management of the third stage of labour on postpartum haemorrhage: multicentre randomized controlled trial (TRACOR). MIDIRS Midwifery Digest. 2013;23:351-2. X-4, X-5.
2484 Deneux-Tharaux C, Sentilhes L, Maillard F, et al. Effect of routine controlled cord traction as part of the active management of the third stage of labour on postpartum haemorrhage: multicentre randomised controlled trial (TRACOR). BMJ. 2013;346:f1541. X-4. [pmid: 23538918].
2485 Deng L, Chang Q, Wang Y, et al. Tourniquet device for hemorrhage control during cesarean section of complete placenta previa pregnancies. J Obstet Gynaecol Res. 2013. Oct. 22. X-2, X-5. [pmid: 24147797].
2486 Desai M, Phillips-Howard PA, Odhiambo FO, et al. An analysis of pregnancy-related mortality in the KEMRI/CDC health and demographic surveillance system in western Kenya. PLoS One. 2013;8:e68733. X-2, X-4. [pmid: 23874741].
2487 Desille H, Ouldamer L, Bleuzen A, et al. Novel use of contrast-enhanced sonography in the diagnosis of central uterine necrosis following embolization for postpartum hemorrhage. J Ultrasound Med. Oct. 2013;32:1869-76. X-5. [pmid: 24065269].
2488 Dibble S, Andersen A, Lassen MR, et al. Inflammatory and procoagulant cytokine levels during pregnancy as predictors of adverse obstetrical complications. Clin Appl Thromb Hemost. Mar. 2013;20:152-8. X-4. [pmid: 23869055].
2489 Dikman D, Elstein D, Levi GS, et al. Effect of thrombocytopenia on mode of analgesia/anesthesia and maternal and neonatal outcomes. J Matern Fetal Neonatal Med. 2013. Oct. 11. X-4. [pmid: 23962227].
2490 Dohan A, Pelage JP, Soyer P. How to avoid uterine necrosis after arterial embolization for post-partum hemorrhage: a proposal based on a single center experience of 600 cases. Eur J Obstet Gynecol Reprod Biol. Dec. 2013;171:392-3. X-1, X-4, X-5. [pmid: 24139543].
2491 Dohan A, Soyer P, Subhani A, et al. Postpartum hemorrhage resulting from pelvic pseudoaneurysm: a retrospective analysis of 588 consecutive cases treated by arterial embolization. Cardiovasc Intervent Radiol. Oct. 2013;36:1247-55. X-4, X-5. [pmid: 23756881].
2492 Domingo S, Perales-Puchalt A, Soler I, et al. Clinical outcome, fertility and uterine artery Doppler scans in women with obstetric bilateral internal iliac artery ligation or embolisation. J Obstet Gynaecol. Oct. 2013;33:701-4. X-5. [pmid: 24127959].
2493 Doumouchtsis S, Nikolopoulos K, Talaulikar V, et al. Menstrual and fertility outcomes following the surgical management of postpartum haemorrhage: a systematic review. Bjog. 2013. Dec. 9. X-1. [pmid: 24321038].
2494 Duley L, Meher S, Jones L. Drugs for treatment of very high blood pressure during pregnancy. Cochrane Database Syst Rev. 2013;7. CD001449. X-1, X-4. [pmid: 23900968].
2495 Dupont C, Rudigoz RC, Cortet M, et al. Frequency, causes and risk factors of postpartum haemorrhage: A population-based study in 106 French maternity units. J Gynecol Obstet Biol Reprod (Paris). 2013. Jun. 19. X-4. [pmid: 23790963].
2496 Edhi MM, Aslam HM, Naqvi Z, et al. Post partum hemorrhage: causes and management. BMC Res Notes. Jun. 18. 2013;6:236. X-2. [pmid: 23773785].
2497 Eftekhar-Vaghefi R, Foroodnia S, Nakhaee N. Gaining insight into the prevention of maternal death using narrative analysis: an experience from kerman, iran. Int J Health Policy Manag. Nov. 2013;1(4):255-9. X-2, X-4. [pmid: 24596882].
2498 Ejembi CL, Norick P, Starrs A, et al. New global guidance supports community and lay health workers in postpartum hemorrhage prevention. Int J Gynaecol Obstet. Sep. 2013;122:187-9. X-1. [pmid: 23796260].
2499 El Ayadi A, Raifman S, Jega F, et al. Comorbidities and lack of blood transfusion may negatively affect maternal outcomes of women with obstetric hemorrhage treated with NASG. PLoS One. 2013;8:e70446. X-2, X-4. [pmid: 23950937].
2500 El Ayadi AM, Butrick E, Geissler J, et al. Combined analysis of the non-pneumatic anti-shock garment on mortality from hypovolemic shock secondary to obstetric hemorrhage. BMC Pregnancy Childbirth. Nov. 15. 2013;13:208. X-2, X-4, X-5. [pmid: 24237656].
2501 Elgafor El Sharkwy IA. Carbetocin versus sublingual misoprostol plus oxytocin infusion for prevention of postpartum hemorrhage at cesarean section in patients with risk factors: a randomized, open trail study. Arch Gynecol Obstet. Dec. 2013;288:1231-6. X-4. [pmid: 23689739].
2502 Elhanafy MM, French DD, Braun U. Understanding jejunal hemorrhage syndrome. J Am Vet Med Assoc. Aug. 1. 2013;243:352-8. X-1. [pmid: 23865877].
2503 Elkins D, Taylor JS. Evidence-based strategies for managing gestational diabetes in women with obesity. Nurs Womens Health. Oct. 2013;17:420-9. quiz 30. X-1. [pmid: 24138661].
2504 El-Refaeey AA, Gibreel A, Fawzy M. Novel modification of B-Lynch uterine compression sutures for management of atonic postpartum hemorrhage: VV uterine compression sutures. J Obstet Gynaecol Res. Feb. 2013;40:387-91. X-2, X-5. [pmid: 24118407].
2505 Erhabor O, Isaac I, Muhammad A, et al. Some hemostatic parameters in women with obstetric hemorrhage in Sokoto, Nigeria. Int J Womens Health. 2013;5:285-91. X-2, X-4. [pmid: 23807863].
2506 Erhabor O, Isaac IZ, Muhammad AM, et al. Some hemostatic parameters in women with obstetric hemorrhage in Sokoto, Nigeria. New Zealand. Dove Medical Press Ltd. (PO Box 300-008, Albany, 44 Corinthian Drive, Albany,Auckland 0752, New Zealand). 2013. http://www.dovepress.com/getfile.php?fileID=16403http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed11&NEWS=N&AN=2013386582. Accessed on (Erhabor, Isaac, Muhammad, Abdulrahaman) Department of Haematology and Transfusion Medicine, Usmanu Danfodio University, Sokoto, Nigeria 5.
2507 Evans H, Lewis E. UK survey of the availability of cell salvage and interventional radiological services for the management of obstetric haemorrhage. Int J Obstet Anesth. Nov. 2013;22:355-6. X-1, X-4, X-5. [pmid: 23958276].
2508 Evsen MS, Sak ME, Soydine HE, et al. Internal iliac artery ligation for severe postpartum hemorrhage. Ginekol Pol. Sep. 2013;83:665-8. X-2. [pmid: 23342894].
2509 Ezeama CO, Eleje GU, Ezeama NN, et al. A comparison of prophylactic intramuscular ergometrine and oxytocin for women in the third stage of labor. Int J Gynaecol Obstet. Jan. 2013;124:67-71. X-2, X-4. [pmid: 24365208].
2510 Ezugwu EC, Agu PU, Nwoke MO, et al. Reducing maternal deaths in a low resource setting in Nigeria. Niger J Clin Pract. Jan-Feb. 2013;17:62-6. X-2, X-4. [pmid: 24326810].
2511 Fakour F, Mirzayi M, Reza Naghipour M, et al. Comparison between sublingual misoprostol and intravenous oxytocin in management of third stage of labor. Iranian Journal of Obstetrics, Gynecology and Infertility. January. 2013;15:7-14. X-2, X-4.
2512 Fallahian M, Foroughi F, Vasei M, et al. Outcome of subsequent pregnancies in familial molar pregnancy. International Journal of Fertility and Sterility. April-June. 2013;7:63-6. X-1, X-3, X-4. [pmid: 24520466].
2513 Farber MK, Sadana N, Kaufman RM, et al. Transfusion Ratios for Postpartum Hemodilutional Coagulopathy: an In Vitro Thromboelastographic Model. Am J Obstet Gynecol. 2013. Nov. 19. X-3, X-4. [pmid: 24269787].
2514 Faulkner B. Applying lean management principles to the creation of a postpartum hemorrhage care bundle. Nurs Womens Health. Oct. 2013;17:400-11. X-1, X-4, X-5. [pmid: 24138659].
2515 Fazel MR, Mansoure S, Esmaeil F. A comparison of rectal misoprostol and intravenous oxytocin on hemorrhage and homeostatic changes during cesarean section. Middle East J Anesthesiol. Feb. 2013;22:41-6. X-2, X-4, X-5. [pmid: 23833849].
2516 Feng BB, Wang L, Zhai JJ. Investigation on delivery analgesia effect of combined spinal epidural anesthesia plus Doula and safety of mother and baby. Clin Exp Obstet Gynecol. 2013;40:574-8. X-3, X-4. [pmid: 24597260].
2517 Firouzbakht M, Kiapour A, Omidvar S. Prevention of post-partum hemorrhage by rectal Misoprostol: A randomized clinical trial. J Nat Sci Biol Med. Jan. 2013;4:134-7. X-2, X-4, X-5. [pmid: 23633849].
2518 Fittro K, Nichols W. Acute dyspnea in a postpartum patient. JAAPA. Jan. 2013;27:29-31. X-1, X-3, X-4. [pmid: 24361652].
2519 Fitzpatrick KE, Sellers S, Spark P, et al. The management and outcomes of placenta accreta, increta, and percreta in the UK: a population-based descriptive study. BJOG. Jan. 2013;121:62-70. discussion -1. X-2, X-4, X-5. [pmid: 23924326].
2520 Flohr-Rincon S, Tucker L, Balestrieri-Martinez B. ‘It Is a Bloody Good Job!’ Utilizing OB Hemorrhage Drills and Standardized Electronic Order Sets to Champion Excellence and Collaboration during Postpartum Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2013;42:S26-S. X-1, X-4, X-5.
2521 Fong F, Rogozinska E, Allotey J, et al. Development of maternal and neonatal composite outcomes for trials evaluating management of late-onset pre-eclampsia. Hypertens Pregnancy. 2013. Dec. 4. X-1, X-3, X-4. [pmid: 24303960].
2522 Foo L, Bewley S, Rudd A. Maternal death from stroke: a thirty year national retrospective review. Eur J Obstet Gynecol Reprod Biol. 2013. Sep. 29. X-3, X-4. [pmid: 24128926].
2523 Fuchs F, Bouyer J, Rozenberg P, et al. Adverse maternal outcomes associated with fetal macrosomia: what are the risk factors beyond birthweight?. BMC Pregnancy Childbirth. 2013;13:90. X-4. [pmid: 23565692].
2524 Fukuda M, Tanaka T, Kamada M, et al. Comparison of the perinatal outcomes after laparoscopic myomectomy versus abdominal myomectomy. Gynecol Obstet Invest. 2013;76:203-8. X-1, X-4. [pmid: 24107786].
2525 Fullerton G, Danielian PJ, Bhattacharya S. Outcomes of pregnancy following postpartum haemorrhage. BJOG. Apr. 2013;120:621-7. X-2, X-4, X-5. [pmid: 23339709].
2526 Furuta M, Sandall J, Bick D. Women's perceptions and experiences of severe maternal morbidity - A synthesis of qualitative studies using a meta-ethnographic approach. Midwifery. 2013. Sep. 25. X-1. [pmid: 24144992].
2527 Gani N, Ali TS. Prevalence and factors associated with maternal postpartum haemorrhage in Khyber Agency, Pakistan. J Ayub Med Coll Abbottabad. Jan-Jun. 2013;25:81-5. X-2, X-4. [pmid: 25098062].
2528 Gawron LM, Kiley JW. Labor induction outcomes in third-trimester stillbirths. Int J Gynaecol Obstet. Dec. 2013;123:203-6. X-2, X-4, X-5. [pmid: 24059984].
2529 Geller S, Carnahan L, Akosah E, et al. Community-based distribution of misoprostol to prevent postpartum haemorrhage at home births: results from operations research in rural Ghana. BJOG. Feb. 2013;121:319-26. X-2, X-4. [pmid: 24283350].
2530 Gerli S, Favilli A, Affronti G, et al. Prophylactic arterial catheterization in the management of high risk patients for obstetric haemorrhage. Eur Rev Med Pharmacol Sci. Oct. 2013;17:2822-6. X-3, X-4. [pmid: 24174367].
2531 Ghasemi M, Tara F, Ashraf H. Maternal-fetal and neonatal complications of water-birth compared with conventional delivery. Iranian Journal of Obstetrics, Gynecology and Infertility. 2013;16:9-15. X-2, X-3, X-4.
2532 Gipson MG, Smith MT. Endovascular therapies for primary postpartum hemorrhage: techniques and outcomes. Semin Intervent Radiol. Dec. 2013;30(4):333-9. X-1. [pmid: 24436559].
2533 Girard T, Brugger S, Hosli I. New aspects of obstetric anesthesia. Anaesthesist. Dec. 2013;62:963-72. X-1, X-2, X-4, X-5. [pmid: 23999765].
2534 Gitz L, Picone O, Mas AE, et al. Postpartum hemorrhage by vaginal laseration: New case and improved management. J Gynecol Obstet Biol Reprod (Paris). 2013. May. 21. X-1, X-4. [pmid: 23706157].
2535 Gizzo S, Noventa M, Anis O, et al. Pharmacological anti-thrombotic prophylaxis after elective caesarean delivery in thrombophilia unscreened women: should maternal age have a role in decision making?. J Perinat Med. Nov. 2013;16:1-9. X-3, X-4. [pmid: 24246285].
2536 Gizzo S, Patrelli TS, Gangi SD, et al. Which uterotonic is better to prevent the postpartum hemorrhage? Latest news in terms of clinical efficacy, side effects, and contraindications: a systematic review. Reprod Sci. Sep. 2013;20:1011-9. X-1. [pmid: 23296037].
2537 Gizzo S, Saccardi C, Patrelli TS, et al. Fertility rate and subsequent pregnancy outcomes after conservative surgical techniques in postpartum hemorrhage: 15 years of literature. Fertil Steril. Jun. 2013;99:2097-107. X-1, X-2, X-4, X-5. [pmid: 23498891].
2538 Goel A, Nair SC, Viswabandya A, et al. Preliminary experience with use of recombinant activated factor VII to control postpartum hemorrhage in acute fatty liver of pregnancy and other pregnancy-related liver disorders. Indian J Gastroenterol. Jul. 2013;32:268-71. X-2, X-4, X-5. [pmid: 23475547].
2539 Goswami U, Sarangi S, Gupta S, et al. Comparative evaluation of two doses of tranexamic acid used prophylactically in anemic parturients for lower segment cesarean section: A double-blind randomized case control prospective trial. Saudi J Anaesth. Oct. 2013;7:427-31. X-2, X-4. [pmid: 24348295].
2540 Grace Tan SE, Jobling TW, Wallace EM, et al. Surgical management of placenta accreta: a 10-year experience. Acta Obstet Gynecol Scand. Apr. 2013;92:445-50. X-4, X-5. [pmid: 23311505].
2541 Gregory KD, Korst LM, Lu MC, et al. AHRQ patient safety indicators: time to hemorrhage and infection during childbirth. Jt Comm J Qual Patient Saf. Mar. 2013;39:114-22. X-4. [pmid: 23516761].
2542 Guerci P, Novy E, Vial F, et al. Sulprostone for postpartum hemorrhage in a parturient with a history of Tako-tsubo cardiomyopathy. J Clin Anesth. Jun. 2013;25:327-30. X-4, X-5. [pmid: 23830846].
2543 Guillaume A, Sananes N, Akladios CY, et al. Amniotic fluid embolism: 10-year retrospective study in a level III maternity hospital. Eur J Obstet Gynecol Reprod Biol. Jul. 2013;169:189-92. X-3, X-4. [pmid: 23522720].
2544 Guler A, Kosus N, Turan A, et al. Antenatal diagnosis of placenta increta and its successful conservative management with methotrexate. Eastern Journal of Medicine. 2013;18:48-51. X-1.
2545 Guleria K, Gupta B, Agarwal S, et al. Abnormally invasive placenta: changing trends in diagnosis and management. Acta Obstet Gynecol Scand. Apr. 2013;92:461-4. X-2, X-4, X-5. [pmid: 23517217].
2546 Gun I, Ozdamar O, Ertugrul S, et al. The effect of placental removal method on perioperative hemorrhage at cesarean delivery; a randomized clinical trial. Arch Gynecol Obstet. Sep. 2013;288:563-7. X-4. [pmid: 23455538].
2547 Gupta A. A comparative study of methylergonovine and 15-methyl prostaglandin F2alpha in active management of third stage of labor. Obstet Gynecol Sci. Sep. 2013;56:301-6. X-4. [pmid: 24328019].
2548 Haas J, Barzilay E, Chayen B, et al. Safety of low-dose prostaglandin E2 induction in grandmultiparous women with previous cesarean delivery. J Matern Fetal Neonatal Med. Mar. 2013;27:445-8. X-4. [pmid: 23841832].
2549 Habib S, Riaz S, Abbasi N, et al. Vaginal breech delivery: still a safe option. J Ayub Med Coll Abbottabad. Jul-Dec. 2013;25(3-4):38-40. X-2, X-4. [pmid: 25226736].
2550 Haeri S, Baker AM. Estimating risk factors and causes for postpartum febrile morbidity in teenage mothers. J Obstet Gynaecol. Feb. 2013;33:149-51. X-4. [pmid: 23445136].
2551 Hafeez R, Memon SR, Bhatti K. Frequency, risk factors and complications in pregnancies associated with placenta praevia. Medical Forum Monthly. January. 2013;24:21-5. X-2, X-4.
2552 Haggar F, Pereira G, Preen D, et al. Maternal and neonatal outcomes in pregnancies following colorectal cancer. Surg Endosc. Jul. 2013;27:2327-36. X-4. [pmid: 23371020].
2553 Haldar R, Samanta S. Post-partum sequential occurrence of two diverse transfusion reactions (transfusion associated circulatory overload and transfusion related acute lung injury). J Emerg Trauma Shock. Oct. 2013;6:283-6. X-1, X-2, X-4, X-5. [pmid: 24339663].
2554 Hammah J, Donkor ES. ASSESSMENT OF PRACTISING MIDWIVES ON THE MANAGEMENT OF THE THIRD STAGE OF LABOUR. African Journal of Midwifery & Women's Health. 2013;7:59-64. X-1, X-4.
2555 Hamza A, Herr D, Solomayer EF, et al. Polyhydramnios: Causes, Diagnosis and Therapy. Geburtshilfe Frauenheilkd. Dec. 2013;73(12):1241-6. X-1. [pmid: 24771905].
2556 Hanf M, Friedman E, Basurko C, et al. Dengue epidemics and adverse obstetrical outcomes in French Guiana: a semi-ecological study. Trop Med Int Health. Feb. 2013;19:153-8. X-2, X-4. [pmid: 24341915].
2557 Hanprasertpong T, Kor-anantakul O, Leetanaporn R, et al. Pregnancy outcomes amongst thalassemia traits. Arch Gynecol Obstet. Nov. 2013;288:1051-4. X-2, X-4. [pmid: 23681496].
2558 Hanson C, Ronsmans C, Penfold S, et al. Health system support for childbirth care in Southern Tanzania: results from a health facility census. BMC Res Notes. Oct. 30. 2013;6:435. X-1, X-3, X-4. [pmid: 24171904].
2559 Harper LM, Caughey AB, Roehl KA, et al. Defining an abnormal first stage of labor based on maternal and neonatal outcomes. Am J Obstet Gynecol. 2013. Dec. 19. X-2, X-4, X-5. [pmid: 24361789].
2560 Hashim H, Nawawi O. Uterine arteriovenous malformation. Malaysian Journal of Medical Sciences. 2013;20:77-81. X-1.
2561 Hashim N, Naqvi S, Khanam M, et al. Primiparity as an intrapartum obstetric risk factor. J Pak Med Assoc. Jul. 2013;62:694-8. X-2, X-4. [pmid: 23866518].
2562 Hastings-Tolsma M, Bernard R, Brody MG, et al. Chorioamnionitis: prevention and management. MCN Am J Matern Child Nurs. Jul-Aug. 2013;38:206-12. quiz 13-4. X-1. [pmid: 23579417].
2563 He Y, Wu YM, Wang T, et al. Perinatal outcomes of pregnant women with cervical intraepithelial neoplasia. Arch Gynecol Obstet. Dec. 2013;288:1237-42. X-2, X-3, X-4. [pmid: 23695508].
2564 Heesen M, Hofmann T, Klohr S, et al. Is general anaesthesia for caesarean section associated with postpartum haemorrhage? Systematic review and meta-analysis. Acta Anaesthesiol Scand. Oct. 2013;57:1092-102. X-1, X-4. [pmid: 24003971].
2565 Hehir MP, Walsh JM, Higgins S, et al. Maternal and neonatal morbidity during off peak hours in a busy obstetric unit. Are deliveries after midnight more complicated?. Acta Obstet Gynecol Scand. Feb. 2013;93:189-93. X-3, X-4. [pmid: 24266619].
2566 Henry L, Britz SP. Loss of Blood = Loss of Breast Milk? The Effect of Postpartum Hemorrhage on Breastfeeding Success. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2013;42:S100-S. X-1, X-2, X-4, X-5.
2567 Hiraizumi Y, Suzuki S. Perinatal outcomes of low-risk planned home and hospital births under midwife-led care in Japan. J Obstet Gynaecol Res. Nov. 2013;39:1500-4. X-4. [pmid: 23855717].
2568 Hofmeyr GJ, Abdel-Aleem H, Abdel-Aleem MA. Uterine massage for preventing postpartum haemorrhage. Cochrane Database Syst Rev. 2013;7. CD006431. X-1. [pmid: 23818022].
2569 Hofmeyr GJ, Gulmezoglu AM, Novikova N, et al. Postpartum misoprostol for preventing maternal mortality and morbidity. Cochrane Database Syst Rev. 2013;7. CD008982. X-1. [pmid: 23857523].
2570 Hofmeyr GJ, Gülmezoglu AM, Novikova N, et al. Postpartum misoprostol for preventing maternal mortality and morbidity. Cochrane Database of Systematic Reviews. 2013;(7). Language: English. Entry Date: 20140606. Publication Type: journal article. X-1.
2571 Huchon C, Dumont A, Traore M, et al. A prediction score for maternal mortality in Senegal and Mali. Obstet Gynecol. May. 2013;121:1049-56. X-2, X-3, X-4. [pmid: 23635742].
2572 Huijgen QC, Gijsen AF, Hink E, et al. Cervical tourniquet in case of uncontrollable haemorrhage during caesarean section owing to a placenta accreta. BMJ Case Rep. 2013;2013. X-1. [pmid: 23608864].
2573 Hwang SM, Jeon GS, Kim MD, et al. Transcatheter arterial embolisation for the management of obstetric haemorrhage associated with placental abnormality in 40 cases. Eur Radiol. Mar. 2013;23:766-73. X-2, X-5. [pmid: 23300034].
2574 Hyginus E, Eric NI, Lawrence I, et al. Morbidity and mortality following high order caesarean section in a developing country. J Pak Med Assoc. Oct. 2013;62:1016-9. X-2, X-4. [pmid: 23866437].
2575 Jabir M, Abdul-Salam I, Suheil DM, et al. Maternal near miss and quality of maternal health care in Baghdad, Iraq. BMC Pregnancy Childbirth. 2013;13:11. X-2, X-3, X-4. [pmid: 23324222].
2576 Jain D. A ray of hope for a woman with Sheehan's syndrome. BMJ Case Reports. 2013. X-3, X-4.
2577 Jayaraman M, Verma A, Harikumar KV, et al. Pregnancy outcomes with thyroxine replacement for subclinical hypothyroidism: Role of thyroid autoimmunity. Indian J Endocrinol Metab. Mar. 2013;17:294-7. X-3, X-4. [pmid: 23776906].
2578 Jia LY, Meng WY, Ma HH, et al. Clinical analysis of uterine rupture during pregnancy. Zhonghua Yi Xue Za Zhi. Sep. 3. 2013;93:2674-6. X-2, X-3, X-4. [pmid: 24360052].
2579 Jiang HX, Han GR, Wang CM, et al. Maternal-fetal outcomes of lamivudine treatment administered during late pregnancy to highly viremic mothers with HBeAg+ chronic hepatitis B. Zhonghua Gan Zang Bing Za Zhi. Dec. 2013;20:888-91. X-2, X-4. [pmid: 23522247].
2580 Johnsdottir A. Superfoods for Postpartum Hemorrhage Recovery. Midwifery Today. 2013:46-7. X-1, X-5.
2581 Jones B, Zhang E, Alzouebi A, et al. Maternal and perinatal outcomes following peripartum hysterectomy from a single tertiary centre. Aust N Z J Obstet Gynaecol. Dec. 2013;53:561-5. X-5. [pmid: 24138323].
2582 Jozwiak M, Van de Lest HA, Burger NB, et al. Cervical ripening with Foley catheter for induction of labor after cesarean section: a cohort study. Acta Obstet Gynecol Scand. 2013. Dec. 16. X-4. [pmid: 24354335].
2583 Kadir RA, Davies J. Hemostatic disorders in women. J Thromb Haemost. Jun. Suppl 1. 2013;11:170-9. X-1. [pmid: 23809121].
2584 Kadir RA, Davies J, Winikoff R, et al. Pregnancy complications and obstetric care in women with inherited bleeding disorders. Haemophilia. Nov. Suppl 4. 2013;19:1-10. X-1. [pmid: 24102860].
2585 Kakiuchi H, Kawarai-Shimamura A, Kuwagata M, et al. Tranexamic acid induces kaolin intake stimulating a pathway involving tachykinin neurokinin 1 receptors in rats. Eur J Pharmacol. Jan. 15. 2013;723:1-6. X-3, X-4. [pmid: 24333477].
2586 Kanter G, Packard L, Sit AS. Placenta accreta in a patient with a history of uterine artery embolization for postpartum hemorrhage. J Perinatol. Jun. 2013;33:482-3. X-1, X-5. [pmid: 23719249].
2587 Kaplanoglu M. The uterine sandwich method for placenta previa accreta in mullerian anomaly: combining the B-lynch compression suture and an intrauterine gauze tampon. Case Rep Obstet Gynecol. 2013;2013:236069. X-1, X-2, X-5. [pmid: 23607012].
2588 Karanj J, Muganyizi P, Rwamushaija E, et al. Confronting maternal mortality due to postpartum hemorrhage and unsafe abortion: a call for commitment. Afr J Reprod Health. Jun. 2013;17:18-22. X-1, X-4, X-5. [pmid: 24069748].
2589 Karanth L, Barua A, Kanagasabai S, et al. Desmopressin acetate (DDAVP) for preventing and treating acute bleeds during pregnancy in women with congenital bleeding disorders. Cochrane Database of Systematic Reviews. 2013. X-1.
2590 Kariya N, Kimura K, Iwasaki R, et al. Intraoperative awake tracheal intubation using the Airway Scope in caesarean section. Anaesth Intensive Care. May. 2013;41:390-2. X-4. [pmid: 23659404].
2591 Karlsson O, Jeppsson A, Hellgren M. Major obstetric haemorrhage: monitoring with thromboelastography, laboratory analyses or both?. Int J Obstet Anesth. Feb. 2013;23:10-7. X-4, X-5. [pmid: 24342222].
2592 Karlstrom A, Lindgren H, Hildingsson I. Maternal and infant outcome after caesarean section without recorded medical indication: findings from a Swedish case-control study. BJOG. Mar. 2013;120:479-86. discussion 86. X-4. [pmid: 23316937].
2593 Karolinski A, Mercer R, Micone P, et al. The epidemiology of life-threatening complications associated with reproductive process in public hospitals in Argentina. BJOG. 2013. Aug. 13. X-4. [pmid: 23937774].
2594 Karolinski A, Mercer R, Micone P, et al. The epidemiology of life-threatening complications associated with reproductive process in public hospitals in Argentina. BJOG. Dec. 2013;120(13):1685-94. discussion 944-5. X-4. [pmid: 23937774].
2595 Kavak SB, Atilgan R, Demirel I, et al. Endouterine hemostatic square suture vs. Bakri balloon tamponade for intractable hemorrhage due to complete placenta previa. J Perinat Med. Nov. 2013;41:705-9. X-2. [pmid: 23828423].
2596 Kawamura Y, Kondoh E, Hamanishi J, et al. Treatment decision-making for post-partum hemorrhage using dynamic contrast-enhanced computed tomography. J Obstet Gynaecol Res. Jan. 2013;40:67-74. X-4. [pmid: 23937115].
2597 Kayem G, Deneux-Tharaux C, Sentilhes L. PACCRETA: clinical situations at high risk of placenta ACCRETA/percreta: impact of diagnostic methods and management on maternal morbidity. Acta Obstet Gynecol Scand. Apr. 2013;92:476-82. X-1. [pmid: 23360123].
2598 Kenyon S, Tokumasu H, Dowswell T, et al. High-dose versus low-dose oxytocin for augmentation of delayed labour. Cochrane Database Syst Rev. 2013;7. CD007201. X-1, X-3. [pmid: 23853046].
2599 Kessous R, Tirosh D, Weintraub AY, et al. Second stage disorders in patients following a previous cesarean section: vacuum versus repeated cesarean section. Arch Gynecol Obstet. Jun. 2013;287:1075-9. X-4. [pmid: 23274791].
2600 Khalifeh A, Grantham J, Byrne J, et al. Tinzaparin safety and efficacy in pregnancy. Ir J Med Sci. 2013. Aug. 11. X-4. [pmid: 23934436].
2601 Khireddine I, Le Ray C, Dupont C, et al. Induction of labor and risk of postpartum hemorrhage in low risk parturients. PLoS One. 2013;8:e54858. X-4. [pmid: 23382990].
2602 Kikuchi M, Itakura A, Miki A, et al. Fibrinogen concentrate substitution therapy for obstetric hemorrhage complicated by coagulopathy. J Obstet Gynaecol Res. Apr. 2013;39:770-6. X-4, X-5. [pmid: 23278972].
2603 Kim GM, Yoon CJ, Seong NJ, et al. Postpartum haemorrhage from ruptured pseudoaneurysm: efficacy of transcatheter arterial embolisation using N-butyl-2-cyanoacrylate. Eur Radiol. Aug. 2013;23:2344-9. X-5. [pmid: 23559143].
2604 Kim TH, Lee HH. Methods of holding the cervix and applying compression based on uterine bleeding: caudal or cephalad to the uterus?. Acta Obstet Gynecol Scand. 2013. Dec. 3. X-1. [pmid: 24299294].
2605 Kim TH, Lee HH, Kim JM, et al. Hysterectomy prevention using the uterine hollow obliterations (HYUNHO) method for placenta previa. Clin Exp Obstet Gynecol. 2013;39:462-5. X-4, X-5. [pmid: 23444744].
2606 Kiran S, Anand A, Singh T, et al. To estimate the minimum effective dose of oxytocin required to produce adequate uterine tone in women undergoing elective caesarean delivery. Egyptian Journal of Anaesthesia. April. 2013;29:161-5. X-2, X-4.
2607 Kjaer MM, Lauenborg J, Breum BM, et al. The risk of adverse pregnancy outcome after bariatric surgery: a nationwide register-based matched cohort study. Am J Obstet Gynecol. Jun. 2013;208:464 e1-5. X-4. [pmid: 23467053].
2608 Kjaer MM, Nilas L. Timing of pregnancy after gastric bypass-a national register-based cohort study. Obes Surg. Aug. 2013;23:1281-5. X-4. [pmid: 23462860].
2609 Km U, Mn D, R S, et al. Effect of a primary postpartum haemorrhage on the “near-miss” morbidity and mortality at a tertiary care hospital in rural bangalore, India. J Clin Diagn Res. Jun. 2013;7:1114-9. X-2, X-4. [pmid: 23905116].
2610 Knuttinen MG, Jani A, Gaba RC, et al. Balloon occlusion of the hypogastric arteries in the management of placenta accreta: a case report and review of the literature. Semin Intervent Radiol. Sep. 2013;29:161-8. X-1. [pmid: 23997407].
2611 Kominiarek MA, Seligman NS, Dolin C, et al. Gestational weight gain and obesity: is 20 pounds too much?. Am J Obstet Gynecol. Sep. 2013;209:214 e1-11. X-4. [pmid: 23635421].
2612 Kong MC, To WW. Balloon tamponade for postpartum haemorrhage: case series and literature review. Hong Kong Med J. 2013. May. 6. X-5. [pmid: 23650196].
2613 Korejo R, Nasir A, Yasmin H, et al. Emergency obstetric hysterectomy. J Pak Med Assoc. Dec. 2013;62:1322-5. X-2, X-4. [pmid: 23866483].
2614 Kramer MS, Berg C, Abenhaim H, et al. Incidence, risk factors, and temporal trends in severe postpartum hemorrhage. Am J Obstet Gynecol. Nov. 2013;209:449 e1-7. X-4. [pmid: 23871950].
2615 Krutman M, Galastri FL, Afonso BB, et al. Review of the cases of 15 patients at high risk of obstetric hemorrhage who underwent temporary bilateral occlusion of internal iliac arteries. Jornal Vascular Brasileiro. 2013;12:202-6. X-2, X-4.
2616 Kumar K, Al Arebi A, Singh I. Accidental intravenous infusion of a large dose of magnesium sulphate during labor: A case report. Journal of Anaesthesiology Clinical Pharmacology. July-September. 2013;29:377-9. X-1, X-4.
2617 Kumar R. Abortion in Sri Lanka: the double standard. Am J Public Health. Mar. 2013;103:400-4. X-1. [pmid: 23327236].
2618 Kumru P, Demirci O, Erdogdu E, et al. The Bakri balloon for the management of postpartum hemorrhage in cases with placenta previa. Eur J Obstet Gynecol Reprod Biol. Apr. 2013;167:167-70. X-2, X-5. [pmid: 23298893].
2619 Kwon HS, Cho YK, Sohn IS, et al. Rupture of a pseudoaneurysm as a rare cause of severe postpartum hemorrhage: analysis of 11 cases and a review of the literature. Eur J Obstet Gynecol Reprod Biol. Sep. 2013;170:56-61. X-5. [pmid: 23746797].
2620 Lambert V, Pouget K, Basurko C, et al. Geophagy and pregnancy: Current knowledge and management. Clinical experiences of an obstetrical department in French Guiana. J Gynecol Obstet Biol Reprod (Paris). 2013. Jul. 17. X-1, X-2, X-3, X-4. [pmid: 23871612].
2621 Lannon SM, Guthrie KA, Reed SD, et al. Mode of delivery at periviable gestational ages: impact on subsequent reproductive outcomes. J Perinat Med. Nov. 2013;41:691-7. X-4. [pmid: 23924520].
2622 Lao TT, Sahota DS, Cheng YK, et al. Advanced maternal age and postpartum hemorrhage - risk factor or red herring?. J Matern Fetal Neonatal Med. Feb. 2013;27:243-6. X-4. [pmid: 23713943].
2623 Larciprete G, Montagnoli C, Frigo M, et al. Carbetocin versus oxytocin in caesarean section with high risk of post-partum haemorrhage. J Prenat Med. Jan. 2013;7:12-8. X-4. [pmid: 23741542].
2624 Latif T, Ali MA, Majeed A, et al. Labor outcome of primigravidae in Mymensingh Medical College Hospital. Mymensingh Med J. Jul. 2013;22:432-7. X-2, X-4. [pmid: 23982529].
2625 Lawani OL, Iyoke CA, Onyebuchi AK. Blood transfusion trends in obstetrics at the Federal Teaching Hospital in Abakaliki, South-East Nigeria. Int J Womens Health. 2013;5:407-12. X-2. [pmid: 23874125].
2626 Lee AI, Wong CA, Healy L, et al. Impact of a third stage of labor oxytocin protocol on cesarean delivery outcomes. Int J Obstet Anesth. Feb. 2013;23:18-22. X-4. [pmid: 24332518].
2627 Levy JH, Welsby I, Goodnough LT. Fibrinogen as a therapeutic target for bleeding: a review of critical levels and replacement therapy. Transfusion. 2013. Oct. 9. X-1. [pmid: 24117955].
2628 Li J, Yu YX, Zheng LY, et al. Clinical research on bilateral arcuate artery suture hemostasis of corpus uteri for postpartum hemorrhage due to uterine inertia during caesarean section. Zhonghua Fu Chan Ke Za Zhi. Mar. 2013;48:165-70. X-2. [pmid: 23849936].
2629 Lim HJ, Kim JY, Kim YD, et al. Intraoperative uterine artery embolization without fetal radiation exposure in patients with placenta previa totalis: Two case reports. Obstet Gynecol Sci. Jan. 2013;56:45-9. X-1, X-4. [pmid: 24327980].
2630 Lim R. Postpartum Hemorrhage in Bali: A Day at Bumi Sehat. Midwifery Today. 2013:9-15. X-1, X-2.
2631 Limmer JS, Grotegut CA, Thames E, et al. Postpartum wound and bleeding complications in women who received peripartum anticoagulation. Thromb Res. Jul. 2013;132:e19-23. X-4. [pmid: 23735589].
2632 Liu S, Joseph KS, Hutcheon JA, et al. Gestational age-specific severe maternal morbidity associated with labor induction. Am J Obstet Gynecol. Sep. 2013;209:209 e1-8. X-4. [pmid: 23702296].
2633 Lo TK, Yung WK, Lau WL, et al. Planned conservative management of placenta accreta - experience of a regional general hospital. J Matern Fetal Neonatal Med. Feb. 2013;27:291-6. X-4, X-5. [pmid: 23796273].
2634 Lopera J, Suri R, Kroma GM, et al. Role of interventional procedures in obstetrics/gynecology. Radiol Clin North Am. Nov. 2013;51:1049-66. X-1. [pmid: 24210444].
2635 Lotfalizadeh M, Mansouri A, Mansouri M, et al. Evaluation of causes and therapeutic methods of controlling of postpartum hemorrhage in two governmental hospital of Mashhad, Iran. Iranian Journal of Obstetrics, Gynecology and Infertility. 2013;16:1-5. X-2, X-4.
2636 Lupattelli A, Spigset O, Koren G, et al. Risk of vaginal bleeding and postpartum hemorrhage after use of antidepressants in pregnancy: a study from the Norwegian Mjournal and Child Cohort Study. J Clin Psychopharmacol. Feb. 2013;34:143-8. X-4. [pmid: 24135843].
2637 Madima NR. Obstetrics drugs. South African Family Practice. May - June. 2013;55:S8-S12. X-1.
2638 Magann EF, Doherty DA, Sandlin AT, et al. The effects of an increasing gradient of maternal obesity on pregnancy outcomes. Aust N Z J Obstet Gynaecol. Jun. 2013;53:250-7. X-4. [pmid: 23432797].
2639 Magee SR, Shields R, Nothnagle M. Low cost, high yield: simulation of obstetric emergencies for family medicine training. Teach Learn Med. 2013;25:207-10. X-3, X-4. [pmid: 23848326].
2640 Mahadik KV, Swami MB, Pandey N, et al. Exsanguinated uterus after massive atonic postpartum haemorrhage. BMJ Case Rep. 2013;2013. X-4. [pmid: 23853190].
2641 Mahajan D, Kang M, Sandhu M, et al. Rare complications of cesarean scar. India. Medknow Publications and Media Pvt. Ltd. (B9, Kanara Business Centre, off Link Road, Ghatkopar (E), Mumbai 400 075, India). 2013. http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed11&NEWS=N&AN=2013780884. Accessed on (Mahajan, Kang, Sandhu, Kalra, Khandelwal) Departments of Radiodiagnosis, Postgraduate Institute of Medical Education and Research, Sector-12, Chandigarh, India 23.
2642 Mahajan D, Kang M, Sandhu MS, et al. Rare complications of cesarean scar. Indian J Radiol Imaging. Jul. 2013;23:258-61. X-1. [pmid: 24347858].
2643 Mahey R, Kaur SD, Chumber S, et al. Splenectomy during pregnancy: Treatment of refractory immune thrombocytopenic purpura. BMJ Case Reports. 2013;20. X-1.
2644 Makvandi S, Shoushtari SZ, Hosseini VZ. Management of third stage of labor: A comparison of intraumbilical oxytocin and placental cord drainage. Shiraz E Medical Journal. 2013;14. X-2, X-3, X-4.
2645 Malhotra V, Bhuria V, Nanda S, et al. Decidual cast following B-Lynch suture: The surgeon's nightmare. Journal of Gynecologic Surgery. 01. Aug. 2013;29:213-5. X-2, X-5.
2646 Marahatta R. Retained placenta--a major cause of maternal morbidity. Nepal Med Coll J. Mar. 2013;14:41-5. X-2, X-4, X-5. [pmid: 23441493].
2647 Martin-Hirsch P, Khan K. BJOG Editors' Choice. BJOG. Feb. 2013;120:i-ii. X-1. [pmid: 23316910].
2648 Martins HE, Souza Mde L, Arzuaga-Salazar MA. Maternal mortality from hemorrhage in the State of Santa Catarina, Brazil. Rev Esc Enferm USP. Oct. 2013;47:1025-30. X-2, X-4. [pmid: 24346439].
2649 Martyn P, Loewenau-Samusionek K, Wasniewski T, et al. Subsequent pregnancy following B-Lynchsuture, bilateral ligationofuterinearteries,utero-ovarian arteries andinternaliliacarteriesduetouterine atony - A casereport. 2013;20:124-7. X-3.
2650 Matsubara S. Combination of an intrauterine balloon and the “holding the cervix” technique for hemostasis of postpartum hemorrhage and for prophylaxis of acute recurrent uterine inversion. Acta Obstet Gynecol Scand. 2013. Oct. 15. X-1, X-4, X-5. [pmid: 24127992].
2651 Matsubara S, Kuwata T, Usui R, et al. ‘Holding the cervix’ technique for post-partum hemorrhage for achieving hemostasis as well as preventing prolapse of an intrauterine balloon. J Obstet Gynaecol Res. May. 2013;39:1116-7. X-1, X-4, X-5. [pmid: 23509951].
2652 Matsubara S, Nakata M, Baba Y, et al. Uterine artery pseudoaneurysm hidden behind septic abortion: Pseudoaneurysm without preceding procedure. J Obstet Gynaecol Res. Feb. 2013;40:586-9. X-2, X-4, X-5. [pmid: 24118644].
2653 Matsubara S, Usui R, Sato T, et al. Adenomyomectomy, curettage, and then uterine artery pseudoaneurysm occupying the entire uterine cavity. J Obstet Gynaecol Res. May. 2013;39:1103-6. X-1, X-3, X-4. [pmid: 23551573].
2654 Matsuwaki T, Khan KN, Inoue T, et al. Evaluation of obstetrical factors related to Sheehan syndrome. J Obstet Gynaecol Res. Jan. 2013;40:46-52. X-5. [pmid: 23945005].
2655 McClure EM, Rouse DJ, Macguire ER, et al. The MANDATE model for evaluating interventions to reduce postpartum hemorrhage. Int J Gynaecol Obstet. Apr. 2013;121:5-9. X-2, X-3, X-4. [pmid: 23313144].
2656 McDonald SJ, Middleton P, Dowswell T, et al. Effect of timing of umbilical cord clamping of term infants on maternal and neonatal outcomes. Cochrane Database Syst Rev. 2013;7. CD004074. X-1. [pmid: 23843134].
2657 McLean MT. Hemorrhage in Childbearing. Midwifery Today. 2013:8. X-1.
2658 Mehrabadi A, Hutcheon J, Lee L, et al. Epidemiological investigation of a temporal increase in atonic postpartum haemorrhage: a population-based retrospective cohort study. BJOG. Jun. 2013;120:853-62. X-4. [pmid: 23464351].
2659 Mehrabadi A, Hutcheon JA, Lee L, et al. Epidemiological investigation of a temporal increase in atonic postpartum haemorrhage: a population-based retrospective cohort study. BJOG. Jun. 2013;120(7):853-62. X-4. [pmid: 23464351].
2660 Melamed N, Segev M, Hadar E, et al. Outcome of trial of labor after cesarean section in women with past failed operative vaginal delivery. Am J Obstet Gynecol. Jul. 2013;209:49 e1-7. X-4. [pmid: 23507547].
2661 Merrick K, Jibodu OA, Rajesh U. The difficult PPH: experience of combined use of B-Lynch brace suture and intrauterine Bakri balloon in York hospital, UK. J Obstet Gynaecol. Apr. 2013;33:314-5. X-5. [pmid: 23550872].
2662 Mesbah Y, Fialla E, Barakat R, et al. Emergency peripartum hysterectomy: The experience of a tertiary referral hospital. Middle East Fertility Society Journal. June. 2013;18:89-93. X-2, X-4.
2663 Mhyre JM, Shilkrut A, Kuklina EV, et al. Massive blood transfusion during hospitalization for delivery in new york state, 1998-2007. Obstet Gynecol. Dec. 2013;122:1288-94. X-4, X-5. [pmid: 24201690].
2664 Mibi Kakisingi J, Zacche MM, Zacche G. The impact of traditional medicinal plants use in prenatal period in a Congolese community. Italian Journal of Gynaecology and Obstetrics. 2013;25:33-40. X-2, X-4.
2665 Miller S, Bergel EF, El Ayadi AM, et al. Non-Pneumatic Anti-Shock Garment (NASG), a First-Aid Device to Decrease Maternal Mortality from Obstetric Hemorrhage: A Cluster Randomized Trial. PLoS One. 2013;8:e76477. X-2. [pmid: 24194839].
2666 Miller S, Skinner J. Are first-time mjournals who plan home birth more likely to receive evidence-based care? A comparative study of home and hospital care provided by the same midwives. Birth. Jun. 2013;39:135-44. X-2, X-4. [pmid: 23281862].
2667 Mir SA, Masoodi SR, Wani AI, et al. Deep vein thrombosis in a patient of Sheehan's syndrome: Autoimmunity or hypercoagulabilty. Indian J Endocrinol Metab. Oct. 2013;17:S105-6. X-1, X-2, X-4. [pmid: 24251124].
2668 Mirteimouri M, Tara F, Teimouri B, et al. Efficacy of rectal misoprostol for prevention of postpartum hemorrhage. Iran J Pharm Res. Spring. 2013;12:469-74. X-2, X-4. [pmid: 24250623].
2669 Mirzabagi E, Deepak NN, Koski A, et al. Uterotonic use during childbirth in Uttar Pradesh: accounts from community members and health providers. Midwifery. Aug. 2013;29:902-10. X-2, X-3, X-4. [pmid: 23415370].
2670 Monod C, Voekt CA, Gisin M, et al. Optimization of competency in obstetrical emergencies: a role for simulation training. Arch Gynecol Obstet. 2013. Dec. 18. X-3, X-4. [pmid: 24346119].
2671 Monteith C, Ni Ainle F, Cooley S, et al. Hepatitis C virus-associated thrombocytopenia in pregnancy: impact upon multidisciplinary care provision. J Perinat Med. Jan. 2013;42:135-8. X-4. [pmid: 24006316].
2672 Montufar-Rueda C, Rodriguez L, Jarquin JD, et al. Severe postpartum hemorrhage from uterine atony: a multicentric study. J Pregnancy. 2013;2013:525914. X-2, X-4, X-5. [pmid: 24363935].
2673 Moonstone BA. Preventing Postpartum Hemorrhage • by Respecting the Natural Process of Third Stage. Midwifery Today. 2013:30-2. X-1, X-2, X-4, X-5.
2674 Mori R, Tokumasu H, Pledge D, et al. High-dose versus low-dose oxytocin for augmentation of delayed labour. Cochrane Database of Systematic Reviews. 2013;(7). Language: English. Entry Date: 20111014. Revision Date: 20140606. Publication Type: journal article. X-1.
2675 Morlando M, Sarno L, Napolitano R, et al. Placenta accreta: incidence and risk factors in an area with a particularly high rate of cesarean section. Acta Obstet Gynecol Scand. Apr. 2013;92:457-60. X-3, X-4. [pmid: 23347183].
2676 Moulder JK, Garrett LA, Salazar GM, et al. The role of radical surgery in the management of acquired uterine arteriovenous malformation. Case Reports in Oncology. May-August. 2013;6:303-10. X-1, X-3, X-4. [pmid: 23898273].
2677 Mpemba F, Kampo S, Zhang X. Towards 2015: post-partum haemorrhage in sub-Saharan Africa still on the rise. J Clin Nurs. 2013. Mar. 8. X-1, X-2, X-4. [pmid: 23472972].
2678 Muir HA. Pharmacologic intervention for managing uterine atony and related maternal hemorrhage: what is the most effective drug dose?. Can J Anaesth. Nov. 2013;60(11):1047-53. X-1. [pmid: 24092476].
2679 Mukta M, Sahay PB. Role of misoprostol 600 mcg oral in active management of third stage of labor: A comparative study with oxytocin 10 IU i.m. Journal of Obstetrics and Gynecology of India. 2013;63:325-7. X-2, X-4. [pmid: 24431668].
2680 Naji O, Wynants L, Smith A, et al. Does the presence of a Caesarean section scar affect implantation site and early pregnancy outcome in women attending an early pregnancy assessment unit?. Hum Reprod. Jun. 2013;28:1489-96. X-4. [pmid: 23585560].
2681 Naoko M, Yaeko K, Hiromi ETO, et al. Literature review of risk factors and preventive interventions for postpartum hemorrhage. Journal of Japan Academy of Midwifery. 2013;27:4-15. X-1.
2682 Nelissen E, Ersdal H, Ostergaard D, et al. Helping mjournals survive bleeding after birth: an evaluation of simulation-based training in a low-resource setting. Acta Obstet Gynecol Scand. 2013. Dec. 18. X-2, X-3, X-4. [pmid: 24344822].
2683 Nelissen EJ, Mduma E, Ersdal HL, et al. Maternal near miss and mortality in a rural referral hospital in northern Tanzania: a cross-sectional study. BMC Pregnancy Childbirth. 2013;13:141. X-2, X-4. [pmid: 23826935].
2684 Nelson BD, Stoklosa H, Ahn R, et al. Use of uterine balloon tamponade for control of postpartum hemorrhage by community-based health providers in South Sudan. Int J Gynaecol Obstet. Jul. 2013;122:27-32. X-2. [pmid: 23623587].
2685 Nelson DB, Yost NP, Cunningham FG. Acute fatty liver of pregnancy: clinical outcomes and expected duration of recovery. Am J Obstet Gynecol. Nov. 2013;209:456 e1-7. X-4. [pmid: 23860212].
2686 Nezvalova-Henriksen K, Spigset O, Nordeng H. Triptan safety during pregnancy: a Norwegian population registry study. Eur J Epidemiol. Sep. 2013;28:759-69. X-1, X-4. [pmid: 23884894].
2687 Ng VK, Lo TK, Tsang HH, et al. Intensive care unit admission of obstetric cases: a single centre experience with contemporary update. Hong Kong Med J. Feb. 2013;20:24-31. X-4, X-5. [pmid: 23784532].
2688 Ngowa JD, Ngassam AN, Dohbit JS, et al. Pregnancy outcome at advanced maternal age in a group of African women in two teaching Hospitals in Yaounde, Cameroon. Pan Afr Med J. 2013;14:134. X-2, X-4. [pmid: 23734279].
2689 Nguyen TN, Crowther CA, Wilkinson D, et al. Magnesium sulphate for women at term for neuroprotection of the fetus. Cochrane Database of Systematic Reviews. 2013. X-1.
2690 Nielsen C, Stengarde L, Bergsten C, et al. Relationship between herd-level incidence rate of energy-related postpartum diseases, general risk factors and claw lesions in individual dairy cows recorded at maintenance claw trimming. Acta Vet Scand. 2013;55:55. X-1, X-3, X-4. [pmid: 23880035].
2691 Nili F, McLeod L, O'Connell C, et al. Maternal and neonatal outcomes in pregnancies complicated by systemic lupus erythematosus: a population-based study. J Obstet Gynaecol Can. Apr. 2013;35:323-8. X-4. [pmid: 23660039].
2692 Nimbargi VR, Karmarkar MD. Intra uterine fetal death due to trauma - A case report. Indian Journal of Forensic Medicine and Toxicology. January-June. 2013;7:100-2. X-1.
2693 Nooren M, Nawal R. Obstetric hysterectomy: A life saving emergency. Indian J Med Sci. May. 2013;67:99-102. X-2, X-5. [pmid: 24326761].
2694 Noreen Z, Hassan S, Kazi A, et al. The influence of antenatal care on pregnancy outcome in Primigravidae. 2013;7:782-4. X-2, X-4.
2695 Nwankwo TO, Aniebue UU, Ezenkwele E, et al. Pregnancy outcome and factors affecting vaginal delivery of twins at University of Nigeria Teaching Hospital, Enugu. Niger J Clin Pract. Oct-Dec. 2013;16:490-5. X-2, X-4. [pmid: 23974745].
2696 Odent M. Preventing postpartum haemorrhage. Midwifery Today Int Midwife. Spring. 2013:18-9. [pmid: 23581193]. X-1, X-4, X-5.
2697 Okby R, Shoham-Vardi I, Ruslan S, et al. Is induction of labor risky for twins compare to singleton pregnancies?. J Matern Fetal Neonatal Med. Dec. 2013;26:1804-6. X-4. [pmid: 23662640].
2698 Okeke TC, Ezenyeaku CC, Ikeako LC. Caesarean hysterectomy. Niger J Med. Apr-Jun. 2013;22:83-8. X-2, X-4. [pmid: 23829115].
2699 Okeke TC, Ugwu EO, Okezie OA, et al. Trends and determinants of episiotomy at the University of Nigeria Teaching Hospital (Unth), Enugu, Nigeria. Niger J Med. Jul-Sep. 2013;21:304-7. X-2, X-4. [pmid: 23304925].
2700 Okonofua FE, Ogu RN, Akuse JT, et al. Assessment of sublingual misoprostol as first-line treatment for primary post-partum hemorrhage: Results of a multicenter trial. J Obstet Gynaecol Res. 2013. Dec. 10. X-2. [pmid: 24320203].
2701 Olefile KM, Khondowe O, M'Rithaa D. Misoprostol for prevention and treatment of postpartum haemorrhage: A systematic review. Curationis. 2013;36:E1-E10. X-1. [pmid: 23718882].
2702 Olsen R, Reisner DP, Benedetti TJ, et al. Bakri balloon effectiveness for postpartum hemorrhage: a “real world experience”. J Matern Fetal Neonatal Med. Nov. 2013;26:1720-3. X-5. [pmid: 23611683].
2703 Osmundson SS, Wong AE, Gerber SE. Second-trimester placental location and postpartum hemorrhage. J Ultrasound Med. Apr. 2013;32:631-6. X-4. [pmid: 23525388].
2704 Oteng-Ntim E, Kopeika J, Seed P, et al. Impact of obesity on pregnancy outcome in different ethnic groups: calculating population attributable fractions. PLoS One. 2013;8:e53749. X-4. [pmid: 23341993].
2705 Owolabi MS, Blake RE, Mayor MT, et al. Incidence and determinants of peripartum hysterectomy in the metropolitan area of the District of Columbia. J Reprod Med. Mar-Apr. 2013;58:167-72. X-4. [pmid: 23539887].
2706 Paidas MJ, Hossain N. Unexpected Postpartum Hemorrhage Due to an Acquired Factor VIII Inhibitor. Am J Perinatol. 2013. Dec. 11. X-1. [pmid: 24338123].
2707 Palmsten K, Hernandez-Diaz S, Huybrechts KF, et al. Use of antidepressants near delivery and risk of postpartum hemorrhage: cohort study of low income women in the United States. BMJ. 2013;347:f4877. X-4. [pmid: 23965506].
2708 Palsson R, Vidarsson B, Gudmundsdottir BR, et al. Complementary effect of fibrinogen and rFVIIa on clotting ex vivo in Bernard-Soulier syndrome and combined use during three deliveries. Platelets. 2013. Aug. 2. X-3, X-4. [pmid: 23909788].
2709 Palumbo MA, Fauzia M, Gulino FA, et al. Macrosomia: Effect, predictive maternal factor, neonatal complications. Our casuistry. Giornale Italiano di Ostetricia e Ginecologia. May-June. 2013;35:453-6. X-4.
2710 Parna FH, Latif T, Sultana N, et al. Maternal & fetal outcome of eclamptic patients admitted in obstetrics & gynaecology department of secondary care hospital in Bangladesh. Mymensingh Med J. Jul. 2013;22:522-6. X-2, X-4. [pmid: 23982543].
2711 Patacchiola F, D'Alfonso A, Di Fonso A, et al. Intrauterine balloon tamponade as management of postpartum haemorrhage and prevention of haemorrhage related to low-lying placenta. Clin Exp Obstet Gynecol. 2013;39:498-9. X-5. [pmid: 23444752].
2712 Pereira N, Delvadia D. A tool for teaching the B-Lynch brace suture method: An inexpensive new simulator allows obstetricians to polish an essential technique. Am J Obstet Gynecol. Dec. 2013;209:591 e1. X-1. [pmid: 23954532].
2713 Pervez SN, Javed K. Adenomyosis among samples from hysterectomy due to abnormal uterine bleeding. J Ayub Med Coll Abbottabad. Jan-Jun. 2013;25:68-70. X-3, X-4. [pmid: 25098058].
2714 Pongsatha S, Tongsong T. Randomized controlled trial comparing efficacy between a vaginal misoprostol loading and non-loading dose regimen for second-trimester pregnancy termination. J Obstet Gynaecol Res. Jan. 2013;40:155-60. X-3, X-4. [pmid: 24033985].
2715 Portilla D, Hernandez-Giraldo C, Moreno B, et al. A local hemostatic agent for the management of postpartum hemorrhage due to placenta previa and placenta accreta: a cross-sectional study. Arch Gynecol Obstet. Sep. 2013;288:543-9. X-2. [pmid: 23532388].
2716 Poujade O, Ceccaldi PF, Davitian C, et al. Uterine necrosis following pelvic arterial embolization for post-partum hemorrhage: review of the literature. Eur J Obstet Gynecol Reprod Biol. Oct. 2013;170:309-14. X-1. [pmid: 23932304].
2717 Prabhu TRB. Cerebrovascular complications in pregnancy and puerperium. Journal of Obstetrics and Gynecology of India. April. 2013;63:108-11. X-2, X-3, X-4. [pmid: 24431615].
2718 Prata N, Bell S, Weidert K. Prevention of postpartum hemorrhage in low-resource settings: current perspectives. Int J Womens Health. 2013;5:737-52. X-1. [pmid: 24259988].
2719 Prick BW, Vos AA, Hop WC, et al. The current state of active third stage management to prevent postpartum hemorrhage: a cross-sectional study. Acta Obstet Gynecol Scand. Nov. 2013;92:1277-83. X-4. [pmid: 23962221].
2720 Raees M, Yasmeen S, Jabeen S, et al. Maternal morbidity associated with emergency versus elective caesarean section. Journal of Postgraduate Medical Institute. 2013;27:55-62. X-2, X-4.
2721 Rajab KE, Al Sibai R. Ostpartum hemorrhage caused by pseudoaneurysm associated with malformations of the uterus. Bahrain Medical Bulletin. 2013;35. X-1, X-2.
2722 Ramachandra Bhat PB, Navada MH, Rao SV, et al. Evaluation of obstetric admissions to intensive care unit of a tertiary referral center in coastal India. Indian J Crit Care Med. Jan. 2013;17:34-7. X-2, X-4, X-5. [pmid: 23833474].
2723 Rana A, Baral G, Dangal G. Maternal near-miss: a multicenter surveillance in kathmandu valley. JNMA J Nepal Med Assoc. Apr-Jun. 2013;52:299-304. X-2, X-4. [pmid: 24362650].
2724 Rani S, Huria A, Al-Sawaf A, El-Mazny A, Shohayeb A. A randomised controlled trial of sublingual misoprostol and intramuscular oxytocin for prevention of postpartum haemorrhage. Journal of Obstetrics and Gynaecology. 2013;33:277-279. J Obstet Gynaecol. 2013 Oct;33:751. X-1, X-2, X-4, X-5. [pmid: 23550857].
2725 Rashid N, Asif R, Zahra A, et al. Morbidity & mortality associated with placenta previa in emergency versus elective cesarean section. 2013;7. X-2.
2726 Rath W. Active management of the third stage of labour (AMTSL) - the end of a 50 years-dogma?. Z Geburtshilfe Neonatol. Oct. 2013;217:173-6. X-1. [pmid: 24170442].
2727 Ray A, Suri JC, Gupta M. Rifampicin induced adrenal crisis in an uncommon setting. Lung India. October-December. 2013;30:363-4. X-1. [pmid: 24339502].
2728 Rishard MR, Galgomuwa GV, Gunawardane K. Improvised condom catheter with a draining channel for management of atonic post partum haemorrhage. Ceylon Med J. Sep. 2013;58:124-5. X-2, X-4, X-5. [pmid: 24081174].
2729 Robert T, Kawkabani Marchini A, Oumarou G, et al. Reversible cerebral vasoconstriction syndrome identification of prognostic factors. Clin Neurol Neurosurg. Nov. 2013;115:2351-7. X-3, X-4. [pmid: 24021453].
2730 Rohwer AC, Khondowe O, Young T. Antispasmodics for labour. Cochrane Database of Systematic Reviews. 2013. X-1.
2731 Rushing LK, Greene VM. Combating Obstetric Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2013;42:S27-8. X-1, X-4, X-5.
2732 Sadler LC, Austin DM, Masson VL, et al. Review of contributory factors in maternity admissions to intensive care at a New Zealand tertiary hospital. Am J Obstet Gynecol. Dec. 2013;209:549 e1-7. X-4, X-5. [pmid: 23911384].
2733 Samejima K, Takai Y, Matsumura H, et al. Recombinant tissue plasminogen activator for massive pulmonary thromboembolism. BMJ Case Reports. 2013. X-1.
2734 Samimi M, Imani-Harsini A, Abedzadeh-Kalahroudi M. Carbetocin vs. syntometrine in prevention of postpartum hemorrhage: A double blind randomized control trial. Iranian Red Crescent Medical Journal. September. 2013;15:817-22. X-2, X-4. [pmid: 24616793].
2735 Schiraldi R, Calderon L, Maggi G, et al. Transoesophageal Doppler-guided fluid management in massive obstetric haemorrhage. Int J Obstet Anesth. Feb. 2013;23:71-4. X-1, X-4, X-5. [pmid: 24315699].
2736 Schmid BC, Rezniczek GA, Rolf N, et al. Uterine packing with chitosan-covered gauze for control of postpartum hemorrhage. Am J Obstet Gynecol. Sep. 2013;209:225 el-5. X-4, X-5. [pmid: 23727525].
2737 Scholten BL, Page-Christiaens GC, Franx A, et al. The influence of pregnancy termination on the outcome of subsequent pregnancies: a retrospective cohort study. BMJ Open. 2013;3. X-4. [pmid: 23793655].
2738 Scholten BL, Page-Christiaens GCML, Franx A, et al. The influence of pregnancy termination on the outcome of subsequent pregnancies: A retrospective cohort study. United Kingdom. BMJ Publishing Group. (Tavistock Square, London WC1H 9JR, United Kingdom). 2013. http://bmjopen.bmj.com/content/3/5/e002803.full.pdf+htmlhttp://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed11&NEWS=N&AN=2013346583. Accessed on (Scholten, Page-Christiaens, Franx, Koster) Department of Obstetrics, University Medical Center Utrecht, Utrecht, Netherlands 3.
2739 Scott-Pillai R, Spence D, Cardwell CR, et al. The impact of body mass index on maternal and neonatal outcomes: a retrospective study in a UK obstetric population, 2004-2011. BJOG. Jul. 2013;120:932-9. X-4. [pmid: 23530609].
2740 Seethala S, Gaur S, Enderton E, et al. Postpartum acquired hemophilia: a rare cause of postpartum hemorrhage. Case Rep Hematol. 2013;2013:735715. X-1, X-4, X-5. [pmid: 23533849].
2741 Sehhati F, Naghizadeh S, Gojazadeh M. Comparison of maternal outcomes in women admitted in latent and active phases of labor. Iranian Journal of Obstetrics, Gynecology and Infertility. June. 2013;16:18-28. X-2, X-4.
2742 Seijmonsbergen-Schermers AE, Geerts CC, Prins M, et al. The use of episiotomy in a low-risk population in the Netherlands: a secondary analysis. Birth. Dec. 2013;40:247-55. X-4. [pmid: 24344705].
2743 Sekhavat L, Karbasi SA, Fallah R, et al. Effect of hyoscine butylbromide first stage of labour in multiparus women. Afr Health Sci. Dec. 2013;12:408-11. X-2, X-4. [pmid: 23515202].
2744 Sellmyer MA, Desser TS, Maturen KE, et al. Physiologic, histologic, and imaging features of retained products of conception. Radiographics. May. 2013;33:781-96. X-1, X-4. [pmid: 23674774].
2745 Shaheen S, Akhtar S. Pregnancy after B-Lynch suture and uterine artery ligation in case of placenta increta. Journal of Postgraduate Medical Institute. 2013;27:459-60. X-2, X-5.
2746 Shahzadi U. Frequency of barriers for non-using of contraception in multigravida women attending a tertiary care hospital. 2013;7:1154-6. X-2, X-4.
2747 Shaikh MM, Bano K, Mujtaba S. Feto-maternal outcomes in women with congenital heart disease. 2013;24:5-9. X-2, X-4.
2748 Shaikh S, Shaikh NB, Abassi R, et al. Obstetric admission to the intensive care unit: A one year review. 2013;19:59-63. X-2, X-4.
2749 Sharief LA, Kadir RA. Congenital factor XIII deficiency in women: a systematic review of literature. Haemophilia. Nov. 2013;19:e349-57. X-1. [pmid: 23992439].
2750 Sharma N, Ganesh D, Devi L, et al. Prompt diagnosis and treatment of uterine arcuate artery pseudoaneurysm: A case report and review of literature. India. Journal of Clinical and Diagnostic Research. (No 3, 1/9 Roop Nagar, G T Road, Delhi 110007, India). 2013. http://www.jcdr.net/articles/PDF/3506/62-%206063_E%28C%29_F%28T%29_PF1%28P_N_P%29_PFA%28NC%29.pdfhttp://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed11&NEWS=N&AN=2013639624. Accessed on (Sharma, Ganesh, Devi, Srinivasan) Department of Obstetrics and Gynaecology, Saveetha Medical College, No.162 Poonamalle High Road, Chennai -6000077, India 7.
2751 Sharma N, Ganesh D, Devi L, et al. Prompt Diagnosis and Treatment of Uterine Arcuate Artery Pseudoaneurysm: A Case Report and Review of Literature. J Clin Diagn Res. Oct. 2013;7:2303-6. X-1, X-2, X-5. [pmid: 24298511].
2752 Shashikala G, Sumathi K, Anuradha C. Pregnancy outcome in patient with adult onset still's disease-a rare case report. International Journal of Pharma and Bio Sciences. October/December. 2013;4:B694-B7. X-1.
2753 Sheikh S, Naz S, Shaikh A, et al. B-Lynch suture in the management of massive post partum hemorrhage. Rawal Medical Journal. 2013;38:404-8. X-2.
2754 Shekhar S, Chauhan N, Singh K, et al. Delayed and successful manual removal of abnormally adherent placenta necessitated by uterine sepsis following conservative management with adjuvant methotrexate - A rewarding clinical experience. South African Journal of Obstetrics and Gynaecology. 2013;19:19-21. X-1, X-2.
2755 Sheldon WR, Durocher J, Winikoff B, et al. How effective are the components of active management of the third stage of labor?. BMC Pregnancy Childbirth. 2013;13:46. X-4. [pmid: 23433172].
2756 Shoib S, Dar MM, Arif T, et al. Sheehan's syndrome presenting as psychosis: a rare clinical presentation. Med J Islam Repub Iran. Feb. 2013;27:35-7. X-1. [pmid: 23483784].
2757 Smit M, Sindram SI, Woiski M, et al. The development of quality indicators for the prevention and management of postpartum haemorrhage in primary midwifery care in the Netherlands. BMC Pregnancy Childbirth. Oct. 20. 2013;13:194. X-1, X-3, X-4. [pmid: 24139411].
2758 Smith JM, Gubin R, Holston M, et al. Misoprostol for postpartum hemorrhage prevention at home birth: an integrative review of global implementation experience to date. MIDIRS Midwifery Digest. 2013;23:399-400. X-1.
2759 Smith JM, Gubin R, Holston MM, et al. Misoprostol for postpartum hemorrhage prevention at home birth: an integrative review of global implementation experience to date. MIDIRS Midwifery Digest. 2013;23(3):399-400. Language: English. Entry Date: 20131220. Revision Date: 20131220. Publication Type: journal article. X-1.
2760 Soni M, Agrawal S, Soni P, et al. Causes of maternal mortality: Our scenario. 2013;5:96-8. X-2, X-4, X-5.
2761 Soresi M, Brunori G, Citarrella R, et al. Late-onset Sheehan's syndrome presenting with rhabdomyolysis and hyponatremia: a case report. J Med Case Rep. 2013;7:227. X-1, X-4. [pmid: 24083446].
2762 Souza JP. The prevention of postpartum hemorrhage in the community. PLoS Med. Oct. 2013;10:e1001525. X-1. [pmid: 24130464].
2763 Souza JP, Gulmezoglu AM, Vogel J, et al. Moving beyond essential interventions for reduction of maternal mortality (the WHO Multicountry Survey on Maternal and Newborn Health): a cross-sectional study. Lancet. May. 18. 2013;381:1747-55. X-2, X-4. [pmid: 23683641].
2764 Stanton CK, Newton S, Mullany LC, et al. Effect on postpartum hemorrhage of prophylactic oxytocin (10 IU) by injection by community health officers in Ghana: a community-based, cluster-randomized trial. PLoS Med. Oct. 2013;10:e1001524. X-2, X-4. [pmid: 24130463].
2765 Steiner N, Weintraub AY, Madi Y, et al. The unfavorable slope from mild preeclampsia through severe preeclampsia, to eclampsia. Pregnancy Hypertension. April. 2013;3:146-50. X-1, X-4.
2766 Stewart L, Kendall A, Knight M, et al. The relationship between type of labour and third stage oxytocic use on postpartum haemorrhage rates. Women & Birth. 2013;26:S27-S. Language: English. Entry Date: 20140404. Revision Date: 20140926. Publication Type: journal article. X-4.
2767 Stock SJ, Ferguson E, Duffy A, et al. Outcomes of induction of labour in women with previous caesarean delivery: a retrospective cohort study using a population database. PLoS One. 2013;8:e60404. X-4. [pmid: 23565242].
2768 Stock SJ, Josephs K, Farquharson S, et al. Maternal and neonatal outcomes of successful Kielland's rotational forceps delivery. Obstet Gynecol. May. 2013;121:1032-9. X-4. [pmid: 23635740].
2769 Stohl HE, Ouzounian J, Rick AM, et al. Thyroid disease and gestational diabetes mellitus (GDM): is there a connection?. J Matern Fetal Neonatal Med. Jul. 2013;26:1139-42. X-3, X-4. [pmid: 23461673].
2770 Straub HL, Morgan G, Ochoa P, et al. Targeted obstetric haemorrhage programme improves incoming resident confidence and knowledge. J Obstet Gynaecol. Nov. 2013;33:798-801. X-3, X-4. [pmid: 24219716].
2771 Sulaiman S, Othman S, Razali N, et al. Obstetric and perinatal outcome in teenage pregnancies. South African Journal of Obstetrics and Gynaecology. 2013;19:77-80. X-2, X-4.
2772 Sutherland T, Downing J, Miller S, et al. Use of the non-pneumatic anti-shock garment (NASG) for life-threatening obstetric hemorrhage: a cost-effectiveness analysis in Egypt and Nigeria. PLoS One. 2013;8:e62282. X-2. [pmid: 23646124].
2773 Suwal A, Shrivastava VR, Giri A. Maternal and Fetal Outcome in Elective versus Emergency Cesarean Section. JNMA J Nepal Med Assoc. Oct-Dec. 2013;52(192):563-6. X-2, X-4. [pmid: 25327227].
2774 Takeda J, Makino S, Ota A, et al. Spontaneous uterine rupture at 32 weeks of gestation after previous uterine artery embolization. J Obstet Gynaecol Res. 2013. Aug. 15. X-1, X-2, X-3. [pmid: 23945024].
2775 Tan PC, Soe MZ, Sulaiman S, et al. Immediate compared with delayed oxytocin after amniotomy labor induction in parous women: a randomized controlled trial. Obstet Gynecol. Feb. 2013;121:253-9. X-4. [pmid: 23344273].
2776 Tang J, Kapp N, Dragoman M, et al. WHO recommendations for misoprostol use for obstetric and gynecologic indications. Int J Gynaecol Obstet. May. 2013;121:186-9. X-1. [pmid: 23433680].
2777 Tempest N, Hart A, Walkinshaw S, et al. A re-evaluation of the role of rotational forceps: retrospective comparison of maternal and perinatal outcomes following different methods of birth for malposition in the second stage of labour. BJOG. Sep. 2013;120:1277-84. X-4. [pmid: 23906197].
2778 Ten Eikelder ML, Neervoort F, Oude Rengerink K, et al. Induction of labour with a Foley catheter or oral misoprostol at term: the PROBAAT-II study, a multicentre randomised controlled trial. BMC Pregnancy Childbirth. 2013;13:67. X-1, X-4. [pmid: 23506128].
2779 Ten Eikelder ML, Neervoort F, Oude Rengerink K, et al. Induction of labour with a Foley catheter or oral misoprostol at term: the PROBAAT-II study, a multicentre randomised controlled trial. BMC Pregnancy Childbirth. 2013;13:67. X-1, X-4, X-5. [pmid: 23506128].
2780 Tewatia R, Rani S, Srivastav U, et al. Sublingual misoprostol versus intravenous oxytocin in prevention of post-partum hemorrhage. Arch Gynecol Obstet. 2013. Sep. 18. X-4. [pmid: 24045979].
2781 Thewjitcharoen Y, Udae S, Treeprasertsuk S. Severe acute fatty liver in pregnancy: A diagnostic dilemma in clinical practice. Asian Biomedicine. February. 2013;7:125-30. X-1, X-2, X-4.
2782 Trinh AT, Khambalia A, Ampt A, et al. Episiotomy rate in Vietnamese-born women in Australia: support for a change in obstetric practice in Viet Nam. Bull World Health Organ. May. 1. 2013;91:350-6. X-4. [pmid: 23678198].
2783 Tufail S, Bangash N, Siddiqui FR. Safety of Abdominal vs. Vaginal delivery in women with cardiac diseases. Rawal Medical Journal. 2013;38:413-6. X-2, X-4.
2784 Tuncalp O, Souza JP, Gulmezoglu M. New WHO recommendations on prevention and treatment of postpartum hemorrhage. Int J Gynaecol Obstet. Dec. 2013;123:254-6. X-1. [pmid: 24054054].
2785 Tyrberg RB, Blomberg M, Kjolhede P. Deliveries among teenage women - with emphasis on incidence and mode of delivery: a Swedish national survey from 1973 to 2010. BMC Pregnancy Childbirth. 2013;13:204. X-4. [pmid: 24207112].
2786 Umashankar KM, Dharmavijaya MN, Sudha R, et al. Effect of a primary postpartum haemorrhage on the “Near-Miss” morbidity and mortality at a tertiary care hospital in Rural Bangalore, India. India. Journal of Clinical and Diagnostic Research. (71 Veer Nagar,G.T. Road, Delhi 110007, India). 2013. http://www.jcdr.net/articles/PDF/3066/34%20-%205376_PF1%28M%29_E%28C%29_F%28T%29_PF1%28PUH%29_PFA%28PUH%29NEW.pdfhttp://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed11&NEWS=N&AN=2013355939. Accessed on (Umashankar, Dharmavijaya, Sudha, Datti, Kavitha, Laxmi) Obstetrics and Gynaecology, MVJ Medical College, Bangalore, India 7.
2787 Un-Nisa S, Un-Nisa M. Maternal outcome in active and expectant management of third stage of labour. 2013;7:758-60. X-2, X-4.
2788 Upson K, Silver RM, Greene R, et al. Placenta accreta and maternal morbidity in the Republic of Ireland, 2005-2010. J Matern Fetal Neonatal Med. Jan. 2013;27:24-9. X-4. [pmid: 23638753].
2789 Usman N, Noblet J, Low D, et al. Intra-aortic balloon occlusion without fluoroscopy for severe postpartum haemorrhage secondary to placenta percreta. Int J Obstet Anesth. 2013. Nov. 30. X-1, X-2, X-4, X-5. [pmid: 24300388].
2790 Usmani I, Bakhsh FM. Primary post partum hemorrhage an obstetric catastrophe: A review of 270 cases. Medical Forum Monthly. June. 2013;24:69-72. X-2, X-4.
2791 Usmani SY, Nisa SU, Nisa SS, et al. Out come of pregnancies associated with fibroids. Pakistan. Lahore Medical And Dental College. (Tulspura, North Canal Bank, Lahore, Pakistan). 2013. http://pjmhsonline.com/http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed11&NEWS=N&AN=2013668951. Accessed on (Usmani, Nisa, Nisa, Latif) 1 Demonstrator, QAMC Bahawalpur, 2 WMO, Gynaecology, BVH Bahawalpur, 3 Department of Gynaecology, BVH Bahawalpur, 4 WMO, Gynaecology, BVH Bahawalpur 7.
2792 van Baaren GJ, Jozwiak M, Opmeer BC, et al. Cost-effectiveness of induction of labour at term with a Foley catheter compared to vaginal prostaglandin E(2) gel (PROBAAT trial). BJOG. Jul. 2013;120:987-95. X-3, X-4. [pmid: 23530729].
2793 van Beekhuizen HJ, Tarimo V, Pembe AB, et al. A randomized controlled trial on the value of misoprostol for the treatment of retained placenta in a low-resource setting. Int J Gynaecol Obstet. Sep. 2013;122:234-7. X-2, X-4, X-5. [pmid: 23791153].
2794 van Dam VC, ten Tusscher BL, Girbes ARJ. Sepsis and bleeding in an obstetric patient who is a Jehovah's Witness. Netherlands Journal of Critical Care. 2013;17:19-22. X-1.
2795 Van Wagner V, Osepchook C, Harney E, et al. Remote midwifery in Nunavik, Quebec, Canada: outcomes of perinatal care for the Inuulitsivik health centre, 2000-2007. Birth. Sep. 2013;39:230-7. X-4. [pmid: 23281905].
2796 Velez Alvarez GA, Agudelo Jaramillo B, Gomez Davila J, et al. Validation of Code Red: a proposal for the treatment of obstetric hemorrhage. Rev Panam Salud Publica. Oct. 2013;34:244-9. X-1, X-2, X-5. [pmid: 24301735].
2797 Vetere PF, Wayock CP, Muscat J, et al. A novel approach to teaching placement of a B-lynch suture: description of technique and validation of teaching model. J Grad Med Educ. Sep. 2013;4:367-9. X-3, X-4. [pmid: 23997884].
2798 Vidal F, Simon C, Cristini C, et al. Instrumental rotation for persistent fetal occiput posterior position: a way to decrease maternal and neonatal injury?. PLoS One. 2013;8(10):e78124. X-4. [pmid: 24205122].
2799 Vinayagam D, Chandraharan E. The adverse impact of maternal obesity on intrapartum and perinatal outcomes. ISRN Obstet Gynecol. 2013;2012:939762. X-4. [pmid: 23316381].
2800 von Schmidt Auf Altenstadt JF, Hukkelhoven CW, van Roosmalen J, et al. Pre-eclampsia increases the risk of postpartum haemorrhage: a nationwide cohort study in the Netherlands. PLoS One. 2013;8:e81959. X-4. [pmid: 24367496].
2801 Vrachnis N, Salakos N, Iavazzo C, et al. Bakri balloon tamponade for the management of postpartum hemorrhage. Int J Gynaecol Obstet. Sep. 2013;122:265-6. X-5. [pmid: 23791152].
2802 Wada N, Tachibana D, Nakagawa K, et al. Pathological findings in a case of failed uterine artery embolization for placenta previa. Jpn Clin Med. 2013;4:25-8. X-5. [pmid: 23966814].
2803 Waechter M. Thinking Green. Midwifery Today. 2013:16-7. X-1.
2804 Waheed G, Toheed R, Mansha M, et al. Comparison of causes of postpartum haemorrhage following vaginal deliveries and caesarean sections in a tertiary care hospital of Pakistan. 2013;7:885-9. X-2, X-4.
2805 Waheed SS, Siddique T, Farzand S. Evaluation of complications associated with twin pregnancy. 2013;7. X-2, X-4.
2806 Wan Po JL, Bhatia K. Pre-eclampsia and the anaesthetist. Anaesthesia and Intensive Care Medicine. July. 2013;14:283-6. X-1.
2807 Wandabwa J, Businge C, Longo-Mbenza B, et al. Peripartum hysterectomy: two years experience at Nelson Mandela Academic hospital, Mthatha, Eastern Cape South Africa. Afr Health Sci. Jun. 2013;13:469-74. X-2, X-4. [pmid: 24235951].
2808 Wandabwa JN, Businge C, Longo-Mbenza B, et al. Peripartum hysterectomy: two years experience at Nelson Mandela Academic hospital, Mthatha, Eastern Cape South Africa. Afr Health Sci. Jun. 2013;13(2):469-74. X-2, X-4. [pmid: 24235951].
2809 Wanyonyi SZ, Ngichabe SK. Safety concerns for planned vaginal birth after caesarean section in sub-Saharan Africa. BJOG. Jan. 2013;121:141-3. discussion 4. X-1, X-2, X-4, X-5. [pmid: 24206159].
2810 Watson LF, Taft AJ. Intimate partner violence and the association with very preterm birth. Birth. Mar. 2013;40(1):17-23. X-3, X-4. [pmid: 24635420].
2811 Webbon L. Management of umbilical cord clamping. Pract Midwife. Feb. 2013;16:23-6. X-1. [pmid: 23461232].
2812 Weed S. Hemorrhage!. Midwifery Today. 2013;(105):23-5. [pmid: 2012050612]. Language: English. Entry Date: 20130329. Revision Date: 20140103. Publication Type: journal article. Journal Subset: Nursing. X-1.
2813 Westhoff G, Cotter AM, Tolosa JE. Prophylactic oxytocin for the third stage of labour to prevent postpartum haemorrhage. Cochrane Database Syst Rev. 2013;10. CD001808. X-1, X-4. [pmid: 24173606].
2814 Wetta LA, Szychowski JM, Seals S, et al. Risk factors for uterine atony/postpartum hemorrhage requiring treatment after vaginal delivery. Am J Obstet Gynecol. Jul. 2013;209:51 e1-6. X-4. [pmid: 23507549].
2815 Wikstrom Shemer EA, Thorsell M, Marschall HU, et al. Risks of emergency cesarean section and fetal asphyxia after induction of labor in intrahepatic cholestasis of pregnancy: a hospital-based retrospective cohort study. Sex Reprod Healthc. Mar. 2013;4:17-22. X-4. [pmid: 23427928].
2816 Wuntakal R, Kaler M, Hollingworth T. Women with high BMI: should they be managed differently due to antagonising action of leptin in labour?. Med Hypotheses. Jun. 2013;80:767-8. X-1. [pmid: 23570649].
2817 Xianbao L, Hong Z, Xu Z, et al. Dexmedetomidine reduced cytokine release during postpartum bleeding-induced multiple organ dysfunction syndrome in rats. Mediators Inflamm. 2013;2013:627831. X-1, X-3, X-4. [pmid: 23840096].
2818 Yaju Y, Kataoka Y, Eto H, et al. Prophylactic interventions after delivery of placenta for reducing bleeding during the postnatal period. Cochrane Database Syst Rev. 2013;11. CD009328. X-1, X-4. [pmid: 24277681].
2819 Yang XL, Zhou YF, Huang Y, et al. Analysis of obstetric outcomes for different types of placenta previa. Zhonghua Yi Xue Za Zhi. Mar. 19. 2013;93:849-51. X-2, X-4. [pmid: 23859393].
2820 Yasmin S, Yasmin A, Khattak NN, et al. Active versus conservative management of prelabour rupture of membranes at term. Journal of Postgraduate Medical Institute. 2013;27:63-8. X-2, X-4.
2821 Yeniel AO, Ergenoglu AM, Akdemir A, et al. Massive secondary postpartum hemorrhage with uterine artery pseudoaneurysm after cesarean section. Case Rep Obstet Gynecol. 2013;2013:285846. X-2, X-5. [pmid: 23653875].
2822 Zambrana L. OB Hemorrhage Complicated by DIC: Are You Ready?. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2013;42:S95-S. X-1.
2823 Zhang J, Liu Q, Zhang W, et al. Selective arterial occlusion in the treatment of placenta percreta in late trimester of pregnancy. Zhong Nan Da Xue Xue Bao Yi Xue Ban. May. 2013;38:532-6. X-2. [pmid: 23719534].
2824 Zia S, Rafique M, Rizwan A, et al. Maternal outcome in emergency peripartum hysterectomy: Minimizing the risks. 2013;5:91-5. X-2.
2825 Ziyauddin F, Hakim S, Beriwal S. The transcervical foley catheter versus the vaginal prostaglandin E2 gel in the induction of labour in a previous one caesarean section - A clinical study. Journal of Clinical and Diagnostic Research. 01. Jan. 2013;7:140-3. X-2, X-4. [pmid: 23450272].
2826 Ziyauddin F, Hakim S, Khan T. Delivery of the deeply engaged fetal head during cesarean section in advanced labour: A comparative study of head pushing versus reverse breech extraction. Current Pediatric Research. January-June. 2013;17:41-3. X-4.
2827 SSRI antidepressants: postpartum haemorrhage. Prescrire Int. Jul. 2014;23(151):186. X-4. [pmid: 25162096].
2828 Correction... “Interpretation of National Policy Regarding Community-Based Use of Misoprostol for Postpartum Hemorrhage Prevention in Ethiopia: A Tale of Two Regions,” published in the January/February 2014 special issue of the Journal of Midwifery &Women's Health (59[s1]:S83-S90). Journal of Midwifery & Women's Health. 2014;59(5):560. Language: English. Entry Date: 20141017. Revision Date: 20141024. Publication Type: journal article. X-2, X-4.
2829 New from the Cochrane Library. Essentially MIDIRS. 2014;5(4):48-9. Language: English. Entry Date: 20140606. Revision Date: 20140620. Publication Type: journal article. Journal Subset: Editorial Board Reviewed. X-1.
2830 Abdul-Kadir R, McLintock C, Ducloy AS, et al. Evaluation and management of postpartum hemorrhage: consensus from an international expert panel. Transfusion. 2014. Mar. 12. X-1, X-3, X-4. [pmid: 24617726].
2831 Al Wadi K, Schneider C, Burym C, et al. Evaluating the safety of labour in women with a placental edge 11 to 20 mm from the internal cervical Os. J Obstet Gynaecol Can. Aug. 2014;36(8):674-7. X-3, X-4. [pmid: 25222161].
2832 Alam K, Snover A, Sultana N. Safety and feasibility of intrauterine device insertion following post-placental delivery. 2014;39:186-9. X-2, X-3, X-4.
2833 Al-Kadri HM, Dahlawi H, Al Airan M, et al. Effect of education and clinical assessment on the accuracy of post partum blood loss estimation. BMC Pregnancy Childbirth. 2014;14:110. X-2, X-3, X-4. [pmid: 24646156].
2834 Allard S, Green L, Hunt BJ. How we manage the haematological aspects of major obstetric haemorrhage. Br J Haematol. Jan. 2014;164:177-88. X-1. [pmid: 24383841].
2835 Alouini S. Bakri balloon tamponade as first step to manage severe post partum haemorrhage. Ir J Med Sci. Dec. 2014;183(4):693. X-1. [pmid: 25284639].
2836 Ameh CA, Adegoke A, Pattinson RC, et al. Using the new ICD-MM classification system for attribution of cause of maternal death--a pilot study. BJOG. Sep. Suppl 4. 2014;121:32-40. X-2, X-4. [pmid: 25236631].
2837 Amin N. Prophylactic use of misoprostol in management of third stage of labour and prevention of atonic uterus. 2014;28:196-200. X-2, X-4.
2838 Anderson M. From the editor: Observing birth from the sidelines. Essentially MIDIRS. 2014;5(8):5-6. Language: English. Entry Date: 20140926. Revision Date: 20140926. Publication Type: journal article. X-1.
2839 Arjun Sundarsingh R, Jayakumar H, Ajay Kumar A. Life threatening reactions to synthetic oxytocin - a case report. 2014;5:1371-3. X-2, X-5.
2840 Arora N, Kausar H, Jana N, et al. Congenital heart disease in pregnancy in a low-income country. Int J Gynaecol Obstet. 2014. Sep. 18. X-2, X-3, X-4. [pmid: 25270822].
2841 Ashraf N, Mishra SK, Kundra P. Obstetric patients requiring intensive care: a one year retrospective study in a tertiary care institute in India. 2014;2014:789450. X-2. [pmid: 24790597].
2842 Ashraf N, Mishra SK, Kundra P, et al. Obstetric patients requiring intensive care: a one year retrospective study in a tertiary care institute in India. Anesthesiol Res Pract. 2014;2014:789450. X-2, X-4. [pmid: 24790597].
2843 Ashwal E, Yogev Y, Melamed N, et al. Characterizing the need for re-laparotomy during puerperium after cesarean section. Arch Gynecol Obstet. 2014. Feb. 1. X-5. [pmid: 24488580].
2844 Atukunda EC, Siedner MJ, Obua C, et al. Sublingual Misoprostol versus Intramuscular Oxytocin for Prevention of Postpartum Hemorrhage in Uganda: A Double-Blind Randomized Non-Inferiority Trial. PLoS Med. Nov. 2014;11(11):e1001752. X-2, X-4. [pmid: 25369200].
2845 Austin DM, Sadler L, McLintock C, et al. Early detection of severe maternal morbidity: a retrospective assessment of the role of an Early Warning Score System. Aust N Z J Obstet Gynaecol. Apr. 2014;54(2):152-5. X-3, X-4. [pmid: 24359235].
2846 Azam S, Khanam A, Tirlapur S, et al. Planned caesarean section or trial of vaginal delivery? A meta-analysis. Curr Opin Obstet Gynecol. Dec. 2014;26(6):461-8. X-1, X-4. [pmid: 25304604].
2847 Aziz S, Kazi S, Haq G, et al. Oral misoprostol versus oxytocin in the management of third stage of labour. J Pak Med Assoc. Apr. 2014;64:428-32. X-2, X-4. [pmid: 24864638].
2848 Baba Y, Matsubara S, Kuwata T, et al. Uterine artery pseudoaneurysm: not a rare condition occurring after non-traumatic delivery or non-traumatic abortion. Arch Gynecol Obstet. Sep. 2014;290(3):435-40. X-3, X-4. [pmid: 24691826].
2849 Baker K. How to ... manage primary postpartum haemorrhage. Midwives. 2014;17(4):34-5. [pmid: 25145103]. X-1, X-4, X-5.
2850 Baker KC. Postpartum haemorrhage and the management approaches in the third stage of labour. MIDIRS Midwifery Digest. 2014;24(2):191-6. Language: English. Entry Date: 20140620. Publication Type: journal article. X-1.
2851 Balachandran L, Vaswani PR, Mogotlane R. Pregnancy outcome in women with previous one cesarean section. 2014;8:99-102. X-4.
2852 Bas-Lando M, Srebnik N, Farkash R, et al. Elective induction of labor in women with gestational diabetes mellitus: an intervention that modifies the risk of cesarean section. Arch Gynecol Obstet. 2014. Jun. 28. X-4. [pmid: 24973018].
2853 Bassey G, Akani CI. Emergency peripartum hysterectomy in a low resource setting: a 5-year analysis. Niger J Med. Apr-Jun. 2014;23:170-5. X-2. [pmid: 24956692].
2854 Batra P, Suda D, Markovic D, et al. The effect of an obstetric hemorrhage protocol on outcomes in postpartum hemorrhage. Obstet Gynecol. May. Suppl 1. 2014;123:136s. X-1.
2855 Bazzano M, Giannetto C, Fazio F, et al. Hemostatic profile during late pregnancy and early postpartum period in mares. Theriogenology. Mar. 1. 2014;81(4):639-43. X-1, X-3, X-4. [pmid: 24388675].
2856 Begum J, Pallave P, Ghose S. B-lynch: a technique for uterine conservation or deformation? A case report with literature review. J Clin Diagn Res. Apr. 2014;8(4):Od01-3. X-3, X-4. [pmid: 24959485].
2857 Begum M, Alsafi F, ElFarra J, et al. Emergency peripartum hysterectomy in a tertiary care hospital in saudi arabia. J Obstet Gynaecol India. Oct. 2014;64(5):321-7. X-2, X-4. [pmid: 25368454].
2858 Belay T, Yusuf L, Negash S. A comparative study on first stage versus second stage caesarean section on maternal and perinatal outcome. Ethiop Med J. Jan. 2014;52:1-8. X-2, X-4. [pmid: 25069208].
2859 Bell S, Passano P, Bohl DD, et al. Training traditional birth attendants on the use of misoprostol and a blood measurement tool to prevent postpartum haemorrhage: lessons learnt from Bangladesh. J Health Popul Nutr. Mar. 2014;32:118-29. X-2, X-3, X-4. [pmid: 24847601].
2860 Bhatti K, Mahar T, Hafeez R, et al. A randomized controlled trial on prevention of postpartum haemorrhage with sublingual misoprostol or oxytocin. 2014;25:10-2. X-2, X-4.
2861 Bilger A, Pottecher J, Greget M, et al. Extensive pulmonary embolism after severe postpartum haemorrhage: management with an inferior vena cava filter. Int J Obstet Anesth. 2014. Jun. 19. X-3. [pmid: 25223642].
2862 Blix E, Kumle M, Kjaergaard H, et al. Transfer to hospital in planned home births: a systematic review. BMC Pregnancy Childbirth. 2014;14:179. X-1. [pmid: 24886482].
2863 Blomberg M, Birch Tyrberg R, Kjolhede P. Impact of maternal age on obstetric and neonatal outcome with emphasis on primiparous adolescents and older women: a Swedish Medical Birth Register Study. BMJ Open. 2014;4(11):e005840. X-4. [pmid: 25387756].
2864 Brane E, Olsson A, Andolf E. A randomized controlled trial on early induction compared to expectant management of nulliparous women with prolonged latent phases. Acta Obstet Gynecol Scand. 2014. Jun. 27. X-4. [pmid: 24974855].
2865 Briley A, Seed P, Tydeman G, et al. Reporting errors, incidence and risk factors for postpartum haemorrhage and progression to severe PPH: a prospective observational study. BJOG. 2014. Feb. 12. X-4, X-5. [pmid: 24517180].
2866 Briley A, Seed PT, Tydeman G, et al. Reporting errors, incidence and risk factors for postpartum haemorrhage and progression to severe PPH: a prospective observational study. BJOG. Jun. 2014;121(7):876-88. X-4. [pmid: 24517180].
2867 Briley A, Tydeman G, Seed P, et al. PLD.20 Postpartum haemorrhage: immediate management and failures of adherence to guidelines and prompt actions. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A111-2. X-4, X-5.
2868 Brown A, Jordan S. Active Management of the Third Stage of Labor May Reduce Breastfeeding Duration Due to Pain and Physical Complications. Breastfeed Med. 2014. Oct. 27. X-4. [pmid: 25347567].
2869 Buchmann E, Mnyani C, Frank K, et al. Declining maternal mortality in the face of persistently high HIV prevalence in a middle-income country. Bjog. 2014. Sep. 12. X-2, X-4. [pmid: 25213804].
2870 Budden A, Chen LJ, Henry A. High-dose versus low-dose oxytocin infusion regimens for induction of labour at term. Cochrane Database Syst Rev. 2014;10. CD009701. X-1, X-4. [pmid: 25300173].
2871 Butchon R, Liabsuetrakul T, McNeil E, et al. Birth rates and pregnancy complications in adolescent pregnant women giving birth in the hospitals of Thailand. J Med Assoc Thai. Aug. 2014;97(8):785-90. X-2, X-4. [pmid: 25345252].
2872 Butler K, Ramphul M, Dunney C, et al. A prospective cohort study of the morbidity associated with operative vaginal deliveries performed by day and at night. BMJ Open. 2014;4(10):e006291. X-4. [pmid: 25354825].
2873 Butwick AJ, Carvalho B, El-Sayed YY. Risk factors for obstetric morbidity in patients with uterine atony undergoing Caesarean deliverydagger. Br J Anaesth. 2014. Jun. 6. X-4. [pmid: 24907281].
2874 Butwick AJ, Carvalho B, El-Sayed YY. Risk factors for obstetric morbidity in patients with uterine atony undergoing caesarean delivery. Br J Anaesth. Oct. 2014;113(4):661-8. X-4. [pmid: 24907281].
2875 Cao L, Lu Z, Zheng Y. Sheehan's syndrome with cardiac arrest: A case report and review of the literature. Neuro Endocrinol Lett. Sep. 9. 2014;35(5):352-4. X-1, X-3, X-4. [pmid: 25275267].
2876 Capozzola DD, Terrence J, Gratiano A. Excessive bleeding after childbirth leads to mjournal's death, over $15 million in damages. Healthcare Risk Management. 2014:1-3. X-1, X-4, X-5.
2877 Caserta D, Bordi G, Stegagno M, et al. Maternal and perinatal outcomes in spontaneous versus assisted conception twin pregnancies. Eur J Obstet Gynecol Reprod Biol. Mar. 2014;174:64-9. X-4. [pmid: 24405729].
2878 Casini A, Blondon M, Lebreton A, et al. Natural history of patients with congenital dysfibrinogenemia. Blood. 2014. Oct. 15. X-4. [pmid: 25320241].
2879 Cavazos-Rehg PA, Krauss MJ, Spitznagel EL, et al. Maternal Age and Risk of Labor and Delivery Complications. Matern Child Health J. 2014. Nov. 4. X-4. [pmid: 25366100].
2880 Cekmez Y, Ozkaya E, Ocal FD, et al. Experience with different techniques for the management of postpartum hemorrhage due to uterine atony: compression sutures, artery ligation and Bakri balloon. Ir J Med Sci. 2014. May. 15. X-2. [pmid: 24831795].
2881 Chai H, Fang Q, Huang X, et al. Prenatal management and outcomes in mirror syndrome associated with twin-twin transfusion syndrome. Prenat Diagn. 2014. Jul. 9. X-4. [pmid: 25043377].
2882 Chai VY, To WW. Uterine compression sutures for management of severe postpartum haemorrhage: five-year audit. Hong Kong Med J. Apr. 2014;20(2):113-20. X-5. [pmid: 24141858].
2883 Chaudhuri P, Majumdar A. Sublingual misoprostol as an adjunct to oxytocin during cesarean delivery in women at risk of postpartum hemorrhage. Int J Gynaecol Obstet. 2014. Sep. 16. X-2, X-4. [pmid: 25277789].
2884 Chaudhuri P, Mandi S, Mazumdar A. Rectally administrated misoprostol as an alternative to intravenous oxytocin infusion for preventing post-partum hemorrhage after cesarean delivery. J Obstet Gynaecol Res. Sep. 2014;40:2023-30. X-4. [pmid: 25181622].
2885 Childress KM, Holloran-Schwartz MB, Wuebker H, et al. The third stage of labor: a study of outcomes in the second trimester of pregnancy. J Reprod Med. Jul-Aug. 2014;59:348-54. X-3, X-4. [pmid: 25098024].
2886 Chongsomchai C, Lumbiganon P, Laopaiboon M. Prophylactic antibiotics for manual removal of retained placenta in vaginal birth. Cochrane Database Syst Rev. 2014;10. CD004904. X-1, X-3, X-4. [pmid: 25327508].
2887 Chuma C, Kihunrwa A, Matovelo D, et al. Labour management and Obstetric outcomes among pregnant women admitted in latent phase compared to active phase of labour at Bugando Medical Centre in Tanzania. BMC Pregnancy Childbirth. 2014;14:68. X-2, X-4. [pmid: 24521301].
2888 Clark SL, Christmas JT, Frye DR, et al. Maternal mortality in the United States: predictability and the impact of protocols on fatal postcesarean pulmonary embolism and hypertension-related intracranial hemorrhage. Am J Obstet Gynecol. Jul. 2014;211:32 e1-9. X-3, X-4. [pmid: 24631705].
2889 Coeytaux F, Hessini L, Ejano N, et al. Facilitating women's access to misoprostol through community-based advocacy in Kenya and Tanzania. Int J Gynaecol Obstet. 2014. Jan. 2. X-2, X-3, X-4. [pmid: 24447412].
2890 Collins D. Failure to perform vulvar biopsy delays diagnosis of cancer. Contemporary OB/GYN. 2014;59(4):20-73. Language: English. Entry Date: 20140822. Publication Type: journal article. X-1, X-3, X-4.
2891 Collins PW, Lilley G, Bruynseels D, et al. Fibrin-based clot formation an early and rapidly available biomarker for progression of postpartum hemorrhage: a prospective cohort study. Blood. 2014. Jul. 14. X-4, X-5. [pmid: 25024304].
2892 Collins PW, Lilley G, Bruynseels D, et al. Fibrin-based clot formation as an early and rapid biomarker for progression of postpartum hemorrhage: a prospective study. Blood. Sep. 11. 2014;124(11):1727-36. X-4, X-5. [pmid: 25024304].
2893 Cook A, Hirth RL. A Breastfeeding Education Initiative for Registered Nurses Outside the Obstetric Unit: Emergency Department and Medical-Surgical Nurses Learn to be Baby-Friendly. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S33-S. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. X-1, X-3, X-4.
2894 Cortet M, Maucort-Boulch D, Deneux-Tharaux C, et al. Severity of post-partum hemorrhage after vaginal delivery is not predictable from clinical variables available at the time post-partum hemorrhage is diagnosed. J Obstet Gynaecol Res. 2014. Oct. 10. X-4, X-5. [pmid: 25303234].
2895 Crowe SD, Faulkner B. Lean management system application in creation of a postpartum hemorrhage prevention bundle on postpartum units. Obstet Gynecol. May. Suppl 1. 2014;123:45s. X-1, X-4, X-5.
2896 Curry R, Gelson E, Swan L, et al. Marfan syndrome and pregnancy: maternal and neonatal outcomes. BJOG. 2014. Jan. 13. X-4. [pmid: 24418012].
2897 Curry RA, Gelson E, Swan L, et al. Marfan syndrome and pregnancy: maternal and neonatal outcomes. BJOG. Apr. 2014;121(5):610-7. X-4. [pmid: 24418012].
2898 Curtis M, El Ayadi A, Mkumba G, et al. Association between severe obstetric hemorrhage and HIV status. Int J Gynaecol Obstet. Apr. 2014;125(1):79-80. X-2, X-4, X-5. [pmid: 24507890].
2899 Cussen L, O'Donoghue K. PMM.15 Maternal Admissions to Intensive Care. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A128. X-4.
2900 Dajani NK, Magann EF. Complications of shoulder dystocia. Semin Perinatol. Jun. 2014;38:201-4. X-1. [pmid: 24863025].
2901 D'Alton ME, Main EK, Menard MK, et al. The National Partnership for Maternal Safety. Obstet Gynecol. May. 2014;123:973-7. X-1. [pmid: 24785848].
2902 Daniels K, Clark A, Lipman S, et al. Multidisciplinary simulation drills improve efficiency of emergency medication retrieval. Obstet Gynecol. May. Suppl 1. 2014;123:143s-4s. X-4, X-5.
2903 D'Antonio F, Bhide A. Ultrasound in placental disorders. Best Pract Res Clin Obstet Gynaecol. 2014. Jan. 14. X-1. [pmid: 24461676].
2904 de Boer HJ, Cotingting C. Medicinal plants for women's healthcare in southeast Asia: a meta-analysis of their traditional use, chemical constituents, and pharmacology. J Ethnopharmacol. Feb. 3. 2014;151(2):747-67. X-1, X-2, X-4, X-5. [pmid: 24269772].
2905 de Lange NM, van Rheenen-Flach LE, Lance MD, et al. Peri-partum reference ranges for ROTEM(R) thromboelastometry. Br J Anaesth. 2014. Jan. 31. X-4. [pmid: 24486836].
2906 del-Rio-Vellosillo M, Garcia-Medina JJ, Fernandez-Rodriguez LE, et al. Subdural hygroma accompanied by parenchymal and subarachnoid haemorrhage after epidural analgesia in an obstetric patient. Acta Anaesthesiol Scand. Aug. 2014;58:897-902. X-1, X-3, X-4. [pmid: 24628098].
2907 Dhananjaya BS, Charishma S. Comparative study of efficacy and safety of intramuscular oxytocin with intramuscular methylergometrine in the active management of third stage of labour. 2014;5:734-9. X-4, X-5.
2908 Dhariwal SK, Khan KS, Allard S, et al. Does current evidence support the use of intraoperative cell salvage in reducing the need for blood transfusion in caesarean section?. Curr Opin Obstet Gynecol. Dec. 2014;26(6):425-30. X-1. [pmid: 25259949].
2909 Diaz-Castro J, Florido J, Kajarabille N, et al. The timing of cord clamping and oxidative stress in term newborns. Pediatrics. Aug. 2014;134(2):257-64. X-3, X-4. [pmid: 25022744].
2910 Dinyain A, Olutoyin Omoniyi-Esan G, Olaofe OO, et al. Autopsy-certified maternal mortality at Ile-Ife, Nigeria. New Zealand. Dove Medical Press. 2014. http://www.dovepress.com/getfile.php?fileID=18592http://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed12&NEWS=N&AN=2014014088. Accessed on (Dinyain) Department of Anatomic Pathology, Niger Delta University Teaching Hospital, Okolobiri, Bayelsa State, Nigeria 6.
2911 Dinyain A, Omoniyi-Esan GO, Olaofe OO, et al. Autopsy-certified maternal mortality at Ile-Ife, Nigeria. Int J Womens Health. 2014;6:41-6. X-2, X-4. [pmid: 24403844].
2912 Drassinower D, Timofeev J, Huang CC, et al. Racial disparities in outcomes of twin pregnancies: elective cesarean or trial of labor?. Am J Obstet Gynecol. Aug. 2014;211(2):160 e1-7. X-4. [pmid: 24534184].
2913 Ducloy-Bouthors AS, Susen S, Wong CA, et al. Medical advances in the treatment of postpartum hemorrhage. Anesth Analg. Nov. 2014;119(5):1140-7. X-1. [pmid: 25329026].
2914 Dudeja RK, Belavadi P. Trans-oesophageal Doppler-guided fluid management in massive obstetric haemorrhage. Int J Obstet Anesth. 2014. Jun. 2. X-1, X-4, X-5. [pmid: 25066818].
2915 Dutta TK, Verma SP. Rational Use of Recombinant Factor VIIa in Clinical Practice. Indian J Hematol Blood Transfus. Jun. 2014;30(2):85-90. X-1. [pmid: 24839361].
2916 Eboumbou Moukoko CE, Ngo Sack F, Essangui Same EG, et al. HIV, HBV, HCV and T. pallidum infections among blood donors and Transfusion-related complications among recipients at the Laquintinie hospital in Douala, Cameroon. BMC Hematol. Feb. 12. 2014;14:5. X-2, X-4. [pmid: 24517107].
2917 Economou M, Banov L, Ljung R. Perinatal aspects of haemophilia. Eur J Haematol Suppl. Aug. 2014;76:21-5. X-1. [pmid: 24957104].
2918 Ejembi C, Shittu O, Moran M, et al. Community-level distribution of misoprostol to prevent postpartum hemorrhage at home births in northern Nigeria. Afr J Reprod Health. Jun. 2014;18:166-75. X-2, X-4. [pmid: 25022154].
2919 El Ayadi A, Gibbons L, Bergel E, et al. Per-protocol effect of earlier non-pneumatic anti-shock garment application for obstetric hemorrhage. Int J Gynaecol Obstet. Jul. 2014;126:95-6. X-2. [pmid: 24721615].
2920 El-Agwany AS. Postpartum uterine caesarean incision necrosis and pelvic abscess managed by hysterectomy: A complication of puerperal endomyometritis. 2014;8:53-5. X-3.
2921 Eleje GU, lgwegbe AO, Okonkwo JE, et al. Elderly primigravidae versus young primigravidae: a review of pregnancy outcome in a low resource setting. Niger J Med. Jul-Sep. 2014;23:220-9. X-2, X-4. [pmid: 25185379].
2922 Elie N. Maternal and neonatal complications of macrosomia. Trop Doct. 2014. Jun. 23. X-2, X-4. [pmid: 24958734].
2923 Elmir R. Finding Meaning in Life Following Emergency Postpartum Hysterectomy: What Doesn't Kill Us Makes Us Stronger. Journal of Midwifery & Women's Health. 2014;59(5):510-5. Language: English. Entry Date: 20141017. Revision Date: 20141107. Publication Type: journal article. X-1, X-4.
2924 El-Refaeey A-A, Gibreel A, Fawzy M. Novel modification of B- Lynch uterine compression sutures for management of atonic postpartum hemorrhage: VV uterine compression sutures. Journal of Obstetrics & Gynaecology Research. 2014;40(2):387-91. Language: English. Entry Date: 20140307. Revision Date: 20140919. Publication Type: journal article. X-2, X-5. [pmid: 24118407].
2925 Elstein D, Hughes D, Goker-Alpan O, et al. Outcome of pregnancies in women receiving velaglucerase alfa for Gaucher disease. J Obstet Gynaecol Res. Apr. 2014;40:968-75. X-3, X-4. [pmid: 24612151].
2926 Era S, Matsunaga S, Matsumura H, et al. Usefulness of shock indicators for determining the need for blood transfusion after massive obstetric hemorrhage. J Obstet Gynaecol Res. 2014. Aug. 28. X-4, X-5. [pmid: 25164603].
2927 Esakoff TF, Cheng YW, Snowden JM, et al. Velamentous cord insertion: is it associated with adverse perinatal outcomes?. J Matern Fetal Neonatal Med. May. 2014;27:1-4. X-4. [pmid: 24758363].
2928 Evans CL, Johnson P, Bazant E, et al. Competency-based training “Helping Mjournals Survive: Bleeding after Birth” for providers from central and remote facilities in three countries. Int J Gynaecol Obstet. Sep. 2014;126(3):286-90. X-2, X-4, X-5. [pmid: 24834851].
2929 Evans K. Active management of the third stage of labor with and without controlled cord traction: a systematic review and meta-analysis of randomized controlled trials. MIDIRS Midwifery Digest. 2014;24(3):338-40. Language: English. Entry Date: 20141003. Revision Date: 20141003. Publication Type: journal article. X-1.
2930 Ferrazzi E, Visconti E, Paganelli A, et al. The Outcome Of Midwife-Led Labor In Low Risk Women Within An Obstetric Referral Unit. J Matern Fetal Neonatal Med. Sep. 2014;5:1-24. X-4. [pmid: 25190281].
2931 Ferrazzi E, Visconti E, Paganelli AM, et al. The outcome of midwife-led labor in low-risk women within an obstetric referral unit. J Matern Fetal Neonatal Med. Sep. 2014;19:1-7. X-4. [pmid: 25190281].
2932 Fickley SK. Achieving Realism With Low-Tech Simulation. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S27-S. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. Journal Subset: Core Nursing. X-1, X-3, X-4.
2933 Fidan U, Keskin U, Ulubay M, et al. The effect of the use of oxytocin on blood loss during different postpartum periods. J Perinat Med. 2014. May. 15. X-4. [pmid: 24897394].
2934 Filho ALS, Noviello MB, Bessa-Junior RC, et al. Damage control for managing life-threatening postpartum hemorrhage. 2014;30:230-3. X-3.
2935 Fong A, Wu E, Pan D, et al. Temporal trends and morbidities of vacuum, forceps, and combined use of both. J Matern Fetal Neonatal Med. 2014. Apr. 9. X-4. [pmid: 24635372].
2936 Fuglsang J. Later reproductive health after B-Lynch sutures: a follow-up study after 10 years' clinical use of the B-Lynch suture. Fertil Steril. Apr. 2014;101:1194-9. X-5. [pmid: 24534289].
2937 Fuks AM, Khanna P, Yusaf T, et al. Use of prophylactic misoprostol in reduction of blood loss at vaginal delivery. Obstet Gynecol. May. Suppl 1. 2014;123:144s-5s. X-4.
2938 Furuta M, Sandall J, Bick D. Women's perceptions and experiences of severe maternal morbidity--a synthesis of qualitative studies using a meta-ethnographic approach. Midwifery. Feb. 2014;30(2):158-69. X-1. [pmid: 24144992].
2939 Gabrielloni MC, Armellini CJ, Barbieri M, et al. Analysis of hemorrhage at vaginal delivery by erythrocyte and hematocrit indices. Acta Paulista de Enfermagem. 2014;27(2):186-93. Language: English. Entry Date: 20140613. Revision Date: 20140725. Publication Type: journal article. X-4.
2940 Gandhi H. Prevention of postpartum hemorrhage: exogenous oxytocin in the third stage of labor. Ky Nurse. Jul-Sep. 2014;62:4. X-1, X-4, X-5. [pmid: 25087331].
2941 Garcia-Elorrio E, Aleman A, Cafferata ML, et al. A multifaceted intervention to increase prophylactic oxytocin use during the third stage of labor and to reduce routine episiotomies in Nicaragua. Int J Gynaecol Obstet. Oct. 2014;127(1):31-4. X-2, X-4. [pmid: 25005056].
2942 Georgiou C. Menses, fertility and pregnancy following the use of balloon tamponade technology in the management of postpartum haemorrhage. Aust N Z J Obstet Gynaecol. 2014. Feb. 8. X-4, X-5. [pmid: 24506416].
2943 Gerli S, Favilli A, Mosca S, et al. The factors associated with the failure of transcatheter pelvic arterial embolization for intractable postpartum hemorrhage. J Perinat Med. Nov. 1. 2014;42(6):777-8. X-1. [pmid: 24728849].
2944 Ghag K, Bahl R. PLD.18 Recurrence rate of Manual Removal of Placenta and associated Postpartum Haemorrhage. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A111. X-4.
2945 Gheshlagh RG, Baghi V, Aminpour E. The relationship between sleep apnea and hypertension in women with gestational diabetes. 2014;16:18-24. X-2, X-3, X-4.
2946 Girard T, Mortl M, Schlembach D. New approaches to obstetric hemorrhage: the postpartum hemorrhage consensus algorithm. Curr Opin Anaesthesiol. Jun. 2014;27:267-74. X-1. [pmid: 24739248].
2947 Girija BS, Raju VS. A study of combined surgery in control of Atonic PPH during caesarian section and its outcome. 2014;5:174-7. X-2.
2948 Godara SM, Kute VB, Trivedi HL, et al. Clinical profile and outcome of acute kidney injury related to pregnancy in developing countries: A single-center study from India. Saudi J Kidney Dis Transpl. Jul-Aug. 2014;25:906-11. X-1, X-2, X-4. [pmid: 24969215].
2949 Goh A, Nicoll A. PFM.52 Review of maternal and perinatal outcomes for women with polyhydramnios. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A99. X-4.
2950 Gollop ND, Childs CA, Coupe B, et al. Body weight, body image and primary postpartum haemorrhage: a review of the literature. J Obstet Gynaecol. Jul. 2014;34(5):373-82. X-1, X-3, X-4. [pmid: 24694033].
2951 Gordon C, Jimenez-Fernandez S, Daniels L, et al. Pregnancy in women with a history of Kawasaki disease: management and outcomes. BJOG. 2014. Mar. 6. X-1, X-3, X-4. [pmid: 24597833].
2952 Gordon CT, Jimenez-Fernandez S, Daniels LB, et al. Pregnancy in women with a history of Kawasaki disease: management and outcomes. BJOG. Oct. 2014;121(11):1431-8. X-3, X-4. [pmid: 24597833].
2953 Green L, Knight M, Seeney F, et al. 6.4 Transfusion management and haemostatic changes in major obstetric haemorrhage in the UK. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A8. X-4, X-5.
2954 Grillo-Ardila CF, Ruiz-Parra AI, Gaitan HG, et al. Prostaglandins for management of retained placenta. Cochrane Database Syst Rev. 2014;5. Cd010312. X-1, X-2, X-3, X-4. [pmid: 24833288].
2955 Grillo-Ardila CF, Ruiz-Parra AI, Gaitán HG, et al. Prostaglandins for management of retained placenta. Cochrane Database of Systematic Reviews. 2014;(5). Language: English. Entry Date: 20140704. Publication Type: journal article. X-1.
2956 Grobman WA, Bailit JL, Rice MM, et al. Frequency of and factors associated with severe maternal morbidity. Obstet Gynecol. Apr. 2014;123:804-10. X-4. [pmid: 24785608].
2957 Grobman WA, Bailit JL, Rice MM, et al. Can differences in obstetric outcomes be explained by differences in the care provided? The MFMU Network APEX study. Am J Obstet Gynecol. Aug. 2014;211:147 e1-e16. X-4. [pmid: 24631441].
2958 Gronvall M, Tikkanen M, Metsatahti M, et al. Pelvic arterial embolization in severe obstetric hemorrhage. Acta Obstet Gynecol Scand. Jul. 2014;93:716-9. X-5. [pmid: 24617830].
2959 Guillaume A, Sananes N, Poirier V, et al. Benefits of cord blood collection in the prevention of post-partum hemorrhage: a cohort study. J Matern Fetal Neonatal Med. Nov. 2014;14:1-4. X-4. [pmid: 25341670].
2960 Haas T, Gorlinger K, Grassetto A, et al. Thromboelastometry for Guiding Bleeding Management of the Critically Ill Patient: A Systematic Review of the Literature. Minerva Anestesiol. 2014. Feb. 11. X-1. [pmid: 24518216].
2961 Hafeez M, Badar N, Akram N. Placenta previa; prevalence, risk factor and outcome. 2014;8:208-11. X-2, X-4.
2962 Hartwig SM, Schwartz PD. Striving to Attain High Reliability in Perinatal Services: Perinatal Safety SMART Lean Process Improvement. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S46-7. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. X-1.
2963 Heesen M, Bohmer J, Klohr S, et al. Prophylactic tranexamic acid in parturients at low risk for post-partum haemorrhage: systematic review and meta-analysis. Acta Anaesthesiol Scand. Oct. 2014;58:1075-85. X-1, X-4. [pmid: 25069636].
2964 Heesen M, Bohmer J, Klohr S, et al. Prophylactic tranexamic acid in parturients at low risk for post-partum haemorrhage: systematic review and meta-analysis. Acta Anaesthesiol Scand. Oct. 2014;58(9):1075-85. X-1. [pmid: 25069636].
2965 Henderson JT, Whitlock EP, O'Conner E, et al. 2014. Apr. A Systematic Evidence Review for the U.S. Preventive Services Task Force. X-1, X-4. [pmid: 24783270].
2966 Henry D, Harris I, Bosco V, et al. Maternal arrhythmia and perinatal outcomes: a pregnancy and cardiac disease treatment program. Obstet Gynecol. May. Suppl 1. 2014;123:56s. X-4.
2967 Hensch S, Al Shakhshir O, Rajesh S, et al. PMM.03 The management of patients with primary immune thrombocytopenia during pregnancy in Leeds. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A124-5. X-4, X-5.
2968 Herrick TM, Harner-Jay CM, Levisay AM, et al. Prioritizing investments in innovations to protect women from the leading causes of maternal death. BMC Pregnancy Childbirth. 2014;14:10. X-1, X-3, X-4. [pmid: 24405972].
2969 Hewarathna UI, Karunaratne SP, Tennakoon R, et al. Septic embolization of left and right coronary arteries resulting in sudden death: A rare complication of infective endocarditis. 2014;10:22-4. X-3, X-4.
2970 Hobeika E, Abi Chaker S, Harb H, et al. Maternal mortality ratio in Lebanon in 2008: a hospital-based reproductive age mortality study (RAMOS). J Med Liban. Jan-Mar. 2014;62:1-6. X-2, X-4. [pmid: 24684119].
2971 Hodgins S. Oxytocin: taking the heat. Glob Health Sci Pract. Aug. 2014;2(3):259-60. X-1. [pmid: 25276584].
2972 Hongsakul K, Songjamrat A, Rookkapan S. Transarterial embolization for the treatment of massive bleeding in gynecologic and obstetric emergencies: a single center experience. Emerg Radiol. Aug. 2014;21:333-9. X-2, X-5. [pmid: 24522752].
2973 Huber G, Schutz H, Seelbach-Gobel B. Induction of labor in twin pregnancies with oral misoprostol versus vaginal dinoprostone - is it effective and safe?. J Matern Fetal Neonatal Med. Jul. 2014;28:1-4. X-4. [pmid: 24641184].
2974 Hussain SS, Shafqat T. Frequency of postpartum haemorrhage in induced versus spontaneous labour. Pakistan. Lahore Medical And Dental College. (Tulspura, North Canal Bank, Lahore, Pakistan. E-mail: prof_abdulmajeed@hotmail.com). 2014. http://pjmhsonline.com/JulySep2014/frequency_of_postpartum_haemorrh.htmhttp://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed12&NEWS=N&AN=2014808891. Accessed on (Hussain, Shafqat) Department of Obstetrics and Gynaecology, Lady Reading Hospital, Peshawar, Pakistan 8.
2975 Ibrahim M, Ziegler C, Klam SL, et al. Incidence, indications, and predictors of adverse outcomes of postpartum hysterectomies: 20-year experience in a tertiary care centre. J Obstet Gynaecol Can. Jan. 2014;36:14-20. X-4, X-5. [pmid: 24444283].
2976 Iqbal M, Akhtar Z, Jamal T. Outcome of pregnancies associated with FIBROIDS. 2014;22:3-5. X-2, X-4.
2977 Iqbal M, Majid A, Muhammad Z, et al. Perinatal mortality and its related obstetrics risk factors. 2014;22:76-9. X-2, X-4.
2978 Irshad F, Ikram MA. Role of misoprostol for the management of post partum hemorrhage due to uterine atony. 2014;39:182-5. X-2.
2979 Islam AK, Hasnat MA, Doza F, et al. Sheehan's syndrome with reversible dilated cardiomyopathy: A case report and brief overview. J Saudi Heart Assoc. Apr. 2014;26:117-20. X-1, X-3, X-4. [pmid: 24719543].
2980 Iyoke CA, Ugwu GO, Ezugwu FO, et al. Risks associated with subsequent pregnancy after one caesarean section: A prospective cohort study in a Nigerian obstetric population. Niger J Clin Pract. Jul-Aug. 2014;17:442-8. X-2, X-4. [pmid: 24909467].
2981 James AH, Konkle BA, Kouides P, et al. Postpartum von Willebrand factor levels in women with and without von Willebrand disease and implications for prophylaxis. Haemophilia. 2014. Oct. 21. X-4. [pmid: 25333737].
2982 Jani M, Hor K, Brolly A, et al. PLD.38 Major Obstetric Haemorrhage in a Tertiary Maternity Unit in Scotland: Review of Practice and Future Implications. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A117. X-2, X-4.
2983 Janion-Sadowska A, Sadowski M, Zandecki L, et al. Pregnancy after myocardial infarction and coronary artery bypass grafting - Is it safe?. 2014;10:29-31. X-1, X-4.
2984 Jayanna K, Mony P, B MR, et al. Assessment of facility readiness and provider preparedness for dealing with postpartum haemorrhage and pre-eclampsia/eclampsia in public and private health facilities of northern Karnataka, India: a cross-sectional study. BMC Pregnancy Childbirth. 2014;14:304. X-2, X-3, X-4. [pmid: 25189169].
2985 Jayanna K, Mony P, Bm R, et al. Assessment of facility readiness and provider preparedness for dealing with postpartum haemorrhage and pre-eclampsia/eclampsia in public and private health facilities of northern Karnataka, India: a cross-sectional study. BMC Pregnancy Childbirth. 2014;14(1):304. X-2. [pmid: 25189169].
2986 Ji W, Wang W, Sun S, et al. A clinical analysis of uterine artery embolisation in the treatment of placenta praevia or placenta praevia state. J Obstet Gynaecol. Jun. 2014;9:1-3. X-2, X-5. [pmid: 24911560].
2987 Jin R, Guo Y, Chen Y. Risk factors associated with emergency peripartum hysterectomy. Chin Med J (Engl). 2014;127(5):900-4. X-2, X-4. [pmid: 24571885].
2988 Kabiri D, Hants Y, Shanwetter N, et al. Outcomes of subsequent pregnancies after conservative treatment for placenta accreta. Int J Gynaecol Obstet. 2014. Jul. 6. X-4, X-5. [pmid: 25069629].
2989 Kacmar RM, Mhyre JM, Scavone BM, et al. The use of postpartum hemorrhage protocols in United States academic obstetric anesthesia units. Anesth Analg. Oct. 2014;119(4):906-10. X-3, X-4. [pmid: 25238236].
2990 Kanwal M, Iftikhar PM, Khalil S. Role of B lynch sutures for control of postpartum hemorrhage. 2014;39:190-2. X-2.
2991 Kaoiean S. Successful use of the B-Lynch uterine compression suture in treating intractable postpartum hemorrhage after cesarean delivery in Rajavithi Hospital. J Med Assoc Thai. Nov. 2014;96:1408-15. X-2. [pmid: 24428089].
2992 Kavak SB, Kavak EC, Demirel I, et al. Double-balloon tamponade in the management of postpartum hemorrhage: a case series. Ther Clin Risk Manag. 2014;10:615-20. X-2, X-5. [pmid: 25120367].
2993 Kaya B, Tuten A, Daglar K, et al. Balloon tamponade for the management of postpartum uterine hemorrhage. J Perinat Med. 2014. Mar. 25. X-2, X-5. [pmid: 24663227].
2994 Kerr NL, Hauswald M, Tamrakar SR, et al. An inexpensive device to treat postpartum hemorrhage: a preliminary proof of concept study of health provider opinion and training in Nepal. BMC Pregnancy Childbirth. 2014;14:81. X-2. [pmid: 24564622].
2995 Kevane B, McKenna P, Walsh K, et al. Haemorrhagic and thrombotic complications in pregnant women with acquired and congenital cardiac disease. J Perinat Med. 2014. Jul. 11. X-4. [pmid: 25014516].
2996 Khaskheli M, Baloch S, Farooq S. Hepatitis C in haemorrhagic obstetrical emergencies. J Coll Physicians Surg Pak. Mar. 2014;24:178-81. X-2, X-4. [pmid: 24613113].
2997 Kim JW, Kim YH, Kim CH, et al. Uterine artery pseudoaneurysm manifesting as delayed postpartum hemorrhage after precipitous delivery: three case reports. Gynecol Obstet Invest. 2014;78:136-40. X-1, X-4. [pmid: 25012906].
2998 Kim MS, Uhm YK, Kim JY, et al. Obstetric outcomes after uterine myomectomy: Laparoscopic versus laparotomic approach. Obstet Gynecol Sci. Nov. 2014;56:375-81. X-4. [pmid: 24396816].
2999 Kirke AB, Evans SF, Walters B. Gestational diabetes in a rural, regional centre in south Western Australia: predictors of risk. Rural Remote Health. Jul-Sep. 2014;14:2667. X-4. [pmid: 25171091].
3000 Kirke AB, Evans SF, Walters BN. Gestational diabetes in a rural, regional centre in south Western Australia: predictors of risk. Rural Remote Health. Jul-Sep. 2014;14(3):2667. X-4. [pmid: 25171091].
3001 Kissell N, Mudd JO, Gelow JM, et al. Cardiogenic Shock Due to Non-Ischemic Cardiomyopathy Induced by Severe Anterior Hypopituitarism. Endocr Pract. Nov. 2014;4:1-17. X-1, X-3, X-4. [pmid: 25370320].
3002 Kok N, Ruiter L, Hof M, et al. Risk of maternal and neonatal complications in subsequent pregnancy after planned caesarean section in a first birth, compared with emergency caesarean section: a nationwide comparative cohort study. BJOG. Jan. 2014;121:216-23. X-4, X-5. [pmid: 24373595].
3003 Kondoh E, Konishi M, Kariya Y, et al. Ultrasonographic visualization of bleeding sites can help control postpartum hemorrhage using intrauterine balloon tamponade. J Clin Ultrasound. 2014. Sep. 2. X-4, X-5. [pmid: 25181258].
3004 Koo FH, Chao ST, Wang PH, et al. Delayed postpartum hemorrhage secondary to idiopathic rupture of right uterine artery: a case report and literature review. Taiwan J Obstet Gynecol. Jun. 2014;53(2):276-8. X-1, X-2, X-3. [pmid: 25017287].
3005 Kortekaas JC, Bruinsma A, Keulen JK, et al. Effects of induction of labour versus expectant management in women with impending post-term pregnancies: the 41 week - 42 week dilemma. BMC Pregnancy Childbirth. 2014;14:350. X-1, X-3, X-4. [pmid: 25338555].
3006 Kozinszky Z, Sand S, Klow NE, et al. Shortened cervix in the subsequent pregnancy after embolization for postpartum cervical hemorrhage. Case Rep Obstet Gynecol. 2014;2014:607835. X-1, X-3. [pmid: 24800090].
3007 Krishnan D, Ongso Y, Leknys M. Misoprostol for post-partum haemorrhage in the Australian bush. Aust Fam Physician. Aug. 2014;43:569-70. X-1, X-4, X-5. [pmid: 25114997].
3008 Kulkarni VG, Kulkarni JV. Sreekantha, et al. The study of comparision of sublinguinal versus vaginal 25 micro gram of misoprostol in the induction of labour at term. International Journal of Pharma and Bio Sciences. January/March. 2014;5:P1-P13. X-4.
3009 Kumar N, Singh P, Kumar J, et al. Recurrent hypoglycaemia: a delayed presentation of Sheehan syndrome. BMJ Case Rep. 2014;2014. X-1, X-3, X-4. [pmid: 24842349].
3010 Lagrew DC Jr. Postpartum hemorrhage: state and national response. Curr Opin Hematol. 2014. Sep. 17. X-1. [pmid: 25232833].
3011 Laway BA, Mir SA, Zargar AH. Recovery of prolactin function following spontaneous pregnancy in a woman with Sheehan's syndrome. Indian J Endocrinol Metab. Dec. 2014;17:S696-9. X-1, X-3. [pmid: 24910842].
3012 Laws PJ, Xu F, Welsh A, et al. Maternal morbidity of women receiving birth center care in new South wales: a matched-pair analysis using linked health data. Birth. Sep. 2014;41:268-75. X-4. [pmid: 24935768].
3013 Lawton B, Macdonald EJ, Brown SA, et al. Preventability of severe acute maternal morbidity. Am J Obstet Gynecol. 2014. Feb. 1. X-2, X-4, X-5. [pmid: 24508582].
3014 Le Bas A, Chandraharan E, Addei A, et al. Use of the “obstetric shock index” as an adjunct in identifying significant blood loss in patients with massive postpartum hemorrhage. Int J Gynaecol Obstet. Mar. 2014;124:253-5. X-4, X-5. [pmid: 24373705].
3015 Lee HH, Kim TH. Uterus preservation as an alternative to an emergency hysterectomy for postpartum hemorrhage. Arch Gynecol Obstet. May. 2014;289(5):929-30. X-1, X-4, X-5. [pmid: 24643803].
3016 Lee JW, Song IA, Ryu J, et al. Anesthetic management of a parturient with placenta previa totalis undergoing preventive uterine artery embolization before placental expulsion during cesarean delivery: a case report. Korean J Anesthesiol. Oct. 2014;67(4):279-82. X-3. [pmid: 25368788].
3017 Lee YJ, Ju DH, Yi SW, et al. Successful management of maternal factor VII deficiency in a cesarean section. Obstet Gynecol Sci. Jul. 2014;57(4):314-7. X-3, X-4. [pmid: 25105106].
3018 Leung EY, Daniels JP. A report from #BlueJC: fertility implications following the surgical management of postpartum haemorrhage. Bjog. May. 2014;121(6):776. X-1, X-4, X-5. [pmid: 24738905].
3019 Li GT, Li XF, Liu YJ, et al. Symbol “&” suture to control atonic postpartum hemorrhage with placenta previa accreta. Arch Gynecol Obstet. 2014. Oct. 7. X-2. [pmid: 25288270].
3020 Lindqvist PG, Nasiell J, Gustafsson LL, et al. Selective serotonin reuptake inhibitor use during pregnancy increases the risk of postpartum hemorrhage and anemia: a hospital-based cohort study. J Thromb Haemost. 2014. Oct. 16. X-4. [pmid: 25322909].
3021 Litorp H, Kidanto HL, Roost M, et al. Maternal near-miss and death and their association with caesarean section complications: a cross-sectional study at a university hospital and a regional hospital in Tanzania. BMC Pregnancy Childbirth. 2014;14:244. X-2, X-4. [pmid: 25056517].
3022 Liu S, Mathur M, Tagore S. Complications and pregnancy outcome following uterine compression suture for postpartum haemorrhage: A single centre experience. J Obstet Gynaecol. 2014. Mar. 28. X-2, X-5. [pmid: 24678816].
3023 Liu X, Zhang W. Effect of maternal age on pregnancy: a retrospective cohort study. Chin Med J (Engl). 2014;127:2241-6. X-2, X-4. [pmid: 24931235].
3024 Loustau V, Debouverie O, Canoui-Poitrine F, et al. Effect of pregnancy on the course of immune thrombocytopenia: a retrospective study of 118 pregnancies in 82 women. Br J Haematol. Sep. 2014;166(6):929-35. X-4. [pmid: 24957165].
3025 Luangruangrong P, Sudjai D, Wiriyasirivaj B, et al. Pregnancy outcomes of placenta previa with or without antepartum hemorrhage. J Med Assoc Thai. Nov. 2014;96:1401-7. X-4. [pmid: 24428088].
3026 Ma LK, Cao DY, Yang JX, et al. Pregnancy outcome and obstetric management after vaginal radical trachelectomy. Eur Rev Med Pharmacol Sci. Oct. 2014;18(20):3019-24. X-1, X-2, X-4. [pmid: 25392098].
3027 Mahmud G, Javaid K, Tasnim N, et al. Where does ergometrine stand in prevention of postpartum haemorrhage in caesarean section?. J Pak Med Assoc. Aug. 2014;64(8):911-4. X-2, X-4. [pmid: 25252517].
3028 Manning E, Lutomski J, O'Connor L, et al. PPO.02 Severe maternal morbidity in Ireland. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A151. X-4, X-5.
3029 Marchetti D, Vellone V, Dhimitri O, et al. Post-partum hemorrhage and malpractice claims: what can we learn from the findings of placental examination and endometrial curettage? A retrospective analysis of surgical pathology reports. Med Sci Law. 2014. Feb. 4. X-3, X-4. [pmid: 24496591].
3030 Marinez-Gaytan V, Torcida-Gonzalez ME, Felix-Zamudio LL, et al. Gelatin-thrombin matrix hemostatic for management of severe obstetric hemorrhage. Obstet Gynecol. May. Suppl 1. 2014;123:67s-8s. X-2, X-5.
3031 Marshall NE, Vanderhoeven J, Eden KB, et al. Impact of simulation and team training on postpartum hemorrhage management in non-academic centers. J Matern Fetal Neonatal Med. May. 2014;29:1-5. X-4. [pmid: 24824110].
3032 Masood MQ, Ali SA. Long Standing Undiagnosed Sheehan's Syndrome Presenting as Polymorphic & Monomorphic Ventricular Tachycardia: A Case Series of Two Patients. Endocr Pract. Aug. 2014;6:1-13. X-4. [pmid: 25100393].
3033 Matsuzaki S, Ueda Y, Egawa-Takata T, et al. Placenta percreta with a vaginal fistula after successful management by uterine transverse fundal incision and subsequent cesarean hysterectomy. Obstet Gynecol Sci. Sep. 2014;57(5):397-400. X-3, X-4. [pmid: 25264531].
3034 McCloskey C, Rada C, Bailey E, et al. The inwardly rectifying K+ channel KIR7.1 controls uterine excitability throughout pregnancy. EMBO Mol Med. 2014;6:1161-74. X-3, X-4. [pmid: 25056913].
3035 McClure EM, Jones B, Rouse DJ, et al. Tranexamic Acid to Reduce Postpartum Hemorrhage: A MANDATE Systematic Review and Analyses of Impact on Maternal Mortality. Am J Perinatol. 2014. Oct. 7. X-1, X-2, X-3. [pmid: 25289705].
3036 McGiveron A, Foster S, Pearce J, et al. Limiting antenatal weight gain improves maternal health outcomes in severely obese pregnant women: findings of a pragmatic evaluation of a midwife-led intervention. J Hum Nutr Diet. 2014. May. 9. X-4. [pmid: 24809211].
3037 McKenna DS, Rudinsky K, Sonek J. Effects of a new patient safety-driven oxytocin dosing protocol on postpartum hemorrhage. J Pregnancy. 2014;2014:157625. X-4. [pmid: 24868465].
3038 McLean MT, Marchant G, Rannisi C, et al. Is there a time or circumstance in the 3rd stage of labor when it is appropriate to massage the fundus?. Midwifery Today Int Midwife. Summer. 2014;(110):66-7. [pmid: 25112078]. X-4.
3039 Meena M, Chopra S, Jain V, et al. Prevalence of antithyroid peroxidase antibodies in pregnant women and the effect on the outcome of pregnancy. Obstet Gynecol. May. Suppl 1. 2014;123:157S. X-4.
3040 Mehrabadi A, Liu S, Bartholomew S, et al. Temporal trends in postpartum hemorrhage and severe postpartum hemorrhage in Canada from 2003 to 2010. J Obstet Gynaecol Can. Jan. 2014;36:21-33. X-4. [pmid: 24444284].
3041 Miller JA, Junes A. A Progressive Format for Annual Interdisciplinary Education Featuring High-Risk Obstetric Simulation. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S9-s10. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. Journal Subset: Core Nursing. X-1.
3042 Mirkuzie AH, Sisay MM, Reta AT, et al. Current evidence on basic emergency obstetric and newborn care services in Addis Ababa, Ethiopia; a cross sectional study. BMC Pregnancy Childbirth. 2014;14:354. X-2, X-3, X-4. [pmid: 25300789].
3043 Mone F, Adams B, Manderson JG, et al. The East Timorese: A High-Risk Ethnic Minority in UK Obstetrics: A Cohort Study. J Matern Fetal Neonatal Med. Sep. 2014;5:1-16. X-2, X-4. [pmid: 25189758].
3044 Monteith CW, Berger GS, Zerden ML. Pregnancy success after hysteroscopic sterilization reversal. Obstet Gynecol. Dec. 2014;124(6):1183-9. X-3, X-4. [pmid: 25415170].
3045 Montgomery AL, Fadel S, Kumar R, et al. The effect of health-facility admission and skilled birth attendant coverage on maternal survival in India: a case-control analysis. PLoS One. 2014;9:e95696. X-2. [pmid: 24887586].
3046 Mullany LC, Newton S, Afari-Asiedu S, et al. Cumulative effects of heat exposure and storage conditions of Oxytocin-in-Uniject in rural Ghana: implications for scale up. Glob Health Sci Pract. Aug. 2014;2(3):285-94. X-2, X-3, X-4. [pmid: 25276588].
3047 Naranjo-Gutierrez LA, Oliva-Cristerna J, Ramirez-Montiel ML, et al. Pelvic packing with vaginal traction for the management of intractable hemorrhage. Int J Gynaecol Obstet. 2014. May. 29. X-2. [pmid: 24950907].
3048 Nascimento B, Goodnough LT, Levy JH. Cryoprecipitate therapy. Br J Anaesth. 2014. Jun. 27. X-1. [pmid: 24972790].
3049 Nathan H, Hezelgrave N, Briley A, et al. PLD.37 Shock Index (SI) as a Predictor of Adverse Outcome in Women with Post Partum Haemorrhage (PPH). Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A116. X-1, X-4, X-5.
3050 Nebout S, Merbai N, Faitot V, et al. Management of major postpartum hemorrhage. Presse Med. 2014. Dec. 26. X-1. [pmid: 24373716].
3051 Nelissen E, Ersdal H, Ostergaard D, et al. Helping mjournals survive bleeding after birth: an evaluation of simulation-based training in a low-resource setting. Acta Obstet Gynecol Scand. Mar. 2014;93(3):287-95. X-2, X-3, X-4. [pmid: 24344822].
3052 Nichols SD, Furey PM, Palmer JP, et al. Lights, Camera, Hemorrhage: Using Creative Learning Strategies to Engage Nurses. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S23-S. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. X-1.
3053 Nilsson C, Sorensen BL, Sorensen JL. Comparing hands-on and video training for postpartum hemorrhage management. Acta Obstet Gynecol Scand. May. 2014;93:517-20. X-2, X-3, X-4. [pmid: 24754607].
3054 Niola R, Cavaliere C, Marcello L, et al. Role of interventional radiology in treating obstetric haemorrhages. Radiol Med. 2014. Jan. 10. X-4, X-5. [pmid: 24408047].
3055 Nkwabong E. Maternal and neonatal complications of macrosomia. Trop Doct. Oct. 2014;44(4):201-4. X-2, X-3, X-4. [pmid: 24958734].
3056 Nor Azlin MI, Maisarah AS, Rahana AR, et al. Pregnancy outcomes with a primary complaint of perception of reduced fetal movements. J Obstet Gynaecol. Jul. 2014;2:1-3. X-3, X-4. [pmid: 24987985].
3057 Nutter E, Meyer S, Shaw-Battista J, et al. Waterbirth: an integrative analysis of peer-reviewed literature. J Midwifery Womens Health. May-Jun. 2014;59:286-319. X-1, X-4. [pmid: 24850284].
3058 Obert E. Herbal management of postpartum hemorrhage. Midwifery Today Int Midwife. Winter. 2014:48-9. [pmid: 24511843]. X-1, X-5.
3059 Oguz Orhan E, Dilbaz B, Aksakal SE, et al. Prospective randomized trial of oxytocin administration for active management of the third stage of labor. Int J Gynaecol Obstet. 2014. Jul. 17. X-2, X-4. [pmid: 25108586].
3060 Olmedo B, Miranda E, Cordon O, et al. Improving maternal health and safety through adherence to postpartum hemorrhage protocol in Latin America. Int J Gynaecol Obstet. May. 2014;125:162-5. X-2, X-4, X-5. [pmid: 24548891].
3061 Orbach-Zinger S, Aviram A, Ioscovich A, et al. Anesthetic considerations in pregnant women at advanced maternal age. J Matern Fetal Neonatal Med. 2014. Apr. 9. X-3, X-4. [pmid: 24593845].
3062 Ortiz SR, Perez RA, Hernandez RS, et al. WITHDRAWN: Carbetocin versus oxytocin for prevention of postpartum hemorrhage: a randomised controlled trial. Eur J Obstet Gynecol Reprod Biol. 2014. Sep. 16. X-1. [pmid: 25266913].
3063 Ostri C, Zibrandtsen N, Larsen M, et al. Profound bilateral visual loss after hysterectomy indicated for severe postpartum haemorrhage. BMJ Case Rep. 2014;2014. X-1, X-4, X-5. [pmid: 24395872].
3064 Ovesen P, Jensen D, Damm P, et al. Maternal and neonatal outcomes in pregnancies complicated by gestational diabetes. A nation-wide study. J Matern Fetal Neonatal Med. Sep. 2014;17:1-14. X-4. [pmid: 25228278].
3065 Owolabi H, Ameh CA, Bar-Zeev S, et al. Establishing cause of maternal death in Malawi via facility-based review and application of the ICD-MM classification. BJOG. Sep. Suppl 4. 2014;121:95-101. X-2, X-4. [pmid: 25236641].
3066 Oyerinde K, Baravilala W. Alternative Measures of Spatial Distribution and Availability of Health Facilities for the Delivery of Emergency Obstetric Services in Island Communities. Maternal & Child Health Journal. 2014;18(10):2245-9. Language: English. Entry Date: 20141114. Revision Date: 20141121. Publication Type: journal article. X-1, X-2. [pmid: 24234278].
3067 Parveen T, Iqbal T, Kausar T. Grand multiparity and its obstetrical complications at Bahawal Victoria Hospital Bahawalpur. Pakistan. Lahore Medical And Dental College. (Tulspura, North Canal Bank, Lahore, Pakistan. E-mail: prof_abdulmajeed@hotmail.com). 2014. http://pjmhsonline.com/JulySep2014/grand_multiparity_and_its_obstet.htmhttp://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed12&NEWS=N&AN=2014808809. Accessed on (Parveen, Iqbal, Kausar) Department of Obstetrics and Gynaecology, Bahawal Victoria Hospital, 489/1 B-VI, Karbala Road, Model Town-B, Bahawalpur, Pakistan 8.
3068 Patterson JA, Roberts CL, Bowen JR, et al. Blood transfusion during pregnancy, birth, and the postnatal period. Obstet Gynecol. Jan. 2014;123:126-33. X-4. [pmid: 24463672].
3069 Patterson JA, Roberts CL, Taylor LK, et al. Reporting postpartum haemorrhage with transfusion: a comparison of NSW birth and hospital data. N S W Public Health Bull. Jun. 2014;24:153-8. X-4. [pmid: 24939224].
3070 Paxton JL, Presneill J, Aitken L. Characteristics of obstetric patients referred to intensive care in an Australian tertiary hospital. Aust N Z J Obstet Gynaecol. 2014. Apr. 17. X-4. [pmid: 24738907].
3071 Pembe AB, Paulo C, D'Mello B S, et al. Maternal mortality at muhimbili national hospital in Dar-es-Salaam, Tanzania in the year 2011. BMC Pregnancy Childbirth. 2014;14:320. X-2, X-4. [pmid: 25217326].
3072 Penn N, Oteng-Ntim E, Doyle P. PPO.39 Advanced maternal age and adverse pregnancy outcomes in a South London population. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A163. X-4.
3073 Perez-Munuzuri A, Couce-Pico ML, Bana-Souto A, et al. Preclinical screening for retinopathy of prematurity risk using IGF1 levels at 3 weeks post-partum. PLoS One. 2014;9:e88781. X-3, X-4. [pmid: 24523937].
3074 Peterson W, Deonandan R, Arole S, et al. Village health worker training for complications of labor and delivery in rural Maharashtra, India. Int J Gen Med. 2014;7:295-301. X-2, X-3, X-4. [pmid: 24971034].
3075 Phadungkiatwattana P, Rujivejpongsathron J, Tunsatit T, et al. Analyzing pregnancy outcomes in women of extremely advanced maternal age (> or = 45 years). J Med Assoc Thai. Jan. 2014;97:1-6. X-2, X-4. [pmid: 24701722].
3076 Phuong U L, Emam M, Jouvin-Castro M. REMARKABLE FUNCTIONAL RECOVERY IN A YOUNG GRAVID FEMALE PATIENT SUFFERING FROM A LARGE INTRACRANIAL HEMORRHAGE DUE TO HELLP SYNDROME AND ECLAMPSIA AND CONCOMITANT DEVELOPMENT OF PEMPHIGOID GESTATIONIS. American Journal of Physical Medicine & Rehabilitation. 2014:a91-a. Language: English. Entry Date: 20140704. Revision Date: 20140815. Publication Type: journal article. X-3, X-4.
3077 Prankerd RJ, Nguyen TH, Ibrahim JP, et al. Pulmonary delivery of an ultra-fine oxytocin dry powder formulation: potential for treatment of postpartum haemorrhage in developing countries. PLoS One. 2014;8:e82965. X-3, X-4. [pmid: 24376618].
3078 Prata N, Bell S, Holston M, et al. Is attendant at delivery associated with the use of interventions to prevent postpartum hemorrhage at home births? The case of Bangladesh. BMC Pregnancy Childbirth. 2014;14:24. X-2, X-4. [pmid: 24428902].
3079 Prata N, Bell S, Quaiyum MA. Modeling maternal mortality in Bangladesh: the role of misoprostol in postpartum hemorrhage prevention. BMC Pregnancy Childbirth. 2014;14:78. X-2, X-3, X-4. [pmid: 24555848].
3080 Pulcinella R, Giannone L, Candelori E, et al. Post-traumatic amenorrhea: the role of diagnostic and operative hysteroscopy in the prevention, diagnosis, differential diagnosis and treatment. Minerva Ginecol. Feb. 2014;66:69-76. X-4, X-5. [pmid: 24569405].
3081 Puri S, Mohan B, Verma S, et al. Internal iliac-artery balloon occlusion in a patient with placenta increta during cesarean hysterectomy. 2014;30:121-3. X-2, X-3.
3082 Quintana KA, Hartwig SM. Leveraging Technology to Help Manage Oxytocin/Tachysystole, Hyperbilirubinemia, and Postpartum Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S44-S. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. X-1.
3083 R P, Bhatara U, Iyengar RS. A Rare Case of A2+ve Blood Group in an Obstetric Emergency. J Clin Diagn Res. Feb. 2014;8:181-2. X-1, X-4. [pmid: 24701528].
3084 Raagab AE, Mesbah YH, Brakat RI, et al. Re-laparotomy after cesarean section: risk, indications and management options. Med Arch. 2014;68:41-3. X-2. [pmid: 24783911].
3085 Raba G. Unilateral recanalisation of hypogastric artery after ligation for postpartum haemorrhage treatment. Wideochir Inne Tech Malo Inwazyjne. Jun. 2014;9(2):289-91. X-3. [pmid: 25097703].
3086 Rahim N, Rehana T, Ara A. Risk factors associated with major placenta previa. 2014;22:63-5. X-2, X-4.
3087 Rajaei M, Karimi S, Shahboodaghi Z, et al. Safety and efficacy of misoprostol versus oxytocin for the prevention of postpartum hemorrhage. J Pregnancy. 2014;2014:713879. X-4. [pmid: 24734184].
3088 Rasheed SM, Amin MM, Abd Ellah AH, et al. Reproductive performance after conservative surgical treatment of postpartum hemorrhage. Int J Gynaecol Obstet. Mar. 2014;124:248-52. X-2, X-4, X-5. [pmid: 24380610].
3089 Reynolds A, Briggs L. We Can Save Her: Managing Postpartum Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S8-S. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. X-1.
3090 Ridout A, Nanda S, Robinson S, et al. PMM.33 Twin pregnancy in maternal sickle cell disease: identifying learning points for successful outcome. Arch Dis Child Fetal Neonatal Ed. Jun. 2014;99(Suppl 1):A133-4. X-4.
3091 Rivera-Rosado M, Flores-Perez IS, Mendez K, et al. Risk factors for hysterectomy in abnormal placentation at the University District Hospital. Bol Asoc Med P R. 2014;106:27-9. X-4. [pmid: 24791360].
3092 Robinson N, Kapungu C, Carnahan L, et al. Recommendations for scale-up of community-based misoprostol distribution programs. Int J Gynaecol Obstet. Jun. 2014;125(3):285-8. X-1, X-4. [pmid: 24680582].
3093 Rohilla M, Singh P, Kaur J, et al. Uterine necrosis and lumbosacral-plexopathy following pelvic vessel embolization for postpartum haemorrhage: report of two cases and review of literature. Arch Gynecol Obstet. Oct. 2014;290(4):819-23. X-2, X-5. [pmid: 24947325].
3094 Rossi AC, Prefumo F. Pregnancy outcomes of induced labor in women with previous cesarean section: a systematic review and meta-analysis. Arch Gynecol Obstet. 2014. Sep. 2. X-1, X-4. [pmid: 25178187].
3095 Roth CK, Parfitt SE, Hering SL, et al. Developing protocols for obstetric emergencies. Nurs Womens Health. Oct. 2014;18(5):378-90. X-1, X-4, X-5. [pmid: 25316538].
3096 Ruhl C, Cockey CD. “Don't Rush Me . . . Go the Full 40” as a Public Health Strategy to Promote Spontaneous Labor and Normal Birth. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S24-5. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. Journal Subset: Core Nursing. X-1.
3097 Saad A, Costantine MM. Obstetric hemorrhage: recent advances. Clin Obstet Gynecol. Dec. 2014;57(4):791-6. X-1. [pmid: 25264700].
3098 Sahhaf F, Abbasalizadeh S, Ghojazadeh M, et al. Comparison effect of intravenous tranexamic acid and misoprostol for postpartum haemorrhage. Niger Med J. Jul. 2014;55:348-53. X-2. [pmid: 25114373].
3099 Sahin S, Guzin K, Eroglu M, et al. Emergency peripartum hysterectomy: our 12-year experience. Arch Gynecol Obstet. May. 2014;289(5):953-8. X-4. [pmid: 24213098].
3100 Salman MC, Calis P, Deren O. Uterine Rupture with Massive Late Postpartum Hemorrhage due to Placenta Percreta Left Partially In Situ. Case Rep Obstet Gynecol. 2014;2013:906351. X-1. [pmid: 24392232].
3101 Satish S, Deckers EA, Philip BM, et al. Novel system for rapid assessment of blood loss in elective surgery and cesarean delivery. Obstet Gynecol. May. Suppl 1. 2014;123:170s. X-3, X-4.
3102 Schack SM, Elyas A, Brew G, et al. Experiencing challenges when implementing active management of third stage of labor (AMTSL): a qualitative study with midwives in Accra, Ghana. BMC Pregnancy Childbirth. 2014;14:193. X-2, X-3, X-4. [pmid: 24903893].
3103 Schafer DJ, Larkin J. A Case of Abnormal Placental Invasion. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S100-S. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. X-1, X-3.
3104 Schorn MN, Phillippi JC. Volume replacement following severe postpartum hemorrhage. J Midwifery Womens Health. May-Jun. 2014;59:336-43. X-1. [pmid: 24751109].
3105 Shabbir S, Zahid M, Qazi A. To detect outcome of pregnancy in advanced maternal age among Pakistani women. Pakistan. Lahore Medical And Dental College. (Tulspura, North Canal Bank, Lahore, Pakistan. E-mail: prof_abdulmajeed@hotmail.com). 2014. http://pjmhsonline.com/JulySep2014/to_detect_outcome_of_pregnancy_i.htmhttp://ovidsp.ovid.com/ovidweb.cgi?T=JS&PAGE=reference&D=emed12&NEWS=N&AN=2014808810. Accessed on (Shabbir) KVSS Site Hospital, Karachi, Pakistan 8.
3106 Sharma M, Kaur P, Kaur K, et al. A comparative study of oxytocin/misoprostol/methylergometrine for active management of the third stage of labor. 2014;64:175-9. X-2, X-4.
3107 Sharma NS, Wille KM, Bellot SC, et al. Modern Use of Extracorporeal Life Support in Pregnancy and Post-Partum. ASAIO J. 2014. Sep. 22. X-1, X-4, X-5. [pmid: 25248040].
3108 Sheldon WR, Blum J, Vogel JP, et al. Postpartum haemorrhage management, risks, and maternal outcomes: findings from the World Health Organization Multicountry Survey on Maternal and Newborn Health. Bjog. Mar. Suppl 1. 2014;121:5-13. X-2, X-4, X-5. [pmid: 24641530].
3109 Shen LH, Fang YY, Zheng YB, et al. Retrospective Review on Obstetric Cases of Critically Ill and Dead Patients in Dongguan. Cell Biochem Biophys. 2014. Oct. 15. X-2, X-4. [pmid: 25315638].
3110 Shibata Y, Shigemi D, Ito M, et al. Association between fibrinogen levels and severity of postpartum hemorrhage in singleton vaginal deliveries at a Japanese perinatal center. J Nippon Med Sch. 2014;81:94-6. X-5. [pmid: 24805095].
3111 Shoushtari SZ, Makvandi S, Mirzaeian S, et al. The effect of placental cord drainage on the length of the third stage of labor in primiparous women. 2014;16:20-5. X-2, X-4.
3112 Shripad H, Rai L, Mohan A. Comparison of Blood Loss in Induced vs. Spontaneous Vaginal Delivery Using Specialized Blood Collection Bag. J Clin Diagn Res. Apr. 2014;8:OC01-4. X-2, X-4. [pmid: 24959480].
3113 Sibley LM, Spangler SA, Barry D, et al. A regional comparison of distribution strategies and women's awareness, receipt, and use of misoprostol to prevent postpartum hemorrhage in rural Amhara and Oromiya regions of Ethiopia. J Midwifery Womens Health. Jan. Suppl 1. 2014;59:S73-82. X-2, X-4. [pmid: 24588919].
3114 Silfelera DB, Celikb M, Gokcec C, et al. Sheehan's syndrome with recurrent hyponatremia and anemia: A case report. 2014;19:33-7. X-3, X-4.
3115 Singh N, Varshney P, Tripathi R, et al. Safety and efficacy of low molecular weight heparin therapy during pregnancy: three year experience at a tertiary care center. J Obstet Gynaecol India. Dec. 2014;63:373-7. X-2, X-4. [pmid: 24431682].
3116 Singhal S, Singh A, Raghunandan C, et al. Uterine artery embolization: exploring new dimensions in obstetric emergencies. Oman Med J. May. 2014;29(3):217-9. X-1, X-2, X-5. [pmid: 24936273].
3117 Smit M, Dijkman A, Rijnders M, et al. Haemorrhage after home birth: audit of decision making and referral. Pract Midwife. Nov. 2014;16:12-5. X-4. [pmid: 24371910].
3118 Smith JM, Baawo SD, Subah M, et al. Advance distribution of misoprostol for prevention of postpartum hemorrhage (PPH) at home births in two districts of Liberia. BMC Pregnancy Childbirth. 2014;14:189. X-2, X-4. [pmid: 24894566].
3119 Smith JM, Currie S, Cannon T, et al. Are national policies and programs for prevention and management of postpartum hemorrhage and preeclampsia adequate? A key informant survey in 37 countries. Glob Health Sci Pract. Aug. 2014;2(3):275-84. X-3, X-4. [pmid: 25276587].
3120 Smith JM, Dimiti A, Dwivedi V, et al. Advance distribution of misoprostol for the prevention of postpartum hemorrhage in South Sudan. Int J Gynaecol Obstet. 2014. Jul. 9. X-2, X-4. [pmid: 25051905].
3121 Snowden JM, Cheng YW, Emeis CL, et al. The impact of hospital obstetric volume on maternal outcomes in term, non-low-birthweight pregnancies. Am J Obstet Gynecol. 2014. Sep. 28. X-4. [pmid: 25263732].
3122 Spangler SA, Gobezayehu AG, Getachew T, et al. Interpretation of national policy regarding community-based use of misoprostol for postpartum hemorrhage prevention in Ethiopia: a tale of two regions. J Midwifery Womens Health. Jan. Suppl 1. 2014;59:S83-90. X-2, X-3, X-4. [pmid: 24588920].
3123 Sparic R, Lazovic B, Sulovic N, et al. Our experience with intraoperative cell salvage during cesarean delivery in women with uterine myomas--four case reports. Med Pregl. Mar-Apr. 2014;67:111-7. X-3, X-4. [pmid: 24961054].
3124 Spatling L, Schneider H. “Sumo-Kompression” stoppt postpartale Blutungen. Z Geburtshilfe Neonatol. Oct. 2014;218(5):223-5. X-5. [pmid: 25353217].
3125 Spitzer RF, Steele SJ, Caloia D, et al. One-year evaluation of the impact of an emergency obstetric and neonatal care training program in Western Kenya. Int J Gynaecol Obstet. 2014. Jul. 17. X-2. [pmid: 25124101].
3126 Stanton C, Nand D, Koski A, et al. Accessibility and potency of uterotonic drugs purchased by simulated clients in four districts in India. BMC Pregnancy Childbirth. Nov. 13. 2014;14(1):386. X-2, X-3, X-4. [pmid: 25392131].
3127 Stanton CK, Deepak NN, Mallapur AA, et al. Direct observation of uterotonic drug use at public health facility-based deliveries in four districts in India. Int J Gynaecol Obstet. Oct. 2014;127(1):25-30. X-2, X-4. [pmid: 25026891].
3128 Steel A, Adams J, Sibbritt D, et al. Relationship between complementary and alternative medicine use and incidence of adverse birth outcomes: An examination of a nationally representative sample of 1835 Australian women. Midwifery. 2014. Mar. 29. X-3, X-4. [pmid: 24742636].
3129 Steele HB, Goetzl L. The practical utility of routine postpartum hemoglobin assessment. Am J Obstet Gynecol. Jun. 2014;210:576 e1-6. X-4, X-5. [pmid: 24583198].
3130 Stephens-Hennessy BM. The Modern Woman's Labor Curve. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S53-S. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. X-1.
3131 Straface G, Bassi E, De Santis M, et al. Tranfusion risk: is “two-step” vaginal delivery a risk for postpartum hemorrhage?. J Matern Fetal Neonatal Med. Nov. 2014;14:1-4. X-4. [pmid: 25354292].
3132 Subramaniam A, Abramovici AR, Szychowski JM, et al. Higher-Dose Oxytocin to Prevent Obstetric Hemorrhage at Vaginal Delivery-Does Duration of Infusion Matter?. Am J Perinatol. 2014. Feb. 28. X-4, X-5. [pmid: 24585000].
3133 Subramaniam A, Abramovici AR, Szychowski JM, et al. Higher-Dose Oxytocin to Prevent Obstetric Hemorrhage at Vaginal Delivery—Does Duration of Infusion Matter?. American Journal of Perinatology. 2014;31(11):1003-7. Language: English. Entry Date: 20141024. Publication Type: journal article. X-2, X-4, X-5. [pmid: 24585000].
3134 Suidan RS, Rondon KC, Apuzzio JJ, et al. Labor Outcomes of Obese Patients Undergoing Induction of Labor with Misoprostol compared to Dinoprostone. Am J Perinatol. 2014. Jun. 10. X-4. [pmid: 24915563].
3135 Suzuki S. Selective uterine fundal pressure maneuver during the second stage of the first twin delivery at near term. J Matern Fetal Neonatal Med. May. 2014;29:1-3. X-3, X-4. [pmid: 24809223].
3136 Szkodziak P, Wozniak S, Czuczwar P, et al. Usefulness of three dimensional transvaginal ultrasonography and hysterosalpingography in diagnosing uterine anomalies. Ginekol Pol. May. 2014;85:354-9. X-3, X-4. [pmid: 25011216].
3137 Tadakawa M, Sugawara J, Saito M, et al. Fertility and pregnancy outcomes following B-Lynch sutures for post-partum hemorrhage. J Obstet Gynaecol Res. 2014. Oct. 20. X-5. [pmid: 25331482].
3138 Takebayashi A, Kimura F, Yamanaka A, et al. Exaggerated placental site, consisting of implantation site intermediate trophoblasts, causes massive postpartum uterine hemorrhage: case report and literature review. Tohoku J Exp Med. 2014;234:77-82. X-1, X-3, X-4. [pmid: 25186195].
3139 Takeda A, Koike W, Imoto S, et al. Three-dimensional computerized tomographic angiography for diagnosis and management of intractable postpartum hemorrhage. Eur J Obstet Gynecol Reprod Biol. May. 2014;176:104-11. X-5. [pmid: 24630300].
3140 Takeda A, Koike W, Imoto S, et al. Conservative management of uterine artery pseudoaneurysm after laparoscopic-assisted myomectomy and subsequent pregnancy outcome: case series and review of the literature. Eur J Obstet Gynecol Reprod Biol. Sep. 19. 2014;182C:146-53. X-3, X-4. [pmid: 25277771].
3141 Tam T, Calero D. Does morbid obesity in preeclampsia affect maternal and neonatal outcomes?. Obstet Gynecol. May. Suppl 1. 2014;123:81S-2S. X-4.
3142 Tandon P, Juneja SK, Mohan B. Angiographic embolization for intractable obstetrical bleeding. Int J Appl Basic Med Res. Jan. 2014;4:25-7. X-2, X-5. [pmid: 24600574].
3143 Tatler S, Nicoll T. PPO.57 Antenatal Mental Health Status and Pregnancy Outcomes. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A168-9. X-3, X-4.
3144 Teixidor Vinas M, Chandraharan E, Moneta MV, et al. The role of interventional radiology in reducing haemorrhage and hysterectomy following caesarean section for morbidly adherent placenta. Clin Radiol. Aug. 2014;69:e345-51. X-4, X-5. [pmid: 24880757].
3145 Tran NT, Portela A, de Bernis L, et al. Developing capacities of community health workers in sexual and reproductive, maternal, newborn, child, and adolescent health: a mapping and review of training resources. PLoS One. 2014;9:e94948. X-3, X-4. [pmid: 24736623].
3146 Ur Din N, Bukhari AS, Kawan S, et al. The B-lynch surgical technique for the control of massive postoperative haemorrhage an alternative to hysterectomy, clinical trial at Nishtar hospital, Multan. 2014;8:247-8. X-2.
3147 Urner F, Zimmermann R, Krafft A. Manual removal of the placenta after vaginal delivery: an unsolved problem in obstetrics. 2014;2014:274651. X-1. [pmid: 24812585].
3148 Urushiyama D, Yoshizato T, Kora S, et al. Predictive factors related to the efficacy of pelvic arterial embolization for postpartum hemorrhage: a retrospective analysis of 21 cases. Taiwan J Obstet Gynecol. Sep. 2014;53(3):366-71. X-2, X-5. [pmid: 25286792].
3149 Uygur D, Altun Ensari T, Ozgu-Erdinc AS, et al. Successful use of BT-Cath balloon tamponade in the management of postpartum haemorrhage due to placenta previa. Eur J Obstet Gynecol Reprod Biol. Aug. 13. 2014;181c:223-8. X-2. [pmid: 25171267].
3150 Uygur D, Altun Ensari T, Ozgu-Erdinc AS, et al. Successful use of BT-Cath((R)) balloon tamponade in the management of postpartum haemorrhage due to placenta previa. Eur J Obstet Gynecol Reprod Biol. Oct. 2014;181:223-8. X-2, X-4, X-5. [pmid: 25171267].
3151 Vagge DS, Mamatha KR, Shivamurthy G, et al. A comparative study to assess the efficacy and tolerability of per rectal misoprostol and intravenous oxytocin in prevention of primary postpartum haemorrhage in a tertiary care hospital. 2014;6:1134-40. X-2, X-4.
3152 van der Bom JG. Rotem in postpartum hemorrhage. Blood. Sep. 11. 2014;124(11):1700-1. X-1, X-2, X-4, X-5. [pmid: 25214195].
3153 Vaswani PR, Sabharwal S. Trends in the occurrence of antenatal and perinatal complications with increasing parity. J Obstet Gynaecol India. Aug. 2014;63:260-7. X-2, X-4. [pmid: 24431653].
3154 Waechter M. Tricks of the Trade: Placenta Stories by Marlene. Midwifery Today. 2014;(109):6. [pmid: 2012518406]. Language: English. Entry Date: 20140404. Revision Date: 20140530. Publication Type: journal article. X-1.
3155 Wakimoto S, Hidaka N, Fukushima K, et al. Spontaneous post-partum rupture of an ovarian artery aneurysm: A case report of successful embolization and a review of the published work. J Obstet Gynaecol Res. 2014. Sep. 26. X-3, X-4. [pmid: 25256954].
3156 Walker D, Cohen S, Fritz J, et al. PRONTO: Obstetric and Neonatal Emergency Simulation in Mexico Improves Patient Outcomes, Provider Knowledge, Team Coordination, and Identifies Latent Systems Errors. Journal of Midwifery & Women's Health. 2014;59(5):548-9. Language: English. Entry Date: 20141017. Revision Date: 20141024. Publication Type: journal article. X-2, X-3, X-4.
3157 Walker R. Improved Birth Outcomes With Implementation of a Perinatal Quality and Patient Safety Collaborative. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S53-4. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. X-1.
3158 Wang W, Wang AM, Huang XQ, et al. Thromboelastography in women with pathological pregnancies: a preliminary study. Chin Med Sci J. Mar. 2014;29:63-4. X-2, X-3, X-4. [pmid: 24698684].
3159 Watson H, Sihra N, Sau A. PA.21 Does all placenta praevia need hospital admission?. Arch Dis Child Fetal Neonatal Ed. Jun. Suppl 1. 2014;99:A23-4. X-4.
3160 Weedin EA, Mercer LT, Wood DL, et al. Ovarian artery aneurysm after postpartum hemorrhage: a case report. Obstet Gynecol. May. Suppl 1. 2014;123:177s. X-1, X-3, X-4.
3161 Weeks A. The prevention and treatment of postpartum haemorrhage: what do we know, and where do we go to next?. Bjog. 2014. Oct. 7. X-1. [pmid: 25289730].
3162 Wenckus DJ, Gao W, Kominiarek MA, et al. The effects of labor and delivery on maternal and neonatal outcomes in term twins: a retrospective cohort study. BJOG. Aug. 2014;121:1137-44. X-4. [pmid: 24575851].
3163 Williams C. Should midwives measure blood loss in the fourth stage of labour?. British Journal of Midwifery. 2014;22(6):394-8. Language: English. Entry Date: 20140620. Revision Date: 20140704. Publication Type: journal article. Journal Subset: Double Blind Peer Reviewed. X-1.
3164 Wohlmuth C, Tulzer G, Arzt W, et al. Maternal Aspects Of Fetal Cardiac Intervention. Ultrasound Obstet Gynecol. 2014. Jun. 11. X-3, X-4. [pmid: 24920505].
3165 Wolfe H, Timofeev J, Tefera E, et al. Risk of Cesarean in Obese Nulliparous Women with Unfavorable Cervix: Elective Induction vs. Expectant Management at Term. Am J Obstet Gynecol. 2014. Jan. 30. X-4. [pmid: 24486226].
3166 Wright CE, Chauhan SP, Abuhamad AZ. Bakri Balloon in the Management of Postpartum Hemorrhage: A Review. Am J Perinatol. 2014. Apr. 4. X-1. [pmid: 24705972].
3167 Wu E, Jolley JA, Hargrove BA, et al. Implementation of an obstetric hemorrhage risk assessment: validation and evaluation of its impact on pretransfusion testing and hemorrhage outcomes. J Matern Fetal Neonatal Med. 2014. Apr. 9. X-4. [pmid: 24670202].
3168 Xiang L, Wei Z, Wu J, et al. Clinical significance of first-trimester intrauterine haematomas detected in pregnancies achieved by IVF-embryo transfer. Reprod Biomed Online. 2014. Jul. 11. X-3, X-4. [pmid: 25164168].
3169 Yamada T, Akaishi R, Oda Y, et al. Antenatal fibrinogen concentrations and postpartum haemorrhage. Int J Obstet Anesth. 2014. Jun. 25. X-4. [pmid: 25262279].
3170 Yan JY, Zhou ZM, Xu X, et al. Risk factors and surgical interventions associated with primary postpartum haemorrhage unresponsive to first-line therapies. J Obstet Gynaecol. Jun. 2014;9:1-5. X-2, X-5. [pmid: 24911676].
3171 Yang G, Lee D, Lee S, et al. Successful live births after surgical treatments for symptomatic cesarean scar pregnancies: report of 3 cases. Gynecol Obstet Invest. 2014;78(3):208-12. X-3, X-4. [pmid: 25228400].
3172 Yang S, Zhang B, Zhao J, et al. Progress on the maternal mortality ratio reduction in Wuhan, China in 2001-2012. PLoS One. 2014;9(2):e89510. X-2, X-4. [pmid: 24586836].
3173 Yang Z, Mei-Ying L, Shan-Mi W, et al. Pregnancy and myelodysplastic syndrome: an analysis of the clinical characteristics, maternal and fetal outcomes. J Matern Fetal Neonatal Med. Nov. 2014;14:1-5. X-4. [pmid: 25354291].
3174 Yates Huwe V, Mullen M. Can We Save Her Without Giving Blood? An Incredible Case of Obstetric Hemorrhage. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing. 2014;43(Supp 1):S99-s100. Language: English. Entry Date: 20140926. Revision Date: 20141107. Publication Type: journal article. X-3.
3175 Ye C, Ruan Y, Zou L, et al. The 2011 survey on hypertensive disorders of pregnancy (HDP) in China: prevalence, risk factors, complications, pregnancy and perinatal outcomes. PLoS One. 2014;9(6):e100180. X-2, X-3, X-4. [pmid: 24937406].
3176 Yee LM, Liu LY, Grobman WA. The relationship between obstetricians' cognitive and affective traits and their patients' delivery outcomes. Am J Obstet Gynecol. 2014. Jun. 4. X-3, X-4. [pmid: 24907699].
3177 Yogender P, Balram Singh T, Rangaswamy R, et al. The study of folic acid and vitamin B12 levels in anaemia in pregnancy. 2014;5:B41-B7. X-2, X-3, X-4.
3178 Yonemoto N, Dowswell T, Nagai S, et al. Schedules for home visits in the early postpartum period. Evid Based Child Health. Mar. 2014;9(1):5-99. X-1. [pmid: 25404577].
3179 Yousefi Z, Ghasemian Mehrdizaj S, Bidar Frimany M, et al. Metastatic choriocarcinoma in the small bowel: A case report. 2014;72:335-9. X-2, X-3, X-4.
3180 Yuce T, Acar D, Kalafat E, et al. Thrombocytopenia in pregnancy: do the time of diagnosis and delivery route affect pregnancy outcome in parturients with idiopathic thrombocytopenic purpura?. Int J Hematol. 2014. Oct. 8. X-4. [pmid: 25293555].
3181 Yulia A, Johnson MR. Myometrial oxytocin receptor expression and intracellular pathways. Minerva Ginecol. Jun. 2014;66:267-80. X-1. [pmid: 24971782].
3182 Zanette E, Parpinelli MA, Surita FG, et al. Maternal near miss and death among women with severe hypertensive disorders: a Brazilian multicenter surveillance study. Reprod Health. 2014;11:4. X-2, X-4. [pmid: 24428879].
3183 Zatta AJ, McQuilten ZK, Mitra B, et al. Elucidating the clinical characteristics of patients captured using different definitions of massive transfusion. Vox Sang. Jul. 2014;107:60-70. X-3, X-4. [pmid: 24697251].
3184 Zeitler H, Ulrich-Merzenich G, Marquardt N, et al. Immunoadsorption for pregnancy-associated severe acquired hemophilia. Ther Apher Dial. Feb. 2014;18:103-10. X-4, X-5. [pmid: 24499091].
3185 Zhang Y, Li W, Xiao J, et al. The complication and mode of delivery in Chinese women with severe preeclampsia: a retrospective study. Hypertens Pregnancy. 2014. Jan. 29. X-2, X-4. [pmid: 24475773].
3186 Zhang Z, Liu C, Yu N, et al. Removable uterine compression sutures for postpartum haemorrhage. BJOG. 2014. Sep. 1. X-2, X-5. [pmid: 25175111].
3187 Zhao Y, Zhang Y, Li Z. Appropriate second-line therapies for management of severe postpartum hemorrhage. Int J Gynaecol Obstet. 2014. Jul. 5. X-2. [pmid: 25277790].
3188 Zia S, Rafique M. Intra-operative complications increase with successive number of cesarean sections: Myth or fact?. Obstet Gynecol Sci. May. 2014;57:187-92. X-4. [pmid: 24883289].
3189 Zou CJ, Wang XF, Ye ZH. Maternal health care services in Zhejiang Province, China: From 1998 to 2010. 2014;19:151-60. X-2, X-4.
3190 Zubor P, Kajo K, Dokus K, et al. Recurrent secondary postpartum hemorrhages due to placental site vessel subinvolution and local uterine tissue coagulopathy. BMC Pregnancy Childbirth. 2014;14:80. X-3. [pmid: 24558972].