# Screening and Quality Assessment Forms

## Screening Forms

Abstract Review Form

Full-Text Review Form

## Quality Assessment Forms

Cochrane Collaboration Modified Tool for Assessing Risk of Bias in RCTs

Newcastle-Ottawa Quality Assessment Form for Case-Control Studies

Newcastle-Ottawa Quality Assessment Form for Cohort Studies

Case Series Quality/Risk of Bias Form

Harms Risk of Bias Assessment Form