# Search Strategies

Table A-1 MEDLINE search strategies (PubMed interface)

Search terms | | Search results
#1 | “postpartum hemorrhage”[MeSH Terms] OR “postpartum hemorrhage”[tiab] OR “postpartum haemorrhage”[tiab] OR (PPH[tiab] AND postpartum[tiab]) OR “obstetric hemorrhage”[tiab] OR “obstetric haemorrhage”[tiab] OR ((“postpartum period”[MeSH Terms] OR post-partum[tiab]) AND (“hemorrhage”[MeSH Terms] OR hemorrhage[tiab] OR haemorrhage[tiab])) | 7128
#2 | management[tiab] OR therapy[tiab] OR “Therapeutics”[Mesh:NoExp] OR treatment[tiab] OR “fundal massage”[tiab] OR “uterine massage”[tiab] OR ((fundus[tiab] OR fundal[tiab] OR uterus[tiab] OR “uterus”[MeSH Terms] OR uterine[tiab]) AND (massage[tiab] OR “massage”[MeSH Terms])) OR compression[tiab] OR “antishock garment”[tiab] OR “antishock garments”[tiab] OR “Gravity Suits”[MeSH Terms] OR “Fluid Therapy”[mh] OR uterotonic[tiab] OR oxytocin[tiab] OR “oxytocin”[MeSH Terms] OR Pitocin[tiab] OR oxytoxic[tiab] OR Oxytocics[mesh] OR misoprostol[tiab] OR “misoprostol”[MeSH Terms] OR Cytotec[tiab] OR methylergonovine[tiab] OR “methylergonovine”[MeSH Terms] OR methergine[tiab] OR ergonovine[tiab] OR “ergonovine”[MeSH Terms] OR ergotrate[tiab] OR “Ergot Alkaloids”[mh] OR ergot[tiab] OR ergometrine[tiab] OR carboprost[tiab] OR “carboprost”[MeSH Terms] OR “carboprost tromethamine”[Supplementary Concept] OR “PGE1”[tiab] OR hemabate[tiab] OR transfusion[tiab] OR “Blood Transfusion”[mh] OR “fluid resuscitation”[tiab] OR “isotonic crystalloids”[tiab] OR “isotonic crystalloid”[tiab] OR “crystalloid solutions”[Supplementary Concept] OR “Ringer's Lactate”[tiab] OR “lactated ringer's”[tiab] OR “Ringer's lactate”[Supplementary Concept] OR “isotonic saline”[tiab] OR “blood products”[tiab] OR “volume replacement”[tiab] OR fibrinogen[tiab] OR “fibrinogen”[MeSH Terms] OR “fresh frozen plasma”[tiab] OR “plasma”[MeSH Terms] OR “packed cells”[tiab] OR cryoprecipitate[tiab] OR “uterine tamponade”[tiab] OR “balloon tamponade”[tiab] OR “intrauterine balloon”[tiab] OR “uterine balloon”[tiab] OR “Uterine Balloon Tamponade”[mh] OR “Bakri balloon”[tiab] OR ((uterus[tiab] OR “uterus”[MeSH Terms] OR uterine[tiab] OR intrauterine[tiab]) AND pack*[tiab]) OR “Bakri balloon”[tiab] OR “arterial embolization”[tiab] OR “artery embolization”[tiab] OR “Embolization, Therapeutic”[mh] OR “artery ligation”[tiab] OR “ligation”[MeSH Terms] OR “arterial ligation”[tiab] OR “laceration repair”[tiab] OR “recombinant activated factor VII”[tiab] OR “rFVIIa”[tiab] OR “Factor VIIa”[mh] OR Laparotomy[tiab] OR “laparotomy”[MeSH Terms] OR Hysterectomy[tiab] OR “hysterectomy”[MeSH Terms] OR “B-lynch”[tiab] OR “Suture Techniques”[MeSH Terms] OR suture[tiab] OR suturing[tiab] OR “Uterine Inertia/prevention and control”[Mesh] OR “Uterine Inertia/therapy”[Mesh] OR “Uterine Inversion/therapy”[Mesh] OR “Uterine Rupture/therapy”[Mesh] OR “Dilatation and Curettage”[MeSH Terms] OR curettage[tiab] OR “uterine exploration”[tiab] OR “urinary catheterization”[tiab] OR “Urinary Catheterization”[Mesh] OR “catheter balloon”[tiab] OR “balloon catheter”[tiab] OR “foley catheter”[tiab] OR “condom catheter”[tiab] OR “condom tamponade”[tiab] OR (Condoms[Mesh] AND balloon[tiab]) OR “Rusch balloon”[tiab] OR “Sengstaken-Blakemore”[tiab] OR (“manual removal”[tiab] AND placenta[tiab]) OR “Placenta, Retained/therapy”[Mesh] OR “Resource Allocation”[Mesh] OR “Delivery of Health Care”[Mesh:NoExp] OR “Program Development”[Mesh] OR “Critical Pathways”[Mesh] OR “Guideline Adherence”[Mesh] OR “Clinical Protocols”[Mesh] OR “Algorithms”[Mesh] OR algorithm*[tiab] OR protocol*[tiab] OR system[tiab] OR systems[tiab] OR systemic*[tiab] OR “Patient Care Team/organization and administration”[Mesh] OR “Practice Guidelines as Topic”[Mesh] OR “Checklist”[Mesh] OR “adverse effects”[Subheading] OR unsafe[tiab] OR safety[tiab] OR harm[tiab] OR harms[tiab] OR harmful[tiab] OR complication[tiab] OR complications[tiab] OR “side-effect”[tiab] OR “side-effects”[tiab] OR ((undesirable OR adverse) AND (effect OR effects OR reaction OR reactions OR event OR events OR outcome OR outcomes)) OR sequelae[tiab] OR sequela[tiab] OR “Postoperative Complications”[Mesh] OR ((postoperative[tiab] OR surgical[tiab] OR postsurgical[tiab] OR “post operative”[tiab] OR “post surgical”[tiab]) AND (complication[tiab] OR complications[tiab])) OR “adverse effects”[Subheading] OR complications[Subheading] OR contraindications[Subheading] | 8820233
#3 | #1 AND #2 AND English[lang] | 4379
#4 | newspaper article[pt] OR letter[pt] OR comment[pt] OR case reports[pt] OR review[pt] OR practice guideline[pt] OR guideline[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR legal cases[pt] OR published erratum[pt] OR congresses[pt] | 5019085
#5 | #3 NOT #4 | 2729
#6 | #5 AND (“1990/01/01”[PDAT] : “3000/12/31”[PDAT]) | 2124^*^

Key: [mh] Medical Subject Heading; [tiab] title/abstract word; [pt] publication type; [sh] subheading; [PDAT] publication date

* Note: numbers do not tally as some articles are excluded in more than one category

Table A-2 CINAHL (via Ebsco) search results

Search terms | | Search results
#1 | (MH “Postpartum Hemorrhage”) OR “postpartum hemorrhage” OR “postpartum haemorrhage” OR “obstetric hemorrhage” OR “obstetric haemorrhage” OR (“PPH” AND “postpartum”) OR (((MH “Postnatal Period”) OR “post-partum”) AND ((MH “Hemorrhage”) OR (MH “Uterine Hemorrhage”) OR hemorrhage OR “haemorrhage” OR “excessive bleeding” OR “excessive blood loss”)) | 1258
#2 | “management” OR “therapy” OR (MH “Therapeutics”) OR treatment OR “fundal massage” OR “uterine massage” OR (((MH “Uterine Fundus”) OR fundus OR fundal OR (MH “Uterus”) OR uterus OR uterine) AND ((MH “Massage”) OR massage)) OR compression OR (MH “Compression Garments”) OR (MH “Compression Therapy”) OR “antishock garment” OR “antishock garments” OR (MH “Fluid Therapy”) OR “fluid therapy” OR “uterotonic” OR (MH “Oxytocin”) OR “oxytocin” OR “oxytoxic” OR “oxytoxics” OR (MH “Misoprostol”) OR “misoprostol” OR “cytotec” OR “methylergonovine” OR “methergine” OR (MH “Ergonovine”) OR “ergonovine” OR “ergotrate” OR (MH “Ergot Alkaloids”) OR “ergot” OR “ergometrine” OR “carboprost” OR “PGE1” OR “hemabate” OR (MH “Blood Transfusion”) OR “transfusion” OR (MH “Fluid Resuscitation”) OR “fluid resuscitation” OR (MH “Isotonic Solutions”) OR (MH “Crystalloid Solutions”) OR “isotonic crystalloids” OR “isotonic crystalloid” OR (MH “Lactated Ringer's Solution”) OR “ringer's lactate” OR “isotonic saline” OR (MH “Normal Saline”) OR “blood products” OR “volume replacement” OR (MH “Fibrinogen”) OR “fibrinogen” OR “fresh frozen plasma” OR (MH “Plasma”) OR “cryoprecipitate” OR “uterine tamponade” OR (MH “Balloon Dilatation”) OR “balloon tamponade” OR “intrauterine balloon” OR “uterine balloon” OR (((MH “Uterus”) OR “uterus” OR “uterine” OR “intrauterine”) AND “pack*”) OR (MH “Uterine Artery Embolization”) OR “arterial embolization” OR “artery embolilization” OR (MH “Embolization, Therapeutic”) OR “artery ligation” OR (MH “Ligation”) OR “arterial ligation” OR “laceration repair” OR “recombinant activated factor VII” OR “Factor VIIa” OR (MH “Blood Coagulation Factors”) OR (MH “Laparotomy”) OR “laparotomy” OR (MH “Hysterectomy”) OR “hysterectomy” OR “B-lynch” OR (MH “Suture Techniques”) OR (MH “Sutures”) OR “suture” OR “suturing” OR (MH “Uterine Inertia/TH/PC”) OR (MH “Uterine Inversion/TH”) OR (MH “Uterine Rupture/TH”) OR (MH “Dilatation and Curettage”) OR “curettage” | 842318
#3 | #1 AND #2 | 872
#4 | #3 AND limiters: English language, Exclude MEDLINE records | 196^*^

Key: [mh] Medical Subject Heading

* Note: numbers do not tally as some articles are excluded in more than one category

Table A-3 Embase search strategy (OvidSP interface, MEDLINE results)

Search terms | | Search results
#1 | postpartum hemorrhage/ OR “postpartum hemorrhage” OR “postpartum haemorrhage” OR (PPH AND postpartum) OR “obstetric hemorrhage” OR “obstetric haemorrhage” OR ((puerperium/ OR post-partum) AND (hemorrhage OR haemorrhage)) | 10554
#2 | management OR therapy OR therapy/ OR treatment OR fundal massage OR ((fundus OR uterine fundus/ OR fundal OR uterus OR uterus/ OR uterine) AND (massage OR massage/)) OR compression OR compression instrument/ OR artery compression/ OR compression stocking/ or compression bandage/ or compression sleeve/ or compression/ or compression therapy/ or compression garment/ OR mast suit/ OR “antishock garment” OR “antishock garments” OR “fluid therapy” OR fluid therapy/ OR uterotonic OR oxytocin OR oxytocin/ OR pitocin or uterotonic agent/ OR oxytocic agent/ OR misoprostol/ OR misoprostol OR cytotecOR methylergometrine/ OR methylergonovine OR methergine OR methylergometrine maleate/ OR ergometrine/ OR ergonovine OR ergotrate OR ergot alkaloid/ OR carboprost/ OR carboprost trometamol/ OR “carboprost tromethamine” OR prostaglandin E1/ OR PGE1 OR hemabate OR transfusion OR blood transfusion/ OR fluid resuscitation/ OR “isotonic crystalloids” OR “isotonic crystalloid” OR “crystalloid solutions” OR “crystalloid solution” OR crystalloid/ OR Ringer lactate solution/ OR “ringer's lactate” OR “lactated ringer's” OR isotonic solution/ OR “isotonic saline” OR whole blood/ OR blood product/ OR “blood products” OR “volume replacement” OR fibrinogen/ OR fibrinogen OR fresh frozen plasma/ OR “fresh frozen plasma” OR plasma/ OR erythrocyte concentrate/ OR “packed cells” OR cryoprecipitate/ OR cryoprecipitate OR uterine tamponade/ OR “uterine tamponade” OR “balloon tamponade” OR intrauterine balloon/ OR “intrauterine balloon” OR “uterine balloon tamponade” OR “Bakri balloon” OR ((uterus OR uterus/ OR uterine OR intrauterine) AND (pack?)) OR artificial embolism/ OR “arterial embolization” OR “artery embolization” OR “therapeutic embolization” OR artery ligation/ OR “artery ligation” OR “arterial ligation” OR “laceration repair” OR laceration/su OR recombinant blood clotting factor 7a/ OR “recombinant activated factor VII” OR “rFVIIa” OR blood clotting factor 7a/ AND laparotomy/ OR laparotomy OR hysterectomy/ OR hysterectomy OR “B-lynch” OR suturing method/ OR suture? OR suturing OR uterine atony/dm, dt, su, th OR uterus rupture/dm, su, th, dt OR curettage OR curettage/ OR “uterine exploration” OR bladder catheterization/ OR “urinary catheterization” OR “catheter balloon” OR balloon catheter/ OR Foley balloon catheter/ OR “foley catheter” OR condom catheter/ OR “condom catheter” OR “condom tamponade” OR (condom/ AND balloon) OR “Rusch balloon” OR “Sengstaken-Blakemore” OR (“manual removal” AND placenta) OR retained placenta/dt, su, th OR resource allocation/ OR “resource allocation” OR health care delivery/ OR program development/ OR “program development” OR clinical pathway/ OR “critical pathways” OR “guideline adherence” OR clinical protocol/ OR “clinical protocol” OR “clinical protocols” OR algorithm/ OR algorithm? OR protocol? OR system OR systems OR systemic OR patient care/ OR “guideline implementation” OR checklist/ OR checklist? OR ae.fs OR unsafe OR safety OR harm OR harms OR harmful OR complication/ OR complication OR complications OR side effect/ OR adverse drug reaction/ OR “side effect” OR “side effects” OR ((undesirable OR adverse) AND (effect OR effects OR reaction OR reactions OR event OR events OR outcome OR outcomes)) OR sequelae OR sequela OR postoperative complication/ OR “postoperative complications” OR ((postoperative OR surgical OR postsurgical OR “post operative” OR “post surgical”) AND (complication OR complications)) OR drug contraindication/ OR treatment contraindication/ OR co.fs | 8527763
#3 | #1 AND #2 | 7916
| Limit #3 to (human and english language and yr=“1990 -Current”) | 5624

Key: ?=truncation; fs=floating subheading; / s all subheadings; ae=adverse drug reaction subheading; co=complication subheading; dm=disease management subheading; dt=drug therapy subheading; su=surgery subheading; th=therapy subheading;

* Note: numbers do not tally as some articles are excluded in more than one category

Table A-4 MEDLINE search strategies (PubMed interface) for Key Question 4

Search terms | | Search results
#1 | “postpartum hemorrhage”[MeSH Terms] OR “postpartum hemorrhage”[tiab] OR “postpartum haemorrhage”[tiab] OR (PPH[tiab] AND postpartum[tiab]) OR “obstetric hemorrhage”[tiab] OR “obstetric haemorrhage”[tiab] OR ((“postpartum period”[MeSH Terms] OR post-partum[tiab]) AND (“hemorrhage”[MeSH Terms] OR hemorrhage[tiab] OR haemorrhage[tiab])) | 7348
#2 | “Anemia, Iron-Deficiency/therapy”[mesh] OR ((Erythropoietin[mesh] OR erythropoietin*[tiab] OR epoetin*[tiab] OR ferric*[tiab] OR ferrous*[tiab] OR “Iron Compounds”[mesh] OR Iron[mesh] OR iron*[tiab]) AND (“Anemia, Iron-Deficiency” [mesh] OR anemia[tiab] OR anaemia[tiab] OR anemic[tiab])) | 25489
#3 | #1 AND #2 AND English[lang] | 36
#4 | newspaper article[pt] OR letter[pt] OR comment[pt] OR case reports[pt] OR review[pt] OR practice guideline[pt] OR guideline[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR legal cases[pt] OR published erratum[pt] OR congresses[pt] | 5118038
#5 | #3 NOT #4 | 21
#6 | #5 AND (“1990/01/01”[PDAT] : “3000/12/31”[PDAT]) | 18^*^

Key: [mh] Medical Subject Heading; [tiab] title/abstract word; [pt] publication type; [sh] subheading; [PDAT] publication date

* Note: numbers do not tally as some articles are excluded in more than one category

Table A-5 CINAHL search strategies (EbscoHost interface) for Key Question 4

Search terms | | Search results
#1 | ((MH “Postpartum Hemorrhage”) OR “postpartum hemorrhage” OR “postpartum haemorrhage” OR (PPH AND postpartum) OR “obstetric hemorrhage” OR “obstetric haemorrhage”) OR ((MH “Postnatal Period+”) OR postpartum OR post-partum) AND ((MH “Hemorrhage”) OR (MH “Uterine Hemorrhage+”) OR hemorrhage OR haemorrhage)) | 1450
#2 | (MH “Anemia, Iron Deficiency/TH”) OR (((MH “Erythropoietin”) OR erythropoietin* OR epoetin* OR ferric* OR ferrous* OR iron* OR (MH “Iron Compounds+”) OR (MH “Iron”)) AND ((MH “Anemia, Iron Deficiency”) OR anemia OR anaemia OR anemic)) | 3724
#3 | #1 AND #2 | 10
#4 | #3 AND limiters: English language, Human, Exclude MEDLINE records | 1
#5 | #5 AND limiter: Published Date: 19900101-20140731 | 1^*^

Key: [mh] Medical Subject Heading;

* Note: numbers do not tally as some articles are excluded in more than one category

Table A-6 Embase search strategy (OvidSP interface) for Key Question 4

Search terms | | Search results
#1 | exp postpartum hemorrhage/ OR “postpartum hemorrhage” OR “postpartum haemorrhage” OR (PPH AND postpartum) OR “obstetric hemorrhage” OR “obstetric haemorrhage” OR obstetric hemorrhage/ OR ((puerperium/ OR postpartum OR post-partum) AND (bleeding/ OR hemorrhage OR haemorrhage)) | 11971
#2 | iron deficiency anemia/th OR ((erythropoietin/ OR recombinant erythropoietin/ OR erythropoietin* OR epoetin* OR ferric* OR ferrous* OR iron derivative/ OR iron/ OR iron therapy/ OR iron*) AND (iron deficiency anemia/ OR anemia OR anaemia OR anemic* OR anaemic*)) | 6883
#3 | #1 AND #2 | 19
#4 | Limit #3 to (human and english language and yr=“1990 -Current”) | 15

Key: exp=explode, s terms narrower than the search term;

* Note: numbers do not tally as some articles are excluded in more than one category