# Abbreviations and Acronyms

AHRQ: Agency for Healthcare Research and Quality
ANZHR: Australian and New Zealand Haemostasis Registry
ARDS: Acute respiratory distress syndrome
BMI: Body Mass Index
CER: Comparative Effectiveness Review
CI: Confidence Interval
DIC: Disseminated Intravascular Coagulation
DVT: Deep Vein Thrombosis
EBL: Estimated blood loss
EPC: Evidence-Based Practice Center
FFP: Fresh Frozen Plasma
ICU: Intensive Care Unit
Hb: Hemoglobin
HELLP: Hemolysis, Elevated Liver enzymes, Low Platelet counts syndrome
KQ: Key Question
L: Liter
LOS: Length of Stay
mL: Milliliter
MRI: Magnetic Resonance Imaging
NHLBI: National Heart, Lung, and Blood Institute
NR: Not Reported
OR: Odds ratio
PE: Pulmonary Embolism
PICOTS: Population, Intervention, Comparator, Outcomes, Timing, and Setting
PPH: Post-Partum Hemorrhage
PRBCs: Packed Red Blood Cells
PT: Prothrombin Time
RBC: Red Blood Cells
RCT: Randomized Controlled Trial
rFVIIa: Recombinant activated factor VII
RR: Relative risk
rTM: Recombinant Human Soluble Thrombomodulin
SD: Standard Deviation
SVT: Superficial Venous Thrombosis
TEP: Technical Expert Panel
TRALI: Transfusion-related acute lung injury
TXA: Tranexamic Acid
UKOSS: U.K. Obstetric Surveillance System