# Results

## Results of Literature Searches

We identified 4,359 unique citations searching five bibliography databases (Figure 3) from 1990 to August 2014. After excluding articles at title and abstract, full texts of 198 articles were reviewed to determine final inclusion. Seven articles were added through hand search. Of the 61 articles retained for Key Question (KQ) 1, 11 were specific to discontinuing natalizumab due to increased risk and 12 were specific to discontinuing due to pregnancy. Of the remaining 38 articles comprising 27 unique studies, only 16 studies contained complete information to allow for full analysis. All 38 articles were reviewed for information on reported reasons for discontinuation. For KQ2, 30 articles comprising 27 unique studies were included.

Figure 3 Disposition of studies identified for this review

KQ = Key Question; NTZ = articles for discontinuing natalizumab; PG = articles for discontinuing due to pregnancy

Figure 3 is the literature flow diagram, which is also described in the text. It enumerates articles retrieved through the literature search, articles excluded, and articles retrieved through hand searching.

## KQ1 Consequences of Discontinuing Disease-Modifying Treatments

### Description of Included Studies

Twenty-seven unique observational study populations were represented in 38 articles. (Detailed evidence tables are included in Appendix C.) Studies were conducted in the United States,28-38 Canada,39,40 Ireland,41,42 Italy,16,43-48 Hungary,49 Spain,50-54 Sweden,55,56 Denmark,12 France,57 Serbia,58 and multiple international locations.59-63 Of these, only 16 studies (24 articles) provided sufficient detail to abstract treatment benefit information.16,30-36,38,40,44,48-50,52,53,56,57,59-64 Study comparison arms ranged from early versus delayed treatment, treatment types, treatment dosages, treatment continuers versus treatment stoppers, and treated versus untreated.

Table 4 displays the longest study followup period for each of the 27 studies, although some studies have companion articles that reported specific treatment types or outcome measures with shorter followup periods. The reporting set included all articles meeting all PICOT inclusion criteria. The analytic set used only studies that reported study information with adequate detail to allow abstraction of treatment and followup duration and outcome information. As is often seen in fields working on improving reporting, the articles in the analytic set tend to be newer, and thus tended to report longer followup periods because patient data were available longer. Table 4 presents the analytic set first by type of disease-modifying treatment (DMT), followed by the remaining studies in the full reporting set but not the analytic set.

Table 4 MS study followup and treatment duration^a^

DMT | Author, Year | Duration: | 1 Year | 2 Years | 3 Years | 4 Years | | 5-6 Years | 7-9 Years | ≥10 Years
Interferons | Portaccio, 2008^16^ | Followup | | | | 4.7y β-1a im, 6.0y β-1b
Interferons | Portaccio, 2008^16^ | Treatment | | | β-1a im 3.1y, β-1b 3.3y
Interferons | Carmona, 2008^50^ | Followup | | | | | | 4.6y
Interferons | Carmona, 2008^50^ | Treatment | | | | | | ≤5y
Interferons | Kappos, 2009^60^ | Followup
Interferons | Kappos, 2009^60^ | Treatment | | | Delayed tx: med. 2.9y | | | Early tx: med. 5y
Interferons | Rio, 2007^54^ | Followup | | | | | | med. 5y (range 1-9)
Interferons | Rio, 2007^54^ | Treatment | Mean, median treatment duration not stated. 36% stopped treatment during followup
Interferons | Bencsik, 2006^49^ | Followup | | | | | | 6y
Interferons | Bencsik, 2006^49^ | Treatment | | | | | | 6y
Interferons | Patti, 2006^44^ | Followup | | | | | | 6y
Interferons | Patti, 2006^44^ | Treatment | | | | | | 6y
Interferons | Uitdehaag, 2011^61-63^ | Followup | | | | | | 7-8 y after RCT enrollment
Interferons | Uitdehaag, 2011^61-63^ | Treatment | | | 96=3 y* | | | | 95=7y*
Interferons | Shirani, 2012^40^ | Followup | | | | Contemporary untreated 4.5y | | IFNbeta: 5.2y | | Historical untreated. 10.5y
Interferons | Shirani, 2012^40^ | Tx: pt-yrs | Treatment was time-varying covariate in regression model.
Interferons | Goodin, 2012,^35,36^ | Followup | | | | | | | | 21.1y
Interferons | Goodin, 2012,^35,36^ | Treatment | | | RCT 3.3y | After RCT extension, treated by standard clinical practice.
Teri-flunomides | Confavreux, 2012^59^ | Followup
Teri-flunomides | Confavreux, 2012^59^ | Treatment | | | | | | | med. 7.1y (0.1-8.5)
Glatiramer Acetate | Debouverie, 2007^57^ | Followup | | | 3.5-8y
Glatiramer Acetate | Debouverie, 2007^57^ | Treatment | | | | med. 5y
Glatiramer Acetate | Ford, 2010^30-34^ | Followup | | | | | | | | Up to 15y
Glatiramer Acetate | Ford, 2010^30-34^ | Treatment | | | | withdrawn 4.8y | | | mITT 8.6y | ongoing 13.6y
Glatiramer Acetate | Miller, 2008^38^ | Followup | | | | Discontinued | | | | Continuing
Glatiramer Acetate | Miller, 2008^38^ | Treatment | | | Discontinued 3.5y(0.7-13y) | | | | | Cont15y(13-22)
Multiple Drugs | Rio, 2005 and 2006^51-53^ | Followup | | | | 4y
Multiple Drugs | Rio, 2005 and 2006^51-53^ | Treatment | | | NR
Multiple Drugs | Tedeholm, 2013^56^ | Followup | | | | | | | | 12 y
Multiple Drugs | Tedeholm, 2013^56^ | Treatment | | | Treated all DMT (interferons and glatiramer acetate) as single | | | | | 12 y
Multiple Drugs | Bergamaschi, 2012^48^ | Followup | | | | | | | | up to 35y
Multiple Drugs | Bergamaschi, 2012^48^ | Treatment | | t | Treated all DMT as single class | | | | | up to 35y
Interferons Not in Analytic Set | Cunningham, 2010^55^ | Followup
Interferons Not in Analytic Set | Cunningham, 2010^55^ | Treatment | | stoppers, switchers 1.2y | continuers ≥3y
Interferons Not in Analytic Set | Mesaros, 2012^58^ | Followup | | | *3.5±2.1 ys
Interferons Not in Analytic Set | Mesaros, 2012^58^ | Treatment | | | β1b 3.2±2 y | β1a 3.7±2 y
Interferons Not in Analytic Set | O'Rourke, 2005^41^ | Followup | | IFNbeta-1a 1.6y | IFNbeta-1a 3y | IFNbeta-1a 4.5y
Interferons Not in Analytic Set | O'Rourke, 2005^41^ | Treatment | | | varied by DMT
Interferons Not in Analytic Set | O'Rourke, 2007^42^ | Followup | | | hist. controls 3y | | | 5.1y
Interferons Not in Analytic Set | O'Rourke, 2007^42^ | Treatment | | | | 8.5% stopped at 4.1y | | NR
Interferons Not in Analytic Set | Trojano, 2005^45^ | Followup | | | | | | up to 6 y
Interferons Not in Analytic Set | Trojano, 2005^45^ | Treatment | | | | Results 4y
Interferons Not in Analytic Set | Trojano, 2007^46^ | Followup | | | | | | med 5.7 y. | up to 7 y
Interferons Not in Analytic Set | Trojano, 2007^46^ | Treatment | | | Tx covered 75% of followed days
Interferons Not in Analytic Set | Trojano, 2009^47^ | Followup | | | | | | | up to 7 y
Interferons Not in Analytic Set | Trojano, 2009^47^ | Treatment | | | NR
Interferons Not in Analytic Set | Bermel, 2010 and 2013^28,29^ | Followup | | | | | | | | med.16.3y
Interferons Not in Analytic Set | Bermel, 2010 and 2013^28,29^ | Treatment | | | | stop 4.2y (0-15) | | | | med.13.3y (3-15)
Multiple Medications Not in Analytic Set | Sorensen, 2006^12^ | Followup | | | | 3.7y
Multiple Medications Not in Analytic Set | Sorensen, 2006^12^ | Treatment | | | β-1b 3.8y, β-1a 2.7-3.7y, GA 1.8y
Multiple Medications Not in Analytic Set | Milanese, 2005^43^ | Followup | | | | | | up to 5 y
Multiple Medications Not in Analytic Set | Milanese, 2005^43^ | Treatment | | GA 1.6y | β-1a 2.3-3.2y | β-1b 3.5y
Multiple Medications Not in Analytic Set | Evans, 2012^39^ | Followup | | | | | | | | up to 14y
Multiple Medications Not in Analytic Set | Evans, 2012^39^ | Treatment | | | med 6.3 y any first-line DMT

a Mean unless otherwise noted.

DMT = disease-modifying treatment; IFNbeta = interferon beta; GA = glatiramer acetate; im = intramuscular; med=median; mITT = modified intention-to-treat; MS = multiple sclerosis; NR = not reported; RCT = randomized controlled trial; sc = subcutaneous; Tx = treatment; y = year

### KQ1a Evidence for Benefits for Continuing Treatment Versus Discontinuing

No studies directly assessed continuing versus discontinuing DMT in comparable populations. We therefore turned to literature examining benefits for continuing DMT long-term.

Sixteen observational studies from 24 articles on long-term benefits for DMT provided sufficient detail to abstract treatment benefit information.16,30-36,38,40,44,48-50,52-54,56,57,59-63 (Detailed evidence table are included in Appendix C.) Four studies were funded by industry,30,35,59,60 three by governmental funding,40,49,56 three reported not receiving funding,44,48,62 and six did not report funding sources.16,38,50,53,57,64

Table 5 provides outcomes reported by type of DMT and the range of followup.

Table 5 Outcomes reported from unique studies included in the analytic set for long-term DMT use

DMT | Author, Year | Type of MS at Baseline | Median or Mean Years to Final Assessment | All-Cause Mortality; Convert to SPMS | Progression | Annual Relapse Rate (ARR) | Strength of Evidence
INFB1a | Uitdehaag, 2011^61-63^ | RRMS | 7-8 | N (%) convert to SPMS | N (%) with EDSS progression; time to sustained 1-point EDSS progression | N (%) relapse-free; change in ARR from baseline, Annual relapse count by year; | Insufficient
INFB1b | Kappos, 2009^60^ | CIS | 5 | Primary: time to clinically-definite MS | Change in EDSS from baseline | | Insufficient
INFB1b | Carmona, 2008^50^ | RRMS | 5.6 | N (%) convert to SPMS | Change in EDSS from baseline; time to 1 –point EDSS progression | Change in ARR from baseline | Insufficient
INFB1b | Bencsik, 2006^49^ | RRMS, RPMS | 6 | | Change in EDSS from baseline | Change in ARR from baseline | Insufficient
INFB1b | Rio, 2007^54^ | SPMS | 5 | | Time to 1-point increase in EDSS (or 0.5 points if above 6 at entry) | Change in ARR, % decrease in relapse rate | Insufficient
INFB1b | Goodin, 2012^35,36^ | RRMS | 21 | All-cause mortality: 250 mg arm vs. placebo – HR 0.532 (98% CI, 0.31-0.90) 50 mg arm vs. placebo – HR 0.54 (95% CI, 0.32-0.92) favors treatment | | | Low
INFB Mixed | Portaccio, 2008^16^ | RRMS | 4.2 | | | | (Discontinuation or harms only reported)
INFB Mixed | Patti, 2006^44^ | RRMS | ≤6 | | Change in EDSS from baseline; progression by year to 6 years | Change in ARR from baseline | Insufficient
INFB Mixed | Shirani, 2012^40^ | RRMS | 4.5-10.5 | Time to sustained EDSS ≥6, No difference from contemporary control (HR 1.30; 95% CI,: 0.92–1.83) or historical control (HR 0.77; 95% CI: 0.58–1.02) | - | - | Low
Glatiramer Acetate | Debouverie, 2007^57^ | RRMS | 3-8 | | Change in EDSS from baseline; % progression by at least 1-point EDSS | Change in ARR from baseline; mean ARR by year | Insufficient
Glatiramer Acetate | Ford, 2010^30-34^ | RRMS | 4.8-13.6 | Proportion reaching EDSS 4, 6, 8; progression to SPMS | Change in EDSS from baseline | Change in ARR from baseline | Insufficient
Glatiramer Acetate | Miller, 2008^38^ | RRMS | 3.5-15 | % changed from EDSS<4 to>4; EDSS <6 to >6 | Change in EDSS from baseline | ARR over time | Insufficient
Glatiramer Acetate | Teriflunomide
Glatiramer Acetate | Confavreux, 2012^59^ | RRMS, SPMS | 7.1 | | Change in EDSS from baseline | Change in ARR from baseline | Insufficient
Multiple Drugs | Rio, 2005^51-53^ | RRMS | 5 | Proportion relapse-free; proportion reaching EDSS of 6 | % sustained disability progression | Change in ARR from baseline; proportion with decrease in ARR | Insufficient
Multiple Drugs | Tedeholm, 2013^56^ | RRMS | 12 | Time to SPMS | | | Insufficient
Multiple Drugs | Bergamaschi, 2012^48^ | RRMS | 20 | Proportion converting to SPMS | | | Insufficient

CIS = clinically isolated syndrome; DMT = disease-modifying treatment; EDSS = extended disability scale score; FU = followup; IFNbeta = interferon beta; GA = glatiramer acetate; LTFU = long-term followup; med=median; MS = multiple sclerosis; NR = not reported; RRMS = relapsing remitting multiple sclerosis; SD = standard deviation; SPMS = secondary-progressive multiple sclerosis; y = year

#### Key Points

- Low-strength evidence from one moderate risk of bias study suggests long-term all-cause survival is higher for treatment naïve relapsing-remitting MS (RRMS) patients who did not delay starting interferon beta 1b by 2 years and used DMTs for a longer duration than those who started later.
- Low-strength evidence from one moderate risk of bias study suggests that interferon use did not change disability progression for RRMS patients.
- Insufficient evidence was available to assess long-term benefits for DMTs for secondary progressive MS (SPMS) patients, and most outcomes for RRMS patients. Except for those noted above, studies were high risk of bias, had small sample sizes, and reported effects were small in magnitude.

#### Detailed Synthesis

Variation among the included studies on patient populations, interventions, outcome measurements, and time frames, precluded meaningful pooling. Risk of bias for all but two studies was also high. Selection bias, attrition, and lack of accounting for patient populations over time accounted for the greatest threat to risk of bias. Only two studies provide a low strength of evidence for two benefit outcomes measured long-term for interferons.

One moderate risk of bias study examined all-cause mortality over a 21-year period for 366 patients who had enrolled in a randomized controlled trial (RCT) (98.4% of the original RCT participants) testing interferon beta-1b for treatment naïve RRMS patients in 11 clinics in North America.35 The study's strength lies in the nearly complete followup of patients and the objective outcome measure. The missing patients were evenly spread across the study arms at two each. After the 2-year RCT, participants used DMTs according to patient and physician discretion, but analysis was based on RCT intention to treat. Participants in the treatment arms showed lower all-cause mortality compared with the placebo arm, with the 250 mg arm slightly lower than the 50 mg arm. The survival rate for the placebo arm was consistent with survival rates reported in MS natural history studies. Median treatment duration for the three groups ranged between 7 years for the placebo group, 14 years for the 50 mg arm, and 12 years for the 250 mg arm. Patients assigned to placebo had both later starts and shorter exposure to DMTs. Thus, the study cannot distinguish between the effects of early use and the effects of long-term use.

Three studies examined the effects of DMTs on disease progression measured by conversion to SPMS.40,48,56 While the studies were not pooled due to heterogeneity of treatments and methodological approaches, they represent on-target studies that directly attempt to evaluate the effects of DMTs on the long-term patient goal of delaying, or possibly preventing, conversion to SPMS, a more severe disease state. Thus, while only one study provided at least low strength of evidence findings, all three are presented in more detail.

One moderate risk of bias study examined the association between interferon beta use and progression to sustained Expanded Disability Status Scale (EDSS) for 6 of 2656 RRMS patients in Canada.40 Three arms were used: a treatment cohort followed for 5.1 years (interquartile range, 3 to 7 years), a contemporary cohort followed 4 years (interquartile range, 2.1 to 6.4 years), and a historical cohort (drawn from pre-interferon period) followed 10.8 years (interquartile range, 6.3 to 14.7 years). The strength of the study by Shirani et al. lies in the almost complete capture of MS patients since patients were unable to obtain DMTs other than from the participating clinic, and the multiple statistical approaches used to test for association, including use of comorbidities (Charlson score) and socioeconomic status along with age, sex, disease duration, and EDSS. Propensity score adjustments did not substantially change the results. The study did not find statistically significant differences in hazard rates for reaching EDSS 6 for either contemporary or historical cohort comparisons. Analyses used a time-dependent treatment variable and accounted for changing treatment status over time to address immortal time bias, a special form of selection bias. The study does not report the percent of patients prescribed different DMTs, or patients with neutralizing antibodies.

One high risk of bias study used selected patients' data from a Swedish MS registry, also using both a contemporary and historical cohort as comparisons.56 Adjusting for sex, age at MS symptom onset, whether onset was monofocal or polyfocal, and location of lesions, the study found a statistically significant difference in time to SPMS conversion for DMT (interferons and glatiramer acetate) treated patients versus a historical control of untreated patients. Treatment initiation (whether treatment was delayed or began earlier in the disease course) did not rise to statistical significance. Treatment duration was not a factor in the model. The reported results are inconsistent with Shirani et al. Significant concerns regarding selection bias of the treatment and contemporary groups and treatment by indication determined the study's high risk of bias.

A second study published only as an e-publication ahead of print used Bayesian techniques to model propensity for treatment – Bayesian risk estimate for MS (BREMS) – and then Bayesian modeling to estimate effects for DMT use in aggregate.48 The study reports that the technique they used allowed for typical switching and start/stop usage. However, there is insufficient information to assess model quality, and guidelines for model risk of bias are still new to the field and have not yet been translated to systematic review use; thus the risk of bias remains unclear. Bergamaschi et al. found that a smaller proportion of patients using DMTs (the vast majority of patients used interferons or glatiramer acetate) converted to SPMS compared to the historical control. This result is inconsistent with the other two studies.

Insufficient evidence exists to address long-term benefits for glatiramer acetate, teriflunomide, and natalizumab for either RRMS or SPMS, as well as other important MS outcomes for interferon beta for RRMS beyond all-cause mortality or 5-year disability progression for interferon beta.

### KQ1b Evidence for Long-Term Harms

Eleven of the 16 unique studies reported harms in enough detail for abstraction.16,30-36,38,44,52-54,57,59-63 (Detailed evidence table is included in Appendix C.) Only one of the studies was moderate risk of bias;35 all others were rated as high risk of bias.

Table 6 provides categories of harms reported by type of DMT and the range of followup.

Table 6 Harms reported from unique studies included in the analytic set

DMT | Number of Studies Total N Followup | Any Adverse Event | At Least One Serious Adverse Event | Treatment Discontinuation for Adverse Event | Comparator Groups | Reported Results
IFNbeta-1a61 | 1 N=429 4 y- | Most common AEs: Injection site reactions, headache, flu-like symptoms | NR | NR | No | No difference from short-term events
IFNbeta-1b36,60 | 2 N=746 5 – 16 y | Most common AEs: Injection site reactions, depression, flu-like symptoms, headache | 21% to 24% | Discontinuation rates “high” but numbers not reported | No | No difference from short-term events Frequency declined over 16 y time in continuers
IFNbeta mixed16,44,53 | 3 N=587 4 - 8 y | Most common AEs: Injection site reactions, depression, flu-like symptoms, headache. | NR | 3% during LT FU. Discontinue for serious AE more likely to happen early in treatment course (1 y) | No | Headache more likely for β-1a, injection site reactions for β-1b, no other differences between type of IFNbeta Majority of discontinuation occur early/short term.
INFbeta mixed54 SPMS | 1 N=146 5 y | NR | NR | 3.4%, although timing isn't clear | No | Majority of discontinuation occur early/short term.
Glatiramer acetate30,38,57 | 3 N=483 4y – 22 y | Only one reported overall rates: 87.3% Most common AE: injection site reactions | NR | Only one reported overall rates: 4.9% in long-term extension | No | Majority of discontinuation occur early/short term No difference from short-term events
Teriflunomide59 | 1 N=147 8.5 y followup | 98% of 7 mg dose and 100% of 14 mg dose experienced treatment emergent AE | 36% of 7 mg dose and 29% of 14 mg dose | 13.6% of 7 mg dose and 13.6% of 14 mg dose for AE | One comparison to general population rates for cancer | No difference from short-term events

AEs = adverse events; DMT = disease-modifying treatment; FU = followup; IFNbeta = interferon beta; GA = glatiramer acetate; im = intramuscular; LTFU = long-term followup; med = median; mg = milligram; MS = multiple sclerosis; NR = not reported; RRMS = relapsing remitting multiple sclerosis; sc = subcutaneous; SD = standard deviation; SPMS = secondary-progressive multiple sclerosis; y = year

#### Key Points

- Limited low-strength evidence suggests harms for injectable DMTs do not differ between short term (2-3 years) and long term (up to 16 years for interferon, 22 years for glatiramer acetate, and 8.5 years for teriflunomide).
- The majority of discontinuation tends to occur in the short-term (2 to 3 years from start).
- Broad variation in harms reporting precludes informative aggregation and summary.

#### Detailed Synthesis

The included studies used a wide range of reporting methods and adverse event categories that precluded simple aggregation over the studies. The most commonly reported adverse events were injection site reactions, flu-like symptoms, depression, and headache. Serious adverse events were generally not reported, although two studies gave rates of about 25 percent to 30 percent of participants. Discontinuations tended to occur during the first or second year of the study. When reported, discontinuation rates during long-term followup were low, about 3 to 4 percent. However, the studies generally did not separate discontinuation rates due to adverse events from total discontinuation rates, which would also include perceived lack of efficacy and other reasons not necessarily related to adverse events or side effects. Further, all studies lost participants to attrition. Dropouts from observational studies are more likely to bias reporting towards lack of adverse events. Patients on long-term treatment are self-selected for positive outcomes, even though this may be due to any combination of treatment effects and benign disease course. The studies also did not use large enough patient populations to adequately detect rare events.

The Cochrane overview of reviews of RCTs by Filippini et al. provides another basis for comparing short-term and long-term harms.10 They assessed treatment discontinuation for any reason as acceptability of treatment. The included RCTs were generally 2 to 3 years followup. They assessed treatment harms as counts of participants with 1) at least one adverse event, 2) at least one serious adverse event as defined by the authors of the primary study, 3) withdrawal due to adverse event at any time during the followup period, 4) serious infections as defined by the authors of the primary study, and 5) a new diagnosis of leukemia, lymphoma, or any other type of cancer during the followup period.10 They found, similar to our results, that studies tended to report number of adverse events rather than number of participants reporting adverse events, and that the range of adverse events and reporting methods was too diverse to allow for data aggregation. Filippini et al. found no statistically significant differences in serious adverse events, serious infections, or cancer between treatment and placebo groups. However, participants in treatment groups were more likely to withdraw from the studies than placebo groups (OR 2.41, 95% CI, 1.92 to 3.03).

### Natalizumab Discontinuation or Drug Holiday

Eleven observational studies (one moderate and 10 high risk of bias) addressed the risks of rebound disease activity, disease activity above-and-beyond that experienced by the patient prior to starting natalizumab, with natalizumab treatment interruption. (Detailed evidence tables are included in Appendix C.) Studies were conducted in the United States,65,66 Canada,67 Germany,68,69 France,70 Italy, 71 Denmark,72 Australia,73 and Spain.74,75 Three studies were funded by industry;66,67,71 one was funded by a combination of government, nongovernmental, and industry;73 two were unfunded;65,75 and five did not report funding sources.68-70,72,74

Eight of the 11 included annualized relapse rate and MRI measures to assess rebound,65,67-73 while three included MRI measures only.66,74,75 Reported reasons for natalizumab interruption were drug holiday in five studies,66,67,71,74,75 mostly drug holiday or not clearly reported in three studies,65,68,73 and mixed reasons in three studies.69,70,72 Five of the eight studies included RRMS patients only,65,69-71,74 while the others were mixed or unspecified. Sample size ranged from 13 to 48, with three exceptions: Sorensen (n=375),72 Jokubaitis (n-536),73 and O'Connor (n=949).67

Mean duration of natalizumab treatment ranged from 12 to 32.4 months, while treatment interruption ranged from median 2.6 to mean 11.3 months. Other DMT use during the natalizumab interruption was heterogeneous. DMT was not administered during the treatment interruption in three studies,66,70,75 glatiramer acetate was used in two studies,68,71 fingolimod in three studies,69,72,73 mixed DMTs in three studies,65,67,72 and pulsed steroids in one study,74 although only two studies administered DMTs to all MS patients.71,74 All66,68-70 or most patients used DMTs prior to natalizumab, with details not reported65,71,75 or not analyzed.72 Three studies did not report prior DMT use,73,74,76 one of which compared patients who switched from natalizumab to fingolimod with cohorts who switched to fingolimod from injectable DMT or no treatment.73

Table 7 provides definitions of rebound reported in the studies.

Table 7 Natalizumab rebound definitions

| Author, Year Location Risk of Bias | Reported Rebound | Definition of Rebound/Severe Flare
ARR and MRI Measures | Jokubaitis, 2014^73^ Australia and International Moderate | None | Quantified: compared ARR pre- and post-natalizumab; also compared ARR and distribution of severe relapse among those who switched to fingolimod from natalizumab, injectable, or no DMT
ARR and MRI Measures | O'Connor, 2011^76^ Canada High | None | Quantified: comparison to placebo: peak mean ARR during treatment interruption was not higher than the placebo group
ARR and MRI Measures | Havla, 2013^69^ Germany High | 3/13 | Quantified: Sustained EDSS worsening (>1 EDSS steps) and widespread disease activity (>1 GELs) on MRI
ARR and MRI Measures | Havla, 2011^68^ Germany High | 4/13 | Subjective: severe relapse with sustained EDSS worsening and widespread disease activity on MRI
ARR and MRI Measures | Kaufman, 2011^65^ United States High | None | Subjective: severe relapse as has been reported by others subjective: clinically severe flare and mean 16 GELs (range 6-40))
ARR and MRI Measures | Kerbrat, 2011^70^ France High | 4/27 | Subjective: severe relapse and 20+ GELs (range 23-50)
MRI Measures Only | Rossi, 2013^71^ Italy High | None | Subjective: MRI parameters were not consistent with rebound of disease activity
MRI Measures Only | Sorensen, 2014^72^ Denmark, High | 83/375 or 42/375^a^ | Quantified: Higher individual relapse rate after cessation of NTZ than before NTZ
MRI Measures Only | Borriello, 2012^74^ Spain High | 2 | Subjective: severe disabling relapse and a large number of GELs
MRI Measures Only | Borriello, 2011^75^ Spain High | None | Subjective: disease activity worsens beyond pre-treatment severity
MRI Measures Only | Miravalle, 2011^66^ United States High | 1 | Subjective: NR for observational study design

ARR = annualized relapse rate; EDSS = Expanded Disability Status Scale; GELs = gadolinium-enhancing lesions; MRI = magnetic resonance imaging; NR = not reported

a Excluding 51 patients treated with mitoxantrone prior to natalizumab

#### Key Points

- Overall, evidence is insufficient for whether the rebound phenomenon exists due to the high risk of bias and small study sample sizes.
- Operational definition of rebound lacks consensus. Rebound is subjectively measured and not clearly defined in studies.
- Evidence is lacking for rebound based on the best available evidence of one large study with high risk of bias.
- Studies that reported cases of rebound had high risk of bias, mostly small sample size, were mixed in providing DMTs during the interruption, and did not account for DMT use prior to natalizumab.

#### Detailed Synthesis

Determining whether rebound exists requires comparing disease activity prior to receiving natalizumab and disease activity after interrupting treatment. The comparisons need to examine people who discontinued natalizumab due to risk of progressive multifocal leukoencephalopathy (PML) rather than lack of treatment efficacy, compare pre and post measures on an individual level if rebound is heterogeneous, and account for other medications used both prior to natalizumab and after treatment interruption. None of the studies met these criteria.

One study addressed the issue of prior treatment by comparing patients who switched from natalizumab to fingolimod with patients who started fingolimod after interferon beta, glatiramer acetate or treatment naïve.73 Although this study did not examine individual level outcomes or treatment prior to natalizumab, mean annual relapse rate (ARR) did not increase pre- and post-natalizumab among the 89 patients who used natalizumab followed by fingolimod. Additionally, comparison of quarterly relapse rates for each 3-month period in the 15 months before and 9 months after fingolimod initiation found no differences between the natalizumab to fingolimod and injectable DMTs to fingolimod cohorts. No differences were found between any of the three cohorts except that during the 3-6 month period after beginning fingolimod, relapse rates were significantly lower among the treatment naïve cohort (with only one relapse across the cohort) compared with the post-natalizumab cohort. Relapse severity was assessed by comparing relapse treatment (ambulatory, hospitalization, or none) across the cohorts. Fifteen percent of relapses required hospitalization, and these relatively severe relapses were distributed evenly across the three cohorts and across the full observation period, with no evidence of rebound observed during the transition from natalizumab to fingolimod.

One large (n=949) industry-funded high risk-of-bias study examined 8 months of treatment interruptions gathered from large clinical trials.67 About 13 percent of patients used other DMTs during the interruption. Peak mean ARR following natalizumab discontinuation remained below the on-study placebo ARR. However, ARR and magnetic resonance imaging (MRI) outcomes were assessed only as averages, with no examination of pre and post measures for individual patients. Sampling of MRI outcomes was limited. Of the 949 study participants who underwent natalizumab treatment interruption, 339 had baseline MRI measures, and followup MRI during treatment interruption ranged from a sample of 147 at 2-3 months after discontinuation to 60 participants at 6 or more months after discontinuation, the time period with peak MRI activity.

Three small, high risk-of-bias studies also reported no rebound. One study examined only mean ARR, with no MRI outcomes or individual pre/post ARR comparisons in 48 patients, some of which used other DMTs during the interruption.65 One study of patients who did not use DMTs during the interruption did not report ARR outcomes after treatment interruption and included a sample of less than 20 with complete MRI data.75 One industry-funded study reported that the mean number of gadolinium-enhancing lesions (GELs) was significantly higher prior to natalizumab treatment compared with after natalizumab discontinuation in 40 patients. However, all patients were switched to glatiramer acetate, to which they had been treatment naïve, and thus the study lacked a true comparison group.71

In contrast, six high risk of bias (five small) studies reported cases of rebound disease activity. Four studies used subjective rebound definitions.66,68,70,74 None of the studies accounted for prior use of DMTs and all lacked the quantitative detail necessary to generate confidence in the study findings.66,68-70,72,74 Two studies each reported four rebounds and one reported three rebounds despite small sample sizes (n=13, 27, 36) but lacked quantitative detail on reported MRI outcomes.68-70 Prior to natalizumab, all patients in both studies used some type of DMT (details not reported). During the interruption, patients in one study used no DMTs.70 In the other two studies, some patients used DMTs while others did not, with all of the reported rebounds occurring in the group taking no DMTs during the interruption.68,69 In all four studies reporting ARR, mean ARR did not increase after natalizumab interruption compared with prior to natalizumab treatment. Two other studies did not report ARR after natalizumab interruption.66,74 One found no median change in MRI outcomes and reported two cases of rebound despite pulsed steroids use in all patients.74 DMT use prior to natalizumab was not reported; 18 of 23 patients had used mitoxantrone. One study found significantly higher mean GELs among the 12 patients with GELs after natalizumab interruption and described one case of rebound.66 All patients used DMTs prior to natalizumab, with details not reported, and none during the interruption. One large study reported 83 rebounds based on individual-level comparison of ARR pre- and post-natalizumab. However, this study did not account for the sample's high disease activity at baseline, included individuals who stopped natalizumab due to treatment failure, and did not address prior DMT (except to report 42 rebounds after excluding patients who had been on mitoxantrone prior to natalizumab).

Since pre-treatment disease activity may return following natalizumab interruption, comparisons that do not account for DMTs used prior to natalizumab are insufficient. Studies found some evidence that those with higher disease activity prior to natalizumab were more likely to relapse after natalizumab interruption. In one study, those with three or more relapses in the year prior to natalizumab treatment were twice as likely to experience relapse following natalizumab interruption (p=0.04) compared with those with fewer relapses prior to natalizumab.71 In this study, 88 percent of the total sample (n=40) were on interferon beta prior to natalizumab, and all received glatiramer acetate during the treatment interruption. Two studies reported trends toward higher ARR prior to natalizumab among those who relapsed during interruption.66,68 One study found that relapse on fingolimod was predicted by the number of relapses during the 6 months prior to fingolimod, regardless of whether patients started fingolimod after natalizumab discontinuation or after injectable treatment or treatment naïve, and among the natalizumab to fingolimod cohort, relapses on fingolimod were not predicted by relapse rates prior to natalizumab.73

### Pregnancy Drug Holiday

Twelve observational studies (all high risk of bias) addressed the benefits and risks to mothers and fetuses of treatment discontinuation due to pregnancy or intended pregnancy. (Detailed evidence tables are included in Appendix C.) Published from 2005 to 2012, these 12 studies comprised 11 cohort studies comparing DMT-exposed to unexposed pregnancies, and one large case series, and ranged in size from 14 to 425 DMT exposed pregnancies. The case series was drawn from a global drug safety database, included 425 pregnancies exposed to IFNbeta-1a with prospectively recorded outcomes.77 Studies were conducted in Sweden,77,78 Italy,79-81 Canada,13,82 Brazil,15 and Germany,83-85 and one was an international study with data from the United Kingdom, Brazil, Argentina, and Mexico.86 Two studies were funded by industry,77,78 two by governmental organizations,13,85 three reported that no specific funding was received for the study,83,84,86 and five did not report funding sources.14,15,79-82

Definitions of exposed versus unexposed differed (Table 8). Of the 12 studies, 10 reported on IFNbeta (14-88 exposed pregnancies),13,15,77-80,82,83,85,86 six reported on GA (6 - 41 exposed pregnancies),13,15,81,84-86 and one reported on natalizumab (35 exposed pregnancies).83 Of the 10 studies reporting results for IFN exposure, 2 studies reported on IFNbeta-1a,77,78 and 8 studies did not report results by specific IFNbeta preparation.

Table 8 Studies reporting pregnancy outcomes by drug

DMT | Total Number of Studies Total N | Spontaneous Abortion | Fetal Death | Preterm Delivery | Postpartum Relapse Rate
IFNbeta1a (sc or im) | 2 N=466 | 2 | 2 | 1 | 0
IFN mixed | 8 N=373 | 6 | 6 | 5 | 2
GA | 6 N=156 | 4 | 5 | 3 | 2
NTZ | 1 N=35 | 1 | 1 | 1 | 1

DMT = disease-modifying treatment; IFNbeta = interferon beta; GA = glatiramer acetate; im = intramuscular; NR = not reported; sc = subcutaneous; NTZ = natalizumab

#### Key Points

- Overall, high risk of bias and small sample sizes rendered the evidence insufficient to address the risks of fetal exposure to DMT during pregnancy in women with MS or the risks to the mother from the drug holiday.
- Women who discontinued DMT to attempt pregnancy but did not conceive were not observed as comparison groups, nor were data gathered or grouped by time on drug holiday prior to and during pregnancy.
- IFNbeta-1a exposure did not impact spontaneous abortion rates based on the best available evidence from one high risk-of-bias study.

#### Detailed Synthesis

The studies were not pooled for several reasons: (1) the outcomes are relatively rare events and the studies were not appropriately powered, (2) comparison groups were heterogeneous due to lack of reporting specific types of IFNbeta, and (3) definitions of exposure differed.

Maternal risks and benefits of discontinuation were investigated by examining post-partum relapse rate. Improvement in relapse rates during pregnancy is well established.87 Women who discontinue DMT with the intention of becoming pregnant risk increased relapses between discontinuation and pregnancy, as well as post-partum. Given that the studied populations are those who became pregnant, none of the studies capture what happens to women who discontinue DMT but do not become pregnant. Therefore, no research has observed whether such women are at increased risk of relapse. A German study using a retrospective survey found that women stopped DMT due to intended pregnancy for a mean of 4 years,88 thus the period a woman with MS remains untreated is not insignificant.

##### Maternal Outcomes

Three small, high risk-of- bias studies reported data on the outcome of post-partum maternal relapse rate.83,84,86 These studies were limited by sample size and aggregation of DMTs. One study reported on natalizumab with prospective data and found no significant difference but a trend toward fewer post-partum relapses among the exposed.83 One study reported on glatiramer acetate and aggregated IFNbeta with mixed prospective and retrospective data and found exposed women had a lower postpartum relapse rate during the first trimester after delivery compared with the unexposed group (p<0.05).84 One study reported on DMT in aggregate and found women receiving any DMT at least 8 weeks during pregnancy had a significantly lower relapse rate following delivery compared with those receiving no DMT at least 3 months prior to pregnancy, with no significant differences between the exposed and unexposed groups in relapse rates during the year prior to pregnancy or during pregnancy.86 However, the study timing and details of the postpartum relapse rates were not clearly reported.

##### Fetal Outcomes

All 12 studies reported on fetal outcomes. Two studies on IFNbeta-1a, including a large case series, found that rates of spontaneous abortion did not differ significantly from population estimates.77,78 Neither study reported a significant difference in fetal death from population estimates. One small, high risk-of-bias study reported no difference in preterm delivery between the exposed and unexposed groups.78

Of the six studies reporting on spontaneous abortions in pregnancies exposed to aggregated IFN, one small, high risk-of-bias study found significantly higher rates of spontaneous abortion among the exposed group.82 This study used multivariate analysis with mixed models on an inappropriately small sample, and the population was heterogeneous, including women with non-MS diseases in both the exposed and unexposed groups. In the exposed group, the two mothers without MS discontinued DMT at 21 and 38 weeks of gestation, while the 14 mothers with MS discontinued during the first trimester.

One small, high risk-of-bias study found no overall difference in spontaneous rates between the exposed and unexposed groups. The reported rate of spontaneous abortion was statistically significantly higher among those exposed to IFNbeta 1b compared with exposure to IFNbeta 1a, glatiramer acetate, or the control group without MS (rates in these groups ranged from 3.9% to 9.1%), with as few as one or two events per group. However, the result was not significant compared with the MS control group (9.8%).85 General population estimates of spontaneous abortion are 10 to 20 percent.89 This outcome is subject to surveillance bias; spontaneous abortions may be unobserved, contributing to the low rates reported by many of the included studies.

No studies on IFNbeta found significant differences in fetal death rates. One small, high risk-of-bias study found an increased risk of preterm delivery with exposure to IFNbeta, based on propensity score adjustment.79 The study did not report the percentage of nonoverlapping subjects that were dropped from the analysis.

Six small, high risk-of-bias studies on glatiramer acetate and one small, high risk-of-bias study of natalizumab reported no significantly higher rates of spontaneous abortion, fetal death, or preterm delivery among exposed pregnancies.

A published systematic review on DMT during pregnancy among women with MS rated the evidence level and quality as good across most IFNbeta outcomes and fair for glatiramer acetate and natalizumab.90 However, the review based the ratings on one small study, did not report maternal outcomes, and inappropriately used an instrument for assessing systematic reviews to assess individual study risk of bias. Two other systematic reviews on pregnancy did not assess study quality or risk of bias and performed meta-analysis without regard to underpowered sample sizes or heterogeneity (such as pooling spontaneous and elective abortions).87,91 Several recent reviews have summarized FDA categorization for DMTs including oral drugs with or without current FDA approval as treatment for MS, along with early data from clinical trial registries.92,93

### KQ1c Reasons for Discontinuation of Disease-Modifying Treatments Reported in Long-Term Observational Cohort Studies

Twenty of the 27 articles in the full reporting set reported reasons for discontinuing treatment. (Detailed evidence table is included in Appendix C.) Table 9 provides a summary of the number of articles reporting discontinuations by categories.

Table 9 Studies reporting reasons for discontinuing medication

DMT | Total Number of Studies | Adverse Event | Inefficacy or Progression of Disability^a^ | Intended Pregnancy | Long-Term Stable MS | Death | Protocol Violation^b^ | Patient Decision
Glatiramer acetate | 3 | 3 | 3 | 2 | 1 | 1 | 2 | 3
Teriflunomide | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1
Interferon beta-1a | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 1
Interferon beta-1b | 4 | 4 | 4 | 3 | 0 | 3 | 2 | 3
Interferon beta mixed | 7 | 7 | 7 | 5 | 1 | 1 | 0 | 5
DMT mixed | 3 | 3 | 3 | 3 | 0 | 1 | 0 | 3

a Category includes counts of both discontinuation based on clinician evaluation of disease progression and patient evaluation of lack of efficacy.

b Protocol violations are from studies that were RCT extensions.

#### Key Points

- The broad variation in discontinuation reporting prevented useful aggregation of studies.
- All studies reported one or more adverse events and inefficacy or progression of disability as reasons to discontinue.
- Patient reasons for discontinuing DMT were not explored.

#### Detailed Synthesis

As was seen with harms, the wide range of reporting methods and discontinuation categories prohibited detailed quantitative aggregation over the studies. Most articles reported numerous reasons for discontinuations. An article was categorized as reporting lack of efficacy or progression of disability based on study author definitions and use of the specific terms. In this category we included both physicians' and patients' perceptions of lack of efficacy, and it was often unclear who was the source of such a determination. Progression of disability was also study author defined but included articles that provided objective measures of progression such as a one-step increase in the EDSS. Protocol violations was included as a category since several studies were open label surveillance extensions of RCTs. Unfortunately, the category of most interest, the patient's decision to discontinue, remained largely unexplored by the study authors. Minimal text was generally provided for this category, such as “by own will,”54,58 “withdrew consent,”38,60 or “voluntary withdrawal.”45,50,52 One study labeled patients stopping DMT for “no discernable reason, without discussion with their neurologists” as noncompliant.41

## KQ2 Individuals' Values, Beliefs, and Preferences Regarding Discontinuing Disease-Modifying Treatments

### Description of Included Studies

The 27 included unique studies (30 total articles) represented a wide range of study aims. Designs ranged from factor analysis of questionnaires to experimental psychology lab tests to trials of shared decisionmaking interventions. Study locations were international, including the United States,94-101 Netherlands,102-104 Germany,105-116 Norway,117 a consortium of European countries,118 Canada,119,120 Italy,121,122 and Ireland.123 The included studies, organized by the KQ sub-questions and relevant section of the conceptual framework, are shown in Figure 1.

### Overarching Key Point

Given the complexity of understanding preferences and behaviors, and the wide range of study designs used over a small literature set, all KQ2 key points should be viewed as preliminary.

### KQ2a Patients' and Providers' Preferences for Discontinuation of Disease-Modifying Treatments in Patients

Literature for this KQ sub-question is categorized as intrapersonal or interpersonal literature. Intrapersonal literature examines preferences, values, knowledge, beliefs, and other behaviors of people with MS to improve our understanding of the inputs that may enter on a personal level into deciding whether or not to discontinue DMTs. The interpersonal literature addresses the relationship between patients and providers, and the preferences each brings to the encounters and decisions.

#### Intrapersonal Literature

We found few studies to populate the intrapersonal portion of Figure 1 (reproduced in Figure 4). Table 10 provides information on the 14 studies that addressed intrapersonal factors in the values and preferences literature. The literature tended to examine attitudes and cognition rather than patient knowledge and how that knowledge affected decisions. Studies examined risk expectation, preferences for DMT treatment and treatment trade-offs, knowledge of cost factors, reasons for using or discontinuing DMTs, and theoretical approaches to understanding decisionmaking and behavior processes. Study designs varied widely, including survey questionnaires, qualitative interviews, preferences, elicitation techniques, prospective cohorts, cross-sectional analysis of claims data, and one RCT.116 Four studies received industry funding,96,100,116,118 five did not report funding sources,97,98,105,112,117 one was unfunded,99 and four received governmental or nongovernmental funds.101-104

Figure 4 Intrapersonal factors

Figure 4 repeats the section of Figure 1 that depicts the individual's internal decision context and process, showing factors such as preferences, values, knowledge, beliefs, and cognitive behaviors/habits.

Table 10 Included studies for intrapersonal literature

First Author, Year Country Funder | Study Aim | Population | Design | Study Author Findings
Janssens, 2003^103^ Netherlands Nongovernmental | Quantify expectations of wheelchair dependency in newly diagnosed MS patients and partners | 101 MS patients diagnosed within previous 2 years, mean diagnosis time 8 months, 70% female, only 10% current DMT users; 78 partners | Survey questionnaire and neurological exams; compared perceived risk to actual at 2 years, 10 years, and lifetime; differences by clinical characteristics | - Both groups overestimate 2 and 10 year, but underestimate lifetime risk.; - Patients with more functional limitation perceived lower seriousness for wheelchair use.; - Concordance between patient and partner was moderate.
Boeije, 2004^102^ Netherlands Nongovernmental | Examine how patients explain perception of prognostic risk | 85 MS patients included in Janssens, 2003 who were interviewed | Qualitative; one-on-one interviews in patients' homes | - Uncertainty of future progression was predominant factor in risk perception.; - Patients discriminated over time in the perception of absolute risk.; - Use of heuristics was clearly evident.
Kopke, 2014^116^ Germany Industry | Evaluate efficacy of an evidence-based patient information program; increase informed choice in MS patients | 192 RRMS or CIS enrolled in RCT evaluating effectiveness of education program for informed decision making based on theory of planned behavior | RCT of complex intervention including education program presenting best available evidence regarding diagnostic testing, prognosis, and early DMT therapy. Control received stress management program by trained psychologist. Outcomes: Multidimensional measure of informed choice | - Intervention arm more likely to demonstrate good risk knowledge after 4 weeks than control (p<0.001); - Intervention arm more likely to achieve informed choice after 6 months compared with control (OR 0.2, 95% CI 0.1 to 0.4)
Prosser, 2003^101^ U.S. Nongovernmental | Examine preferences for MS disability states and three DMTs. Also compare differences in utility weights between MS and healthy community | 62 RRMS patients, median age 38, 79% female; 67 healthy community respondents, similar to U.S. population but more educated and fewer children | Computer-based survey using standard gamble methods to elicit and quantify preferences for health states as input to a modeling project | - Patients discontinue DMT when side effects and discomfort from treatment are equal to or worse than disease symptoms.; - Patients assigned higher utilities to MS-related health states and treatment states than community respondents.; - Ratings diverged as health states worsened. For the EDSS 8 health state, there was very little overlap between patient and community respondents.
Johnson, 2009^100^ U.S. Industry | Examine willingness to accept a life-threatening adverse event in exchange for improvement | 651 MS patients drawn from consumer advocacy and industry website lists, and participants in a clinical trial; similar to national MS sample | Computer-based survey using choice-format stated preferences, also known as discrete choice experiment or conjoint analysis, to elicit and quantify preferences for health states | - Delay in years to progression was the most important factor in willingness to accept risk, followed by risk of severe adverse event; relapse rate was least important.; - Respondents were willing to trade higher risk for greater benefit.; - Maximum acceptable risk was relatively insensitive to SES or patient experience with MS.
Dor, 2010^98^ U.S. Not reported | Examine the impact of copayments or coinsurance on reducing adherence | 1974 MS patients with prescription or procedure codes for IFN or GA (MedStat MarketScan Commercial Claims and Encounters database of private sector health data) | Two-stage least squares model using secondary data; copayment vs. coinsurance and effects on medication possession ratio; patients with copay matched to patients with coinsurance. | - Increases in coinsurance associated with decreased adherence. 10% increase in cost sharing led to an 8.6% decline in adherence. (monthly price range $44 to $1162); - Copayment, which is inherently more price stable than coinsurance, did not show an effect. (monthly price range $37 to $42)
Gleason, 2009^99^ U.S. No external funds | Examine the relationship between DMT abandonment and out-of-pocket expenses | 2791 MS patients with continuous enrollment and new to DMT (BlueCross BlueShield database, Midwestern and southern) | Cochran-Armitage test for trend and multivariate logistic regression; defined prescription abandonment as never taking possession of DMT | - Abandonment rate increased with increasing out-of-pocket cost. (p<0.001); - 5.7% abandonment rate at monthly cost of $100 or less; - OR between 6.1 and 7.3 for expense groups greater than $200/claim (1 in 4 MS patients abandoned DMT at $200/claim)
Visser, 2011^104^ Netherlands Dutch MS Foundation | Examine patient perception regarding decisions and reasons for using or not using DMT | 1403 MS patients recruited through Dutch National MS Foundation and MS nurses (89% response rate) Includes 41% RRMS, 31% SPMS, 19% benign MS, 9% PPMS | Survey questionnaire, descriptive statistics; patients categorized by never used, stopped using, currently on 1^st^ DMT, currently on switched DMT | - Patients attributed the decisive role in starting (70%) or changing (66%) DMT to the neurologist, but claimed the decisive role for stopping (62%).; - 1/3 of current DMT users were uncertain DMT had a beneficial effect.; - Reasons for stopping: side-effects, uncertainty of benefit, administration method, aggravation of signs and symptoms, frequency of administration, and phase of disease
Bischoff, 2012^105^ Germany Not reported | Examine reasons for discontinuation; who made and what influenced decision | 396 MS patients discontinuing DMT in last 3 months, 75% female; 40 clinics; includes 54 SPMS on DMT | Telephone standardized questionnaire, descriptive statistics | - Mean duration of DMT was 30.5 months, ±32.1.; - Positive expectations from therapy declined from 59% to 49% at discontinuation.; - 75% claimed responsibility for decision; no outside influence. (Half were willing to restart.); - Reasons for stopping: not wanting to be reminded of MS, side effects, loss of efficacy, adverse events (same in all DMTs)
Grytten, 2013^117^ Norway Not reported | Examine psychosocial factors of nonstarters and stoppers of DMT | 424 RRMS respondents (84%), 69% female | Survey questionnaire, descriptive statistics and multivariate regression; patients categorized by never used, stopped using, currently on 1^st^ DMT, currently on switched DMT. | - Patient decision to stop 37%, Patient/MD decision to stop 45%, MD decision to stop 18%.; - Risk of stopping increased with high education.; - Psychosocial factors not significant.; - Significant factors: lack of efficacy, tolerability, adverse events.
Meyniel, 2012^118^ International Industry | Assess factors leading to first treatment discontinuation | 2314 CIS patients from 44 centers; MSBase Incident Study; 1247 started DMT (followed 2.7 years, during which 90% converted to definite MS) | Prospective cohort, multivariate survival analysis for factors predicting stopping | - 40% stopped within the observation period.; - Significant factors for stopping: female, increasing EDSS, and using IFN.; - Stopping varied by country; - Not significant: MRI features, age, time to treatment, relapse on treatment
Daugherty, 2005^97^ U.S. Not reported | Examine patient reported factors for discontinuing treatment | 108 MS patients prescribed DMT at a Midwest university neurology clinic. | Telephone questionnaire, descriptive statistics; a priori discontinuation reason categories. | - Adverse events 52%; - Physician-documented disease progression 40%; - Perception of drug ineffectiveness 20%; - Cost 4%.
Berger, 2004^96^ U.S. Industry | Assess extent to which Transtheoretical Model of Change predicts discontinuation | 530 (of 946, 56%) MS patients in Biogen Alliance program prescribed Avonex (INF beta 1a) 79% currently on Avonex | Survey, split into current, previous, or never users; factor analysis of readiness stages, decisional balance (pros and cons), self-efficacy; regression for predictors including cognitive impairment, injection info, demographics | - Predictors of use: average pros of DMT, average cons of DMT for decisional balance, education, and level of disability.; - Model predicted 82% of discontinuers, 81% continuers.
Kasper, 2012^112^ Germany Not reported | Use theory of planned behavior to describe decision process for intention to use DMT; test evidence-based education intervention | 192 RRMS enrolled in RCT evaluating effectiveness of education program for informed decision making | Survey; validation study of measures of planned behavior factors; logistic regression using intention, attitude, subjective social norms, perceived behavioral beliefs, expectations, and values | - Planned behavior questionnaire explained 68% of variance in intention to use DMT.

CIS = clinically isolated syndrome; DMT = disease-modifying treatment; EDSS = extended disability scale score; GA = glatiramer acetate; IFN = interferon; MS = multiple sclerosis; MD = medical doctor; PML = Progressive multifocal leukoencephalopathy; QoL =-quality of life; RRMS = relapsing remitting multiple sclerosis; SES = socioeconomic status

##### Key Points

- Patients overestimated intermediate term risk of wheelchair use but underestimated the lifetime risk. This underestimation may indicate the uncertainty felt by MS patients when contemplating their personal trajectories rather than lack of knowledge (two studies).
- Patients are likely to use heuristics in risk assessments (one study).
- With training, patients can improve risk understanding and sense of informed choice (one study).
- Quantified preference studies suggest patients are willing to make risk trade-offs for benefits only to the point where the discomfort from side effects and treatment are equal to or worse than the disease symptoms (two studies).
- Increasing out-of-pocket cost reduces DMT purchases (two studies).
- Common reasons for discontinuing include side-effects, uncertainty about or perceived lack of efficacy against disease progression, administration method and frequency, and cost (five studies).
- MS patients tended to take responsibility for the decision to discontinue (three studies), while viewing their neurologist as the driver for decisions regarding choice of DMT (one study).
- Psychological models of behavior support the presence of rational processes contributing to patient decisionmaking (two studies).

##### Detailed Discussion

###### Risk

Risk is fundamental to decisionmaking. Expectations regarding an uncertain future can figure heavily in both rational thought processes and emotional appraisals. Risk expectations have particular salience for people with MS due to the enormous prognostic uncertainty regarding the disease course. One mixed-methods study, using quantitative survey data and interviews, along with a neurological clinical examination, looked at perceptions of risk of future wheelchair use.102,103 The study did not directly examine individual choice to use or discontinue DMT, but it provides empirical literature regarding MS patient perceptions of risk. These perceptions would presumably factor into decisions regarding DMT use.

MS patients within 2 years of having been diagnosed tend to overestimate risk of becoming wheelchair-bound in the short and immediate term but underestimate the lifetime risk.103 The authors chose this particular risk factor because wheelchair use is one of the most major and well-recognized consequences of MS. In 101 MS patients, 2-year expected risk was 22.5 percent versus 5-10 percent actual, 10-year expected risk was 38.8 percent versus 20-25 percent actual, and lifetime risk was estimated at 54 percent versus 70-80 percent actual. People with more functional limitations were less concerned about wheelchair use than people with fewer functional limitations (p <0.01). This may reflect that MS patients with higher mobility impairment view wheelchair use as an improvement in mobility, while those with higher mobility view it as a significant loss.

Followup interviews with 85 MS patients indicated the use of heuristics—or cognitive short-cuts—to simplify complex judgments.102 The enormous uncertainty of the MS disease course was the predominant explanation for risk perceptions. One-third of MS patients in the quantitative study perceived their 10-year and lifetime risk of wheelchair use to be 50 percent. However, all but one patient indicating a 50 percent risk gave reasons such as “I've no idea,” or “it might happen or it might not.” This indicates that their response was based more on uncertainty about their prognosis rather than on a belief that the risk was actually 50 percent.

MS patients' risk comprehension can be improved with education. An RCT with 192 RRMS or CIS patients receiving a 4 hour education program including MS basics, diagnostics, prognostic studies, therapeutic options, and pros and cons of DMT retained improved risk understanding after 4 weeks.116

###### Quantified Preferences

Patients' preferences for different health states are addressed by two studies using different methodological approaches to estimate or model the trade-offs contributing to the preferences.100,101 While some of the findings may seem evident, such as the importance of delaying disease progression, other findings are cautionary. MS patients placed more value on disabled health than did study participants without MS. Further, their preferences change over time and do so differentially for different quality of life domains.

One study used standard gamble to elicit preferences, or utilities, for health states.101 The standard gamble measures the risk patients are willing to take for a better outcome and the value they attach to their current health state. Patients are asked to gamble between their current certain health state and an uncertain outcome that has a probability P of full health and a corresponding probability 1-P of death.124 For this study, MS patients were asked to choose between a chronic treatment or a one-time treatment with some chance of perfect health and some risk of immediate death. Three treatment profiles were created to mimic IFNbeta-1A, IFNbeta-1b, and glatiramer acetate. The treatment descriptions did not include information on the rare but potentially serious adverse events of treatments. Respondents indicated they would discontinue DMT when the severity of side effects and discomfort from treatment are equal to or worse than disease symptoms. This creates a challenge when MS patients are early in the disease course. Such a person may not yet be experiencing significant disease symptoms, but considering treatment with negative quality of life consequences today in exchange for the possibility of delaying disease symptoms and disability. The differing preferences between MS patients and healthy people underscore that the hypothetical nature of the gamble and highlight the fact that choices made in a hypothetical situation differ from actual decisions and behaviors.

Choice-format stated-preference, also known as discrete choice experiments or conjoint analysis, was used to quantify the relative preferences MS patients assigned to various treatment attributes.100 This technique can estimate the maximum risk patients are willing to accept in trade for treatment benefits. This study included several major risks associated with DMTs, including death or severe disability from PML, death from liver failure, and death from leukemia. These risks were traded against different 5-year annualized relapse rates and years to disease progression. The study claimed the maximum acceptable risk estimates for the levels of benefit observed in clinical trials were higher than the observed risk but did not provide the data necessary for the comparison. The study design tried to reduce respondent burden, given the number of trade-offs to assess, and tested for result validity through mathematical rules and logic validity tests. However, as with the standard gamble, the hypothetical nature of the questions fails to inform us about actual choices. Further, respondents may have lacked the numeracy skills to fully appreciate the information provided and evaluate their choices accordingly. Heuristics may also have come into play. Although the heuristics may not have differed substantially from the actual cognitive behaviors of the decision process, heuristics itself is not consistent with the assumption of rational processes underlying this preference elicitation technique.

###### Cost as a Contributor to Discontinuing

Costs, especially out-of-pocket costs, have a serious impact on a patient's decision to discontinue DMT. Two studies examined the effect of out-of-pocket costs on MS patients choosing not to fill prescriptions for DMTs.98,99 Both studies found increasing costs related to decreasing possession of DMTs. Both studies considered patient demographics (age, sex, geographic region). One study relied on zip codes to represent education and income levels.98 The other study matched patients by demographics plus employment status and employer industry; it also included general health status as assessed by the Charlson score and other comorbid conditions.99 MS patients with copayments rather than coinsurance did not exhibit a relationship between increasing cost and medication possession but still showed variation in medication possession. This finding underscores that finances are not the only factor responsible for DMT discontinuation.

###### Stated Reasons and Predictors for Discontinuing

Stated reasons and predictors for discontinuing DMT were examined in five studies.97,104,105,117,118 Four studies used surveys,97,104,105,117 while one used prospective cohort data.118 While all studies converged on common reasons to discontinue—side-effects, perceived lack of efficacy, aggravation of signs and symptoms/disease progression, and administration method and frequency—surveys allowing open responses, rather than a priori discontinuation categories, found more nuanced responses. For example, patients who said they did not want to be reminded of the disease were not responding to fear of injections; patients injecting the DMT weekly were more likely to express this desire than patients injecting several times weekly or daily.105 Rather, these patients were expressing the psychological response to being confronted with the disease at the time of injection. As another example, uncertainty of DMT benefit is qualitatively different than perceived lack of benefit.104

###### Who Makes the Decision To Discontinue?

The majority of patients took responsibility for the decision to discontinue, a finding similar in three studies that reported 62 percent,104 75 percent,105 and even up to 82 percent if unilateral patient and patient/physician shared categories are combined.117

###### Tests of Psychological Theories

Two studies used theories or models of behavior to explore patient preferences for DMT.96,112 The Theory of Planned Behavior, an expectancy-value model, assumes that behavior reflects past experiences and anticipated barriers. A person's intent to perform a specific behavior depends on the individual's favorable or unfavorable attitudes toward the behavior, perceived pressure to comply to social norms regarding the behavior, and perceived ease or difficulty of performing the behavior.125 In contrast, the Transtheoretical Model of Change assumes that behavior change is a six-step process, and people move through precontemplation, contemplation, preparation, action (new behavior for fewer than 6 months), maintenance (longer than 6 months), and termination.126 This model incorporates concepts from numerous influential theories in psychology, including motivational theory, social learning theory, self-efficacy theory, conflict decisionmaking theory, the health belief model, and the theory of reasoned action.

Kasper and colleagues112 identified domains in a questionnaire based on the Theory of Planned Behavior. These domains predicted 68 percent of the variance in the intention to use DMTs in 192 patients with RRMS enrolled in an evidence-based education intervention for informed decisionmaking, suggesting rational processes contribute to decisionmaking regarding DMTs. The assessed domains included attitudes, social norms, and beliefs regarding the perceived ease or ability of the patient to perform expected behaviors. The questionnaire also incorporated emotional appraisals of DMTs, through questions such as “the risk I would be taking by putting off immunotherapy for too long frightens me.” However, the study examined intention to use DMT, not the actual behavior.

Rational processes also contributed to decisionmaking when modeled using the Transtheoretical Model of Change.96 Along with level of education and disability, average pros and average cons of DMT use, specifically IFNbeta-1a in this case, predicted 81 percent of discontinuation. The study authors determined an equation for calculating an individual's likelihood of discontinuing treatment. Very simply, as patients lose confidence in the DMT's ability to prevent or slow disease progression, they move closer to discontinuing. The study was conducted by one firm to develop a company-based program to promote treatment persistence, so generalizability of the findings is uncertain.

#### Interpersonal Literature

Much less literature populates the interpersonal portion of Figure 1 (reproduced in Figure 5). Table 11 provides information on the three studies that addressed interpersonal factors in the values and preferences literature. Interpersonal concerns include the knowledge, values, beliefs, and preferences that both the patient and physician bring to a decisionmaking encounter, and also the extent to which this information is shared between the two. Communication issues also are important at the interpersonal level. Study designs included survey questionnaires and qualitative interviews. One study received industry funding,119 one was unfunded,110 and one received nongovernmental funds.120

Figure 5 Interpersonal factors

Figure 5 repeats the section of Figure 1 that depicts with overlapping circles the interpersonal decision context and processes betwe3en the physician and patient

Table 11 Included studies for interpersonal literature

First Author, Year Country Funder | Study Aim | Population | Design | Study Author Findings
Heesen, 2010^110^ Germany Not funded | Assess risk tolerance of MS patients and treating physicians for natalizumab adverse events | 69 MS patients from a university clinic (average EDSS = 4), 192 affiliated neurologists | Survey to investigate prerequisites for shared decisionmaking (part of an intervention study of shared decisionmaking). A 3-page information leaflet on natalizumab was provided to both groups. Test and correlation statistics | - 49% of physicians would stop natalizumab for a PML risk of 2 per 10,000; only 17% of patients would do so (p<0.001).; - Both groups overestimated natalizumab treatment effects.; - Similar to risk perceptions, patients were more strongly in favor of continuing than physicians, who were more ambivalent
Kremenchutzky, 2013^119^ Canada Biogen | Compare neurologist and MS patient perceptions of MS related health status | 99 MS patient and neurologist pairs. 6 clinics in Ontario and Alberta; excluded patients receiving natalizumab or IFNbeta marketed by Biogen | Survey questionnaire using standard gamble methods to elicit and quantify preferences for health states to assess communication | - Significant differences between patient and provider perceptions of relapse frequency and QoL; patients rate as worse.; - Little concordance on identified important health domains; providers identify physical functioning while patients emphasize mental health
Thorne, 2004.^120^ Canada Nongovernmental | Describe health care communication issues | 12 long-term MS patients, 7 unemployed due to disability; prior to illness, 6 had been professionals, 3 health care professions | In-depth, loosely structured interviews, recorded, transcribed, and analyzed using NVivo software. | - Provides table of helpful and unhelpful communication specifics

EDSS = extended disability scale score; MS = multiple sclerosis; PML = Progressive multifocal leukoencephalopathy; QoL = quality of life

##### Key Points

- MS patients and their physicians can differ significantly in their perceptions of the relative importance of health states and risks (two studies).
- Physicians and patients must communicate in order to clarify differences in perceptions and preferences (one study).

##### Detailed Discussion

###### Differences Between Patient and Physician Perceptions

MS patients and their physicians may differ in their perceptions of the relative importance of health states and risks. Two studies examined these differences, one using a survey,110 the other using the standard gamble to quantify preferences.119 Standard gamble was described briefly in the section on intrapersonal literature. Both studies found differences between patient and physician relative assessments of risks and health states. The lack of concordance carried into preferences to discontinue DMT for given risk levels for serious adverse events, in this case, discontinuing natalizumab for given risk levels for PML.110 Patients had a more negative perception of MS than physicians and were willing to tolerate greater risk of PML. Physicians tended to value health states more highly than patients, and emphasized physical health states, while patients gave greater relative weight to mental health.119 With only six neurologists for the 99 patients in this study, generalizability is low. Further, the MS patients were recently diagnosed and thus had limited experience with their condition. Possibly, the discord between physician and MS patients would have lessened with a more experienced group of long-term MS patients. However, these studies highlight the need for good communication between physician and patient for successful shared decisionmaking.

One study examined communication issues from the perspective of the patient using qualitative interviews of 12 long-term MS patients.120 While the study was not strictly related to DMT use and discontinuation, we include it in this section as a resource for communication based on empirical research. The table of communication tips from that study is recreated in Table 12.

Table 12 Helpful and unhelpful communications in MS

Coping Focus | Helpful Communication | Unhelpful Communication
Managing Fear | Timely, relevant, accurate information | Withholding information Using statistics Sugar coating
Managing Fear | Validating patient experience | Dismissing patient claims
Managing Fear | Planned appointments to discuss test results, ongoing management, and followup | Waiting for referrals and appointments
Taking Charge | Assistance from health care professionals | Feeling alone and isolated in managing MS
Taking Charge | Providing as much information as possible – more is better than less | Inaccurate or outdated information
Taking Charge | Convenient access to medical professionals | Difficulty accessing medical services
Taking Charge | Acknowledging the limits of medical science | Belief that medical science has all the answers
Crafting a Life | MS is only one aspect of their life | MS is their life
Crafting a Life | Validating symptoms | Minimizing symptoms
Crafting a Life | Ongoing interest | Giving up
Crafting a Life | Willingness to learn and explore alternative therapeutic options | Inflexibility in thinking and researching
Crafting a Life | Respecting the patient as a competent and knowledgeable partner | Condescension Platitudes Reprimanding

MS = multiple sclerosis

Table adapted from Thorne, 2004.^120^

### KQ2b Patients' and Providers' Preferences for Participation in Shared Decisionmaking To Discontinue Disease-Modifying Treatments

Literature for this KQ subquestion relates to shared decisionmaking for patients and providers. All but one of the identified studies populate the center box in the shared decisionmaking portion of Figure 1 (reproduced in Figure 6). Table 13 provides information on the five studies addressing shared decisionmaking from the patient side, four addressing the physician side, and a test of a decision aid to improve shared decisionmaking. Study designs included survey questionnaires, experimental psychology, third party observation of physician shared decisionmaking skills, and a randomized controlled trial of the decision aid. Six studies received governmental or nongovernmental funding,95,107,108,113,121,122 four did not report funding,94,106,115,123 and one was unfunded.94

Figure 6 Shared decisionmaking factors

Figure 6 repeats the section of Figure 1 that depicts with 3 boxes the possible decision states from a shared decisionmaking process, including a physician decision that is not concordant with the patient's views, a concordant shared decision, or a patient decision that is not concordant with the physician's views.

Table 13 Included studies for shared decisionmaking literature

| First Author, Year Funder | Study Aim | Population | Design | Study Author Findings
Patient SDM | Baker, 1995^94^ U.S. Not reported | Test if general orientation and length of MS affects interest in and desire for (1) more information about MS, (2) general or specific information | 1. 160 women with MS; 2. 95 women with MS | Survey questionnaire to identify monitors vs. information blunters, comparative tests of; 1. Interest in and amount wanted for 29 MS topics; 2. Relevance of information | - Monitors want both general and specific information from the beginning.; - Blunters want information for some topics only after having MS for period of time.
Patient SDM | Basso, 2010^95^ U.S. Governmental and nongovernmental | Assess whether aspects of neurocognition correspond with understanding treatment disclosures, and if disclosure understanding can be enhanced | Experimental: 36 people with MS; 24 unimpaired, 12 cognitively compromised Control: 16 adult community participants without MS | Experimental psychology lab Measures of new learning, executive function, attention Understanding of treatment disclosures scale. Significance tests and correlations | - Lower new learning and executive function correlated with poor understanding of treatment disclosures; understanding about 60% of control group mean.; - Repetition and cuing improved understanding of cognitively compromised back to the level of control adults; - MS patients without cognitive impairments understood information as well as the control group.
Patient SDM | Giordano, 2008^121^ Italy Nongovernmental | Assess preferences of Italians with MS regarding participating in treatment decisions | 129 people with stable MS, 71% female, 69% RRMS, average EDSS 3.5. | Survey using Control Preference Scale. Sex, age, disease duration, EDSS score, education level, whether on DMT, length of followup time at clinic. | - 61% preferred a collaborative role, 33% passive role, 6% active.; - Sex, age, disease duration, EDSS score, and whether on DMT were not associated with preferred role.; - Those with ≥5 years followup time at the clinic were more likely to prefer passive.
Patient SDM | Hamann,2007^107^ Germany Governmental | Assess if decisionmaking participation preferences vary by chronicity of disease | 1393 German patients with hypertension (164), depression (230), breast cancer (178), Schizophrenia (120) RRMS (105), Minor traumas (596) | Pooled preferences from SDM trials. Examined age, gender, education, diagnosis, and autonomy preference index scale Descriptive and test statistics | - MS patients significantly more likely to have higher preferences for participation than other patient groups (p <0.001)
Patient SDM | Heesen, 2007^108,109,111^ Germany Governmental | Assess decision role preferences and MS risk knowledge | 113 RRMS and 100 PPMS patients randomly selected from MS database | Survey questionnaire (performed during decision aid development) Descriptive and test statistics | - 79% (132/168) prefer an active role in decisionmaking.; - Patients on INF had higher knowledge (risk calculation ability) than those not on INF.; - People who preferred an active role had higher knowledge
Provider SDM | Hamann, 2010^106^ Germany Not reported | Examine how accurately neurologists and psychiatrists can predict patient participation preferences | 203 patients; 102 MS patients, 66% female, mean MS duration 10 years; 101 schizophrenia. 51 providers | Survey questionnaire Autonomy preference index scale. Descriptive and test statistics | - Physicians tended to over predict patient preference for participation; - Physicians correctly predicted 74% of preferences, but agreement between physician and patient was overall poor.; - Participation preferences depended on the physicians' and patients' expertise with MS
Provider SDM | Pietrolongo, 2013^122^ Italy Nongovernmental | Assess physician shared decisionmaking from third party observer and patient perspectives | 88 MS patients, 10 physicians | Audio recordings of first consultations rated using Observing Patient Involvement in Shared Decision Making tool | - Physicians were rated as showing limited skills at patient involvement by both patients and third party observers; patients rated physicians higher than the third party observer.
Provider SDM | Mendel, 2011^115^ Germany Not funded | Examine if physicians influence patients away from their preferred treatment option. | 102 MS patients, 66% female, mean MS duration 10 years | Fictitious clinician recommendation contrary to stated preference Stated choice, satisfaction with choice | - 26% of MS patients followed the physician's advice, but were less satisfied with their choice.
Provider SDM | Lonergan, 2009^123^ Ireland Not reported | Assess utilization of DMT in patients with SPMS and PPMS, and examine approaches by physicians to counsel discontinuation in SPMS | 336 Irish patients with MS living in urban southeast Dublin, and rural counties Wexford and Donegal. 26 neurologists in Europe, North America, and New Zealand | Survey questionnaires to physicians. Patients recruited through clinical services and MS Society, medical chart review for utilization. | - 27% of patients with EDSS >6.5 were using DMT and were PPMS or SPMS, 99% of which were in rural locations.; - 15 physicians made an effort to stop treatment; 2 never stopped prescribing, and 11 generally continued DMT.; - Despite stated preference to stop, most did not insist to avoid affecting the relationship.
Decision Aids | Kasper, 2008^113,114^ Germany Government | Evaluate effects of a patient decision aid to improve achieving a preferred role in decisionmaking and DMT use | 297 MS patients considering or reconsidering DMT. 14% CIS, 53% RRMS, 19% SPMS, 11% PPMS. Recruited from community, consumer advocate group, MS clinic. Experimental: 150, Control: 147 | RCT of evidence-based decision aid. Control received standard treatment information. Outcomes: Achieved participation role preference; treatment choice | - No differences between groups on role preference or treatment choice.; - 50% of patients achieved preferred role. Patients tended to use shared decisionmaking as an actual role.; - 18% of patients reconsidering treatment chose to interrupt treatment.; - Experimental group was more critical of DMT use than control group.

CIS = clinically isolated syndrome; DMT = disease-modifying treatment; EDSS = extended disability scale score; MS = multiple sclerosis; PPMS = primary progressive multiple sclerosis; RCT = randomized controlled trial; RRMS = relapsing remitting multiple sclerosis; SDM = shared decisionmaking; SPMS = secondary progressive multiple sclerosis

#### Key Points

- MS patients may bring different information-seeking orientations to shared decisionmaking (one study).
- Mildly cognitively impaired MS patients show a significantly reduced capacity to understand treatment disclosures, but understanding may be brought back to the level of healthy controls through repetition and recognition cuing (one study).
- The large majority of people with MS prefer a collaborative or active role in treatment decisions (three non-U.S. studies).
- Physicians cannot reliably predict patient preferences for an active participation role and may inadvertently pull patients away from their preferred treatment (two studies).
- Both patient and third party observers rated physicians as showing limited skill at involving patients in shared decisionmaking (one study).
- Providing balanced, evidence-based information alone is not sufficient to alter decisionmaking processes to help patients achieve their preferred participation role (one study).

#### Detailed Discussion

##### Patients in Shared Decisionmaking

Two studies examined information-seeking and information-processing, necessary steps in shared decisionmaking.94,95 The type and timing of information sought by women with MS differed depending on the individual orientation toward information—whether the person was a monitor or blunter of information.94 Monitors prefer a high information input before a stressful event and suffer less psycho-physiological arousal when they have information while blunters prefer less information and suffer more arousal when they have a high information input. A person's tendency toward monitoring or blunting differed according to time from diagnosis: monitors wanted information early while blunters' preference for information that was specific increased with the time they had MS. This was a small study of women with MS, so the applicability of the findings is highly constrained. However, it does suggest that patients bring different orientations to the information search aspect of shared decisionmaking.

Cognitively compromised MS patients had impaired understanding of treatment disclosures in one study using experimental psychology lab methods.95 Cognitively unimpaired MS patients understood treatment disclosures as well as people without MS. Among those with cognitive impairment, probing for understanding, repeating information, and recognition cuing brought understanding performance back to the level of the healthy control group. The cognitively impaired group was relatively small and the impairment was generally mild rather than severe, thus limiting applicability. Yet, the mildly compromised MS patient may be less likely to be recognized as having reduced decisional capacity for informed consent and shared decisionmaking.

Three studies from Italy and Germany examined patient preferences for participating in shared decisionmaking.107,108,121 Overall, the large majority of people with MS preferred an active participatory role in treatment decisions (68% to 79%). People with MS were significantly more likely than people with hypertension, major depression, breast cancer, or schizophrenia to prefer an active role.107 Those who preferred an active role also tended to have higher knowledge regarding risk.108 The applicability of these studies to MS patients in the United States is difficult to judge without U.S. studies for comparison.

##### Physicians in Shared Decisionmaking

Two studies examined physician ability to predict MS patient preferences to participate in treatment decisions. Both studies used the same MS patient population in Germany.106,115 Physicians tended to overestimate patient preference for participation overall, and individual predictions correlated poorly to individual patient preferences.106 In a test using fictitious clinician's recommendations, 26 percent of MS patients followed the fictitious recommendation and chose the treatment option that went against their initial preferences.115 A third study found both third party observers and patients rated physicians as showing limited skill at involving patients in shared decisionmaking.122

One study surveyed an international sample of physicians regarding their experience with discontinuing DMT when it is no longer effective.123 While primarily influenced by absence of relapses and evidence of disease progression, EDSS scores in the 6.0 to 8.0 range were cited as indicators of likely lack of efficacy, although reimbursement policies in several countries were also influential. Most physicians noted the challenge of negotiating discontinuing a DMT that is well-tolerated even if it appeared to the physician to lack efficacy. Physicians tended to defer to patient preferences for discontinuing, noting the importance of a good patient-physician relationship. Several mentioned that patients expressed insecurity with discontinuing.

##### Decision Aids for Shared Decisionmaking

Simply providing patients with balanced information did not in itself alter the decisionmaking process, although providing evidence-based information to MS patients improved assessment of information, with the experimental group more critical of DMTs than the control group.113,114 In one RCT of a decision aid to improve patient achievement of their preferred participation role, MS patients had a high preference rate for active or autonomous decisionmaking roles, 79 percent at baseline and 81 percent at followup in the experimental group. Actual participation roles, however, tended toward shared decisionmaking styles. In an applied context, 27 percent of the patients with stated preferences for autonomy participated at a shared level. No major differences were seen in achieving preferred roles between the intervention and control groups at followup. Across the groups, half of the MS patients reported an actual participation role other than their preferred role.

Patients and assessors were masked as to whether the patient received the decision aid or standard information packet. Patients were asked to not directly discuss the details of the information they received with their physicians. It is not possible to determine if factors related to the masking itself may have resulted in patients feeling constrained in communicating with their physician.