# References

1 Hilas O, Patel P, Lam S. Disease modifying agents for multiple sclerosis. Open Neurol J. May. 2010;4:15-24. [pmid: 21258574].
2 Society NM. Accessed Dec 15, 2014.
3 Hurwitz B. Analysis of current multiple sclerosis registries. Neurology. Jan. 4. 2011;76(1 Suppl 1):S7-13. [pmid: 21205683].
4 Lublin FD, Reingold SC, Cohen JA, et al. Defining the clinical course of multiple sclerosis: the 2013 revisions. Neurology. Jul. 15. 2014;83(3):278-86. [pmid: 24871874].
5 Fisniku LK, Brex PA, Altmann DR, et al. Disability and T2 MRI lesions: a 20-year follow-up of patients with relapse onset of multiple sclerosis. Brain. Mar. 2008;131(Pt 3):808-17. [pmid: 18234696].
6 Nylander A, Hafler DA. Multiple sclerosis. J Clin Invest. Apr. 2. 2012;122(4):1180-8. [pmid: 22466660].
7 Stys PK, Zamponi GW, van Minnen J, et al. Will the real multiple sclerosis please stand up?. Nat Rev Neurosci. Jul. 2012;13(7):507-14. [pmid: 22714021].
8 Corthals AP. Multiple sclerosis is not a disease of the immune system. Q Rev Biol. Dec. 2011;86(4):287-321. [pmid: 22384749].
9 Daumer M, Neuhaus A, Herbert J, et al. Prognosis of the individual course of disease: the elements of time, heterogeneity and precision. J Neurol Sci. Dec. Suppl 1. 2009;287:S50-5. [pmid: 20106349].
10 Filippini G, Del Giovane C, Vacchi L, et al. Immunomodulators and immunosuppressants for multiple sclerosis: a network meta-analysis. Cochrane Database Syst Rev. 2013;6. CD008933. [pmid: 23744561].
11 Weber MS, Menge T, Lehmann-Horn K, et al. Current treatment strategies for multiple sclerosis - efficacy versus neurological adverse effects. Curr Pharm Des. 2012;18(2):209-19. [pmid: 22229582].
12 Sorensen PS, Koch-Henriksen N, Ravnborg M, et al. Immunomodulatory treatment of multiple sclerosis in denmark: a prospective nationwide survey. Mult Scler. Jun. 2006;12(3):253-64. [pmid: 16764337].
13 Lu E, Dahlgren L, Sadovnick A, et al. Perinatal outcomes in women with multiple sclerosis exposed to disease-modifying drugs. Mult Scler. Apr. 2012;18(4):460-7. [pmid: 21914689].
14 De Las Heras V, De Andres C, Tellez N, et al. Pregnancy in multiple sclerosis patients treated with immunomodulators prior to or during part of the pregnancy: a descriptive study in the Spanish population. Mult Scler. Sep. 2007;13(8):981-4. [pmid: 17623725].
15 Finkelsztejn A, Fragoso YD, Ferreira ML, et al. The Brazilian database on pregnancy in multiple sclerosis. Clin Neurol Neurosurg. May. 2011;113(4):277-80. [pmid: 21159421].
16 Portaccio E, Zipoli V, Siracusa G, et al. Long-term adherence to interferon beta therapy in relapsing-remitting multiple sclerosis. Eur Neurol. 2008;59(3-4):131-5. [pmid: 18057899].
17 Sormani MP, Arnold DL, De Stefano N. Treatment effect on brain atrophy correlates with treatment effect on disability in multiple sclerosis. Ann Neurol. 2014;75:43-9. PMID. [pmid: 24006277].
18 Tintore M, Sastre-Garriga J. New treatment measurements for treatment effects on relapses and progression. J Neurol Sci. Nov. 15. 2008;274(1-2):80-3. [pmid: 18822433].
19 Koopman W. Needs assessment of persons with multiple sclerosis and significant others: using the literature review and focus groups for preliminary survey questionnaire development. Axon. Jun. 2003;24(4):10-5. [pmid: 12852337].
20 Moher D, Altman DG, Liberati A, et al. PRISMA statement. Epidemiology. Jan. 2011;22(1):128. author reply. [pmid: 21150360].
21 [computer program]. Version.
22 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-78. [pmid: 21959223].
23 Treadwell JR, Reston JT, Singh S, et al. A framework for “best evidence” approaches in systematic reviews. Quality AfHRa, editor. Methods Research Report Vol AHRQ Publication No. 11-EHC046-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
24 Turner R, Spiegelhalter D, Smith G, et al. Bias modelling in evidence synthesis. J. R. Statis. Soc. A. 2009;172(Part 1):21-47.
25 Kurtzke JF. Rating neurologic impairment in multiple sclerosis: an expanded disability status scale (EDSS). Neurology. Nov. 1983;33(11):1444-52. [pmid: 6685237].
26 Berkman ND, Lohr K, Ansari M, et al. Grading the strength of a body of evidence when assessing health care interventions for the effective health care program of the Agency for Healthcare Research and Quality: An update. 290-2007-10056-I PbtR-UE-bPCuCN, trans. Methods Guide for Comparative Effectiveness Reviews. Vol AHRQ Publication No. 13(14)-EHC 130-EF. November ed. Rockville, MD. Agency for Healthcare Research and Quality. 2013.
27 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies When Comparing Medical Interventions. 2010. December. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=603#2412. AHRQ Publication No. 11-EHC019-EF.
28 Bermel RA, Weinstock-Guttman B, Bourdette D, et al. Intramuscular interferon beta-1a therapy in patients with relapsing-remitting multiple sclerosis: a 15-year follow-up study. Mult Scler. May. 2010;16(5):588-96. [pmid: 20167591].
29 Bermel RA, You X, Foulds P, et al. Predictors of long-term outcome in multiple sclerosis patients treated with interferon. Ann Neurol. Jan. 2013;73(1):95-103. [pmid: 23378325].
30 Ford C, Goodman AD, Johnson K, et al. Continuous long-term immunomodulatory therapy in relapsing multiple sclerosis: results from the 15-year analysis of the US prospective open-label study of glatiramer acetate. Mult Scler. Mar. 2010;16(3):342-50. [pmid: 20106943].
31 Ford CC, Johnson KP, Lisak RP, et al. A prospective open-label study of glatiramer acetate: over a decade of continuous use in multiple sclerosis patients. Mult Scler. Jun. 2006;12(3):309-20. [pmid: 16764344].
32 Johnson KP, Brooks BR, Ford CC, et al. Sustained clinical benefits of glatiramer acetate in relapsing multiple sclerosis patients observed for 6 years. Copolymer 1 Multiple Sclerosis Study Group. Mult Scler. Aug. 2000;6(4):255-66. [pmid: 10962546].
33 Johnson KP, Brooks BR, Ford CC, et al. Glatiramer acetate (Copaxone): comparison of continuous versus delayed therapy in a six-year organized multiple sclerosis trial. Mult Scler. Dec. 2003;9(6):585-91. [pmid: 14664471].
34 Johnson KP, Ford CC, Lisak RP, et al. Neurologic consequence of delaying glatiramer acetate therapy for multiple sclerosis: 8-year data. Acta Neurologica Scandinavica. Jan. 2005;111(1):42-7. [pmid: 15595937].
35 Goodin DS, Reder AT, Ebers GC, et al. Survival in MS: a randomized cohort study 21 years after the start of the pivotal IFN-1b trial. Neurology. Apr. 24. 2012;78(17):1315-22. [pmid: 22496198].
36 Reder AT, Ebers GC, Traboulsee A, et al. Cross-sectional study assessing long-term safety of interferon-beta-1b for relapsing-remitting MS. Neurology. Jun. 8. 2010;74(23):1877-85. [pmid: 20530324].
37 Ebers GC, Reder AT, Traboulsee A, et al. Long-term follow-up of the original interferon-beta1b trial in multiple sclerosis: design and lessons from a 16-year observational study. Clin Ther. Aug. 2009;31(8):1724-36. [pmid: 19808131].
38 Miller A, Spada V, Beerkircher D, et al. Long-term (up to 22 years), open-label, compassionate-use study of glatiramer acetate in relapsing-remitting multiple sclerosis. Mult Scler. May. 2008;14(4):494-9. [pmid: 18208875].
39 Evans C, Tam J, Kingwell E, et al. Long-term persistence with the immunomodulatory drugs for multiple sclerosis: a retrospective database study. Clin Ther. Feb. 2012;34(2):341-50. [pmid: 22296946].
40 Shirani A, Zhao Y, Karim ME, et al. Association between use of interferon beta and progression of disability in patients with relapsing-remitting multiple sclerosis. Jama. Jul. 18. 2012;308(3):247-56. [pmid: 22797642].
41 O'Rourke KE, Hutchinson M. Stopping beta-interferon therapy in multiple sclerosis: an analysis of stopping patterns. Mult Scler. Feb. 2005;11(1):46-50. [pmid: 15732266].
42 O'Rourke K, Walsh C, Antonelli G, et al. Predicting beta-interferon failure in relapsing-remitting multiple sclerosis. Mult Scler. Apr. 2007;13(3):336-42. [pmid: 17439902].
43 Milanese C, Beghi E, Giordano L, et al. A post-marketing study on immunomodulating treatments for relapsing-remitting multiple sclerosis in Lombardia: preliminary results. Neurol Sci. Dec. Suppl 4. 2005;26:S171-3. [pmid: 16388352].
44 Patti F, Pappalardo A, Florio C, et al. Effects of interferon beta-1a and -1b over time: 6-year results of an observational head-to-head study. Acta Neurologica Scandinavica. Apr. 2006;113(4):241-7. [pmid: 16542163].
45 Trojano M, Paolicelli D, Zimatore GB, et al. The IFNbeta treatment of multiple sclerosis (MS) in clinical practice: the experience at the MS Center of Bari, Italy. Neurol Sci. Dec. Suppl 4. 2005;26:S179-82. [pmid: 16388354].
46 Trojano M, Pellegrini F, Fuiani A, et al. New natural history of interferon-beta-treated relapsing multiple sclerosis. Ann Neurol. Apr. 2007;61(4):300-6. [pmid: 17444502].
47 Trojano M, Pellegrini F, Paolicelli D, et al. Real-life impact of early interferon beta therapy in relapsing multiple sclerosis. Ann Neurol. Oct. 2009;66(4):513-20. [pmid: 19847899].
48 Bergamaschi R, Quaglini S, Tavazzi E, et al. Immunomodulatory therapies delay disease progression in multiple sclerosis. Mult Scler. published online. May. 31. 2012:1-9. [pmid: 22653657].
49 Bencsik K, Fuvesi J, Fricska-Nagy Z, et al. Short communication: treatment of relapsing-remitting multiple sclerosis 96 patients with IFN-beta 1b: results of a 6-year follow-up. J Interferon Cytokine Res. Feb. 2006;26(2):96-100. [pmid: 16487029].
50 Carmona O, Casado V, Moral E, et al. Interferon-beta1b in multiple sclerosis: effect on progression of disability and clinical markers of treatment response. Eur Neurol. 2008;60(6):279-84. [pmid: 18824855].
51 Rio J, Nos C, Tintore M, et al. Defining the response to interferon-beta in relapsing-remitting multiple sclerosis patients. Ann Neurol. Feb. 2006;59(2):344-52. [pmid: 16437558].
52 Rio J, Porcel J, Tellez N, et al. Factors related with treatment adherence to interferon beta and glatiramer acetate therapy in multiple sclerosis. Mult Scler. Jun. 2005;11(3):306-9. [pmid: 15957512].
53 Rio J, Tintore M, Nos C, et al. Interferon beta in relapsing-remitting multiple sclerosis. An eight years experience in a specialist multiple sclerosis centre. Journal of Neurology. Jul. 2005;252(7):795-800. [pmid: 15772741].
54 Rio J, Tintore M, Nos C, et al. Interferon beta in secondary progressive multiple sclerosis : daily clinical practice. Journal of Neurology. Jul. 2007;254(7):849-53. [pmid: 17361342].
55 Cunningham A, Gottberg K, von Koch L, et al. Non-adherence to interferon-beta therapy in Swedish patients with multiple sclerosis. Acta Neurologica Scandinavica. Mar. 2010;121(3):154-60. [pmid: 20055771].
56 Tedeholm H, Lycke J, Skoog B, et al. Time to secondary progression in patients with multiple sclerosis who were treated with first generation immunomodulating drugs. Mult Scler. 2013;19(6):765-74. [pmid: 23124789].
57 Debouverie M, Moreau T, Lebrun C, et al. A longitudinal observational study of a cohort of patients with relapsing-remitting multiple sclerosis treated with glatiramer acetate. Eur J Neurol. Nov. 2007;14(11):1266-74. [pmid: 17956447].
58 Mesaros S, Stojsavljevic N, Dujmovic-Basuroski I, et al. Long-term adherence to interferon-beta treatment in a cohort of RRMS patients in Belgrade, Serbia. Clin Neurol Neurosurg. Oct. 2012;114(8):1145-8. [pmid: 22425462].
59 Confavreux C, Li DK, Freedman MS, et al. Long-term follow-up of a phase 2 study of oral teriflunomide in relapsing multiple sclerosis: safety and efficacy results up to 8.5 years. Mult Scler. Sep. 2012;18(9):1278-89. [pmid: 22307384].
60 Kappos L, Freedman MS, Polman CH, et al. Long-term effect of early treatment with interferon beta-1b after a first clinical event suggestive of multiple sclerosis: 5-year active treatment extension of the phase 3 BENEFIT trial. Lancet neurol. Nov. 2009;8(11):987-97. [pmid: 19748319].
61 Gold R, Rieckmann P, Chang P, et al. The long-term safety and tolerability of high-dose interferon beta-1a in relapsing-remitting multiple sclerosis: 4-year data from the PRISMS study. Eur J Neurol. Aug. 2005;12(8):649-56. [pmid: 16053475].
62 Uitdehaag B, Constantinescu C, Cornelisse P, et al. Impact of exposure to interferon beta-1a on outcomes in patients with relapsing-remitting multiple sclerosis: Exploratory analyses from the PRISMS long-term follow-up study. Therapeutic Advances in Neurological Disorders. 2011;4(1):3-14. [pmid: 21339904].
63 Prisms Study Group, the University of British Columbia MSMRIAG. PRISMS-4: Long-term efficacy of interferon-beta-1a in relapsing MS. [Erratum appears in Neurology 2001 Sep 25;57(6):1146]. Neurology. Jun. 26. 2001;56(12):1628-36. [pmid: 11425926].
64 Barbero P, Verdun E, Bergui M, et al. High-dose, frequently administered interferon beta therapy for relapsing-remitting multiple sclerosis must be maintained over the long term: the interferon beta dose-reduction study. J Neurol Sci. Jul. 15. 2004;222(1-2):13-9. [pmid: 15240190].
65 Kaufman MD, Lee R, Norton HJ. Course of relapsing-remitting multiple sclerosis before, during and after natalizumab. Mult Scler. Apr. 2011;17(4):490-4. [pmid: 21135017].
66 Miravalle A, Jensen R, Kinkel RP. Immune reconstitution inflammatory syndrome in patients with multiple sclerosis following cessation of natalizumab therapy. Archives of Neurology. Feb. 2011;68(2):186-91. [pmid: 20937940].
67 O'Connor P, Devonshire V, Canadian Network of MSC. The use of disease-modifying agents in multiple sclerosis--by the Canadian Network of MS Clinics. Can J Neurol Sci. May. 2008;35(2):127-32. [pmid: 18574923].
68 Havla J, Gerdes LA, Meinl I, et al. De-escalation from natalizumab in multiple sclerosis: recurrence of disease activity despite switching to glatiramer acetate. Journal of Neurology. Sep. 2011;258(9):1665-9. [pmid: 21431380].
69 Havla J, Tackenberg B, Hellwig K, et al. Fingolimod reduces recurrence of disease activity after natalizumab withdrawal in multiple sclerosis. Journal of Neurology. May. 2013;260(5):1382-7. [pmid: 23266894].
70 Kerbrat A, Le Page E, Leray E, et al. Natalizumab and drug holiday in clinical practice: an observational study in very active relapsing remitting multiple sclerosis patients. J Neurol Sci. Sep. 15. 2011;308(1-2):98-102. [pmid: 21665227].
71 Rossi S, Motta C, Studer V, et al. Effect of glatiramer acetate on disease reactivation in MS patients discontinuing natalizumab. Eur J Neurol. Jan. 2013;20(1):87-94. [pmid: 22741530].
72 Sorensen PS, Koch-Henriksen N, Petersen T, et al. Recurrence or rebound of clinical relapses after discontinuation of natalizumab therapy in highly active MS patients. Journal of Neurology. 2014;261(6):1170-7. [pmid: 24728334].
73 Jokubaitis VG, Li V, Kalincik T, et al. Fingolimod after natalizumab and the risk of short-term relapse. Neurology. Apr. 8. 2014;82(14):1204-11. [pmid: 24610329].
74 Borriello G, Prosperini L, Mancinelli C, et al. Pulse monthly steroids during an elective interruption of natalizumab: a post-marketing study. Eur J Neurol. May. 2012;19(5):783-7. [pmid: 22054236].
75 Borriello G, Prosperini L, Marinelli F, et al. Observations during an elective interruption of natalizumab treatment: a post-marketing study. Mult Scler. Mar. 2011;17(3):372-5. [pmid: 21148264].
76 O'Connor PW, Goodman A, Kappos L, et al. Disease activity return during natalizumab treatment interruption in patients with multiple sclerosis. Neurology. May. 31. 2011;76(22):1858-65. [pmid: 21543733].
77 Sandberg-Wollheim M, Alteri E, Moraga MS, et al. Pregnancy outcomes in multiple sclerosis following subcutaneous interferon beta-1a therapy. Mult Scler. Apr. 2011;17(4):423-30. [pmid: 21220368].
78 Sandberg-Wollheim M, Frank D, Goodwin TM, et al. Pregnancy outcomes during treatment with interferon beta-1a in patients with multiple sclerosis. Neurology. Sep. 27. 2005;65(6):802-6. [pmid: 16093457].
79 Amato MP, Portaccio E, Ghezzi A, et al. Pregnancy and fetal outcomes after interferon- exposure in multiple sclerosis. Neurology. Nov. 16. 2010;75(20):1794-802. [pmid: 21079181].
80 Patti F, Cavallaro T, Lo Fermo S, et al. Is in utero early-exposure to interferon beta a risk factor for pregnancy outcomes in multiple sclerosis?. Journal of Neurology. Aug. 2008;255(8):1250-3. [pmid: 18677640].
81 Giannini M, Portaccio E, Ghezzi A, et al. Pregnancy and fetal outcomes after Glatiramer Acetate exposure in patients with multiple sclerosis: a prospective observational multicentric study. BMC Neurol. 2012;12:124. [pmid: 23088447].
82 Boskovic R, Wide R, Wolpin J, et al. The reproductive effects of beta interferon therapy in pregnancy: A longitudinal cohort. Neurology. 2005;65(6):807-11. [pmid: 16186517].
83 Hellwig K, Haghikia A, Gold R. Pregnancy and natalizumab: results of an observational study in 35 accidental pregnancies during natalizumab treatment. Mult Scler. Aug. 2011;17(8):958-63. [pmid: 21613333].
84 Hellwig K, Haghikia A, Rockhoff M, et al. Multiple sclerosis and pregnancy: experience from a nationwide database in Germany. Therapeutic advances in neurological disorders. 2012;5(5):247-53. [pmid: 22973421].
85 Weber-Schoendorfer C, Schaefer C. Multiple sclerosis, immunomodulators, and pregnancy outcome: a prospective observational study. Mult Scler. Sep. 2009;15(9):1037-42. [pmid: 19692433].
86 Fragoso YD, Boggild M, MacIas-Islas MA, et al. The effects of long-term exposure to disease-modifying drugs during pregnancy in multiple sclerosis. Clinical Neurology and Neurosurgery. 2013;115(2):154-9. [pmid: 22633835].
87 Finkelsztejn A, Brooks JB, Paschoal FM Jr., et al. What can we really tell women with multiple sclerosis regarding pregnancy? A systematic review and meta-analysis of the literature. Bjog. Jun. 2011;118(7):790-7. [pmid: 21401856].
88 Hellwig K, Brune N, Haghikia A, et al. Reproductive counselling, treatment and course of pregnancy in 73 German MS patients. Acta Neurologica Scandinavica. Jul. 2008;118(1):24-8. [pmid: 18205883].
89 Regan L, Rai R. Epidemiology and the medical causes of miscarriage. Best Pract Res Clin Obstet Gynaecol. Oct. 2000;14(5):839-54. [pmid: 11023804].
90 Lu E, Wang BW, Guimond C, et al. Disease-modifying drugs for multiple sclerosis in pregnancy: a systematic review. Neurology. Sep. 11. 2012;79(11):1130-5. [pmid: 22933738].
91 Fragoso YD, Fragoso SD, Finkelsztejn A, et al. Systematic review versus internet search: considerations about availability and reliability of medical information regarding pregnancy in women with multiple sclerosis. Rev. Dec. 2012;15(4):896-903. [pmid: 23515783].
92 Cree BA. Update on reproductive safety of current and emerging disease-modifying therapies for multiple sclerosis. Mult Scler. Jun. 2013;19(7):835-43. [pmid: 23319073].
93 Houtchens MK, Kolb CM. Multiple sclerosis and pregnancy: therapeutic considerations. Journal of Neurology. May. 2013;260(5):1202-14. [pmid: 22926165].
94 Baker LM. A new method for studying patient information needs and information-seeking patterns. Top Health Inf Manage. Nov. 1995;16(2):19-28. [pmid: 10152475].
95 Basso MR, Candilis PJ, Johnson J, et al. Capacity to make medical treatment decisions in multiple sclerosis: a potentially remediable deficit. J Clin Exp Neuropsychol. Dec. 2010;32(10):1050-61. [pmid: 20446143].
96 Berger BA, Hudmon KS, Liang H. Predicting treatment discontinuation among patients with multiple sclerosis: application of the transtheoretical model of change. J Am Pharm Assoc (2003). Jul-Aug. 2004;44(4):445-54. [pmid: 15372865].
97 Daugherty KK, Butler JS, Mattingly M, et al. Factors leading patients to discontinue multiple sclerosis therapies. J Am Pharm Assoc (2003). May-Jun. 2005;45(3):371-5. [pmid: 15991759].
98 Dor A, Lage MJ, Tarrants ML, et al. Cost sharing, benefit design, and adherence: the case of multiple sclerosis. Adv Health Econ Health Serv Res. 2010;22:175-93. [pmid: 20575233].
99 Gleason PP, Starner CI, Gunderson BW, et al. Association of prescription abandonment with cost share for high-cost specialty pharmacy medications. J Manage Care Pharm. Oct. 2009;15(8):648-58. [pmid: 19803554].
100 Johnson FR, Van Houtven G, Ozdemir S, et al. Multiple sclerosis patients' benefit-risk preferences: serious adverse event risks versus treatment efficacy. Journal of Neurology. Apr. 2009;256(4):554-62. [pmid: 19444531].
101 Prosser LA, Kuntz KM, Bar-Or A, et al. Patient and community preferences for treatments and health states in multiple sclerosis. Mult Scler. Jun. 2003;9(3):311-9. [pmid: 12814182].
102 Boeije HR, Janssens AC. ‘It might happen or it might not’: how patients with multiple sclerosis explain their perception of prognostic risk. Soc Sci Med. Aug. 2004;59(4):861-8. [pmid: 15177841].
103 Janssens AC, de Boer JB, van Doorn PA, et al. Expectations of wheelchair-dependency in recently diagnosed patients with multiple sclerosis and their partners. Eur J Neurol. May. 2003;10(3):287-93. [pmid: 12752403].
104 Visser LH, van der Zande A. Reasons patients give to use or not to use immunomodulating agents for multiple sclerosis. Eur J Neurol. Nov. 2011;18(11):1343-9. [pmid: 21496180].
105 Bischoff C, Schreiber H, Bergmann A. Background information on multiple sclerosis patients stopping ongoing immunomodulatory therapy: A multicenter study in a community-based environment. Journal of Neurology. 2012;259(11):2347-53. [pmid: 22527237].
106 Hamann J, Mendel R, Schebitz M, et al. Can psychiatrists and neurologists predict their patients' participation preferences?. J Nerv Ment Dis. Apr. 2010;198(4):309-11. [pmid: 20386262].
107 Hamann J, Neuner B, Kasper J, et al. Participation preferences of patients with acute and chronic conditions. Health Expectations: An International Journal of Public Participation in Health Care & Health Policy. Dec. 2007;10(4):358-63. [pmid: 17986072].
108 Heesen C, Kasper J, Kopke S, et al. Informed shared decision making in multiple sclerosis--inevitable or impossible?. J Neurol Sci. Aug. 15. 2007;259(1-2):109-17. [pmid: 17400253].
109 Heesen C, Kasper J, Segal J, et al. Decisional role preferences, risk knowledge and information interests in patients with multiple sclerosis. Mult Scler. Dec. 2004;10(6):643-50. [pmid: 15584489].
110 Heesen C, Kleiter I, Nguyen F, et al. Risk perception in natalizumab-treated multiple sclerosis patients and their neurologists. Mult Scler. Dec. 2010;16(12):1507-12. [pmid: 20826527].
111 Heesen C, Kopke S, Richter T, et al. Shared decision making and self-management in multiple sclerosis--a consequence of evidence. [Erratum appears in J Neurol. 2008 Feb;255(2):309-10]. Journal of Neurology. May. Suppl 2. 2007;254:II116-21. [pmid: 17503119].
112 Kasper J, Kopke S, Fischer K, et al. Applying the theory of planned behaviour to multiple sclerosis patients' decisions on disease modifying therapy--questionnaire concept and validation. BMC Med Inf Decis Mak. 2012;12:60. [pmid: 22747904].
113 Kasper J, Kopke S, Muhlhauser I, et al. Evidence-based patient information about treatment of multiple sclerosis--a phase one study on comprehension and emotional responses. Patient Educ Couns. Jul. 2006;62(1):56-63. [pmid: 16098706].
114 Kasper J, Kopke S, Muhlhauser I, et al. Informed shared decision making about immunotherapy for patients with multiple sclerosis (ISDIMS): a randomized controlled trial. Eur J Neurol. Dec. 2008;15(12):1345-52. [pmid: 19049552].
115 Mendel R, Traut-Mattausch E, Frey D, et al. Do physicians' recommendations pull patients away from their preferred treatment options?. Health Expect. Mar. 2011;15(1):23-31. [pmid: 21323824].
116 Köpke S, Solari A, Khan F, et al. Information provision for people with multiple sclerosis. John Wiley & Sons, Ltd. 2014. Available at: www.onlinelibrary.wiley.com.
117 Grytten N, Aarseth J, Espeset K, et al. Stoppers and non-starters of disease-modifying treatment in multiple sclerosis. Acta Neurologica Scandinavica. Feb. 2013;127(2):133-40. [pmid: 22924678].
118 Meyniel C, Spelman T, Jokubaitis VG, et al. Country, sex, EDSS change and therapy choice independently predict treatment discontinuation in multiple sclerosis and clinically isolated syndrome. PLoS ONE. 2012;7(6):e38661. [pmid: 22768046].
119 Kremenchutzky M, Walt L. Perceptions of health status in multiple sclerosis patients and their doctors. The Canadian Journal of Neurological Sciences. Le Journal Canadien Des Sciences Neurologiques. Mar. 2013;40(2):210-8.
120 Thorne S, Con A, McGuinness L, et al. Health care communication issues in multiple sclerosis: an interpretive description. Qual Health Res. Jan. 2004;14(1):5-22. [pmid: 14725173].
121 Giordano A, Mattarozzi K, Pucci E, et al. Participation in medical decision-making: attitudes of Italians with multiple sclerosis. J Neurol Sci. Dec. 15. 2008;275(1-2):86-91. [pmid: 18786682].
122 Pietrolongo E, Giordano A, Kleinefeld M, et al. Decision-making in multiple sclerosis consultations in Italy: third observer and patient assessments. PLoS ONE. 2013;8(4):e60721. [pmid: 23565270].
123 Lonergan R, Kinsella K, Duggan M, et al. Discontinuing disease-modifying therapy in progressive multiple sclerosis: can we stop what we have started?. Mult Scler. Dec. 2009;15(12):1528-31. [pmid: 19995848].
124 Torrance G. Measurement of health state utilities for economic approaisl. Journal of Health Economics. 1985;5(1-30).
125 Fishbein m, Ajzen I. Belief, attitude, intention and behaviour: An introduction to theory and research. Reading, MA. Addison-Wesley. 1975.
126 Prochaska J, Velicer W. The transtheoretical model of health behavior change. American Journal of Health Promotion. Sep-Oct. 1997;12(1):38-48. [pmid: 10170434].
127 La Mantia L, Vacchi L, Rovaris M, et al. Interferon beta for secondary progressive multiple sclerosis: a systematic review. Journal of Neurology, Neurosurgery and Psychiatry. 2013;84(4):420-6. [pmid: 22952326].
128 FDA. Accessed Dec 15, 2014.
129 Kind P, Dolan P. The effect of past and present illness experience of the valuations of health states. Medical Care. April. 1995;33(4 Suppl):AS255-63. [pmid: 7723454].
130 Sackett D, Torrance G. The utility of different health states as perceived by the general public. Journal of Chronic Disease. 1978;31(11):697-704. [pmid: 730825].
131 Ubel P, Loewenstein G, Schwartz N, et al. Misimagining the unimaginable: the disability paradox and health care decision making. Health Psychology. Jul. 2005;24(4 Suppl):S57-62. [pmid: 16045420].
132 Dolan P. Addressing misconceptions in valuing health. Expert Rev Parmacoecon Outcomes Res. Feb. 2013;13(1):1-3. [pmid: 23402439].
133 Fischer J, LaRocca N, Miller D, et al. Recent developments in the assessment of quality of life in multiple sclerosis (MS). Mult Scler. Aug. 1999;5(4):251-9. [pmid: 10467384].
134 Cella D, Dineen K, Arnason B, et al. Validation of the functional assessment of multiple sclerosis quality of life instrument. Neurology. Jul. 1996;47(1):129-39. [pmid: 8710066].
135 Vickrey B, Hays R, Harooni R, et al. A health-related quality of life measure for multiple sclerosis. Qual Life Res. June. 1995;4(3):187-206. [pmid: 7613530].
136 Prosser L, Kuntz KM, Bar-Or A, et al. Cost-effectiveness of interferon beta-1a, interferon beta-1b, and glatiramer acetate in newly diagnosed non-primary progressive multiple sclerosis. Value Health. 2004;7(5):554-68. [pmid: 15367251].
137 Thompson J, Noyes K, Dorsey E, et al. Quantitative risk-benefit analysis of natalizumab. Neurology. 2008;71(5):357-64. [pmid: 18663181].
138 Tappenden P, McCabe C, Chilcott J, et al. Cost-effectiveness of disease-modifying therapies in the management of multiple sclerosis for the Medicare population. Value Health. Jul-Aug. 2009;12(5):657-65. [pmid: 19508662].
139 Parkin D, McNamee P, Jacoby A, et al. A cost-utility analysis of interferon beta for multiple sclerosis. Health Technol Assess. 1998;2(4):iii-54. [pmid: 9580870].
140 Kendrick M, Johnson KI. Long-term treatment of multiple sclerosis with interferon-beta may be cost effective. Pharmacoeconomics. Jul. 2000;18(1):45-53. [pmid: 11010603].
141 Earnshaw SR, Graham J, Oleen-Burkey M, et al. Cost effectiveness of glatiramer acetate and natalizumab in relapsing-remitting multiple sclerosis. Appl Health Econ Health Policy. 2009;7(2):91-108. [pmid: 19731967].
142 Chilcott J, McCabe C, Tappenden P, et al. Modelling the cost effectiveness of interferon beta and glatiramer acetate in the management of multiple sclerosis. Commentary: evaluating disease modifying treatments in multiple sclerosis. BMJ. Mar. 8. 2003;326(7388):522. discussion. [pmid: 12623909].
143 Casado V, Martinez-Yelamos S, Martinez-Yelamos A, et al. Direct and indirect costs of Multiple Sclerosis in Baix Llobregat (Catalonia, Spain), according to disability. BMC Health Serv Res. 2006;6:143. [pmid: 17078879].
144 Brown MG, Kirby S, Skedgel C, et al. How effective are disease-modifying drugs in delaying progression in relapsing-onset MS?. Neurology. Oct. 9. 2007;69(15):1498-507. [pmid: 17699802].
145 Bell C, Graham J, Earnshaw S, et al. Cost-effectiveness of four immunomodulatory therapies for relapsing-remitting multiple sclerosis: a Markov model based on long-term clinical data. J Manage Care Pharm. Apr. 2007;13(3):245-61. [pmid: 17407391].
146 Becker RV 3rd, Dembek C. Effects of cohort selection on the results of cost-effectiveness analysis of disease-modifying drugs for relapsing-remitting multiple sclerosis. J Manage Care Pharm. Jun. 2011;17(5):377-81. [pmid: 21657808].
147 Bakhshai J, Bleu-Laine R, Jung M, et al. The cost effectiveness and budget impact of natalizumab for formulary inclusion. J Med Econ. Mar. 2010;13(1):63-9. [pmid: 20028199].
148 Project AC. Opt-Up Program and Clinical Study. Dec. 15. 2014.
149 National Institute for Health and Care Excellence (NICE). Multiple sclerosis--beta interferon and glatiramer acetate. Technology appraisal 32. www.nice.org.uk/Guidance/TA32. July 31, 2013.
150 Multiple Sclerosis Trust. Information, education, research and support. www.mstrust.org.uk/atoz/risk-sharing-scheme.jsp. July 26, 2014.
151 Boggild M, Palace J, Barton P, et al. Multiple sclerosis Risk-sharing Scheme: two year results of clinical cohort study with historical comparator. BMJ. Dec. 2. 2009;339:b4677. [pmid: 19955128].
152 Palace J, Bregenzer T, Tremlett H, et al. UK multiple sclerosis risk-sharing scheme: a new natural history dataset and an improved Markov model. BMJ Open. 2014;4(1).
153 Auto M. S. group. Auto MS project. Dec. 15. 2014.