# Methods

The methods for this review follow the methods established for the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program. Key Question (KQ) 1 uses methods suggested in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (available at www.effectivehealthcare.ahrq.gov). Since KQ2 was not amenable to usual comparative effectiveness review (CER), we approached KQ2 using Technical Brief methodology. This section focuses on the elements of the protocol; certain methods map to the PRISMA checklist.20 All methods and analyses were determined a priori.

## Topic Refinement and Review Protocol

Initially a panel of key informants comprised of MS researchers, clinicians, consumer advocates, and consumers gave input on the Key Questions (KQs). The draft KQs were then posted for public comment from May 31, 2013, through June 30, 2013, and revised as needed. We then drafted a protocol for the review and recruited a panel of technical experts to provide high-level content and methodological expertise during the development of the review. The Key Informants and members of the Technical Expert Panel (TEP) were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts. Any potential conflicts of interest were balanced or mitigated. Neither key informants nor members of the TEP performed analysis of any kind, nor did any of them contribute to the writing of this report. Members of the TEP were invited to provide feedback on an initial draft of the review protocol, which was then refined based on their input, reviewed by AHRQ, and posted for public access at the AHRQ Effective Health Care Website.

### Role of the AHRQ Task Order Officer

The Task Order Officer (TOO) was responsible for overseeing all aspects of this project. The TOO helped to develop a common understanding among all parties involved in the project, resolved questions and ambiguities, and addressed our queries regarding the scope and processes of the project. The TOO reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## Analytic Framework

Figure 2 provides an analytic framework describing the treatment path and long-term benefits and harms of continuing versus discontinuing disease-modifying treatment for KQ1. The conceptual framework in Figure 1 provides a conceptual basis for KQ2 literature.

Figure 2 Analytic framework for discontinuing disease-modifying treatments for MS

DMT = disease-modifying treatment; KQ = Key Question; MS = multiple sclerosis

Figure 2 depicts key question 1 within the context of PICOTS described in the previous section. In general, the figure illustrates how disease modifying treatments may result in intermediate outcomes such as lesions detected or number of patients treated with steriods and/or long-term outcomes such as relapse rates or change in disability. For key question 1, treatments specifically means continuation versus discontinuation of long term immunomodulating or immunosoppressive treatments.

## Literature Search Strategy

### Search Strategy

We used bibliographic database searching to identify previous randomized controlled trials (RCTs) and observational studies published from 1990 to August 2014 for studies enrolling adults with clinically isolated syndrome (CIS) or multiple sclerosis (MS). Relevant bibliographic databases for this topic include MEDLINE®, the Cochrane Central Register of Controlled Trials (CENTRAL), PsychInfo®, and Scopus. Our search strategy appears in Appendix A. The search strategy used relevant Medical Subject Headings and natural language terms to find studies on the topic. The concept search was supplemented with filters designed to select experimental designs. Bibliographic database searches were supplemented with backward citation searches of highly relevant systematic reviews.

We conducted additional grey literature searching to identify relevant completed and ongoing studies. Relevant grey literature resources include trial registries and FDA databases. We searched ClinicalTrials.gov, the International Controlled Trials Registry Platform (ICTRP), and Health Services Research Projects in Progress (HSRProj) for observational literature. Scientific information packet (SIP) letters and emails were sent to 11 identified relevant industry stakeholders requesting submission of published and unpublished information on their product(s). Four submissions were subsequently received and reviewed. Grey literature search results were used to identify studies, outcomes, and analyses not reported in the published literature that may further inform findings for KQs. Since we did not find RCTs of sufficient length to be included in this review, we were not able to assess publication and reporting bias using the grey literature.

### Inclusion and Exclusion Criteria

We included studies based on the PICOTS (population, intervention, comparator, outcomes, timing, setting) framework outlined in Table 2 and further publication or study characteristics outlined in Table 3.

Table 2 Review PICOTS

PICOT | Included | Excluded
Population | Adults with CIS, RRMS, SPMS, PPMS, or PRMS using FDA-approved DMTs | Pediatric MS patients
Interventions used in long-term studies assessing discontinuing or continuing DMTs | DMTs IFNbeta-1a, IFNbeta 1b, glatiramer acetate, natalizumab, teriflunomide, fingolimod | Mitoxantrone – it has a lifetime use limit, so ultimately discontinuing is not a choice. (Dimethyl fumarate has not been approved long enough to generate long-term data. Alemtuzumab was approved too late for inclusion in this review.)
Comparator groups used in long-term studies assessing discontinuing or continuing DMTS | Patients who received placebo, FDA-approved DMTS, or patients who did not receive any DMT. | DMTs not FDA-approved
Outcomes and Concepts/Topics of Interest | KQ1 Patient-centered benefits compared with baseline: reduction in annualized relapse rate (at least one relapse); change in disability, change in EDSS, disease progression (determined by functional assessment); time to sustained disease progression Any reported adverse events Any reported reason for discontinuing treatment | KQ 1 Intermediate outcomes Exception: MRI as intermediate outcome exclusion was relaxed for patients discontinuing natalizumab due to changes in risk of PML, since the time frame was within the short-term 2-3 window.
Outcomes and Concepts/Topics of Interest | KQ2 Individuals' attitudes, values, preferences for discontinuing treatments and health states Perceptions of risk and seriousness of health states Factors and processes patients with MS and clinicians use in shared decisionmaking | KQ2 Adherence to treatment plan
Timing | Treatment and followup must be greater than 3 years. Exception: timing was relaxed for:; - Women considering pregnancy or are pregnant; - Patients discontinuing natalizumab due to changes in risk of PML
Setting | Outpatient

CIS = clinically isolated syndrome; DMT = disease-modifying treatment; EDSS = Expanded Disability Status Scale; FDA = U.S. Food and Drug Administration; IV = intravenous; MS = multiple sclerosis; PICOTS = population, intervention, comparator, outcomes, timing, setting; PML = progressive multifocal leukoencephalopathy; PPMS = primary progressive multiple sclerosis; PRMS = progressive relapsing multiple sclerosis; RRMS = relapsing-remitting multiple sclerosis; SPMS = secondary progressive multiple sclerosis

Table 3 Study inclusion criteria

Category | Criteria for Inclusion
Study Enrollment | Studies that enrolled adults with CIS, RRMS, SPMS, PPMS, or PRMS
Study Design | RCTs, nonrandomized controlled trials, prospective and retrospective cohort studies, case control studies, and case series were included for each population and treatment option.
Time of Publication | 1990 forward. FDA-approved disease-modifying drugs were only available in the U.S. after 1993.
Study Quality | All studies that met inclusion criteria were screened for eligibility. Studies that did not adequately report study information to allow abstraction of treatment and followup duration or that had indeterminable numerators and denominators for outcomes and adverse event were excluded.
Language of Publication | English language

CIS = clinically isolated syndrome; FDA = U.S. Food and Drug Administration; PPMS = primary progressive multiple sclerosis; PRMS = progressive relapsing multiple sclerosis; RCT = randomized controlled trial; RRMS = relapsing-remitting multiple sclerosis; SPMS = secondary progressive multiple sclerosis

### Study Selection

Bibliographic database search results were exported to EndNote21 for screening studies relevant to our PICOTS framework and study-specific criteria. Titles and abstracts were reviewed by two independent investigators to identify studies meeting PICOTS framework and inclusion/exclusion criteria. All studies identified as relevant by either investigator underwent full-text screening. Two independent investigators screened full text to determine if inclusion criteria were met. Differences in screening decisions were resolved by consultation between investigators and, if necessary, a third investigator. We documented the inclusion and exclusion status of citations undergoing full-text screening. A bibliography of studies excluded at full text, and their reasons for exclusion, is provided in Appendix B.

### Data Extraction

Studies that met inclusion criteria were distributed among investigators for data abstraction and risk of bias assessment. Two investigators abstracted relevant study, population demographic, and outcomes data. Data fields included author; year of publication; setting, subject inclusion and exclusion criteria; and study design characteristics. For KQ1, we also abstracted intervention and control characteristics (intervention components, timing, frequency, duration); followup duration; participant baseline demographics; type of CIS or MS, MS severity; descriptions and results of outcomes and adverse effects; reasons for discontinuation; and study funding source. Studies that only reported long-term benefits and harms aggregated across multiple disease-modifying treatments (DMTs) were not abstracted. Such studies were accounted for, however, in the article flow-diagram and references are made available. Similarly, studies that did not meet minimum quality levels, or had incomplete reporting to allow analysis, were also accounted for and references made available. Evidence tables are provided in Appendix C.

For KQ2, we abstracted study aims, characteristics, and study findings. Relevant data were extracted directly into summary tables. Summary tables were reviewed and verified for accuracy by a second investigator.

## Risk of Bias Assessment of Individual Studies

Because we found only observational literature for this review, we developed an instrument for assessing risk of bias for observational studies using the RTI Observational Studies Risk of Bias and Precision Item Bank for KQ1.^22^ We selected items most relevant in assessing risk of bias for this topic, including participant selection, ascertainment, attrition, performance, and appropriateness of analytic methods.

Overall summary risk of bias assessments for each individual study were classified as low, moderate, or high based upon the collective risk of bias inherent in each domain and confidence that the results are believable given the study's limitations. Two investigators independently assessed the studies for risk of bias and consulted to reconcile any discrepancies. When agreement was not reached through consultation, a third party was consulted to reconcile the summary judgment. Information about risk of bias for individual studies is available in Appendix D. Following Technical Brief methods, risk of bias was not assessed for KQ2.

## Data Synthesis

For KQ1, we summarized the results into evidence tables and qualitatively synthesized evidence for specific disease-modifying medications and unique population, duration of DMT, length of study followup, and outcomes combinations. Studies were grouped by length of followup to examine changes over time, if any, in outcomes and reasons for discontinuing disease-modifying treatments. We used the best of the available evidence provided by the identified observational literature.23 Our literature search found no RCTs of sufficient length and significant numbers of observational studies, and many observational studies were found on preliminary examination to have high risk of bias. So while all identified articles underwent abstraction, only the best evidence, based on those studies closest to an “ideal” study design24 (those studies with the lowest risk of bias) are included in the evidence synthesis.

We synthesized data on several outcomes. The Expanded Disability Status Scale (EDSS) is an ordinal measure assigned by clinical observation, with scores ranging from 0 (no evident disability) to 10 (death).25 The patient remains at a given score level until enough functional declines are observed to move one step on the scale; for example, from 4.0 to 4.5. A score of 4.5 indicates changes in a person's mobility. A score of 6.5 indicates a person requires bilateral and generally constant assistance (canes, crutches, braces, walker, or people) to walk 20 meters without resting. Changes in EDSS are commonly used to calculate change in disability or progression of disease. Other measures included changes in the annual or annualized relapse rates from baseline.

For KQ2, we summarized the results into evidence tables and conducted a qualitative synthesis. We grouped the literature by mapping the included studies to the conceptual framework (Figure 1) and analyzed the study findings for emergent patterns for patient perspectives, clinician perspectives, and clinician/patient interpersonal interactions.

## Strength of the Body of Evidence

The overall strength of evidence for select outcomes for KQ1 (relapse rate, change in disability, progression of disease, time to sustained disease progression) within each comparison were evaluated based on four required domains: 1) study limitations (internal validity); 2) directness (single, direct link between intervention and outcome); 3) consistency (similarity of effect direction and size); and 4) precision (degree of certainty around an estimate).26 A fifth domain, reporting bias, was assessed when strength of evidence based upon the first four domains was moderate or high.26 Based on study design and conduct, risk of bias was rated as low, medium, or high. Consistency was rated as consistent, inconsistent, or unknown/not applicable (e.g., single study). Directness was rated as either direct or indirect. Precision was rated as precise or imprecise. Other factors that may be considered in assessing strength of evidence include dose-response relationship, the presence of confounders, and strength of association. Based on these factors, the overall evidence for each outcome was rated as:26

- High: Very confident that estimate of effect lies close to true effect. Few or no deficiencies in body of evidence, findings believed to be stable.
- Moderate: Moderately confident that estimate of effect lies close to true effect. Some deficiencies in body of evidence; findings likely to be stable, but some doubt.
- Low: Limited confidence that estimate of effect lies close to true effect; major or numerous deficiencies in body of evidence. Additional evidence necessary before concluding that findings are stable or that estimate of effect is close to true effect.
- Insufficient: No evidence, unable to estimate an effect, or no confidence in estimate of effect. No evidence is available or the body of evidence precludes judgment.

Strength of evidence was not assessed for KQ2. This KQ was approached in a hypothesis-generating manner. Following Technical Brief methods, strength of evidence was not assessed for KQ2.

## Applicability

Applicability of studies was determined according to the PICOTS framework. Study characteristics that may affect applicability include, but are not limited to, type of MS or CIS, unobserved differences in patient preferences, or country within which treatment is provided, given differences in international regulations and treatment preferences.27