# Introduction

## Background

Since the efficacy of DMTs has been recently reported elsewhere, the goal of this report was to address those patients who have used DMT for prolonged periods. The report presents the state of the science that helps inform the decision to continue or discontinue DMTs and the place that shared decisionmaking by patient and physicians has in such situations.

### Condition

Multiple sclerosis (MS) is a variably debilitating disease characterized by demyelination (deterioration of the protective myelin sheaths covering nerve cell processes in the brain and spinal cord) and axon loss within the central nervous system. The lesions created by the myelin destruction and resulting scar tissue interfere with normal transmission along nerve fibers within the brain and to and from the brain. This results in classic symptoms associated with MS. The condition affects 2.5 million individuals worldwide and approximately 400,000 in the United States.1 Twice as many women as men are affected, and diagnosis usually occurs between the ages of 20 and 50.^1^ About 40 percent of people with MS receive some form of disability income.2 Both symptoms and disease course are highly individualized, depending on where the lesions occur within the central nervous system and the type of MS. Clinically definite MS types have been commonly described as:

- Relapsing-remitting MS (RRMS) is the most common form, affecting approximately 85 percent of patients. Patients typically are diagnosed in their 20s or 30s. Neurologic symptoms of a relapse typically develop over a course of days, stabilize, and spontaneously improve; however, over time permanent disability often accrues with further relapses. Many patients with RRMS will eventually transition to secondary progressive MS (below); estimates of the median time to this transition range from 15 to 29 years.3
- Secondary progressive MS (SPMS) is characterized by worsening disability with or without relapses. Patients may have exacerbations, but the trend over time is a relatively steady progression of disease and disability.1
- Primary progressive MS (PPMS) represents about 15 percent of patients and affects women and men about equally. This form has the worst prognosis and is characterized by gradual and progressive worsening of function without distinct relapses.1
- Progressive relapsing MS (PRMS) affects about 5 percent of patients. This form is usually initially diagnosed as PPMS due to a steady worsening of functioning and changed to PRMS when the patient experiences a relapse. Recently, a recommendation has been made to eliminate this type, incorporating such patients in PPMS.4

People with clinically isolated syndrome (CIS), a first neurological episode, consistent with an MS relapse, may or may not go on to develop MS. CIS involves neurological symptoms such as vision loss, numbness, or weakness that lasts at least 24 hours and are caused by inflammation or demyelination in one (monofocal) or more (multifocal) sites in the central nervous system. In a cohort of 107 CIS patients followed for 20 years, 60 patients with three or more lesions (seen via magnetic resonance imaging [MRI]) converted to definite MS, while only seven with normal baseline MRI converted.5

Debate continues to surround the underlying etiology of MS. Most literature considers MS as an autoimmune, inflammatory disease, and this hypothesis underlies current drug treatments.6 Others suggest that MS is best understood as a neurodegenerative disease, leading to autoimmune reaction to the neurodegenerative debris.7 Still others hypothesize that MS is a chronic metabolic disorder.8 Disease-modifying treatments (DMTs) are aimed at modifying autoimmune activity, even though we do not yet know whether autoimmune activity is primary or secondary in MS pathology.

### Treatment Strategies – and Their Discontinuation

MS cannot be cured with current therapies, and clinicians and patients face challenges balancing benefits and risks when choosing a treatment course.9 Current DMTs comprise immunomodulating and immunosuppressant medications, which aim to slow the progression of MS and improve quality of life. The working hypothesis is that reducing or preventing new lesions and their sequelae slows the worsening of disease.

Given the unpredictable nature of MS relapses and progression, clinical trials for MS treatments are run for 2 to 3 years to allow for more accurate measurement of reductions in relapse rates and evidence of slowed disease progression. Table 1 provides a list of currently FDA approved DMTs.

Table 1 FDA-approved disease-modifying treatments for MS

Generic (Administration) | Manufacturer (Trade Name) | FDA-Approved Indication | FDA Warnings
Interferon beta-1a (IFNbeta-1a) (Injection: Avonex-weekly, Rebif-thrice weekly. Plegridy – every 2 weeks) | Biogen (Avonex^®^) | May 17, 1996, for CIS and RRMS | Yes
Interferon beta-1a (IFNbeta-1a) (Injection: Avonex-weekly, Rebif-thrice weekly. Plegridy – every 2 weeks) | EMD Serono (Rebif^®^) | August 2014 (Plegridy) March 7, 2002, for RRMS | Yes
Interferon beta-1b (IFNbeta-1b) (Injection every other day) | Bayer Healthcare Pharms (Betaseron^®^) | July 23, 1993, for RRMS | Yes
Interferon beta-1b (IFNbeta-1b) (Injection every other day) | Novartis (Extavia^®^) | August 14, 2009, for CIS and RRMS | Yes
Glatiramer acetate (Injection-daily) | Teva (Copaxone^®^) | December 20, 1996, for RRMS | Yes
Mitoxantrone (IV) | Bedford; Hospira; Teva Parenteral; Fresenius; EMD Serono Inc., Kabi USA, Mylan Institutional; Onco Therapies LTD | 2000 for RRMS, SPMS, PRMS | Yes, black box
Natalizumab (IV) | Biogen (Tysabri^®^) | November 23, 2004, for RRMS | Yes, black box
Teriflunomide | Sanofi Aventis US (Aubagio) (leflunomide by Sanofi Aventis US as Arava for arthritis) | September 12, 2012, for RRMS | Yes, black box
Fingolimod (Oral) | Novartis (Gilenya) | September 21, 2010, RRMS | Yes
Dimethyl fumarate (Oral) | Biogen (Tecfidera) | March 27, 2013, RRMS | Yes
Alemtuzumab (Injection) | Genzyme (Lemtrada) | November, 2014, RRMS | Yes

CIS = clinically isolated syndrome; FDA = U.S. Food and Drug Administration; IV = intravenous; MS=multiple sclerosis; PRMS=primary relapsing multiple sclerosis; RRMS = relapsing-remitting multiple sclerosis; SPMS = secondary progressive multiple sclerosis

A 2013 Cochrane overview review and network analysis of 44 trials of DMTs for MS found moderate to high quality evidence that DMTs are effective against recurrence of relapses in RRMS during the first 24 months of treatment compared with placebo.10 The network analysis ranked natalizumab as the most effective drug, followed in order by IFNbeta-1a (Rebif), mitoxantrone, glatiramer acetate (Copaxone), and IFNbeta-1b (Betaseron). Confidence in the evidence dropped to moderate for direct comparisons of mitoxantrone and IFNbeta-1b versus placebo and very low for glatiramer acetate versus placebo. Included trials did not report relapse outcomes for RRMS at 3 years. Further, natalizumab and IFNbeta-1b were more effective than IFNbeta-1a in reducing the number of RRMS participants with disease progression as measured with surrogate markers. In patients with progressive MS, both pairwise and network analysis found no DMTs analyzed prevented disability progression over 2 or 3 years. The overview and network analysis were too recent to include the newest approved drugs such as fingolimod or dimethylfumerate.

Unfortunately, the efficacy of MS treatments appears to correlate with the frequency and severity of side effects.11 The injectable treatments, the interferon drugs and glatiramer acetate, were modestly efficacious and side-effects were tolerable by many patients.10 Mitoxantrone, an escalation medication, has a lifetime maximum dosage due to cardiotoxicity, and risks of leukemia.11 Natalizumab, the first monoclonal antibody approved for treating MS, can induce the potentially fatal brain infection progressive multifocal leukoencephalopathy (PML). Risk for PML increases with natalizumab use longer than 2 years, anti-JC virus antibody status, and prior use of immunosuppressive agents.12 People taking natalizumab may take a drug holiday or discontinue use completely if their risk factor increases, assessed by a positive test for the anti-JCV antibody status.

Women considering pregnancy face special considerations for drug holidays. There are no class A drugs (drugs safe for use during pregnancy, according to the Food and Drug Administration) for MS. Women and their physicians must weigh the possible risks of DMT exposure to the unborn fetus against the maternal risk of disease progression if she discontinues DMT. Rates of fetal exposure to DMTs vary greatly by country. While a Canadian study reported an exposure rate of 5 percent,13 much higher rates have been reported by studies outside of North America. A Spanish study found 39 percent of pregnancies were exposed to DMTs,14 and a Brazilian study found an exposure rate of 70 percent.15 Unfortunately, conception isn't always easily planned.

The optimal duration of DMT use remains an open and controversial question. Many patients do not use these medications throughout their entire life after diagnosis. However, with few exceptions (such as natalizumab use or intended pregnancy), patients who opt for DMT for MS may end up using it for several years to decades, as long as they tolerate the treatment and the DMT seems effective. Patients may switch between DMTs in order to find one that is more effective or more tolerable, and studies have found high rates of switching between drugs.16 Some patients cannot tolerate any of the DMTs, but if a tolerable drug regime is determined, treatment generally continues until the individual reaches a disease stage where DMTs are no longer considered to be helping. Such a point may be reached when a person is determined to be nonresponsive to the medication due to disease progression. Determining when DMT is no longer helpful is challenging. Thus, major questions of interest are whether or not DMTs for MS alter the natural history of the disease in the long run and when (if ever) to discontinue DMT.

## Scope and Key Questions

### Scope of the Review

This review examines the long-term (more than 3 years) consequences of discontinuing DMT. We looked for evidence that directly assessed discontinuing versus continuing DMT, and also evidence for long-term (more than 3 years) benefits and harms for either continuing or discontinuing, since that decision can be informed by the benefits or harms directly linked to either course of action. This information would extend understanding beyond the short-term trials examined in the 2013 Cochrane review. We were also interested in the reasons for discontinuing treatment reported in the long-term studies.

We concentrated on outcomes that patients notice or factor directly into their decisionmaking, such as relapse rates and changes in disability level, rather than intermediate outcomes such as lab tests for neutralizing antibodies. MRI to identify MS-related lesions has been shown to correlate with short-term relapse rates, 6 months to 2 years.11 However, long-term MRI followup as a surrogate marker for relapse rates or, more importantly, disease progression, currently lacks evidence.17,18 Further, short-term MRI followup as a predictor of long-term disability progression answers a different research question, that is, does short-term treatment effect the long-term outcomes, than the research questions asked for this review. Thus, we did not use MRI as a long-term outcome in this review. However, we included MRI as a short-term outcome in the subset of patients discontinuing natalizumab due to risk of PML.

People with MS commonly switch between the available DMTs depending on tolerance, presence of adverse effects, and perceived helpfulness of the treatment. The pertinent clinical question for switching medications is how to define the threshold of disease activity for changing medications. This important question is qualitatively different than that of when, if ever, to stop DMTs completely. To adequately address the question of when to switch medication will likely require a review of both short- and long-term research. Therefore, questions related to switching between DMTs are outside the scope of this review.

The review also examines the evidence for patient values, beliefs, and preferences regarding discontinuing DMTs. Such information should support clinicians, patients, consumer advocates, and other decisionmakers in understanding the factors and processes that may inform decisions to discontinue treatment.

### Key Questions

We synthesized the evidence in the published literature to address the following two Key Questions (KQ):

KQ1: What are the consequences of discontinuing disease-modifying treatments in adult patients?

a. What is the evidence for benefits for continuing versus discontinuing treatment?
b. What is the evidence for long-term harms?
c. What reasons for discontinuation of disease-modifying treatments have been reported in long-term observational cohort studies?

KQ2: What are individual values, beliefs, and preferences regarding discontinuing disease-modifying treatments?

a. What are patient and provider preferences for discontinuation of disease–modifying treatments?
b. What are patient and provider preferences for participation in shared decisionmaking to discontinue disease-modifying treatments?

Figure 1 provides a conceptual framework that links the KQs. At the top it depicts the logic path both physicians and patients must travel when considering DMTs:

- Does it work?
- What drug should I start with?
- When should I switch a patient to a new drug and what should that drug be?
- When should a patient discontinue disease-modifying treatment?

Figure 1 Conceptual framework for Key Questions

Figure 1 depicts at the top the logic path both physicians and patients must travel when considering disease modifying treatments - does it work, what drug should I start with, when should I switch to a new drug and what should that drug be, and when should I discontinue disease modifying treatment? This logic path creates the context within which patients are making frequent decisions regarding disease modifying treatment. The lower part of the figure depicts the movement from an individual's internal decision context and process (such as preferences, values, knowledge, beliefs, and cognitive behaviors and habits) to interpersonal decision context and processes between the physician and patient, which eventually results in decisions which may or may not be concordant between the physician and patient.

This logic path describes the context within which patients and clinicians consider clinical factors—tolerability of the medication, disease characteristics at the time of discontinuation (relapses, progression, MRI activity), risk of ongoing disease treatment, other impediments to continued medication use (e.g., difficulty of obtaining, injecting or ingesting, cost, etc.)—and make decisions about DMTs or, in the case of this review, discontinuation (KQ1). The lower part of the figure depicts the progression from an individual's internal decision context and process (such as preferences, values, knowledge, beliefs, and cognitive behaviors and habits) to an interpersonal decision context and processes between the physician and patient. The overlapping ovals representing the clinician and the patient indicate information shared between the two parties versus information and other cognitive processes specific to one individual. Any overlap depends in part on the level of sophistication a patient brings to the decisionmaking process and in part on how well a physician understands a patient's beliefs, values, goals, and preferences. For example, a patient newly diagnosed with MS in the novice phase of learning about MS would likely have a smaller overlap.19 The interaction between the physician and patient results in decisions that can vary in their level of concordance.

## Organization of This Report

The report describes our review methods, including our search strategy, inclusion and exclusion criteria, approach to reviewing abstracts and full publications, and our method for extracting data and summarizing evidence. We also describe the approach to grading the quality of the literature and to evaluating the strength of the body of evidence.

The results section synthesizes the findings by KQ. For KQ1, we report the available evidence on consequences of discontinuing DMT, including long-term benefits and harms for DMTs. We also report the evidence regarding special cases of treatment discontinuation due to pregnancy and natalizumab discontinuation due to increased risk of PML. For KQ2, we present the empirical literature that populates the conceptual framework provided in Figure 1.