# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- *Gary S. Gronseth, M.D.
  * Also served as Peer Reviewer.
  Department of Neurology
  University of Kansas
  Kansas City, KS
- *Michael Kaufman, M.D.
  Knoxville Neurology Clinic
  University of Tennessee (Knoxville) MS Center
  Knoxville, TN
- *Nicholas LaRocca, Ph.D.
  National Multiple Sclerosis Society
  New York, NY
- *Brant Oliver, Ph.D., M.S., M.P.H., A.P.R.N.-B.C.
  Assistant Professor, School of Nursing, MGH Institute of Health Professions
  Boston, MA
  Faculty Senior Scholar
  Department of Veterans Affairs National Quality Scholars Fellowship Program
  White River Junction, VT
- Alex Duart Rae-Grant, M.D.
  Mellen Center for Multiple Sclerosis
  Cleveland Clinic Main Campus
  Cleveland, OH