# Acknowledgments

The authors gratefully acknowledge Suchitra Iyer, Melissa McPherson, Marilyn Eells, and Jeannine Ouellette for their contributions to this project; this report is better for them.

## Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Thomas Getchius, Ph.D.
  Associate Director, Clinical Practice
  American Academy of Neurology
  Minneapolis, MN
- Gary S. Gronseth, M.D.
  Department of Neurology
  University of Kansas
  Kansas City, KS
- Michael Kaufman, M.D.
  Knoxville Neurology Clinic
  University of Tennessee (Knoxville) MS Center
  Knoxville, TN
- Nicholas LaRocca, Ph.D.
  National Multiple Sclerosis Society
  New York, NY
- Brant Oliver, Ph.D., M.S., M.P.H., A.P.R.N.-B.C.
  MGH Institute of Health Professions
  Boston MA
- Alex Duart Rae-Grant, M.D.
  Mellen Center for Multiple Sclerosis
  Cleveland Clinic Main Campus
  Cleveland, OH
- Lisa Taylor Skutnik, P.T., M.A.
  National Multiple Sclerosis Society
  New York, NY